# List of Excluded Studies

Reasons for Exclusion:

- X-1. Not relevant to topic
- X-1a. Post-PCI
- X-1b. Post-CABG
- X-1c. Diagnostic
- X-1d. Prognostic
- X-1e. Etiologic
- X-1f. Not a risk tool
- X-1g. Other
- X-2. Does not attempt internal or external validation (evaluation of risk model)
- X-3. Not published in English
- X-4. Not original research
- X-5. Not an eligible study type
- X-6. Does not report relevant outcomes
- X-7. Study size of <200
- X-8. Study population symptomatic for CVD
- X-9. Study population aged <18 years

1 Blood pressure predicts heart disease differently in males and females. J Gend Specif Med. Nov-Dec. 2000;3(8):8. X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9.
2 Prediction of mortality from coronary heart disease among diverse populations: is there a common predictive function?. Heart. Sep. 2002;88(3):222-8. X-4,X-5. [pmid: 12181209].
3 Special report: C-reactive protein for risk stratification in coronary heart disease screening. TEC Bull (Online). Nov. 11. 2002;19(3):31-7. X-1. [pmid: 12839025].
4 Report on the SA Hypertension Congress (7-9 March 2003): successful combination of CME and new research. Cardiovasc J S Afr. Mar-Apr. 2003;14(2):103-6. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12861999].
5 Treatment modalities of non-ST-elevation acute coronary syndromes in the real world. Results of the prospective R.OS.A.I.-2 registry. Ital Heart J. Nov. 2003;4(11):782-90. X-1,X-8. [pmid: 14699708].
6 Chest pain relief by nitroglycerin doesn't predict active coronary artery disease. Cleve Clin J Med. Apr. 2004;71(4):280. X-1. [pmid: 15117167].
7 C-reactive protein: crystal ball or redundancy? Is this heart risk biomarker useful independently, or does it only confirm the results of other tests?. Health News. Dec. 2004;10(12):3. X-1,X-2,X-4,X-5,X-6,X-7,X-8.
8 Coronary risk prediction for those with and without diabetes. Eur J Cardiovasc Prev Rehabil. Feb. 2006;13(1):30-6. X-4,X-5. [pmid: 16449861].
9 The impact of cardiovascular risk factors on the age-related excess risk of coronary heart disease. Int J Epidemiol. Aug. 2006;35(4):1025-33. X-4,X-5. [pmid: 16581818].
10 Risk assessment chart for death from cardiovascular disease based on a 19-year follow-up study of a Japanese representative population. Circ J. Oct. 2006;70(10):1249-55. X-2. [pmid: 16998254].
11 Simplicity still rules for heart disease forecast. New heart disease tests add little to the predictive power of blood pressure, cholesterol, and other traditional risk factors. Harv Heart Lett. Nov. 2006;17(3):3. X-2,X-4,X-5,X-6,X-7,X-8.
12 Summaries for patients. C-reactive protein and prediction of risk for cardiovascular disease in women. Ann Intern Med. Jul. 4. 2006;145(1):I19. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 16818922].
13 Does diagnosis of the metabolic syndrome detect further men at high risk of cardiovascular death beyond those identified by a conventional cardiovascular risk score? The DECODE Study. Eur J Cardiovasc Prev Rehabil. Apr. 2007;14(2):192-9. X-1G,X-2. [pmid: 17446796].
14 The final 10-year follow-up results from the BARI randomized trial. J Am Coll Cardiol. Apr. 17. 2007;49(15):1600-6. X-1,X-8. [pmid: 17433949].
15 Tests that predict your cardiac future. Several tests assess risk of coronary heart disease, heart attack and death from heart disease, but can better prediction lead to successful prevention?. Heart Advis. Jul. 2007;10(7):3. X-1G,X-2,X-4,X-5,X-6,X-7,X-8,X-9.
16 2007 Focused update of the ACC/AHA/SCAI 2005 guideline update for percutaneous coronary intervention A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. Catheter Cardiovasc Interv. Jan. 1. 2008;71(1):E1-40. X-1,X-2,X-4,X-5,X-6.
17 Appropriately screened geriatric chest pain patients in an observation unit are not admitted at a higher rate than nongeriatric patients. Crit Pathw Cardiol. [Comparative Study]. Dec. 2008;7(4):245-7. X-1,X-2,X-6,X-7,X-8.
18 Assessing new biomarkers and predictive models for use in clinical practice: a clinician's guide. Arch Intern Med. [Research Support, Non-U.S. Gov't]. Nov. 24. 2008;168(21):2304-10. X-1,X-2,X-4,X-5,X-6,X-7,X-8.
19 Calcium-channel blockers reduce the antiplatelet effect of clopidogrel. J Am Coll Cardiol. [Comparative Study Research Support, Non-U.S. Gov't]. Nov. 4. 2008;52(19):1557-63. X-1,X-2,X-8.
20 Cardiovascular disease risk factors, metabolic syndrome and obesity in an Iranian population. East Mediterr Health J. [Research Support, Non-U.S. Gov't]. Sep-Oct. 2008;14(5):1070-9. X-1,X-2,X-5,X-6.
21 Comparison of 12 risk stratification schemes to predict stroke in patients with nonvalvular atrial fibrillation. Stroke. Jun. 2008;39(6):1901-10. X-2,X-4,X-5,X-7. [pmid: 18420954].
22 Conventional and non-conventional coronary risk factors in male premature coronary artery disease patients already having a low Framingham risk score. Acta Cardiol. [Comparative Study]. Oct. 2008;63(5):623-8. X-1,X-2,X-5,X-6,X-7,X-8.
23 Cost-effectiveness analysis of aldosterone blockade with eplerenone in patients with heart failure after acute myocardial infarction in the French context: the EPHESUS study. Arch Cardiovasc Dis. [Comparative Study Randomized Controlled Trial]. Sep. 2008;101(9):515-21. Epub 2008 Nov 6. X-1,X-2,X-5,X-7.
24 Diagnostic and prognostic value of rapid pacing stress echocardiography for the detection of coronary artery disease: influence of pacing mode and concomitant antiischemic therapy (final results of multicenter study Pol-RAPSE). Echocardiography. [Multicenter Study]. Sep. 2008;25(8):827-34. X-1,X-2,X-7,X-8.
25 Diagnostic performance of 64-multidetector row coronary computed tomographic angiography for evaluation of coronary artery stenosis in individuals without known coronary artery disease: results from the prospective multicenter ACCURACY (Assessment by Coronary Computed Tomographic Angiography of Individuals Undergoing Invasive Coronary Angiography) trial. J Am Coll Cardiol. [Multicenter Study Randomized Controlled Trial Research Support, Non-U.S. Gov't]. Nov. 18. 2008;52(21):1724-32. X-1,X-2,X-6,X-8.
26 Diagnostic performance of coronary angiography by 64-row CT. N Engl J Med. [Clinical Trial Comparative Study Multicenter Study Research Support, N.I.H., Extramural Research Support, Non-U.S. Gov't]. Nov. 27. 2008;359(22):2324-36. X-1,X-6,X-8.
27 Efficacy and safety of ezetimibe added on to atorvastatin (20 mg) versus uptitration of atorvastatin (to 40 mg) in hypercholesterolemic patients at moderately high risk for coronary heart disease. Am J Cardiol. [Clinical Trial Multicenter Study Randomized Controlled Trial Research Support, Non-U.S. Gov't]. Dec. 1. 2008;102(11):1489-94. Epub 2008 Oct 23. X-1,X-2,X-6,X-7,X-8.
28 Ejection fraction assessment and survival: an analysis of the Sudden Cardiac Death in Heart Failure Trial (SCD-HeFT). Am Heart J. [Comparative Study Multicenter Study Randomized Controlled Trial Research Support, N.I.H., Extramural Research Support, Non-U.S. Gov't]. Dec. 2008;156(6):1196-200. Epub 2008 Nov 6. X-1,X-2,X-6,X-8.
29 Elevated blood pressure, race/ethnicity, and C-reactive protein levels in children and adolescents. Pediatrics. [Research Support, N.I.H., Extramural Research Support, Non-U.S. Gov't Research Support, U.S. Gov't, P.H.S.]. Dec. 2008;122(6):1252-7. X-1,X-2,X-5,X-6.
30 First report on 30-day and operative mortality in risk model of isolated coronary artery bypass grafting in Japan. Ann Thorac Surg. Dec. 2008;86(6):1866-72. X-1,X-8. [pmid: 19021998].
31 Frequency, predictors, and neurologic outcomes of vaso-occlusive strokes associated with cardiac surgery in children. Pediatrics. [Research Support, Non-U.S. Gov't]. Dec. 2008;122(6):1292-8. X-1,X-2,X-8.
32 Genetic testing for atherosclerosis risk: inevitability or pipe dream?. Can J Cardiol. [Research Support, Non-U.S. Gov't Review]. Nov. 2008;24(11):851-4. X-2,X-4,X-5,X-6,X-7.
33 Impact of clopidogrel in patients with acute coronary syndromes requiring coronary artery bypass surgery: a multicenter analysis. J Am Coll Cardiol. [Comparative Study Multicenter Study Research Support, Non-U.S. Gov't]. Nov. 8. 2008;52(21):1693-701. X-1,X-2,X-8.
34 Impact of surgical ventricular restoration on diastolic function: implications of shape and residual ventricular size. Ann Thorac Surg. Dec. 2008;86(6):1849-54. X-1,X-2,X-6,X-7,X-8. [pmid: 19021992].
35 Inflammation and hemostasis biomarkers for predicting stroke in postmenopausal women: the Women's Health Initiative Observational Study. J Stroke Cerebrovasc Dis. [Research Support, N.I.H., Extramural Research Support, U.S. Gov't, Non-P.H.S.]. Nov-Dec. 2008;17(6):344-55. X-5,X-8.
36 Lack of observed association between high plasma osteoprotegerin concentrations and ischemic stroke risk in a healthy population. Clin Chem. Dec. 2008;54(12):1969-74. Epub 2008 Oct 30. X-1,X-2,X-5,X-8. [pmid: 19042987].
37 Lower pretreatment cerebral blood volume affects hemorrhagic risks after intra-arterial revascularization in acute stroke. Neurosurgery. [Multicenter Study]. Nov. 2008;63(5):874-8. discussion 878-9. X-1,X-2,X-6,X-8.
38 Nurse-led risk assessment/management clinics reduce predicted cardiac morbidity and mortality in claudicants. J Vasc Nurs. Dec. 2008;26(4):118-22. X-1,X-2,X-6,X-7. [pmid: 19022170].
39 Paclitaxel-eluting versus bare-metal stents in acute ST elevation myocardial infarction (STEMI). Crit Pathw Cardiol. [Comparative Study]. Dec. 2008;7(4):232-8. X-1,X-2,X-7,X-8.
40 Predicting future risk of depressive episode in adolescents: the Chicago Adolescent Depression Risk Assessment (CADRA). Ann Fam Med. [Research Support, N.I.H., Extramural Research Support, Non-U.S. Gov't]. Nov-Dec. 2008;6(6):503-11. X-1,X-6.
41 Predicting postoperative renal failure requiring dialysis, and an analysis of long-term outcome in patients undergoing valve surgery. J Heart Valve Dis. [Validation Studies]. Nov. 2008;17(6):657-65. X-1,X-6,X-8.
42 Predictive value of myocardial perfusion single-photon emission computed tomography and the impact of renal function on cardiac death. Circulation. Dec. 9. 2008;118(24):2540-9. Epub 2008 Dec 1. X-1,X-2,X-8. [pmid: 19047585].
43 Predictors for contrast media-induced nephropathy and long-term survival: prospectively assessed data from the randomized controlled Dialysis-Versus-Diuresis (DVD) trial. Can J Cardiol. [Randomized Controlled Trial Research Support, Non-U.S. Gov't]. Nov. 2008;24(11):845-50. X-1,X-2.
44 Predictors of smoking relapse in women with cardiovascular disease in a 30-month study: extended analysis. Heart Lung. [Comparative Study Multicenter Study Randomized Controlled Trial Research Support, N.I.H., Extramural]. Nov-Dec. 2008;37(6):455-65. Epub 2008 Oct 5. X-1,X-2,X-6.
45 Prevalence of coronary artery calcification in patients undergoing assessment for orthotopic liver transplantation. Liver Transpl. [Research Support, Non-U.S. Gov't]. Dec. 2008;14(12):1725-31. X-1,X-2,X-5,X-6,X-7.
46 A proposed functional clinical classification predicts in-hospital and long-term survival in the setting of acute right ventricular infarction. Arch Cardiol Mex. [Validation Studies]. Oct-Dec. 2008;78(4):369-78. X-1,X-8.
47 Relation of mortality to failure to prescribe beta blockers acutely in patients with sustained ventricular tachycardia and ventricular fibrillation following acute myocardial infarction (from the VALsartan In Acute myocardial iNfarcTion trial [VALIANT] Registry). Am J Cardiol. [Research Support, Non-U.S. Gov't]. Dec. 1. 2008;102(11):1427-32. Epub 2008 Sep 11. X-1,X-2,X-8.
48 Results and predictors of early and late outcome of coronary artery bypass graft surgery in patients with ejection fraction less than 20%. Arch Cardiovasc Dis. Sep. 2008;101(9):547-56. Epub 2008 Nov 20. X-1,X-2,X-8. [pmid: 19041839].
49 Revisiting rose: comparing the benefits and costs of population-wide and targeted interventions. Milbank Q. [Comparative Study Research Support, N.I.H., Extramural]. Dec. 2008;86(4):581-600. X-1,X-2,X-4,X-5,X-6,X-7,X-8.
50 Risk predictors of retroperitoneal hemorrhage following percutaneous coronary intervention. Am J Cardiol. Dec. 1. 2008;102(11):1473-6. Epub 2008 Sep 11. X-1X-2,X-6,X-8. [pmid: 19026298].
51 A risk score to predict intracranial hemorrhage after recombinant tissue plasminogen activator for acute ischemic stroke. J Stroke Cerebrovasc Dis. [Multicenter Study Research Support, Non-U.S. Gov't]. Nov-Dec. 2008;17(6):331-3. X-1,X-8.
52 Role of myocardial perfusion imaging in patients with end-stage renal disease undergoing coronary angiography. Am J Cardiol. Dec. 1. 2008;102(11):1451-6. Epub 2008 Sep 11. X-1,X-2,X-6,X-7,X-8. [pmid: 19026294].
53 Short sleep duration as an independent predictor of cardiovascular events in Japanese patients with hypertension. Arch Intern Med. [Research Support, N.I.H., Extramural Research Support, Non-U.S. Gov't]. Nov. 10. 2008;168(20):2225-31. X-1,X-2.
54 Significance of the treadmill scores and high-risk criteria for exercise testing in non-high-risk patients with unstable angina and an intermediate Duke treadmill score. Acta Cardiol. [Comparative Study]. Oct. 2008;63(5):557-64. X-1,X-7,X-8.
55 A simple algorithm to predict incident kidney disease. Arch Intern Med. [Research Support, N.I.H., Extramural Research Support, Non-U.S. Gov't Validation Studies]. Dec. 8. 2008;168(22):2466-73. X-1,X-6.
56 Simultaneous aortic and mitral valve replacement in octogenarians: a viable option?. Ann Thorac Surg. Dec. 2008;86(6):1804-8. X-1,X-2,X-8. [pmid: 19021981].
57 TCF7L2 variant genotypes and type 2 diabetes risk in Brazil: significant association, but not a significant tool for risk stratification in the general population. BMC Med Genet. Dec. 4. 2008;9:106. X-1,X-6. [pmid: 19055834].
58 Total arterial revascularization in triple-vessel disease with off-pump and aortic no-touch technique. Ann Thorac Surg. Dec. 2008;86(6):1861-5. X-1,X-2,X-8. [pmid: 19021996].
59 Updated Strategies and Therapies for Reducing Ischemic and Vascular Events (STRIVE) ST-segment elevation myocardial infarction critical pathway toolkit. Crit Pathw Cardiol. [Research Support, Non-U.S. Gov't Review]. Dec. 2008;7(4):223-31. X-1,X-2,X-4,X-5,X-6,X-7,X-8.
60 Usefulness of self-reported periodontal disease to identify individuals with elevated inflammatory markers at risk of cardiovascular disease. Am J Cardiol. [Research Support, N.I.H., Extramural Research Support, Non-U.S. Gov't]. Dec. 2008;102(11):1509-13. Epub 2008 Sep 15. X-1,X-2,X-5,X-6.
61 Ambulatory blood pressure monitoring and all-cause mortality in elderly people with diabetes mellitus. Hypertension. [Research Support, U.S. Gov't, P.H.S.]. Feb. 2009;53(2):120-7. Epub 2009 Jan 5. X-1,X-2.
62 Assessment of the multiple-biomarker approach for diagnosis of myocardial infarction in patients presenting with symptoms suggestive of acute coronary syndrome. Clin Chem. [Research Support, Non-U.S. Gov't]. Jan. 2009;55(1):93-100. Epub 2008 Nov 21. X-1,X-8.
63 Cognitive consequences of multiple lacunes and leukoaraiosis as vascular cognitive impairment in community-dwelling elderly individuals. J Stroke Cerebrovasc Dis. Jan. 2009;18(1):32-7. X-1,X-2,X-6. [pmid: 19110142].
64 Comparison of computer tomography and magnetic resonance imaging scans on the third day of life in term newborns with neonatal encephalopathy. Pediatrics. [Comparative Study Research Support, Non-U.S. Gov't Validation Studies]. Jan. 2009;123(1):319-26. X-1,X-8.
65 Early and late outcomes of cardiac surgery in octogenarians. Ann Thorac Surg. Jan. 2009;87(1):71-8. X-1,X-8. [pmid: 19101271].
66 Effectiveness of atrial fibrillation as an independent predictor of death and coronary events in patients having coronary angiography. Am J Cardiol. [Comparative Study]. Jan. 1. 2009;103(1):36-40. Epub 2008 Oct 23. X-1,X-8.
67 The Essen stroke risk score predicts recurrent cardiovascular events: a validation within the REduction of Atherothrombosis for Continued Health (REACH) registry. Stroke. [Research Support, Non-U.S. Gov't Validation Studies]. Feb. 2009;40(2):350-4. Epub 2008 Nov 20. X-8.
68 The influence of body mass index obesity status on vascular surgery 30-day morbidity and mortality. J Vasc Surg. Comparative Study Multicenter Study Research Support, U.S. Gov't, P.H.S.]. 2009 Jan discussion 147. Jan. 2009;49(1):140-7. X-1.
69 Is cardiac surgery safe in extremely obese patients (body mass index 50 or greater)?. Ann Thorac Surg. [Comparative Study]. Feb. 2009;87(2):540-6. X-1,X-7,X-8.
70 Is high-sensitivity C-reactive protein associated with subclinical peripheral atherosclerosis?. Angiology. Feb-Mar. 2009;60(1):8-11. X-1. [pmid: 19190029].
71 Joint effects of sodium and potassium intake on subsequent cardiovascular disease: the Trials of Hypertension Prevention follow-up study. Arch Intern Med. [Comparative Study Research Support, N.I.H., Extramural]. Jan. 12. 2009;169(1):32-40. X-1.
72 Late results of conventional versus all-arterial revascularization based on internal thoracic and radial artery grafting. Ann Thorac Surg. [Comparative Study]. Jan. 2009;87(1):19-26.e2. X-1, X-8.
73 Lipoprotein-associated phospholipase A2 and high-sensitivity C-reactive protein improve the stratification of ischemic stroke risk in the Atherosclerosis Risk in Communities (ARIC) study. Stroke. [Research Support, N.I.H., Extramural Research Support, Non-U.S. Gov't]. Feb. 2009;40(2):376-81. Epub 2008 Dec 18. X-1.
74 Long-term benefit-risk balance of drug-eluting vs. bare-metal stents in daily practice: does stent diameter matter? Three-year follow-up of BASKET. Eur Heart J. [Comparative Study Randomized Controlled Trial Research Support, Non-U.S. Gov't]. Jan. 2009;30(1):16-24. Epub 2008 Nov 25. X-1,X-2,X-8.
75 Prediction of survival after coronary revascularization: modeling short-term, mid-term, and long-term survival. Ann Thorac Surg. [Comparative Study Research Support, Non-U.S. Gov't]. Feb. 2009;87(2):463-72. X-1,X-2,X-8.
76 Prior inferior myocardial infarction has worse early outcomes in patients undergoing coronary artery bypass grafting than prior anterior myocardial infarction. Ann Thorac Surg. [Comparative Study]. Feb. 2009;87(2):475-80. X-1,X-2,X-6,X-8.
77 Prospective study on occupational stress and risk of stroke. Arch Intern Med. [Multicenter Study Research Support, Non-U.S. Gov't]. Jan. 12. 2009;169(1):56-61. X-1,X-2.
78 Risk stratification after coronary artery bypass surgery by a point-of-care test of platelet function. Ann Thorac Surg. [Comparative Study]. Feb. 2009;87(2):496-502. X-1,X-2,X-8.
79 Risk-adjusted 30-day outcomes of carotid stenting and endarterectomy: results from the SVS Vascular Registry. J Vasc Surg. [Comparative Study Multicenter Study]. Jan. 2009;49(1):71-9. Epub 2008 Nov 22. X-1,X-2,X-8.
80 Subjective memory symptoms in surgical and nonsurgical coronary artery patients: 6-year follow-up. Ann Thorac Surg. [Comparative Study Research Support, N.I.H., Extramural Research Support, Non-U.S. Gov't]. Jan. 2009;87(1):27-34. X-1,X-2,X-6,X-8.
81 The Toronto score for in-hospital mortality after percutaneous coronary interventions. Am Heart J. Jan. 2009;157(1):156-63. X-1,X-2,X-8. [pmid: 19081413].
82 Value of cardiac troponin I cutoff concentrations below the 99th percentile for clinical decision-making. Clin Chem. [Evaluation Studies Research Support, Non-U.S. Gov't]. Jan. 2009;55(1):85-92. Epub 2008 Nov 6. X-1,X-8.
83 Aadahl M, Kjaer M, Kristensen JH, et al. Self-reported physical activity compared with maximal oxygen uptake in adults. Eur J Cardiovasc Prev Rehabil. Jun. 2007;14(3):422-8. X-1,X-5,X-6. [pmid: 17568243].
84 Aarabi M, Jackson PR. Predicting coronary risk in UK South Asians: an adjustment method for Framingham-based tools. Eur J Cardiovasc Prev Rehabil. Feb. 2005;12(1):46-51. X-1,X-2,X-5. [pmid: 15703505].
85 Abaci A, Sen N, Yazici H, et al. Renal dysfunction is the most important predictor of the extent and severity of coronary artery disease in patients with diabetes mellitus. Coron Artery Dis. Sep. 2007;18(6):463-9. X-1,X-6,X-8. [pmid: 17700218].
86 Abbate A, Biondi-Zoccai GG, Brugaletta S, et al. C-reactive protein and other inflammatory biomarkers as predictors of outcome following acute coronary syndromes. Semin Vasc Med. Nov. 2003;3(4):375-84. X-1,X-2,X-4,X-5,X-6. [pmid: 15199444].
87 Abbott AL, Levi CR, Stork JL, et al. Timing of clinically significant microembolism after carotid endarterectomy. Cerebrovasc Dis. 2007;23(5-6):362-7. X-1,X-2,X-7,X-8. [pmid: 17268167].
88 Abbott RD, Ando F, Masaki KH, et al. Dietary magnesium intake and the future risk of coronary heart disease (the Honolulu Heart Program). Am J Cardiol. Sep. 15. 2003;92(6):665-9. X-1F,X-2. [pmid: 12972103].
89 Abdu TA, Neary R, Elhadd TA, et al. Coronary risk in growth hormone deficient hypopituitary adults: increased predicted risk is due largely to lipid profile abnormalities. Clin Endocrinol (Oxf). Aug. 2001;55(2):209-16. X-1,X-6,X-7. [pmid: 11531927].
90 Abe Y, Kondo M, Kubota T, et al. Noninvasive assessment of coronary microvascular dysfunction using Tc-99m tetrofosmin SPECT in patients with acute myocardial infarction. J Nucl Cardiol. Sep-Oct. 2004;11(5):562-9. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15472641].
91 Abidov A, Hachamovitch R, Berman DS. Modern nuclear cardiac imaging in diagnosis and clinical management of patients with left ventricular dysfunction. Minerva Cardioangiol. Dec. 2004;52(6):505-19. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15729211].
92 Abidov A, Hachamovitch R, Hayes SW, et al. Prognostic impact of hemodynamic response to adenosine in patients older than age 55 years undergoing vasodilator stress myocardial perfusion study. Circulation. Jun. 17. 2003;107(23):2894-9. X-1,X-5,X-6. [pmid: 12796141].
93 Abou Diwan CH, Oghlakian GO, Antonios SI, et al. The role of high sensitivity C-reactive protein in coronary artery disease risk prediction: a review. J Med Liban. Jan-Mar. 2004;52(1):39-47. X-1,X-2,X-4,X-5. [pmid: 15881701].
94 Acampa W, Spinelli L, Petretta M, et al. Prognostic value of myocardial ischemia in patients with uncomplicated acute myocardial infarction: direct comparison of stress echocardiography and myocardial perfusion imaging. J Nucl Med. Mar. 2005;46(3):417-23. X-1,X-5,X-7,X-8. [pmid: 15750153].
95 Acevedo M, Foody JM, Pearce GL, et al. Fibrinogen: associations with cardiovascular events in an outpatient clinic. Am Heart J. Feb. 2002;143(2):277-82. X-1F,X-2,X-5,X-8. [pmid: 11835031].
96 Acevedo M, Pearce GL, Kottke-Marchant K, et al. Elevated fibrinogen and homocysteine levels enhance the risk of mortality in patients from a high-risk preventive cardiology clinic. Arterioscler Thromb Vasc Biol. Jun. 1. 2002;22(6):1042-5. X-1F,X-2,X-5,X-6,X-8. [pmid: 12067918].
97 Achar SA, Kundu S, Norcross WA. Diagnosis of acute coronary syndrome. Am Fam Physician. Jul. 1. 2005;72(1):119-26. X-1C,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 16035692].
98 Achenbach S. Current and future status on cardiac computed tomography imaging for diagnosis and risk stratification. J Nucl Cardiol. Nov-Dec. 2005;12(6):703-13. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16344233].
99 Achenbach S, Nomayo A, Couturier G, et al. Relation between coronary calcium and 10-year risk scores in primary prevention patients. Am J Cardiol. Dec. 15. 2003;92(12):1471-5. X-5. [pmid: 14675591].
100 Acil T, Turkoz R, Acil M, et al. Value of prolonged QRS duration as a predictor of low cardiac output syndrome in patients with impaired left ventricular systolic function who undergo isolated coronary artery bypass grafting. Am J Cardiol. Nov. 15. 2006;98(10):1357-62. X-1,X-2,X-7,X-8. [pmid: 17134629].
101 Ad N, Barnett SD, Speir AM. The performance of the EuroSCORE and the Society of Thoracic Surgeons mortality risk score: the gender factor. Interact Cardiovasc Thorac Surg. Apr. 2007;6(2):192-5. X-1,X-6,X-8. [pmid: 17669807].
102 Adabag AS, Grandits GA, Prineas RJ, et al. Relation of heart rate parameters during exercise test to sudden death and all-cause mortality in asymptomatic men. Am J Cardiol. May. 15. 2008;101(10):1437-43. X-1F,X-2. [pmid: 18471455].
103 Adabag AS, Rector T, Mithani S, et al. Prognostic significance of elevated cardiac troponin I after heart surgery. Ann Thorac Surg. May. 2007;83(5):1744-50. X-1,X-8. [pmid: 17462392].
104 Addala S, Grines CL, Dixon SR, et al. Predicting mortality in patients with ST-elevation myocardial infarction treated with primary percutaneous coronary intervention (PAMI risk score). Am J Cardiol. Mar. 1. 2004;93(5):629-32. X-1,X-2,X-4X-5,X-6. [pmid: 14996596].
105 Addis IB, Ireland CC, Vittinghoff E, et al. Sexual activity and function in postmenopausal women with heart disease. Obstet Gynecol. Jul. 2005;106(1):121-7. X-1,X-6,X-8. [pmid: 15994626].
106 Adesanya CO, Yousuf KA, Co C, et al. Is wider worse? QRS duration predicts cardiac mortality in patients with right bundle branch block. Ann Noninvasive Electrocardiol. Apr. 2008;13(2):165-70. X-1,X-2,X-8. [pmid: 18426442].
107 Adibi P, Sadeghi M, Mahsa M, et al. Prediction of coronary atherosclerotic disease with liver transaminase level. Liver Int. Sep. 2007;27(7):895-900. X-2,X-6,X-8. [pmid: 17696927].
108 Adiloglu AK, Can R, Kinay O, et al. Infection with Chlamydia pneumoniae but not Helicobacter pylori is related to elevated apolipoprotein B levels. Acta Cardiol. Dec. 2005;60(6):599-604. X-1,X-6,X-7,X-9. [pmid: 16385920].
109 Adragao T, Pires A, Lucas C, et al. A simple vascular calcification score predicts cardiovascular risk in haemodialysis patients. Nephrol Dial Transplant. Jun. 2004;19(6):1480-8. X-1,X-7. [pmid: 15034154].
110 Afrasyap L, Ozturk G. NO level and endothelial NO synthase gene polymorphism (Glu298Asp) in the patients with coronary artery disease from the Turkish population. Acta Biochim Biophys Sin (Shanghai). Oct. 2004;36(10):661-6. X-1,X-2,X-5,X-6,X-8. [pmid: 15483745].
111 Afshinnia F, Ayazi P, Chadow HL. Glomerular filtration rate on admission independently predicts short-term in-hospital mortality after acute myocardial infarction. Am J Nephrol. 2006;26(4):408-14. X-1,X-5,X-6X-8. [pmid: 16926535].
112 Afzal AR, Mandal K, Nyamweya S, et al. Association of Met439Thr substitution in heat shock protein 70 gene with postoperative atrial fibrillation and serum HSP70 protein levels. Cardiology. 2008;110(1):45-52. X-1,X-2,X-5,X-6,X-8. [pmid: 17934269].
113 Agostini D, Verberne HJ, Burchert W, et al. I-123-mIBG myocardial imaging for assessment of risk for a major cardiac event in heart failure patients: insights from a retrospective European multicenter study. Eur J Nucl Med Mol Imaging. Mar. 2008;35(3):535-46. X-1,X-2,X-6,X-8. [pmid: 18043919].
114 Agoston-Coldea L, Zdrenghea D, Pop D, et al. Apolipoproteins A-I and B-markers in coronary risk evaluation. Rom J Intern Med. 2007;45(3):251-8. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18333357].
115 Aguiar C, Ferreira J, Seabra-Gomes R. Prognostic value of continuous ST-segment monitoring in patients with non-ST-segment elevation acute coronary syndromes. Ann Noninvasive Electrocardiol. Jan. 2002;7(1):29-39. X-1,X-2,X-7,X-8. [pmid: 11844289].
116 Aguilar D, Fisher MR, O'Connor CM, et al. Metabolic syndrome, C-reactive protein, and prognosis in patients with established coronary artery disease. Am Heart J. Aug. 2006;152(2):298-304. X-1,X-8. [pmid: 16875914].
117 Ahern J, Jones MR, Bakshis E, et al. Revisiting rose: comparing the benefits and costs of population-wide and targeted interventions. Milbank Q. Dec. 2008;86(4):581-600. X-1,X-6,X-7,X-8. [pmid: 19120981].
118 Ahmad I, Zhan M, Miller M. High prevalence of C-reactive protein elevation with normal triglycerides (100-149 mg/dL): are triglyceride levels below 100 mg/dL more optimal in coronary heart disease risk assessment?. Am J Med Sci. Apr. 2005;329(4):173-7. X-1,X-2,X-5,X-6,X-8. [pmid: 15832099].
119 Ahmed A, Lefante CM, Alam N. Depression and nursing home admission among hospitalized older adults with coronary artery disease: a propensity score analysis. Am J Geriatr Cardiol. Mar-Apr. 2007;16(2):76-83. X-1,X-6,X-8. [pmid: 17380615].
120 Ahmed W, Zafar S, Alam AY, et al. Plasma levels of B-type natriuretic Peptide in patients with unstable angina pectoris or acute myocardial infarction: prognostic significance and therapeutic implications. Angiology. Jun-Jul. 2007;58(3):269-74. X-1,X-2,X-5,X-7,X-8. [pmid: 17626979].
121 Aijo M, Heikkinen E, Schroll M, et al. Physical activity and mortality of 75-year-old people in three Nordic localities: a five-year follow-up. Aging Clin Exp Res. Jun. 2002;14(3 Suppl):83-9. X-1. [pmid: 12475137].
122 Aizer A, Stern EH, Gomes JA, et al. Usefulness of programmed ventricular stimulation in predicting future arrhythmic events in patients with cardiac sarcoidosis. Am J Cardiol. Jul. 15. 2005;96(2):276-82. X-1,X-6,X-7. [pmid: 16018857].
123 Ajiro J, Alchi B, Narita I, et al. Mortality predictors after 10 years of dialysis: a prospective study of Japanese hemodialysis patients. Clin J Am Soc Nephrol. Jul. 2007;2(4):653-60. X-1,X-6,X-8. [pmid: 17699478].
124 Akgun S, Ozisik K, Kutsal A, et al. Does intermittent aortic cross clamping decrease the incidence of atrial fibrillation after coronary bypass surgery?. Heart Surg Forum. 2007;10(4):E320-4. X-1,X-8. [pmid: 17599884].
125 Akkerhuis KM, Alexander JH, Tardiff BE, et al. Minor myocardial damage and prognosis: are spontaneous and percutaneous coronary intervention-related events different?. Circulation. Feb. 5. 2002;105(5):554-6. X-1,X-8. [pmid: 11827918].
126 Akosah KO, McHugh VL, Barnhart SI, et al. Pilot Results of the Early Detection by Ultrasound of Carotid Artery Intima-Media Thickness Evaluation (EDUCATE) study. Am J Hypertens. Nov. 2007;20(11):1183-8. X-1D,X-1F,X-2,X-8. [pmid: 17954365].
127 Akosah KO, McHugh VL, Barnhart SI, et al. Carotid ultrasound for risk clarification in young to middle-aged adults undergoing elective coronary angiography. Am J Hypertens. Dec. 2006;19(12):1256-61. X-1,X-5,X-6. [pmid: 17161771].
128 Akosah KO, McHugh VL, Mathiason MA, et al. Metabolic syndrome and coronary heart disease equivalent conditions in predicting cardiovascular events in young to middle-aged adults. J Cardiometab Syndr. Summer. 2006;1(3):173-7. X-2,X-5,X-6,X-8. [pmid: 17679809].
129 Akram K, Voros S. Absolute coronary artery calcium scores are superior to MESA percentile rank in predicting obstructive coronary artery disease. Int J Cardiovasc Imaging. Oct. 2008;24(7):743-9. X-1,X-6,X-864%. [pmid: 18351440].
130 Aktas MK, Ozduran V, Pothier CE, et al. Global risk scores and exercise testing for predicting all-cause mortality in a preventive medicine program. JAMA. Sep. 22. 2004;292(12):1462-8. X-6. [pmid: 15383517].
131 Albert CM, Ma J, Rifai N, et al. Prospective study of C-reactive protein, homocysteine, and plasma lipid levels as predictors of sudden cardiac death. Circulation. Jun. 4. 2002;105(22):2595-9. X-1,X-5,X-8. [pmid: 12045163].
132 Albert MA, Glynn RJ, Ridker PM. Plasma concentration of C-reactive protein and the calculated Framingham Coronary Heart Disease Risk Score. Circulation. Jul. 15. 2003;108(2):161-5. X-1,X-5,X-6. [pmid: 12835213].
133 Albert MA, Ridker PM. C-reactive protein as a risk predictor: do race/ethnicity and gender make a difference?. Circulation. Aug. 1. 2006;114(5):e67-74. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 16880331].
134 Albes JM, Gross M, Franke U, et al. Revascularization during acute myocardial infarction: risks and benefits revisited. Ann Thorac Surg. Jul. 2002;74(1):102-8. X-1,X-2,X-8. [pmid: 12118738].
135 Al-Daghri NM. Hyperhomocysteinemia, coronary heart disease, and diabetes mellitus as predicted by various definitions for metabolic syndrome in a hypertensive Saudi population. Saudi Med J. Mar. 2007;28(3):339-46. X-1,X-2,X-5,X-6,X-8. [pmid: 17334456].
136 Aldea GS, Goss JR, Boyle EM Jr, et al. Use of off-pump and on-pump CABG strategies in current clinical practice: the Clinical Outcomes Assessment Program of the state of Washington. J Card Surg. May-Jun. 2003;18(3):206-15. discussion 216. X-1,X-6,X-8. [pmid: 12809394].
137 Al-Delaimy WK, Manson JE, Solomon CG, et al. Smoking and risk of coronary heart disease among women with type 2 diabetes mellitus. Arch Intern Med. Feb. 11. 2002;162(3):273-9. X-1F,X-2. [pmid: 11822919].
138 Alderman MH. A new model of risk: implications of increasing pulse pressure and systolic blood pressure on cardiovascular disease. J Hypertens Suppl. Dec. 1999;17(5):S25-8. X-1F,X-2.
139 Alehagen U, Lindstedt G, Levin LA, et al. The risk of cardiovascular death in elderly patients with possible heart failure. Results from a 6-year follow-up of a Swedish primary care population. Int J Cardiol. Apr. 8. 2005;100(1):17-27. X-1,X-2,X-5,X-6,X-8. [pmid: 15820281].
140 Aleksic M, Luebke T, Heckenkamp J, et al. Implementation of an artificial neuronal network to predict shunt necessity in carotid surgery. Ann Vasc Surg. Sep. 2008;22(5):635-42. X-1,X-6,X-8. [pmid: 18761224].
141 Alexander KP, Galanos AN, Jollis JG, et al. Post-myocardial infarction risk stratification in elderly patients. Am Heart J. Jul. 2001;142(1):37-42. X-1,X-2,X-6,X-8. [pmid: 11431654].
142 Alexander ME, Cecchin F, Huang KP, et al. Microvolt t-wave alternans with exercise in pediatrics and congenital heart disease: limitations and predictive value. Pacing Clin Electrophysiol. Jul. 2006;29(7):733-41. X-1,X-5,X-6. [pmid: 16884509].
143 Alexandersen P, Tanko LB, Bagger YZ, et al. The long-term impact of 2-3 years of hormone replacement therapy on cardiovascular mortality and atherosclerosis in healthy women. Climacteric. Apr. 2006;9(2):108-18. X-1,X-2,X-4,X-5. [pmid: 16698657].
144 Alexopoulos D, Toulgaridis T, Davlouros P, et al. Prognostic significance of coronary artery calcium in asymptomatic subjects with usual cardiovascular risk. Am Heart J. Mar. 2003;145(3):542-8. X-1,X-5,X-6. [pmid: 12660680].
145 Algra A, Gates PC, Fox AJ, et al. Side of brain infarction and long-term risk of sudden death in patients with symptomatic carotid disease. Stroke. Dec. 2003;34(12):2871-5. X-1,X-5,X-6. [pmid: 14631091].
146 al-Harbi K, Suresh CG, Zubaid M, et al. Establishing a gradient of risk in patients with acute coronary syndromes using troponin I measurements. Med Princ Pract. Jan-Mar. 2002;11(1):18-22. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 12116689].
147 Ali MJ, Davison P, Pickett W, et al. ACC/AHA guidelines as predictors of postoperative cardiac outcomes. Can J Anaesth. Jan. 2000;47(1):10-9. X-1,X-6. [pmid: 10626712].
148 Al-Khalili F, Janszky I, Andersson A, et al. Physical activity and exercise performance predict long-term prognosis in middle-aged women surviving acute coronary syndrome. J Intern Med. Feb. 2007;261(2):178-87. X-8. [pmid: 17241183].
149 Al-Khatib SM, Hellkamp AS, Lee KL, et al. Implantable cardioverter defibrillator therapy in patients with prior coronary revascularization in the Sudden Cardiac Death in Heart Failure Trial (SCD-HeFT). J Cardiovasc Electrophysiol. Oct. 2008;19(10):1059-65. X-1,X-8. [pmid: 18479330].
150 Al-Khatib SM, Sanders GD, Bigger JT, et al. Preventing tomorrow's sudden cardiac death today: part I: Current data on risk stratification for sudden cardiac death. Am Heart J. Jun. 2007;153(6):941-50. X-1,X-2,X-3,X-4,X-5,X-6,X-7,X-8. [pmid: 17540194].
151 Allareddy V, Ward MM, Ely JW, et al. Impact of complications on outcomes following aortic and mitral valve replacements in the United States. J Cardiovasc Surg (Torino). Jun. 2007;48(3):349-57. X-1,X-6.
152 Al-Lawati JA, Barakat NM, Al-Lawati AM, et al. Optimal cut-points for body mass index, waist circumference and waist-to-hip ratio using the Framingham coronary heart disease risk score in an Arab population of the Middle East. Diab Vasc Dis Res. Nov. 2008;5(4):304-9. X-5,X-6, Middle East. [pmid: 18958841].
153 Allison MA, DiTomasso D, Criqui MH, et al. Renal artery calcium: relationship to systemic calcified atherosclerosis. Vasc Med. Nov. 2006;11(4):232-8. X-1,X-6,X-8. [pmid: 17390546].
154 Al-Mallah M, Dajani K, Hudson M, et al. Long-term outcomes based on time-to-angioplasty in patients admitted with non-ST-segment elevation acute coronary syndromes. J Invasive Cardiol. May. 2005;17(5):251-5. X-1,X-8. [pmid: 15879604].
155 Almeda FQ, Hendel RC, Nathan S, et al. Improved in-hospital outcomes in acute coronary syndromes (unstable angina/non-ST segment elevation myocardial infarction) despite similar TIMI risk scores. J Invasive Cardiol. Sep. 2003;15(9):502-6. X-1,X-8. [pmid: 12947210].
156 Almeida R, Mariano L, Gavina C, et al. The value of NT-proBNP in early risk stratification of acute coronary syndromes. Rev Port Cardiol. Jan. 2006;25(1):71-5. X-1,X-7,X-8. [pmid: 16623357].
157 Al-Nozha MM, Arafah MR, Al-Maatouq MA, et al. Hyperlipidemia in Saudi Arabia. Saudi Med J. Feb. 2008;29(2):282-7. X-1,X-2,X-5,X-6. [pmid: 18246242].
158 Al-Nozha MM, Arafah MR, Al-Mazrou YY, et al. Coronary artery disease in Saudi Arabia. Saudi Med J. Sep. 2004;25(9):1165-71. X-1,X-6,X-8. [pmid: 15448760].
159 Alonzo AA. Long-term health consequences of delayed childbirth: NHANES III. Womens Health Issues. Jan-Feb. 2002;12(1):37-45. X-1,X-2,X-5. [pmid: 11786291].
160 Al-Ruzzeh S, Asimakopoulos G, Ambler G, et al. Validation of four different risk stratification systems in patients undergoing off-pump coronary artery bypass surgery: a UK multicentre analysis of 2223 patients. Heart. Apr. 2003;89(4):432-5. X-1,X-6,X-8. [pmid: 12639875].
161 Al-Ruzzeh S, Athanasiou T, George S, et al. Is the use of cardiopulmonary bypass for multivessel coronary artery bypass surgery an independent predictor of operative mortality in patients with ischemic left ventricular dysfunction?. Ann Thorac Surg. Aug. 2003;76(2):444-51. discussion 451-2. X-1,X-2,X-6,X-8. [pmid: 12902081].
162 Alsaileek AA, Osranek M, Fatema K, et al. Predictive value of normal left atrial volume in stress echocardiography. J Am Coll Cardiol. Mar. 7. 2006;47(5):1024-8. X-1,X-5,X-6,X-7,X-8. [pmid: 16516088].
163 Alserius T, Anderson RE, Hammar N, et al. Elevated glycosylated haemoglobin (HbA1c) is a risk marker in coronary artery bypass surgery. Scand Cardiovasc J. Dec. 2008;42(6):392-8. X-1,X-7,X-8. [pmid: 18609043].
164 Alter DA, Austin PC, Tu JV. Community factors, hospital characteristics and inter-regional outcome variations following acute myocardial infarction in Canada. Can J Cardiol. Mar. 2005;21(3):247-55. X-1,X-8. [pmid: 15776114].
165 Alter DA, Eny K. The relationship between the supply of fast-food chains and cardiovascular outcomes. Can J Public Health. May-Jun. 2005;96(3):173-7. X-1,X-5. [pmid: 15913078].
166 Alter DA, Iron K, Austin PC, et al. Influence of education and income on atherogenic risk factor profiles among patients hospitalized with acute myocardial infarction. Can J Cardiol. Oct. 2004;20(12):1219-28. X-1,X-6,X-8. [pmid: 15494774].
167 Alter DA, Venkatesh V, Chong A. Evaluating the performance of the Global Registry of Acute Coronary Events risk-adjustment index across socioeconomic strata among patients discharged from the hospital after acute myocardial infarction. Am Heart J. Feb. 2006;151(2):323-31. X-1,X-6,X-8. [pmid: 16442894].
168 Altin T, Berkalp B, Ozdol C, et al. Angiographic restenosis in ephesos coronary stents: experience from a large medical center in Ankara, Turkey. Angiology. Feb-Mar. 2008;59(1):47-51. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18319221].
169 Altunkeser BB, Ozdemir K, Gok H, et al. Can P wave parameters obtained from 12-lead surface electrocardiogram be a predictor for atrial fibrillation in patients who have structural heart disease?. Angiology. Jul-Aug. 2003;54(4):475-9. X-1,X-5,X-6,X-7. [pmid: 12934768].
170 Alvarez Tamargo JA, Martin-Ambrosio ES, Tarin ER, et al. Significance of the treadmill scores and high-risk criteria for exercise testing in non-high-risk patients with unstable angina and an intermediate Duke treadmill score. Acta Cardiol. Oct. 2008;63(5):557-64. X-7,X-8. [pmid: 19013997].
171 Alverzo JP. Predictors of disorientation among brain injury and stroke patients during rehabilitation. Rehabil Nurs. Nov-Dec. 2005;30(6):230-8. X-1,X-6,X-7,X-8. [pmid: 16294802].
172 Amano T, Matsubara T, Uetani T, et al. Impact of metabolic syndrome on tissue characteristics of angiographically mild to moderate coronary lesions integrated backscatter intravascular ultrasound study. J Am Coll Cardiol. Mar. 20. 2007;49(11):1149-56. X-1,X-2,X-5,X-6,X-7. [pmid: 17367657].
173 Amanullah AM, Berman DS, Kang X, et al. Enhanced prognostic stratification of patients with left ventricular hypertrophy with the use of single-photon emission computed tomography. Am Heart J. Sep. 2000;140(3):456-62. X-1D,X-2,X-8. [pmid: 10966548].
174 Amar D, Shi W, Hogue CW Jr, et al. Clinical prediction rule for atrial fibrillation after coronary artery bypass grafting. J Am Coll Cardiol. Sep. 15. 2004;44(6):1248-53. X-1,X-6,X-8. [pmid: 15364327].
175 Amighi J, Sabeti S, Schlager O, et al. Low serum magnesium predicts neurological events in patients with advanced atherosclerosis. Stroke. Jan. 2004;35(1):22-7. X-1,X-7,X-8. [pmid: 14657448].
176 Amin RS, Kimball TR, Bean JA, et al. Left ventricular hypertrophy and abnormal ventricular geometry in children and adolescents with obstructive sleep apnea. Am J Respir Crit Care Med. May. 15. 2002;165(10):1395-9. X-1,X-6,X-7. [pmid: 12016102].
177 Ammouri AA, Neuberger G. The Perception of Risk of Heart Disease Scale: development and psychometric analysis. J Nurs Meas. 2008;16(2):83-97. X-1,X-2,X-5,X-6. [pmid: 18939714].
178 Amoroso G, Sarti M, Bellucci R, et al. Clinical and procedural predictors of nurse workload during and after invasive coronary procedures: the potential benefit of a systematic radial access. Eur J Cardiovasc Nurs. Sep. 2005;4(3):234-41. X-1,X-6. [pmid: 15914085].
179 Anand DV, Lahiri A, Lim E, et al. The relationship between plasma osteoprotegerin levels and coronary artery calcification in uncomplicated type 2 diabetic subjects. J Am Coll Cardiol. May. 2. 2006;47(9):1850-7. X-1,X-2,X-5,X-6,X-8, (UK). [pmid: 16682312].
180 Ananthasubramaniam K, Chow BJ, Ruddy TD, et al. Does electrocardiographic Q wave burden predict the extent of scarring or hibernating myocardium as quantified by positron emission tomography?. Can J Cardiol. Jan. 2005;21(1):51-6. X-1,X-6,X-7,X-8. [pmid: 15685303].
181 Anavekar NS, Mirza A, Skali H, et al. Risk assessment in patients with depressed left ventricular function after myocardial infarction using the myocardial performance index--Survival and Ventricular Enlargement (SAVE) experience. J Am Soc Echocardiogr. Jan. 2006;19(1):28-33. X-8. [pmid: 16423666].
182 Andersen K, Bregendahl M, Kaestel H, et al. Haematoma after coronary angiography and percutaneous coronary intervention via the femoral artery frequency and risk factors. Eur J Cardiovasc Nurs. Jun. 2005;4(2):123-7. X-1,X-6,X-8. [pmid: 15869905].
183 Andersen LB, Sardinha LB, Froberg K, et al. Fitness, fatness and clustering of cardiovascular risk factors in children from Denmark, Estonia and Portugal: the European Youth Heart Study. Int J Pediatr Obes. 1. 2008;3:58-66. X-1,X-6,X-8.
184 Anderson GL, Limacher M, Assaf AR, et al. Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women's Health Initiative randomized controlled trial. JAMA. Apr. 14. 2004;291(14):1701-12. X-1,X-2. [pmid: 15082697].
185 Anderson JL. Lipoprotein-associated phospholipase A2: an independent predictor of coronary artery disease events in primary and secondary prevention. Am J Cardiol. Jun. 16. 2008;101(12A):23F-33F. X-2,X-4,X-5.
186 Anderson JL, Carlquist JF, Roberts WL, et al. Asymmetric dimethylarginine, cortisol/cortisone ratio, and C-peptide: markers for diabetes and cardiovascular risk?. Am Heart J. Jan. 2007;153(1):67-73. X-1,X-2. [pmid: 17174641].
187 Anderson JL, Krause-Steinrauf H, Goldman S, et al. Failure of benefit and early hazard of bucindolol for Class IV heart failure. J Card Fail. Aug. 2003;9(4):266-77. X-6. [pmid: 13680547].
188 Anderson KM, Odell PM, Wilson PW, et al. Cardiovascular disease risk profiles. Am Heart J. Jan. 1991;121(1 Pt 2):293-8. X-2. [pmid: 1985385].
189 Anderson KM, Wilson PW, Odell PM, et al. An updated coronary risk profile. A statement for health professionals. Circulation. Jan. 1991;83(1):356-62. X-2. [pmid: 1984895].
190 Andre-Petersson L, Hedblad B, Janzon L, et al. Social support and behavior in a stressful situation in relation to myocardial infarction and mortality: who is at risk? Results from prospective cohort study “Men born in 1914,” Malmo, Sweden. Int J Behav Med. 2006;13(4):340-7. X-1,X-2. [pmid: 17228992].
191 Andresdottir MB, Sigfusson N, Sigvaldason H, et al. Erythrocyte sedimentation rate, an independent predictor of coronary heart disease in men and women: The Reykjavik Study. Am J Epidemiol. Nov. 1. 2003;158(9):844-51. X-1F,X-2. [pmid: 14585762].
192 Andresdottir MB, Sigurdsson G, Sigvaldason H, et al. Fifteen percent of myocardial infarctions and coronary revascularizations explained by family history unrelated to conventional risk factors. The Reykjavik Cohort Study. Eur Heart J. Nov. 2002;23(21):1655-63. X-1F,X-2. [pmid: 12398822].
193 Andresen D, Steinbeck G, Bruggemann T, et al. Risk stratification following myocardial infarction in the thrombolytic era: a two-step strategy using noninvasive and invasive methods. J Am Coll Cardiol. Jan. 1999;33(1):131-8. X-1,X-6,X-8. [pmid: 9935019].
194 Andrikoula M, McDowell IF. The contribution of ApoB and ApoA1 measurements to cardiovascular risk assessment. Diabetes Obes Metab. Apr. 2008;10(4):271-8. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 18333887].
195 Ansai T, Takata Y, Soh I, et al. Association of chewing ability with cardiovascular disease mortality in the 80-year-old Japanese population. Eur J Cardiovasc Prev Rehabil. Feb. 2008;15(1):104-6. X-1,X-2. [pmid: 18277194].
196 Anselmi M, Pilati M, Golia G, et al. Ischemia induced by transesophageal atrial pacing stress echocardiography predicts long-term mortality. Cardiology. 2008;111(2):111-8. X-1,X-2,X-8. [pmid: 18376122].
197 Antman EM, Cohen M, Bernink PJ, et al. The TIMI risk score for unstable angina/non-ST elevation MI: A method for prognostication and therapeutic decision making. JAMA. Aug. 16. 2000;284(7):835-42. X-8. [pmid: 10938172].
198 Antonicelli R, Olivieri F, Bonafe M, et al. The interleukin-6 -174 G>C promoter polymorphism is associated with a higher risk of death after an acute coronary syndrome in male elderly patients. Int J Cardiol. Sep. 1. 2005;103(3):266-71. X-1,X-7,X-8. [pmid: 16098388].
199 Antunes PE, Eugenio L, Ferrao de Oliveira J, et al. Mortality risk prediction in coronary surgery: a locally developed model outperforms external risk models. Interact Cardiovasc Thorac Surg. Aug. 2007;6(4):437-41. X-1,X-6,X-8. [pmid: 17669892].
200 Anzai T, Yoshikawa T, Kaneko H, et al. Association between serum C-reactive protein elevation and left ventricular thrombus formation after first anterior myocardial infarction. Chest. Feb. 2004;125(2):384-9. X-1,X-2,X-6,X-7,X-8. [pmid: 14769713].
201 Aono Y, Ohkubo T, Kikuya M, et al. Plasma fibrinogen, ambulatory blood pressure, and silent cerebrovascular lesions: the Ohasama study. Arterioscler Thromb Vasc Biol. Apr. 2007;27(4):963-8. X-1,X-5,X-6. [pmid: 17272746].
202 Appel SJ, Giger JN, Davidhizar RE. Opportunity cost: the impact of contextual risk factors on the cardiovascular health of low-income rural southern African American women. J Cardiovasc Nurs. Sep-Oct. 2005;20(5):315-24. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16141776].
203 Appelros P, Terent A. Characteristics of the National Institute of Health Stroke Scale: results from a population-based stroke cohort at baseline and after one year. Cerebrovasc Dis. 2004;17(1):21-7. X-1,X-6. [pmid: 14530634].
204 Apple FS, Smith SW, Pearce LA, et al. Assessment of the multiple-biomarker approach for diagnosis of myocardial infarction in patients presenting with symptoms suggestive of acute coronary syndrome. Clin Chem. Jan. 2009;55(1):93-100. X-1,X-8. [pmid: 19028826].
205 Appoloni O, Dupont E, Vandercruys M, et al. Association between the TNF-2 allele and a better survival in cardiogenic shock. Chest. Jun. 2004;125(6):2232-7. X-1,X-6,X-7,X-8. [pmid: 15189946].
206 Arad Y. Beyond traditional risk factor analysis for coronary artery disease: the case for coronary artery calcium assessment with electron beam computed tomography. Prev Cardiol. Spring. 2002;5(2):62-7. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 11986549].
207 Arbogast PG, Kaltenbach L, Ding H, et al. Adjustment for multiple cardiovascular risk factors using a summary risk score. Epidemiology. Jan. 2008;19(1):30-7. X-1,X-2,X-5. [pmid: 18091000].
208 Arboix A, Cendros V, Besa M, et al. Trends in risk factors, stroke subtypes and outcome. Nineteen-year data from the Sagrat Cor Hospital of Barcelona stroke registry. Cerebrovasc Dis. 2008;26(5):509-16. X-1,X-8. [pmid: 18810238].
209 Arca M, Montali A, Valiante S, et al. Usefulness of atherogenic dyslipidemia for predicting cardiovascular risk in patients with angiographically defined coronary artery disease. Am J Cardiol. Nov. 15. 2007;100(10):1511-6. X-1,X-8. [pmid: 17996510].
210 Ariceta G, Brooks ER, Langman CB. Assessing cardiovascular risk in children with chronic kidney disease. B-type natriuretic peptide: a potential new marker. Pediatr Nephrol. Dec. 2005;20(12):1701-7. X-1,X-4,X-5. [pmid: 16082547].
211 Ariesen MJ, Algra A, Koudstaal PJ, et al. Risk of intracerebral hemorrhage in patients with arterial versus cardiac origin of cerebral ischemia on aspirin or placebo: analysis of individual patient data from 9 trials. Stroke. Mar. 2004;35(3):710-4. X-1,X-2,X-8. [pmid: 14764931].
212 Ariyarajah V, Fernandes J, Kranis M, et al. Prospective evaluation of atrial tachyarrhythmias in patients with interatrial block. Int J Cardiol. Jun. 12. 2007;118(3):332-7. X-1,X-2,X-6,X-7,X-8. [pmid: 17027099].
213 Ariyarajah V, Malinski M, Zieroth S, et al. Risk stratification for recurrent heart failure in patients post-myocardial infarction with electrocardiographic and echocardiographic left atrial abnormality. Am J Cardiol. May. 15. 2008;101(10):1373-8. X-1,X-8. [pmid: 18471444].
214 Arking DE, Becker DM, Yanek LR, et al. KLOTHO allele status and the risk of early-onset occult coronary artery disease. Am J Hum Genet. May. 2003;72(5):1154-61. X-1,X-6. [pmid: 12669274].
215 Armstrong KA, Rakhit DJ, Case C, et al. Derivation and validation of a disease-specific risk score for cardiac risk stratification in chronic kidney disease. Nephrol Dial Transplant. Oct. 2005;20(10):2097-104. X-1,X-8. [pmid: 16014347].
216 Aroney CN, Dunlevie HL, Bett JH. Use of an accelerated chest pain assessment protocol in patients at intermediate risk of adverse cardiac events. Med J Aust. Apr. 21. 2003;178(8):370-4. X-1,X-5. [pmid: 12697007].
217 Aronow WS, Ahn C. Reduction of coronary events with aspirin in older patients with prior myocardial infarction treated with and without statins. Heart Dis. May-Jun. 2002;4(3):159-61. X-1,X-8. [pmid: 12028600].
218 Aronson D, Hammerman H, Kapeliovich MR, et al. Fasting glucose in acute myocardial infarction: incremental value for long-term mortality and relationship with left ventricular systolic function. Diabetes Care. Apr. 2007;30(4):960-6. X-1E,X-1F,X-2,X-6,X-8. [pmid: 17392556].
219 Aronson S, Dupont F, Savage R, et al. Changes in regional myocardial function after coronary artery bypass graft surgery are predicted by intraoperative low-dose dobutamine echocardiography. Anesthesiology. Sep. 2000;93(3):685-92. X-1,X-6,X-7,X-8. [pmid: 10969301].
220 Arora P, Rajagopalam S, Ranjan R, et al. Preoperative use of angiotensin-converting enzyme inhibitors/angiotensin receptor blockers is associated with increased risk for acute kidney injury after cardiovascular surgery. Clin J Am Soc Nephrol. Sep. 2008;3(5):1266-73. X-1,X-6,X-8. [pmid: 18667735].
221 Arora RC, Legare JF, Buth KJ, et al. Identifying patients at risk of intraoperative and postoperative transfusion in isolated CABG: toward selective conservation strategies. Ann Thorac Surg. Nov. 2004;78(5):1547-54. X-1,X-6,X-8. [pmid: 15511428].
222 Asakimori Y, Yorioka N, Tanaka J, et al. Association between ENOS gene polymorphism and cardiovascular events in nondiabetic hemodialysis patients: a prospective study. Am J Kidney Dis. Jul. 2004;44(1):112-20. X-1. [pmid: 15211444].
223 Asanin M, Perunicic J, Mrdovic I, et al. Significance of recurrences of new atrial fibrillation in acute myocardial infarction. Int J Cardiol. May. 10. 2006;109(2):235-40. X-1,X-6,X-8. [pmid: 16005995].
224 Asayama K, Ohkubo T, Kikuya M, et al. Prediction of stroke by self-measurement of blood pressure at home versus casual screening blood pressure measurement in relation to the Joint National Committee 7 classification: the Ohasama study. Stroke. Oct. 2004;35(10):2356-61. X-1. [pmid: 15331792].
225 Asayama K, Ohkubo T, Kikuya M, et al. Use of 2003 European Society of Hypertension-European Society of Cardiology guidelines for predicting stroke using self-measured blood pressure at home: the Ohasama study. Eur Heart J. Oct. 2005;26(19):2026-31. X-2. [pmid: 15917279].
226 Asayama K, Ohkubo T, Kikuya M, et al. Prediction of stroke by home “morning” versus “evening” blood pressure values: the Ohasama study. Hypertension. Oct. 2006;48(4):737-43. X-1F,X-2,X-8. [pmid: 16952977].
227 Ascherio A, Rimm EB, Giovannucci E, et al. Blood donations and risk of coronary heart disease in men. Circulation. Jan. 2. 2001;103(1):52-7. X-1,X-2. [pmid: 11136685].
228 Ash AS, Posner MA, Speckman J, et al. Using claims data to examine mortality trends following hospitalization for heart attack in Medicare. Health Serv Res. Oct. 2003;38(5):1253-62. X-1,X-8. [pmid: 14596389].
229 Ashburn A, Hyndman D, Pickering R, et al. Predicting people with stroke at risk of falls. Age Ageing. May. 2008;37(3):270-6. X-1,X-6,X-7,X-8. [pmid: 18456791].
230 Ashley E, Myers J, Froelicher V. Exercise testing scores as an example of better decisions through science. Med Sci Sports Exerc. Aug. 2002;34(8):1391-8. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12165697].
231 Ashton WD, Nanchahal K, Wood DA. Leisure-time physical activity and coronary risk factors in women. J Cardiovasc Risk. Aug. 2000;7(4):259-66. X-1,X-6. [pmid: 11006896].
232 Ashton WD, Nanchahal K, Wood DA. Body mass index and metabolic risk factors for coronary heart disease in women. Eur Heart J. Jan. 2001;22(1):46-55. X-1,X-2,X-5,X-6. [pmid: 11133209].
233 Asimakopoulos G, Al-Ruzzeh S, Ambler G, et al. An evaluation of existing risk stratification models as a tool for comparison of surgical performances for coronary artery bypass grafting between institutions. Eur J Cardiothorac Surg. Jun. 2003;23(6):935-41. discussion 941-2. X-1,X-6,X-8. [pmid: 12829069].
234 Askew JW, Miller TD, Araoz PA, et al. Abnormal electron beam computed tomography results: the value of repeating myocardial perfusion single-photon emission computed tomography in the ongoing assessment of coronary artery disease. Mayo Clin Proc. Jan. 2008;83(1):17-22. X-1,X-2,X-5. [pmid: 18174005].
235 Askew JW, Miller TD, Hodge DO, et al. The value of myocardial perfusion single-photon emission computed tomography in screening asymptomatic patients with atrial fibrillation for coronary artery disease. J Am Coll Cardiol. Sep. 11. 2007;50(11):1080-5. X-1F,X-2,X-5,X-6. [pmid: 17825719].
236 Asplund K. What MONICA told us about stroke. Lancet Neurol. Jan. 2005;4(1):64-8. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15620858].
237 Assali AR, Brosh D, Vaknin-Assa H, et al. The impact of circadian variation on outcomes in emergency acute anterior myocardial infarction percutaneous coronary intervention. Catheter Cardiovasc Interv. Feb. 2006;67(2):221-6. X-1,X-8. [pmid: 16404750].
238 Assanelli D, Bonanome A, Grassi M, et al. Determinants of early-onset cardiovascular disease: a case-control study of young myocardial infarction patients. Ital Heart J. Aug. 2004;5(8):604-11. X-1,X-2,X-5,X-7,X-8. [pmid: 15554031].
239 Asselbergs FW, Hillege HL, van Gilst WH. Framingham score and microalbuminuria: combined future targets for primary prevention?. Kidney Int Suppl. Nov. 2004;(92):S111-4. X-2. [pmid: 15485402].
240 Assmann G, Cullen P, Erbey J, et al. Plasma sitosterol elevations are associated with an increased incidence of coronary events in men: results of a nested case-control analysis of the Prospective Cardiovascular Munster (PROCAM) study. Nutr Metab Cardiovasc Dis. Jan. 2006;16(1):13-21. X-2,X-5,X-8(~67%). [pmid: 16399487].
241 Assmann G, Cullen P, Evers T, et al. Importance of arterial pulse pressure as a predictor of coronary heart disease risk in PROCAM. Eur Heart J. Oct. 2005;26(20):2120-6. X-1E,X-1F, (Germany). [pmid: 16141262].
242 Assmann G, Cullen P, Schulte H. The Munster Heart Study (PROCAM). Results of follow-up at 8 years. Eur Heart J. Feb. A. 1998;19:A2-11. X-2. [pmid: 9519336].
243 Asztalos BF, Collins D, Cupples LA, et al. Value of high-density lipoprotein (HDL) subpopulations in predicting recurrent cardiovascular events in the Veterans Affairs HDL Intervention Trial. Arterioscler Thromb Vasc Biol. Oct. 2005;25(10):2185-91. X-1F,X-2,X-5,X-8(100%). [pmid: 16123324].
244 Asztalos BF, Collins D, Horvath KV, et al. Relation of gemfibrozil treatment and high-density lipoprotein subpopulation profile with cardiovascular events in the Veterans Affairs High-Density Lipoprotein Intervention Trial. Metabolism. Jan. 2008;57(1):77-83. X-1,X-2,X-6,X-8(100%). [pmid: 18078862].
245 Atanassova PA, Chalakova NT, Dimitrov BD. Major vascular events after transient ischaemic attack and minor ischaemic stroke: post hoc modelling of incidence dynamics. Cerebrovasc Dis. 2008;25(3):225-33. X-7,X-8. [pmid: 18216464].
246 Attar MN, Wong K, Groves DG, et al. Clinical implications of QRS duration and QT peak prolongation in patients with suspected coronary disease referred for elective cardiac catheterization. Ann Noninvasive Electrocardiol. Apr. 2008;13(2):106-12. X-1F,X-1D,X-8(100%). [pmid: 18426435].
247 Augustin T, Glass TA, James BD, et al. Neighborhood psychosocial hazards and cardiovascular disease: the Baltimore Memory Study. Am J Public Health. Sep. 2008;98(9):1664-70. X-2,X-6. [pmid: 18633086].
248 Austin PC, Alter DA, Anderson GM, et al. Impact of the choice of benchmark on the conclusions of hospital report cards. Am Heart J. Dec. 2004;148(6):1041-6. X-1,X-2,X-5,X-6,X-8. [pmid: 15632891].
249 Austin PC, Mamdani MM. A comparison of propensity score methods: a case-study estimating the effectiveness of post-AMI statin use. Stat Med. Jun. 30. 2006;25(12):2084-106. X-1,X-6,X-8. [pmid: 16220490].
250 Austin PC, Naylor CD, Tu JV. A comparison of a Bayesian vs. a frequentist method for profiling hospital performance. J Eval Clin Pract. Feb. 2001;7(1):35-45. X-1,X-5,X-6,X-7,X-8. [pmid: 11240838].
251 Austin PC, Schull MJ. Quantile regression: a statistical tool for out-of-hospital research. Acad Emerg Med. Jul. 2003;10(7):789-97. X-1,X-4,X-5,X-6. [pmid: 12837655].
252 Avakian SD, Grinberg M, Ramires JA, et al. Outcome of adults with asymptomatic severe aortic stenosis. Int J Cardiol. Jan. 24. 2008;123(3):322-7. X-1,X-7,X-8. [pmid: 17395323].
253 Avierinos JF, Brown RD, Foley DA, et al. Cerebral ischemic events after diagnosis of mitral valve prolapse: a community-based study of incidence and predictive factors. Stroke. Jun. 2003;34(6):1339-44. X-1,X-5,X-6. [pmid: 12738894].
254 Aviv RI, Mandelcorn J, Chakraborty S, et al. Alberta Stroke Program Early CT Scoring of CT perfusion in early stroke visualization and assessment. AJNR Am J Neuroradiol. Nov-Dec. 2007;28(10):1975-80. X-1,X-5,X-6,X-7,X-8. [pmid: 17921237].
255 Ayanian JZ, Landon BE, Landrum MB, et al. Use of cholesterol-lowering therapy and related beliefs among middle-aged adults after myocardial infarction. J Gen Intern Med. Feb. 2002;17(2):95-102. X-1,X-2,X-5,X-6,X-8. [pmid: 11841524].
256 Aylin P, Bottle A, Majeed A. Use of administrative data or clinical databases as predictors of risk of death in hospital: comparison of models. BMJ. May. 19. 2007;334(7602):1044. X-1. [pmid: 17452389].
257 Aytemir K, Aksoyek S, Ozer N, et al. Atrial fibrillation after coronary artery bypass surgery: P wave signal averaged ECG, clinical and angiographic variables in risk assessment. Int J Cardiol. Apr. 30. 1999;69(1):49-56. X-1,X-6. [pmid: 10362372].
258 Azadbakht L, Mirmiranr R, Azizi F. Predictors of cardiovascular risk factors in Tehranian adults: diet and lifestyle. East Mediterr Health J. Jan-Mar. 2006;12(1-2):88-97. X-1,X-2,X-5,X-6. [pmid: 17037225].
259 Azevedo A, Bettencourt P, Almeida PB, et al. Increasing number of components of the metabolic syndrome and cardiac structural and functional abnormalities--cross-sectional study of the general population. BMC Cardiovasc Disord. 2007;7:17. X-2,X-5. [pmid: 17555566].
260 Azevedo Filho CF, Hadlich M, Petriz JL, et al. Quantification of left ventricular infarcted mass on cardiac magnetic resonance imaging: comparison between planimetry and the semiquantitative visual scoring method. Arq Bras Cardiol. Aug. 2004;83(2):118-24. 111. 7. X-1,X-5,X-6,X-7,X-8. [pmid: 15322654].
261 Aziz IN, Lee JT, Kopchok GE, et al. Cardiac risk stratification in patients undergoing endoluminal graft repair of abdominal aortic aneurysm: a single-institution experience with 365 patients. J Vasc Surg. Jul. 2003;38(1):56-60. X-1,X-2,X-8. [pmid: 12844089].
262 Aziz S, Stables RH, Grayson AD, et al. Percutaneous coronary intervention for chronic total occlusions: improved survival for patients with successful revascularization compared to a failed procedure. Catheter Cardiovasc Interv. Jul. 1. 2007;70(1):15-20. X-1,X-5,X-6,X-8. [pmid: 17580364].
263 Aznaouridis K, Vlachopoulos C, Dima I, et al. Triglyceride level is associated with wave reflections and arterial stiffness in apparently healthy middle-aged men. Heart. May. 2007;93(5):613-4. X-5,X-6. [pmid: 17435072].
264 Badr KF, Boudia KM, Alami M, et al. Physician assessment of stroke risk in hypertensive patients in the Middle East and Africa: results of the action survey. Ethn Dis. Spring. 2007;17(2):274-9. X-1F,X-1G,X-2,X-5,X-6, (Various Countries). [pmid: 17682358].
265 Badzioch MD, Thomas DC, Jarvik GP. Summary report: Missing data and pedigree and genotyping errors. Genet Epidemiol. 1. 2003;25:S36-42. X-1,X-4,X-5,X-6. [pmid: 14635167].
266 Bae S, Zhang H, Rivers PA, et al. Managing and analysing a large health-care system database for predicting in-hospital mortality among acute myocardial infarction patients. Health Serv Manage Res. Feb. 2007;20(1):1-8. X-1,X-2,X-6,X-8. [pmid: 17270062].
267 Bahmanyar S, Montgomery SM, Weiss RJ, et al. Maternal smoking during pregnancy, other prenatal and perinatal factors, and the risk of Legg-Calve-Perthes disease. Pediatrics. Aug. 2008;122(2):e459-64. X-1,X-2,X-5,X-6. [pmid: 18625663].
268 Bahr R, Christenson R, Farin H, et al. Prodromal symptoms of acute myocardial infarction: overview of evidence. Md Med. 2001. Spring. 49-59. X-1,X-2,X-4,X-5.
269 Bahrmand AR, Bahadori M, Hossaini A, et al. Chlamydia pneumoniae DNA is more frequent in advanced than in mild atherosclerosis lesions. Scand J Infect Dis. 2004;36(2):119-23. X-1,X-2,X-5,X-6,X-7. [pmid: 15061666].
270 Bailey JJ, Berson AS, Handelsman H. Dysrhythmia hazard after hospitalization for myocardial infarction: two ECG prognostic methods compared. J Electrocardiol. 2000;33. 151-4. X-1,X-8.
271 Bailey JJ, Berson AS, Handelsman H, et al. Utility of current risk stratification tests for predicting major arrhythmic events after myocardial infarction. J Am Coll Cardiol. Dec. 2001;38(7):1902-11. X-1,X-2,X-4,X-5,X-6,X-8. [pmid: 11738292].
272 Bailie GR, Mason NA, Elder SJ, et al. Large variations in prescriptions of gastrointestinal medications in hemodialysis patients on three continents: the Dialysis Outcomes and Practice Patterns Study (DOPPS). Hemodial Int. Apr. 2006;10(2):180-8. X-1,X-2,X-5,X-6. [pmid: 16623672].
273 Bainbridge D, Cheng D, Martin J, et al. Does off-pump or minimally invasive coronary artery bypass reduce mortality, morbidity, and resource utilization when compared with percutaneous coronary intervention? A meta-analysis of randomized trials. J Thorac Cardiovasc Surg. Mar. 2007;133(3):623-31. X-1,X-4,X-5,X-8. [pmid: 17320555].
274 Bairey Merz CN, Olson M, McGorray S, et al. Physical activity and functional capacity measurement in women: a report from the NHLBI-sponsored WISE study. J Womens Health Gend Based Med. Sep. 2000;9(7):769-77. X-1,X-6,X-8. [pmid: 11025869].
275 Bairey Merz N. Assessment of patients at intermediate cardiac risk. Am J Cardiol. Oct. 17. 2005;96(8A):2J-10J. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15979422].
276 Bak S, Andersen M, Tsiropoulos I, et al. Risk of stroke associated with nonsteroidal anti-inflammatory drugs: a nested case-control study. Stroke. Feb. 2003;34(2):379-86. X-1,X-5,X-6.
277 Bak S, Gaist D, Sindrup SH, et al. Genetic liability in stroke: a long-term follow-up study of Danish twins. Stroke. Mar. 2002;33(3):769-74. X-1,X-2,X-8. [pmid: 11872902].
278 Bak S, Tsiropoulos I, Kjaersgaard JO, et al. Selective serotonin reuptake inhibitors and the risk of stroke: a population-based case-control study. Stroke. Jun. 2002;33(6):1465-73. X-1,X-2,X-5,X-8. [pmid: 12052976].
279 Baker WH, Howard VJ, Howard G, et al. Effect of contralateral occlusion on long-term efficacy of endarterectomy in the asymptomatic carotid atherosclerosis study (ACAS). ACAS Investigators Stroke. Oct. 2000;31(10):2330-4. X-1,X-5,X-6.
280 Bakhai A, Collinson J, Flather MD, et al. Diabetic patients with acute coronary syndromes in the UK: high risk and under treated. Results from the prospective registry of acute ischaemic syndromes in the UK (PRAIS-UK). Int J Cardiol. Apr. 8. 2005;100(1):79-84. X-1,X-8. [pmid: 15820289].
281 Bakhtiary F, Keller H, Dogan S, et al. Venoarterial extracorporeal membrane oxygenation for treatment of cardiogenic shock: clinical experiences in 45 adult patients. J Thorac Cardiovasc Surg. Feb. 2008;135(2):382-8. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18242273].
282 Bakken S, Dolter KJ, Holzemer WL. A comparison of three strategies for risk-adjustment of outcomes for AIDS patients hospitalized for Pneumocystis carinii pneumonia. J Adv Nurs. Dec. 1999;30(6):1424-31. X-1,X-6. [pmid: 10583654].
283 Balady GJ, Larson MG, Vasan RS, et al. Usefulness of exercise testing in the prediction of coronary disease risk among asymptomatic persons as a function of the Framingham risk score. Circulation. Oct. 5. 2004;110(14):1920-5. X-1F,X-2. [pmid: 15451778].
284 Baldassarre D, Amato M, Pustina L, et al. Measurement of carotid artery intima-media thickness in dyslipidemic patients increases the power of traditional risk factors to predict cardiovascular events. Atherosclerosis. Apr. 2007;191(2):403-8. X-1, (Italy). [pmid: 16682042].
285 Baldelli R, De Marinis L, Bianchi A, et al. Microalbuminuria in insulin sensitivity in patients with growth hormone-secreting pituitary tumor. J Clin Endocrinol Metab. Mar. 2008;93(3):710-4. X-1,X-2,X-5,X-6,X-7. [pmid: 18160471].
286 Baldinger B, Schwarz C, Jaggy C. Cardiovascular risk factors, BMI and mortality in a cohort of Swiss males (1976-2001) with high-sum-assured life insurance cover. J Insur Med. 2006;38(1):44-53. X-1F,X-2, (Switzerland). [pmid: 16642642].
287 Baldus S, Heeschen C, Meinertz T, et al. Myeloperoxidase serum levels predict risk in patients with acute coronary syndromes. Circulation. Sep. 23. 2003;108(12):1440-5. X-1,X-8. [pmid: 12952835].
288 Balkhy HH, Quinn CC, Lois KH, et al. Routine intracoronary shunting in multivessel off-pump coronary artery bypass: a retrospective review of in-hospital outcomes in 550 consecutive cases. Heart Surg Forum. 2003;6(2):E32-5. X-1,X-6,X-8. [pmid: 12716650].
289 Ballal RS, Kapadia S, Secknus MA, et al. Prognosis of patients with vascular disease after clinical evaluation and dobutamine stress echocardiography. Am Heart J. Mar. 1999;137(3):469-75. X-1,X-5,X-6,X-8. [pmid: 10047628].
290 Ballantyne CM, Hoogeveen RC. Role of lipid and lipoprotein profiles in risk assessment and therapy. Am Heart J. Aug. 2003;146(2):227-33. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12891189].
291 Ballotta E, Da Giau G, Militello C, et al. Major elective surgery for vascular disease in patients aged 80 or more: perioperative (30-day) outcomes. Ann Vasc Surg. Nov. 2007;21(6):772-9. X-1,X-6,X-8. [pmid: 17532607].
292 Banerjee SK, Haque KM, Sharma AK, et al. Role of exercise tolerance test (ETT) and gated single photon emission computed tomography-myocardial perfusion imaging (SPECT-MPI) in predicting severity of ischemia in patients with chest pain. Bangladesh Med Res Counc Bull. Apr. 2005;31(1):27-35. X-1,X-6,X-8. [pmid: 16689138].
293 Bang H, Vupputuri S, Shoham DA, et al. SCreening for Occult REnal Disease (SCORED): a simple prediction model for chronic kidney disease. Arch Intern Med. Feb. 26. 2007;167(4):374-81. X-1,X-6,X-8. [pmid: 17325299].
294 Bangalore S, Gopinath D, Yao SS, et al. Risk stratification using stress echocardiography: incremental prognostic value over historic, clinical, and stress electrocardiographic variables across a wide spectrum of bayesian pretest probabilities for coronary artery disease. J Am Soc Echocardiogr. Mar. 2007;20(3):244-52. X-1D,X-2,X-8(0-74%). [pmid: 17336749].
295 Banks JL, Marotta CA. Outcomes validity and reliability of the modified Rankin scale: implications for stroke clinical trials: a literature review and synthesis. Stroke. Mar. 2007;38(3):1091-6. X-1,X-4,X-5,X-8. [pmid: 17272767].
296 Bansal D, Eigenbrodt M, Gupta E, et al. Traditional risk factors and acute myocardial infarction in patients hospitalized with cocaine-associated chest pain. Clin Cardiol. Jun. 2007;30(6):290-4. X-1,X-2,X-6,X-7. [pmid: 17551964].
297 Bar KJ, Boettger MK, Koschke M, et al. Non-linear complexity measures of heart rate variability in acute schizophrenia. Clin Neurophysiol. Sep. 2007;118(9):2009-15. X-1,X-5,X-7. [pmid: 17646130].
298 Baran KW, Lasala JM, Cox DA, et al. A clinical risk score for prediction of stent thrombosis. Am J Cardiol. Sep. 1. 2008;102(5):541-5. X-6. [pmid: 18721509].
299 Barber M, Morton JJ, Macfarlane PW, et al. Elevated troponin levels are associated with sympathoadrenal activation in acute ischaemic stroke. Cerebrovasc Dis. 2007;23(4):260-6. X-1,X-2,X-6,X-8. [pmid: 17199083].
300 Barber PA, Demchuk AM, Hill MD, et al. The probability of middle cerebral artery MRA flow signal abnormality with quantified CT ischaemic change: targets for future therapeutic studies. J Neurol Neurosurg Psychiatry. Oct. 2004;75(10):1426-30. X-1,X-2,X-5,X-7,X-8. [pmid: 15377690].
301 Barber PA, Hill MD, Eliasziw M, et al. Imaging of the brain in acute ischaemic stroke: comparison of computed tomography and magnetic resonance diffusion-weighted imaging. J Neurol Neurosurg Psychiatry. Nov. 2005;76(11):1528-33. X-1,X-7,X-8. [pmid: 16227545].
302 Barbosa TM, Sgarbieri RN, Moreira Neto FF, et al. Evaluation of the NNECDSG Score in a Brazilian public hospital. Rev Bras Cir Cardiovasc. Jun. 2007;22(2):212-7. X-1,X-8. [pmid: 17992327].
303 Bare LA, Morrison AC, Rowland CM, et al. Five common gene variants identify elevated genetic risk for coronary heart disease. Genet Med. Oct. 2007;9(10):682-9. X-1G,X-2,X-5,X-6. [pmid: 18073581].
304 Baretti R, Pannek N, Knecht JP, et al. Risk stratification scores for predicting mortality in coronary artery bypass surgery. Thorac Cardiovasc Surg. Aug. 2002;50(4):237-46. X-1X-8. [pmid: 12165874].
305 Barlis P, Kaplan S, Dimopoulos K, et al. An indeterminate occlusion duration predicts procedural failure in the recanalization of coronary chronic total occlusions. Catheter Cardiovasc Interv. Apr. 1. 2008;71(5):621-8. X-1,X-2,X-6,X-8. [pmid: 18360843].
306 Barnason S, Zimmerman L, Nieveen J, et al. Usefulness of RISKO Heart Hazard Appraisal to Quantify CAD risk factor burden on the preoperative functioning of coronary artery bypass graft surgery patients. Prog Cardiovasc Nurs. Spring. 2007;22(2):81-7. X-1,X-5,X-6,X-8. [pmid: 17541317].
307 Barnekow-Bergkvist M, Hedberg G, Janlert U, et al. Adolescent determinants of cardiovascular risk factors in adult men and women. Scand J Public Health. Sep. 2001;29(3):208-17. X-1,X-6. [pmid: 11680773].
308 Barnes ME, Miyasaka Y, Seward JB, et al. Left atrial volume in the prediction of first ischemic stroke in an elderly cohort without atrial fibrillation. Mayo Clin Proc. Aug. 2004;79(8):1008-14. X-1. [pmid: 15301328].
309 Barrett-Connor E, Cauley JA, Kulkarni PM, et al. Risk-benefit profile for raloxifene: 4-year data From the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. J Bone Miner Res. Aug. 2004;19(8):1270-5. X-1,X-6. [pmid: 15231013].
310 Barthel P, Schneider R, Bauer A, et al. Risk stratification after acute myocardial infarction by heart rate turbulence. Circulation. Sep. 9. 2003;108(10):1221-6. X-1,X-8. [pmid: 12939209].
311 Bartholomew BA, Harjai KJ, Dukkipati S, et al. Impact of nephropathy after percutaneous coronary intervention and a method for risk stratification. Am J Cardiol. Jun. 15. 2004;93(12):1515-9. X-1,X-6,X-8. [pmid: 15194023].
312 Bartholomew BA, Sheps DS, Monroe S, et al. A population-based evaluation of the thrombolysis in myocardial infarction risk score for unstable angina and non-ST elevation myocardial infarction. Clin Cardiol. Feb. 2004;27(2):74-8. X-1D,X-2,X-8. [pmid: 14979624].
313 Barton CW, Hemphill JC 3rd. Cumulative dose of hypertension predicts outcome in intracranial hemorrhage better than American Heart Association guidelines. Acad Emerg Med. Aug. 2007;14(8):695-701. X-1,X-6,X-8. [pmid: 17656606].
314 Baruch L, Gage BF, Horrow J, et al. Can patients at elevated risk of stroke treated with anticoagulants be further risk stratified?. Stroke. Sep. 2007;38(9):2459-63. X-1,X-2,X-8. [pmid: 17673721].
315 Barud W, Palusinski R, Beltowski J, et al. Inverse relationship between total testosterone and anti-oxidized low density lipoprotein antibody levels in ageing males. Atherosclerosis. Oct. 2002;164(2):283-8. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 12204799].
316 Barzi F, Patel A, Woodward M, et al. A comparison of lipid variables as predictors of cardiovascular disease in the Asia Pacific region. Ann Epidemiol. May. 2005;15(5):405-13. X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9, (Various Countries). [pmid: 15840555].
317 Basarici I, Altekin RE, Demir I, et al. Urinary 8-isoprostane levels can indicate the presence, severity and extent of angiographic coronary artery disease. Acta Cardiol. Aug. 2008;63(4):415-22. X-7. [pmid: 18795577].
318 Basoglu T, Canbaz F, Sahin M, et al. Intracoronary versus intravenous injection of 99mTc-tetrofosmin: comparison of myocardial perfusion patterns and wall motion. Nucl Med Commun. May. 2004;25(5):469-74. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15100505].
319 Bassuk SS. The Reynolds Risk Score--improving cardiovascular risk prediction in women. AAOHN J. Apr. 2008;56(4):180. X-1G,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 18444407].
320 Basu AK, Pal SK, Guha S, et al. Carotid intima media thickness: an independent marker for assessment of macrovascular risk in diabetic patients. J Indian Med Assoc. Apr. 2005;103(4):234-6. X-1,X-5,X-6,X-7,X-8. [pmid: 16173433].
321 Bath P, Algert C, Chapman N, et al. Association of mean platelet volume with risk of stroke among 3134 individuals with history of cerebrovascular disease. Stroke. Mar. 2004;35(3):622-6. X-1,X-8. [pmid: 14976328].
322 Batty GD, Shipley MJ, Gale CR, et al. Does IQ predict total and cardiovascular disease mortality as strongly as other risk factors? Comparison of effect estimates using the Vietnam Experience Study. Heart. Dec. 2008;94(12):1541-4. X-1F,X-2. [pmid: 18801778].
323 Bauer A, Guzik P, Barthel P, et al. Reduced prognostic power of ventricular late potentials in post-infarction patients of the reperfusion era. Eur Heart J. Apr. 2005;26(8):755-61. X-1,X-8. [pmid: 15673543].
324 Bayes-Genis A, Vazquez R, Puig T, et al. Left atrial enlargement and NT-proBNP as predictors of sudden cardiac death in patients with heart failure. Eur J Heart Fail. Aug. 2007;9(8):802-7. X-1,X-6,X-8. [pmid: 17569580].
325 Bazzani LG, Marcin JP. Case volume and mortality in pediatric cardiac surgery patients in California, 1998-2003. Circulation. May. 22. 2007;115(20):2652-9. X-1,X-6. [pmid: 17485577].
326 Bazzano LA, He J, Ogden LG, et al. Legume consumption and risk of coronary heart disease in US men and women: NHANES I Epidemiologic Follow-up Study. Arch Intern Med. Nov. 26. 2001;161(21):2573-8. X-1,X-2. [pmid: 11718588].
327 Bazzano LA, He J, Ogden LG, et al. Dietary intake of folate and risk of stroke in US men and women: NHANES I Epidemiologic Follow-up Study. National Health and Nutrition Examination Survey. Stroke. May. 2002;33(5):1183-8. X-1,X-2. [pmid: 11988588].
328 Beanlands RS, Ruddy TD, deKemp RA, et al. Positron emission tomography and recovery following revascularization (PARR-1): the importance of scar and the development of a prediction rule for the degree of recovery of left ventricular function. J Am Coll Cardiol. Nov. 20. 2002;40(10):1735-43. X-1,X-5,X-6,X-7,X-8. [pmid: 12446055].
329 Bechtel JF, Detter C, Fischlein T, et al. Cardiac surgery in patients on dialysis: decreased 30-day mortality, unchanged overall survival. Ann Thorac Surg. Jan. 2008;85(1):147-53. X-1,X-2,X-8. [pmid: 18154800].
330 Beck AW, Murphy EH, Hocking JA, et al. Aortic reconstruction with femoral-popliteal vein: graft stenosis incidence, risk and reintervention. J Vasc Surg. Jan. 2008;47(1):36-43. discussion 44. X-1,X-2,X-5,X-6,X-8. [pmid: 18060726].
331 Becker CR. Estimation of cardiac event risk by MDCT. Eur Radiol. Feb. 2. 2005;15:B17-22. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15801053].
332 Becker CR, Kleffel T, Crispin A, et al. Coronary artery calcium measurement: agreement of multirow detector and electron beam CT. AJR Am J Roentgenol. May. 2001;176(5):1295-8. X-1,X-6,X-7. [pmid: 11312197].
333 Becker CR, Knez A, Ohnesorge B, et al. Visualization and quantification of coronary calcifications with electron beam and spiral computed tomography. Eur Radiol. 2000;10(4):629-35. X-1,X-2,X-4,X-5,X-6. [pmid: 10795546].
334 Belardi P, Lucertini G. Cerebral vasoreactivity does not predict cerebral ischaemia during carotid endarterectomy. J Cardiovasc Surg (Torino). Dec. 2003;44(6):731-5. X-1,X-2,X-6,X-7,X-8.
335 Beller GA. First annual Mario S. Verani, MD, Memorial lecture: clinical value of myocardial perfusion imaging in coronary artery disease. J Nucl Cardiol. Sep-Oct. 2003;10(5):529-42. X-1,X-2,X-3,X-4,X-5,X-6,X-7,X-8. [pmid: 14569247].
336 Bellocci F, Biasucci LM, Gensini GF, et al. Prognostic role of post-infarction C-reactive protein in patients undergoing implantation of cardioverter-defibrillators: design of the C-reactive protein Assessment after Myocardial Infarction to GUide Implantation of DEfibrillator (CAMI GUIDE) study. J Cardiovasc Med (Hagerstown). Apr. 2007;8(4):293-9. X-1,X-8. [pmid: 17413310].
337 Bendermacher BL, Teijink JA, Willigendael EM, et al. A clinical prediction model for the presence of peripheral arterial disease--the benefit of screening individuals before initiation of measurement of the ankle-brachial index: an observational study. Vasc Med. Feb. 2007;12(1):5-11. X-1,X-6. [pmid: 17451087].
338 Bengtson A, Karlsson T, Herlitz J. On the waiting list for possible coronary revascularisation. Symptoms relief during the first year and association between quality of life and the very long-term mortality risk. Int J Cardiol. Jan. 24. 2008;123(3):271-6. X-1,X-6,X-8. [pmid: 17407796].
339 Ben-Haim S, Kupzov E, Tamir A, et al. Evaluation of 18F-FDG uptake and arterial wall calcifications using 18F-FDG PET/CT. J Nucl Med. Nov. 2004;45(11):1816-21. X-1,X-2,X-5,X-6,X-7. [pmid: 15534049].
340 Benn M, Nordestgaard BG, Jensen GB, et al. Improving prediction of ischemic cardiovascular disease in the general population using apolipoprotein B: the Copenhagen City Heart Study. Arterioscler Thromb Vasc Biol. Mar. 2007;27(3):661-70. X-1F,X-8. [pmid: 17170368].
341 Bennermo M, Held C, Green F, et al. Prognostic value of plasma interleukin-6 concentrations and the -174 G > C and -572 G > C promoter polymorphisms of the interleukin-6 gene in patients with acute myocardial infarction treated with thrombolysis. Atherosclerosis. May. 2004;174(1):157-63. X-1,X-2,X-6,X-8. [pmid: 15135265].
342 Bennett-Guerrero E, Slaughter TF, White WD, et al. Preoperative anti-PF4/heparin antibody level predicts adverse outcome after cardiac surgery. J Thorac Cardiovasc Surg. Dec. 2005;130(6):1567-72. X-1,X-8. [pmid: 16308000].
343 Bensen JT, Li R, Hutchinson RG, et al. Family history of coronary heart disease and pre-clinical carotid artery atherosclerosis in African-Americans and whites: the ARIC study: Atherosclerosis Risk in Communities. Genet Epidemiol. 1999;16(2):165-78. X-1,X-6. [pmid: 10030399].
344 Benton JL, Blumenthal RS, Becker DM, et al. Predictors of low-density lipoprotein particle size in a high-risk African-American population. Am J Cardiol. Jun. 1. 2005;95(11):1320-3. X-1,X-5,X-6. [pmid: 15904636].
345 Benza RL, Cavender MA, Barchue J, et al. Alterations in the fibrinolytic cascade post-transplant: evidence of a bimodal expression pattern. J Heart Lung Transplant. May. 2007;26(5):494-7. X-1,X-2,X-6. [pmid: 17449419].
346 Berger C, Fiorelli M, Steiner T, et al. Hemorrhagic transformation of ischemic brain tissue: asymptomatic or symptomatic?. Stroke. Jun. 2001;32(6):1330-5. X-1,X-6,X-8. [pmid: 11387495].
347 Berger JS, Frye CB, Harshaw Q, et al. Impact of clopidogrel in patients with acute coronary syndromes requiring coronary artery bypass surgery: a multicenter analysis. J Am Coll Cardiol. Nov. 18. 2008;52(21):1693-701. X-1,X-6,X-8. [pmid: 19007688].
348 Berkowitsch A, Zareba W, Neumann T, et al. Risk stratification using heart rate turbulence and ventricular arrhythmia in MADIT II: usefulness and limitations of a 10-minute holter recording. Ann Noninvasive Electrocardiol. Jul. 2004;9(3):270-9. X-1,X-6,X-8. [pmid: 15245344].
349 Berman DS, Abidov A, Kang X, et al. Prognostic validation of a 17-segment score derived from a 20-segment score for myocardial perfusion SPECT interpretation. J Nucl Cardiol. Jul-Aug. 2004;11(4):414-23. X-1. [pmid: 15295410].
350 Berman M, Stamler A, Sahar G, et al. Validation of the 2000 Bernstein-Parsonnet score versus the EuroSCORE as a prognostic tool in cardiac surgery. Ann Thorac Surg. Feb. 2006;81(2):537-40. X-1,X-6,X-8. [pmid: 16427846].
351 Berry C, Kelly J, Cobbe SM, et al. Comparison of femoral bleeding complications after coronary angiography versus percutaneous coronary intervention. Am J Cardiol. Aug. 1. 2004;94(3):361-3. X-1,X-6,X-8. [pmid: 15276106].
352 Berry JD, Lloyd-Jones DM, Garside DB, et al. Social avoidance and long-term risk for cardiovascular disease death in healthy men: the Western Electric study. Ann Epidemiol. Aug. 2007;17(8):591-6. X-1F,X-2. [pmid: 17531506].
353 Bertolini S, Pisciotta L, Di Scala L, et al. Genetic polymorphisms affecting the phenotypic expression of familial hypercholesterolemia. Atherosclerosis. May. 2004;174(1):57-65. X-1,X-2,X-6. [pmid: 15135251].
354 Bertrand OF, Rodes-Cabau J, Larose E, et al. One-year clinical outcome after abciximab bolus-only compared with abciximab bolus and 12-hour infusion in the Randomized EArly Discharge after Transradial Stenting of CoronarY Arteries (EASY) Study. Am Heart J. Jul. 2008;156(1):135-40. X-1,X-6,X-8. [pmid: 18585508].
355 Bestehorn K, Wahle K. Impact of losartan on stroke risk in hypertensive patients in primary care. Clin Drug Investig. 2007;27(5):347-55. X-1F,X-2,X-6,X-8.
356 Bettencourt P, Ferreira A, Pardal-Oliveira N, et al. Clinical significance of brain natriuretic peptide in patients with postmyocardial infarction. Clin Cardiol. Dec. 2000;23(12):921-7. X-1,X-6,X-7,X-8. [pmid: 11129679].
357 Beulens JW, de Bruijne LM, Stolk RP, et al. High dietary glycemic load and glycemic index increase risk of cardiovascular disease among middle-aged women: a population-based follow-up study. J Am Coll Cardiol. Jul. 3. 2007;50(1):14-21. X-1F,X-2. [pmid: 17601539].
358 Bevilacqua S, Alkodami AA, Volpi E, et al. Risk stratification after coronary artery bypass surgery by a point-of-care test of platelet function. Ann Thorac Surg. Feb. 2009;87(2):496-502. X-1,X-8. [pmid: 19161767].
359 Bezanson JL, Weaver M, Kinney MR, et al. Presurgical risk factors for late extubation in Medicare recipients after cardiac surgery. Nurs Res. Jan-Feb. 2004;53(1):46-52. X-1,X-6,X-8. [pmid: 14726776].
360 Bhatt A, Vora NA, Thomas AJ, et al. Lower pretreatment cerebral blood volume affects hemorrhagic risks after intra-arterial revascularization in acute stroke. Neurosurgery. Nov. 2008;63(5):874-8. discussion 878-9. X-1,X-7. [pmid: 19005377].
361 Bhatti F, Grayson AD, Grotte G, et al. The logistic EuroSCORE in cardiac surgery: how well does it predict operative risk?. Heart. Dec. 2006;92(12):1817-20. X-1,X-8. [pmid: 16547206].
362 Biagini E, Elhendy A, Schinkel AF, et al. Prognostic significance of left anterior hemiblock in patients with suspected coronary artery disease. J Am Coll Cardiol. Sep. 6. 2005;46(5):858-63. X-1D,X-1F,X-2, (Netherlands). [pmid: 16139137].
363 Biagioli B, Scolletta S, Cevenini G, et al. A multivariate Bayesian model for assessing morbidity after coronary artery surgery. Crit Care. 2006;10(3):R94. X-1,X-8. [pmid: 16813658].
364 Biancari F, Heikkinen J, Mosorin M, et al. Predictors of diseased ascending aorta in patients undergoing off-pump coronary artery bypass surgery. Heart Surg Forum. 2006;9(6):E857-60. X-1,X-2,X-6,X-8. [pmid: 17060040].
365 Biancari F, Kangasniemi OP, Luukkonen J, et al. EuroSCORE predicts immediate and late outcome after coronary artery bypass surgery. Ann Thorac Surg. Jul. 2006;82(1):57-61. X-1,X-8. [pmid: 16798188].
366 Biancari F, Leo E, Ylonen K, et al. Value of the Glasgow Aneurysm Score in predicting the immediate and long-term outcome after elective open repair of infrarenal abdominal aortic aneurysm. Br J Surg. Jul. 2003;90(7):838-44. X-1,X-2,X-8. [pmid: 12854110].
367 Biancari F, Mahar MA, Mosorin M, et al. Immediate and intermediate outcome after off-pump and on-pump coronary artery bypass surgery in patients with unstable angina pectoris. Ann Thorac Surg. Oct. 2008;86(4):1147-52. X-1,X-8. [pmid: 18805150].
368 Biancari F, Salenius JP, Heikkinen M, et al. Risk-scoring method for prediction of 30-day postoperative outcome after infrainguinal surgical revascularization for critical lower-limb ischemia: a Finnvasc registry study. World J Surg. Jan. 2007;31(1):217-25. discussion 226-7. X-1,X-6. [pmid: 17171494].
369 Bianchi G, Nicolino F, Passerini G, et al. Plasma total homocysteine and cardiovascular risk in patients submitted to liver transplantation. Liver Transpl. Jan. 2006;12(1):105-11. X-1,X-5. [pmid: 16382457].
370 Bibbins-Domingo K, Gupta R, Na B, et al. N-terminal fragment of the prohormone brain-type natriuretic peptide (NT-proBNP), cardiovascular events, and mortality in patients with stable coronary heart disease. JAMA. Jan. 10. 2007;297(2):169-76. X-1. [pmid: 17213400].
371 Bickert AT, Gallagher C, Reiner A, et al. Nursing neurologic assessments after cardiac operations. Ann Thorac Surg. Feb. 2008;85(2):554-60. X-1,X-6,X-8. [pmid: 18222263].
372 Bidulescu A, Chambless LE, Siega-Riz AM, et al. Usual choline and betaine dietary intake and incident coronary heart disease: the Atherosclerosis Risk in Communities (ARIC) study. BMC Cardiovasc Disord. 2007;7:20. X-1F,X-1. [pmid: 17629908].
373 Bigalke B, Geisler T, Stellos K, et al. Platelet collagen receptor glycoprotein VI as a possible novel indicator for the acute coronary syndrome. Am Heart J. Jul. 2008;156(1):193-200. X-1,X-2,X-6,X-8. [pmid: 18585516].
374 Bigi R, Cortigiani L, Gregori D, et al. The Stress-Recovery Index for the risk stratification of women with typical chest pain. Int J Cardiol. Jun. 23. 2008;127(1):64-9. X-7. [pmid: 17692413].
375 Bigi R, Desideri A, Galati A, et al. Incremental prognostic value of stress echocardiography as an adjunct to exercise electrocardiography after uncomplicated myocardial infarction. Heart. Apr. 2001;85(4):417-23. X-1,X-8. [pmid: 11250968].
376 Bigi R, Gregori D, Cortigiani L, et al. Artificial neural networks and robust Bayesian classifiers for risk stratification following uncomplicated myocardial infarction. Int J Cardiol. Jun. 8. 2005;101(3):481-7. X-1,X-6,X-8. [pmid: 15907418].
377 Bijsterveld NR, Peters RJ, Murphy SA, et al. Recurrent cardiac ischemic events early after discontinuation of short-term heparin treatment in acute coronary syndromes: results from the Thrombolysis in Myocardial Infarction (TIMI) 11B and Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q-Wave Coronary Events (ESSENCE) studies. J Am Coll Cardiol. Dec. 17. 2003;42(12):2083-9. X-1,X-6,X-8. [pmid: 14680731].
378 Bindraban NR, van Valkengoed IG, Mairuhu G, et al. Prevalence of diabetes mellitus and the performance of a risk score among Hindustani Surinamese, African Surinamese and ethnic Dutch: a cross-sectional population-based study. BMC Public Health. 2008;8:271. X-1,X-2,X-6,X-8. [pmid: 18673544].
379 Birjmohun RS, Dallinga-Thie GM, Kuivenhoven JA, et al. Apolipoprotein A-II is inversely associated with risk of future coronary artery disease. Circulation. Oct. 30. 2007;116(18):2029-35. X-1E,X-1F,X-2,X-5,X-8(50%), (UK). [pmid: 17923573].
380 Birkmeyer NJ, Marrin CA, Morton JR, et al. Decreasing mortality for aortic and mitral valve surgery in Northern New England. Northern New England Cardiovascular Disease Study Group. Ann Thorac Surg. Aug. 2000;70(2):432-7. X-1,X-8. [pmid: 10969658].
381 Birman-Deych E, Waterman AD, Yan Y, et al. Accuracy of ICD-9-CM codes for identifying cardiovascular and stroke risk factors. Med Care. May. 2005;43(5):480-5. X-1,X-5. [pmid: 15838413].
382 Birschel P, Ellul J, Barer D. Progressing stroke: towards an internationally agreed definition. Cerebrovasc Dis. 2004;17(2-3):242-52. X-1,X-2,X-5,X-6,X-8. [pmid: 14718754].
383 Bittner V, Simon JA, Fong J, et al. Correlates of high HDL cholesterol among women with coronary heart disease. Am Heart J. Feb. 2000;139(2 Pt 1):288-96. X-1,X-5,X-6,X-8. [pmid: 10650302].
384 Bjork J, Forberg JL, Ohlsson M, et al. A simple statistical model for prediction of acute coronary syndrome in chest pain patients in the emergency department. BMC Med Inform Decis Mak. 2006;6:28. X-1D,X-5,X-6,X-8. [pmid: 16824205].
385 Bjorklund E, Jernberg T, Johanson P, et al. Admission N-terminal pro-brain natriuretic peptide and its interaction with admission troponin T and ST segment resolution for early risk stratification in ST elevation myocardial infarction. Heart. Jun. 2006;92(6):735-40. X-1,X-8. [pmid: 16251228].
386 Blacher C, Manfroi W, Fernandes BS. Evaluation of the treadmill stress testing for risk stratification after acute myocardial infarction. Arq Bras Cardiol. Dec. 1999;73(6):527-36. X-1,X-8. [pmid: 10904273].
387 Blacher J, Asmar R, Djane S, et al. Aortic pulse wave velocity as a marker of cardiovascular risk in hypertensive patients. Hypertension. May. 1999;33(5):1111-7. X-1,X-6. [pmid: 10334796].
388 Blacher J, Benetos A, Kirzin JM, et al. Relation of plasma total homocysteine to cardiovascular mortality in a French population. Am J Cardiol. Sep. 15. 2002;90(6):591-5. X-5,X-6. [pmid: 12231082].
389 Blacher J, Cacoub P, Luizy F, et al. Peripheral arterial disease versus other localizations of vascular disease: the ATTEST study. J Vasc Surg. Aug. 2006;44(2):314-8. X-1,X-5. [pmid: 16890860].
390 Black HR. The paradigm has shifted to systolic blood pressure. J Hum Hypertens. Dec. 2. 2004;18:S3-7. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 15592571].
391 Blankenberg S, Godefroy T, Poirier O, et al. Haplotypes of the caspase-1 gene, plasma caspase-1 levels, and cardiovascular risk. Circ Res. Jul. 7. 2006;99(1):102-8. X-1,X-2,X-5,X-8. [pmid: 16778130].
392 Blankenberg S, Luc G, Ducimetiere P, et al. Interleukin-18 and the risk of coronary heart disease in European men: the Prospective Epidemiological Study of Myocardial Infarction (PRIME). Circulation. Nov. 18. 2003;108(20):2453-9. X-1,X-5,X-6. [pmid: 14581397].
393 Blankenberg S, McQueen MJ, Smieja M, et al. Comparative impact of multiple biomarkers and N-Terminal pro-brain natriuretic peptide in the context of conventional risk factors for the prediction of recurrent cardiovascular events in the Heart Outcomes Prevention Evaluation (HOPE) Study. Circulation. Jul. 18. 2006;114(3):201-8. X-8. [pmid: 16831981].
394 Blankenberg S, Rupprecht HJ, Bickel C, et al. Cytomegalovirus infection with interleukin-6 response predicts cardiac mortality in patients with coronary artery disease. Circulation. Jun. 19. 2001;103(24):2915-21. X-1,X-2,X-8. [pmid: 11413080].
395 Blaschke F, Takata Y, Caglayan E, et al. A nuclear receptor corepressor-dependent pathway mediates suppression of cytokine-induced C-reactive protein gene expression by liver X receptor. Circ Res. Dec. 8. 2006;99(12):e88-99. X-1,X-2,X-5,X-6. [pmid: 17110595].
396 Blaser T, Hofmann K, Buerger T, et al. Risk of stroke, transient ischemic attack, and vessel occlusion before endarterectomy in patients with symptomatic severe carotid stenosis. Stroke. Apr. 2002;33(4):1057-62. X-1,X-2,X-7,X-8. [pmid: 11935061].
397 Blomkalns AL, Lindsell CJ, Chandra A, et al. Can electrocardiographic criteria predict adverse cardiac events and positive cardiac markers?. Acad Emerg Med. Mar. 2003;10(3):205-10. X-1,X-5,X-6. [pmid: 12615583].
398 Bloomfield DM, Bigger JT, Steinman RC, et al. Microvolt T-wave alternans and the risk of death or sustained ventricular arrhythmias in patients with left ventricular dysfunction. J Am Coll Cardiol. Jan. 17. 2006;47(2):456-63. X-1,X-8. [pmid: 16412877].
399 Blum CB. Effects of sirolimus on lipids in renal allograft recipients: an analysis using the Framingham risk model. Am J Transplant. Jul. 2002;2(6):551-9. X-1,X-2,X-4,X-5,X-6. [pmid: 12118900].
400 Bluzaite I, Brazdzionyte J, Zaliunas R, et al. QT dispersion and heart rate variability in sudden death risk stratification in patients with ischemic heart disease. Medicina (Kaunas). 2006;42(6):450-4. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16816538].
401 Bo S, Valpreda S, Scaglione L, et al. Implementing hospital guidelines improves warfarin use in non-valvular atrial fibrillation: a before-after study. BMC Public Health. 2007;7:203. X-1,X-6. [pmid: 17692112].
402 Boden WE. Interpretation of new treatment guidelines for non-ST-segment elevation acute coronary syndromes: “ischemia-guided” versus “early invasive” strategies. Minerva Cardioangiol. Oct. 2003;51(5):447-61. X-1,X-4,X-5. [pmid: 14551515].
403 Bodi V, Sanchis J, Llacer A, et al. Risk stratification in non-ST elevation acute coronary syndromes: predictive power of troponin I, C-reactive protein, fibrinogen and homocysteine. Int J Cardiol. Feb. 15. 2005;98(2):277-83. X-1,X-2,X-8. [pmid: 15686779].
404 Bodi V, Sanchis J, Lopez-Lereu MP, et al. Prognostic value of dipyridamole stress cardiovascular magnetic resonance imaging in patients with known or suspected coronary artery disease. J Am Coll Cardiol. Sep. 18. 2007;50(12):1174-9. X-1,X-8. [pmid: 17868810].
405 Boekholdt SM, Hack CE, Sandhu MS, et al. C-reactive protein levels and coronary artery disease incidence and mortality in apparently healthy men and women: the EPIC-Norfolk prospective population study 1993-2003. Atherosclerosis. Aug. 2006;187(2):415-22. X-5. [pmid: 16257408].
406 Boekholdt SM, Peters RJ, de Maat MP, et al. Interaction between a genetic variant of the platelet fibrinogen receptor and fibrinogen levels in determining the risk of cardiovascular events. Am Heart J. Jan. 2004;147(1):181-6. X-1,X-5,X-8. [pmid: 14691438].
407 Boersma E, Kertai MD, Schouten O, et al. Perioperative cardiovascular mortality in noncardiac surgery: validation of the Lee cardiac risk index. Am J Med. Oct. 2005;118(10):1134-41. X-1D,X-1G,X-5,X-6,X-9. [pmid: 16194645].
408 Bolognese L, Carrabba N, Santoro GM, et al. Angiographic findings, time course of regional and global left ventricular function, and clinical outcome in diabetic patients with acute myocardial infarction treated with primary percutaneous transluminal coronary angioplasty. Am J Cardiol. Mar. 1. 2003;91(5):544-9. X-1,X-6,X-8. [pmid: 12615257].
409 Bonacchi M, Prifti E, Battaglia F, et al. In situ retrocaval skeletonized right internal thoracic artery anastomosed to the circumflex system via transverse sinus: technical aspects and postoperative outcome. J Thorac Cardiovasc Surg. Nov. 2003;126(5):1302-13. X-1,X-2,X-6,X-8. [pmid: 14666000].
410 Bonassi S, Neri M, Puntoni R. Validation of biomarkers as early predictors of disease. Mutat Res. Sep. 1. 2001;480-481:349-58. X-1C,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 11506827].
411 Bond J, Gregson B, Smith M, et al. Predicting place of discharge from hospital for patients with a stroke or hip fracture on admission. J Health Serv Res Policy. Jul. 2000;5(3):133-9. X-1,X-6,X-8. [pmid: 11183623].
412 Bonora E, Kiechl S, Oberhollenzer F, et al. Impaired glucose tolerance, Type II diabetes mellitus and carotid atherosclerosis: prospective results from the Bruneck Study. Diabetologia. Feb. 2000;43(2):156-64. X-1F,X-2,X-6. [pmid: 10753036].
413 Boos CJ, Lane DA, Karpha M, et al. Circulating endothelial cells, arterial stiffness, and cardiovascular risk stratification in hypertension. Chest. Nov. 2007;132(5):1540-7. X-7,X-8. [pmid: 17998358].
414 Boos CJ, Soor SK, Kang D, et al. Relationship between circulating endothelial cells and the predicted risk of cardiovascular events in acute coronary syndromes. Eur Heart J. May. 2007;28(9):1092-101. X-1,X-7,X-8. [pmid: 17449878].
415 Bor AS, Rinkel GJ, Adami J, et al. Risk of subarachnoid haemorrhage according to number of affected relatives: a population based case-control study. Brain. Oct. 2008;131(Pt 10):2662-5. X-5,X-8. [pmid: 18819992].
416 Boreas AM, Lodder J, Kessels F, et al. Prognostic value of blood pressure in acute stroke. J Hum Hypertens. Feb. 2002;16(2):111-6. X-1,X-2,X-6,X-8. [pmid: 11850768].
417 Borges-Neto S, Tuttle RH, Shaw LK, et al. Outcome prediction in patients at high risk for coronary artery disease: comparison between 99mTc tetrofosmin and 99mTc sestamibi. Radiology. Jul. 2004;232(1):58-65. X-1. [pmid: 15220493].
418 Bos MJ, Schipper CM, Koudstaal PJ, et al. High serum C-reactive protein level is not an independent predictor for stroke: the Rotterdam Study. Circulation. Oct. 10. 2006;114(15):1591-8. X-8. [pmid: 17015791].
419 Boscarino JA, Chang J. Survival after coronary artery bypass graft surgery and community socioeconomic status: clinical and research implications. Med Care. Feb. 1999;37(2):210-6. X-1,X-6,X-8. [pmid: 10024125].
420 Bosch JG, Nijland F, Mitchell SC, et al. Computer-aided diagnosis via model-based shape analysis: automated classification of wall motion abnormalities in echocardiograms. Acad Radiol. Mar. 2005;12(3):358-67. X-1,X-5,X-6,X-7,X-8. [pmid: 15766696].
421 Bosch X, Theroux P. Left ventricular ejection fraction to predict early mortality in patients with non-ST-segment elevation acute coronary syndromes. Am Heart J. Aug. 2005;150(2):215-20. X-1,X-8. [pmid: 16086920].
422 Boutouyrie P, Tropeano AI, Asmar R, et al. Aortic stiffness is an independent predictor of primary coronary events in hypertensive patients: a longitudinal study. Hypertension. Jan. 2002;39(1):10-5. X-2. [pmid: 11799071].
423 Bovet P, Shamlaye C, Gabriel A, et al. Prevalence of cardiovascular risk factors in a middle-income country and estimated cost of a treatment strategy. BMC Public Health. 2006;6:9. X-1F,X-1G,X-2,X-5,X-6,X-8. [pmid: 16423280].
424 Bowers DC, McNeil DE, Liu Y, et al. Stroke as a late treatment effect of Hodgkin's Disease: a report from the Childhood Cancer Survivor Study. J Clin Oncol. Sep. 20. 2005;23(27):6508-15. X-1,X-2,X-5,X-8,X-9. [pmid: 16170160].
425 Boyar A. Creating a web application that combines Framingham risk with Electron Beam CT Coronary Calcium Score to calculate a new event risk. J Thorac Imaging. Mar. 2006;21(1):91-6. X-1F,X-2,X-4,X-5,X-6,X-7,X-8(CAD),X-9. [pmid: 16538168].
426 Brach JS, Solomon C, Naydeck BL, et al. Incident physical disability in people with lower extremity peripheral arterial disease: the role of cardiovascular disease. J Am Geriatr Soc. Jun. 2008;56(6):1037-44. X-1F,X-1G,X-2,X-6,X-8. [pmid: 18384579].
427 Bradbury BD, Lash TL, Kaye JA, et al. Tamoxifen-treated breast carcinoma patients and the risk of acute myocardial infarction and newly-diagnosed angina. Cancer. Mar. 15. 2005;103(6):1114-21. X-1,X-2,X-5. [pmid: 15712362].
428 Bradshaw PJ, Ko DT, Newman AM, et al. Validity of the GRACE (Global Registry of Acute Coronary Events) acute coronary syndrome prediction model for six month post-discharge death in an independent data set. Heart. Jul. 2006;92(7):905-9. X-1,X-8. [pmid: 16387810].
429 Bradshaw PJ, Ko DT, Newman AM, et al. Validation of the Thrombolysis In Myocardial Infarction (TIMI) risk index for predicting early mortality in a population-based cohort of STEMI and non-STEMI patients. Can J Cardiol. Jan. 2007;23(1):51-6. X-1,X-2. [pmid: 17245483].
430 Brand B, Rydberg E, Ericsson G, et al. Prognostication and risk stratification by assessment of left atrioventricular plane displacement in patients with myocardial infarction. Int J Cardiol. Apr. 2002;83(1):35-41. X-1,X-2,X-8. [pmid: 11959382].
431 Brand-Miller J, Dickinson S, Barclay A, et al. The glycemic index and cardiovascular disease risk. Curr Atheroscler Rep. Dec. 2007;9(6):479-85. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18377788].
432 Brass EP, Allen SE, Melin JM. Potential impact on cardiovascular public health of over-the-counter statin availability. Am J Cardiol. Mar. 15. 2006;97(6):851-6. X-1G,X-2,X-5,X-6,X-8. [pmid: 16516588].
433 Brassard P, Bourgault C, Brophy J, et al. Antibiotics in primary prevention of stroke in the elderly. Stroke. Sep. 2003;34(9):e163-6. X-1,X-2. [pmid: 12907812].
434 Braun LT. Cardiovascular disease: strategies for risk assessment and modification. J Cardiovasc Nurs. Nov-Dec. 2006;21(6 Suppl 1):S20-42. quiz S43-5. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 17293747].
435 Braun S, Ndrepepa G, von Beckerath N, et al. Value of serum ferritin and soluble transferrin receptor for prediction of coronary artery disease and its clinical presentations. Atherosclerosis. May. 2004;174(1):105-10. X-1,X-2,X-5,X-6,X-8. [pmid: 15135258].
436 Brauner EV, Forchhammer L, Moller P, et al. Indoor particles affect vascular function in the aged: an air filtration-based intervention study. Am J Respir Crit Care Med. Feb. 15. 2008;177(4):419-25. X-1,X-6,X-7. [pmid: 17932377].
437 Breddin HK, Lippold R, Bittner M, et al. Spontaneous platelet aggregation as a predictive risk factor for vascular occlusions in healthy volunteers? Results of the HAPARG Study. Haemostatic parameters as risk factors in healthy volunteers. Atherosclerosis. May. 1999;144(1):211-9. X-1,X-6. [pmid: 10381294].
438 Brembilla-Perrot B, Suty-Selton C, Beurrier D, et al. Differences in mechanisms and outcomes of syncope in patients with coronary disease or idiopathic left ventricular dysfunction as assessed by electrophysiologic testing. J Am Coll Cardiol. Aug. 4. 2004;44(3):594-601. X-1,X-6,X-7,X-8. [pmid: 15358027].
439 Brener SJ, Lincoff AM, Bates ER, et al. The relationship between baseline risk and mortality in ST-elevation acute myocardial infarction treated with pharmacological reperfusion: insights from the Global Utilization of Strategies To open Occluded arteries (GUSTO) V trial. Am Heart J. Jul. 2005;150(1):89-93. X-1,X-8. [pmid: 16084153].
440 Brener SJ, Milford-Beland S, Roe MT, et al. Culprit-only or multivessel revascularization in patients with acute coronary syndromes: an American College of Cardiology National Cardiovascular Database Registry report. Am Heart J. Jan. 2008;155(1):140-6. X-1,X-5,X-6,X-8. [pmid: 18082505].
441 Brevetti G, Silvestro A, Schiano V, et al. Endothelial dysfunction and cardiovascular risk prediction in peripheral arterial disease: additive value of flow-mediated dilation to ankle-brachial pressure index. Circulation. Oct. 28. 2003;108(17):2093-8. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 14530195].
442 Brevetti G, Sirico G, Lanero S, et al. The prevalence of hypoechoic carotid plaques is greater in peripheral than in coronary artery disease and is related to the neutrophil count. J Vasc Surg. Mar. 2008;47(3):523-9. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18234465].
443 Bridgewater B, Grayson AD, Jackson M, et al. Surgeon specific mortality in adult cardiac surgery: comparison between crude and risk stratified data. BMJ. Jul. 5. 2003;327(7405):13-7. X-1,X-2,X-6,X-8. [pmid: 12842949].
444 Brilakis ES, Wright RS, Kopecky SL, et al. Association of the PURSUIT risk score with predischarge ejection fraction, angiographic severity of coronary artery disease, and mortality in a nonselected, community-based population with non-ST-elevation acute myocardial infarction. Am Heart J. Nov. 2003;146(5):811-8. X-1,X-6,X-8. [pmid: 14597929].
445 Brindle P, Beswick A, Fahey T, et al. Accuracy and impact of risk assessment in the primary prevention of cardiovascular disease: a systematic review. Heart. Dec. 2006;92(12):1752-9. X-4,X-5. [pmid: 16621883].
446 Britton A, Marmot M. Different measures of alcohol consumption and risk of coronary heart disease and all-cause mortality: 11-year follow-up of the Whitehall II Cohort Study. Addiction. Jan. 2004;99(1):109-16. X-1,X-6. [pmid: 14678069].
447 Broadbent E, Petrie KJ, Ellis CJ, et al. Patients with acute myocardial infarction have an inaccurate understanding of their risk of a future cardiac event. Intern Med J. Oct. 2006;36(10):643-7. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 16958641].
448 Broadley S, Cheek A, Salonikis S, et al. Predicting prolonged dysphagia in acute stroke: the Royal Adelaide Prognostic Index for Dysphagic Stroke (RAPIDS). Dysphagia. Fall. 2005;20(4):303-10. X-1,X-6,X-7,X-8. [pmid: 16633876].
449 Brochu M, Poehlman ET, Savage P, et al. Coronary risk profiles in men with coronary artery disease: effects of body composition, fat distribution, age and fitness. Coron Artery Dis. Mar. 2000;11(2):137-44. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 10758815].
450 Brodie BR, Hansen C, Stuckey TD, et al. Door-to-balloon time with primary percutaneous coronary intervention for acute myocardial infarction impacts late cardiac mortality in high-risk patients and patients presenting early after the onset of symptoms. J Am Coll Cardiol. Jan. 17. 2006;47(2):289-95. X-1,X-6,X-8. [pmid: 16412849].
451 Brook RD, Kansal M, Bard RL, et al. Usefulness of low-density lipoprotein particle size measurement in cardiovascular disease prevention. Clin Cardiol. Nov. 2005;28(11):534-7. X-5,X-6,X-7. [pmid: 16450798].
452 Brosig T, Hoinkes A, Seitz RJ, et al. Ultrasound turbulence index during thromboendarterectomy predicts postoperative cerebral microembolism. Cerebrovasc Dis. 2008;26(1):87-92. X-1,X-5,X-6,X-7,X-8. [pmid: 18535374].
453 Brotman DJ, Davidson MB, Boumitri M, et al. Impaired diurnal blood pressure variation and all-cause mortality. Am J Hypertens. Jan. 2008;21(1):92-7. X-2,X-6. [pmid: 18091750].
454 Brown BG, Morse J, Zhao XQ, et al. Electron-beam tomography coronary calcium scores are superior to Framingham risk variables for predicting the measured proximal stenosis burden. Am J Cardiol. Jul. 19. 2001;88(2A):23E-26E. X-1,X-5,X-6,X-7. [pmid: 11423053].
455 Brown DL, Barsan WG, Lisabeth LD, et al. Survey of emergency physicians about recombinant tissue plasminogen activator for acute ischemic stroke. Ann Emerg Med. Jul. 2005;46(1):56-60. X-1,X-5,X-6. [pmid: 15988427].
456 Brown DW, Ford ES, Giles WH, et al. Associations between white blood cell count and risk for cerebrovascular disease mortality: NHANES II Mortality Study, 1976-1992. Ann Epidemiol. Jul. 2004;14(6):425-30. X-1F,X-2. [pmid: 15246331].
457 Brown DW, Giles WH, Greenlund KJ. Blood pressure parameters and risk of fatal stroke, NHANES II mortality study. Am J Hypertens. Mar. 2007;20(3):338-41. X-1,X-2. [pmid: 17324749].
458 Brown ER, Kronmal RA, Bluemke DA, et al. Coronary calcium coverage score: determination, correlates, and predictive accuracy in the Multi-Ethnic Study of Atherosclerosis. Radiology. Jun. 2008;247(3):669-75. X-1. [pmid: 18413889].
459 Brown JM, Poston RS, Gammie JS, et al. Off-pump versus on-pump coronary artery bypass grafting in consecutive patients: decision-making algorithm and outcomes. Ann Thorac Surg. Feb. 2006;81(2):555-61. discussion 561. X-1,X-2,X-8. [pmid: 16427851].
460 Brown JR, Cochran RP, Leavitt BJ, et al. Multivariable prediction of renal insufficiency developing after cardiac surgery. Circulation. Sep. 11. 2007;116(11 Suppl):I139-43. X-1,X-6,X-8. [pmid: 17846294].
461 Brown JR, Cochran RP, MacKenzie TA, et al. Long-term survival after cardiac surgery is predicted by estimated glomerular filtration rate. Ann Thorac Surg. Jul. 2008;86(1):4-11. X-1,X-2,X-6,X-8. [pmid: 18573389].
462 Brown JR, Malenka DJ, DeVries JT, et al. Transient and persistent renal dysfunction are predictors of survival after percutaneous coronary intervention: insights from the Dartmouth Dynamic Registry. Catheter Cardiovasc Interv. Sep. 1. 2008;72(3):347-54. X-1,X-6,X-8. [pmid: 18729173].
463 Brown RA. Gauging cardiovascular risk with the PLAC test. Nursing. Aug. 2006;36(8):17. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9.
464 Brown TL, Merrill J, Volokh L, et al. Determinants of the response of left ventricular ejection fraction to vasodilator stress in electrocardiographically gated (82)rubidium myocardial perfusion PET. Eur J Nucl Med Mol Imaging. Feb. 2008;35(2):336-42. X-1,X-2,X-5,X-6,X-7. [pmid: 17912523].
465 Bruch C, Kauling D, Reinecke H, et al. Prevalence and prognostic impact of comorbidities in patients with severe aortic valve stenosis. Clin Res Cardiol. Jan. 2007;96(1):23-9. X-1,X-2,X-7,X-8. [pmid: 17066348].
466 Brugts JJ, Knetsch AM, Mattace-Raso FU, et al. Renal function and risk of myocardial infarction in an elderly population: the Rotterdam Study. Arch Intern Med. Dec. 12-26. 2005;165(22):2659-65. X-1F,X-2. [pmid: 16344425].
467 Brune K, Katus HA, Moecks J, et al. N-terminal pro-B-type natriuretic peptide concentrations predict the risk of cardiovascular adverse events from antiinflammatory drugs: a pilot trial. Clin Chem. Jul. 2008;54(7):1149-57. X-1. [pmid: 18451314].
468 Brunelli A, Refai M, Xiume F, et al. Performance at symptom-limited stair-climbing test is associated with increased cardiopulmonary complications, mortality, and costs after major lung resection. Ann Thorac Surg. Jul. 2008;86(1):240-7. discussion 247-8. X-1,X-6. [pmid: 18573431].
469 Bruno G, Merletti F, Biggeri A, et al. Metabolic syndrome as a predictor of all-cause and cardiovascular mortality in type 2 diabetes: the Casale Monferrato Study. Diabetes Care. Nov. 2004;27(11):2689-94. X-1E,X-1F,X-2,X-8. [pmid: 15505006].
470 Bucerius J, Gummert JF, Walther T, et al. Predictors of prolonged ICU stay after on-pump versus off-pump coronary artery bypass grafting. Intensive Care Med. Jan. 2004;30(1):88-95. X-1,X-5,X-6,X-8. [pmid: 14504725].
471 Budaj A, Yusuf S, Mehta SR, et al. Benefit of clopidogrel in patients with acute coronary syndromes without ST-segment elevation in various risk groups. Circulation. Sep. 24. 2002;106(13):1622-6. X-1,X-8. [pmid: 12270853].
472 Budoff MJ, Dowe D, Jollis JG, et al. Diagnostic performance of 64-multidetector row coronary computed tomographic angiography for evaluation of coronary artery stenosis in individuals without known coronary artery disease: results from the prospective multicenter ACCURACY (Assessment by Coronary Computed Tomographic Angiography of Individuals Undergoing Invasive Coronary Angiography) trial. J Am Coll Cardiol. Nov. 18. 2008;52(21):1724-32. X-1. [pmid: 19007693].
473 Budoff MJ, Gopal A. Coronary calcium: does it still play a role in the age of CT angiography. Expert Rev Cardiovasc Ther. Jan. 2007;5(1):1-3. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 17187451].
474 Budoff MJ, Gul KM. Expert review on coronary calcium. Vasc Health Risk Manag. 2008;4(2):315-24. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18561507].
475 Budoff MJ, Shaw LJ, Liu ST, et al. Long-term prognosis associated with coronary calcification: observations from a registry of 25,253 patients. J Am Coll Cardiol. May. 8. 2007;49(18):1860-70. X-6. [pmid: 17481445].
476 Bueti J, Krahn J, Karpinski M, et al. Troponin I testing in dialysis patients presenting to the emergency room: does troponin I predict the 30-day outcome?. Nephron Clin Pract. 2006;103(4):c129-36. X-7. [pmid: 16636580].
477 Bugiardini R. Endothelial function and the prediction of CVD in diabetes. Curr Diab Rep. Feb. 2006;6(1):17-21. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16522276].
478 Bui H, Lee JT, Greenway S, et al. Validation of an updated approach to preoperative cardiac risk assessment in vascular surgery. Am Surg. Nov. 2003;69(11):923-6. X-1,X-5,X-6,X-7. [pmid: 14627248].
479 Bundorf MK, Schulman KA, Stafford JA, et al. Impact of managed care on the treatment, costs, and outcomes of fee-for-service Medicare patients with acute myocardial infarction. Health Serv Res. Feb. 2004;39(1):131-52. X-1,X-2,X-6,X-8. [pmid: 14965081].
480 Burger HG. Hormone therapy in the WHI era. Aust N Z J Obstet Gynaecol. Apr. 2006;46(2):84-91. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16638027].
481 Burke V, Zhao Y, Lee AH, et al. Hospital admissions and length of stay for coronary disease in an Aboriginal cohort. Nutr Metab Cardiovasc Dis. Jun. 2008;18(5):357-64. X-1,X-2,X-6. [pmid: 18042360].
482 Burke V, Zhao Y, Lee AH, et al. Health-related behaviours as predictors of mortality and morbidity in Australian Aborigines. Prev Med. Feb. 2007;44(2):135-42. X-2. [pmid: 17069878].
483 Burkhoff D, Jones JW, Becker LC. Variability of myocardial perfusion defects assessed by thallium-201 scintigraphy in patients with coronary artery disease not amenable to angioplasty or bypass surgery. J Am Coll Cardiol. Oct. 2001;38(4):1033-9. X-1,X-2,X-6,X-7,X-8. [pmid: 11583878].
484 Burr ML, Dolan E, O'Brien EW, et al. The value of ambulatory blood pressure in older adults: the Dublin outcome study. Age Ageing. Mar. 2008;37(2):201-6. X-1F,X-2,X-8. [pmid: 18349014].
485 Bush DE, Ziegelstein RC, Tayback M, et al. Even minimal symptoms of depression increase mortality risk after acute myocardial infarction. Am J Cardiol. Aug. 15. 2001;88(4):337-41. X-1,X-6,X-8. [pmid: 11545750].
486 Bushnell CD, Griffin J, Newby LK, et al. Statin use and sex-specific stroke outcomes in patients with vascular disease. Stroke. Jun. 2006;37(6):1427-31. X-1,X-2,X-4,X-5,X-8. [pmid: 16645137].
487 Butler J, Rodondi N, Zhu Y, et al. Metabolic syndrome and the risk of cardiovascular disease in older adults. J Am Coll Cardiol. Apr. 18. 2006;47(8):1595-602. X-1F,X-2. [pmid: 16630996].
488 Buxton AE. Risk stratification for sudden death: do we need anything more than ejection fraction?. Card Electrophysiol Rev. Dec. 2003;7(4):434-7. X-1,X-2,X-4,X-5,X-6. [pmid: 15071270].
489 Buxton AE, Lee KL, Hafley GE, et al. Limitations of ejection fraction for prediction of sudden death risk in patients with coronary artery disease: lessons from the MUSTT study. J Am Coll Cardiol. Sep. 18. 2007;50(12):1150-7. X-1D,X-2,X-6,X-8(CAD). [pmid: 17868806].
490 Buxton AE, Lee KL, Hafley GE, et al. Relation of ejection fraction and inducible ventricular tachycardia to mode of death in patients with coronary artery disease: an analysis of patients enrolled in the multicenter unsustained tachycardia trial. Circulation. Nov. 5. 2002;106(19):2466-72. X-1,X-2. [pmid: 12417544].
491 Byrne A, Daly C, Rocke L, et al. Can risk stratification of transient ischaemic attacks improve patient care in the emergency department?. Emerg Med J. Sep. 2007;24(9):637-40. X-1,X-6,X-7. [pmid: 17711941].
492 Cai J, Pajak A, Li Y, et al. Total cholesterol and mortality in China, Poland, Russia, and the US. Ann Epidemiol. Jul. 2004;14(6):399-408. X-1. [pmid: 15246328].
493 Cain PA, Ugander M, Palmer J, et al. Quantitative polar representation of left ventricular myocardial perfusion, function and viability using SPECT and cardiac magnetic resonance: initial results. Clin Physiol Funct Imaging. Jul. 2005;25(4):215-22. X-1,X-6,X-7,X-8. [pmid: 15972023].
494 Cakir B, Blue K. How to improve the management of chest pain: hospitalists and use of prediction rules. South Med J. Mar. 2007;100(3):242-7. X-1C,X-1D,X-2,X-5,X-6,X-8(80.8%). [pmid: 17396724].
495 Calafiore AM, Di Mauro M, Canosa C, et al. Myocardial revascularization with and without cardiopulmonary bypass in multivessel disease: impact of strategy on midterm outcome. Ann Thorac Surg. Jul. 2003;76(1):32-6. X-1,X-6,X-8. [pmid: 12842508].
496 Calamante F, Willats L, Gadian DG, et al. Bolus delay and dispersion in perfusion MRI: implications for tissue predictor models in stroke. Magn Reson Med. May. 2006;55(5):1180-5. X-1,X-6,X-8. [pmid: 16598717].
497 Calligaro KD, Dougherty MJ. Correlation of carotid artery stump pressure and neurologic changes during 474 carotid endarterectomies performed in awake patients. J Vasc Surg. Oct. 2005;42(4):684-9. X-1,X-8. [pmid: 16242555].
498 Callister T, Raggi P. Electron-beam computed tomography: a Bayesian approach to risk assessment. Am J Cardiol. Jul. 19. 2001;88(2A):39E-41E. X-1G,X-2,X-5,X-8.
499 Calnon DA, McGrath PD, Doss AL, et al. Prognostic value of dobutamine stress technetium-99m-sestamibi single-photon emission computed tomography myocardial perfusion imaging: stratification of a high-risk population. J Am Coll Cardiol. Nov. 1. 2001;38(5):1511-7. X-1F,X-2,X-8. [pmid: 11691532].
500 Calverley DC, Brass E, Hacker MR, et al. Potential role of platelet FcgammaRIIA in collagen-mediated platelet activation associated with atherothrombosis. Atherosclerosis. Oct. 2002;164(2):261-7. X-1,X-2,X-5,X-8. [pmid: 12204796].
501 Calvet D, Lamy C, Touze E, et al. Management and outcome of patients with transient ischemic attack admitted to a stroke unit. Cerebrovasc Dis. 2007;24(1):80-5. X-1,X-5,X-6. [pmid: 17519548].
502 Calvin JE, Klein L, VandenBerg E, et al. The intermediate CCU admission: a preliminary study. Heart Dis. Jan-Feb. 2001;3(1):18-23. X-1,X-2,X-8. [pmid: 11975766].
503 Campagnucci VP, Pinto ESAM, Pereira WL, et al. EuroSCORE and the patients undergoing coronary bypass surgery at Santa Casa de Sao Paulo. Rev Bras Cir Cardiovasc. Jun. 2008;23(2):262-7. X-1,X-6,X-7,X-8. [pmid: 18820791].
504 Campbell CY, Nasir K, Carvalho JA, et al. The metabolic syndrome adds incremental value to the Framingham risk score in identifying asymptomatic individuals with higher degrees of inflammation. J Cardiometab Syndr. Winter. 2008;3(1):7-11. X-1E,X-2,X-5,X-6. [pmid: 18326979].
505 Campuzano R, Moya JL, Garcia-Lledo A, et al. Endothelial dysfunction, intima-media thickness and coronary reserve in relation to risk factors and Framingham score in patients without clinical atherosclerosis. J Hypertens. Aug. 2006;24(8):1581-8. X-7. [pmid: 16877961].
506 Canale ML, Stroppa S, Caravelli P, et al. Admission C-reactive protein serum levels and survival in patients with acute myocardial infarction with persistent ST elevation. Coron Artery Dis. Dec. 2006;17(8):693-8. X-1,X-2,X-8. [pmid: 17119378].
507 Canbaz F, Basoglu T, Durna K, et al. Left ventricular aneurysm in the scope of gated perfusion SPECT: accuracy of detection and ejection fraction calculation. Int J Cardiovasc Imaging. Aug. 2008;24(6):585-96. X-1,X-6,X-7,X-8. [pmid: 18278565].
508 Candell-Riera J, Arenillas JF, Romero-Farina G, et al. Prognostic value of myocardial perfusion gated SPECT in patients with symptomatic intracranial large-artery atherosclerosis. Cerebrovasc Dis. 2007;24(2-3):247-54. X-1,X-5,X-6,X-7,X-8. [pmid: 17630486].
509 Candido AP, Ferreira S, Lima AA, et al. Lipoprotein(a) as a risk factor associated with ischemic heart disease: Ouro Preto Study. Atherosclerosis. Apr. 2007;191(2):454-9. X-1,X-2,X-4,X-5,X-6,X-8,X-9. [pmid: 16843471].
510 Cannon CP. Updated Strategies and Therapies for Reducing Ischemic and Vascular Events (STRIVE) ST-segment elevation myocardial infarction critical pathway toolkit. Crit Pathw Cardiol. Dec. 2008;7(4):223-31. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 19050418].
511 Cantor WJ, Fitchett D, Borgundvaag B, et al. Rationale and design of the Trial of Routine ANgioplasty and Stenting After Fibrinolysis to Enhance Reperfusion in Acute Myocardial Infarction (TRANSFER-AMI). Am Heart J. Jan. 2008;155(1):19-25. X-1,X-2,X-8. [pmid: 18082484].
512 Cao JJ, Arnold AM, Manolio TA, et al. Association of carotid artery intima-media thickness, plaques, and C-reactive protein with future cardiovascular disease and all-cause mortality: the Cardiovascular Health Study. Circulation. Jul. 3. 2007;116(1):32-8. X-1F. [pmid: 17576871].
513 Cao JJ, Biggs ML, Barzilay J, et al. Cardiovascular and mortality risk prediction and stratification using urinary albumin excretion in older adults ages 68-102: the Cardiovascular Health Study. Atherosclerosis. Apr. 2008;197(2):806-13. X-1. [pmid: 17875308].
514 Cao JJ, Hudson M, Jankowski M, et al. Relation of chronic and acute glycemic control on mortality in acute myocardial infarction with diabetes mellitus. Am J Cardiol. Jul. 15. 2005;96(2):183-6. X-1,X-8. [pmid: 16018838].
515 Cao JJ, Thach C, Manolio TA, et al. C-reactive protein, carotid intima-media thickness, and incidence of ischemic stroke in the elderly: the Cardiovascular Health Study. Circulation. Jul. 15. 2003;108(2):166-70. X-1. [pmid: 12821545].
516 Capellan O, Hollander JE, Pollack C Jr, et al. Prospective evaluation of emergency department patients with potential coronary syndromes using initial absolute CK-MB vs. CK-MB relative index. J Emerg Med. May. 2003;24(4):361-7. X-1,X-5,X-6. [pmid: 12745035].
517 Capes SE, Hunt D, Malmberg K, et al. Stress hyperglycemia and prognosis of stroke in nondiabetic and diabetic patients: a systematic overview. Stroke. Oct. 2001;32(10):2426-32. X-1,X-2,X-4,X-5,X-8. [pmid: 11588337].
518 Capoferri M, Schwick N, Tanner H, et al. Incidence of arrhythmic events in patients with implantable cardioverter-defibrillator for primary and secondary prevention of sudden cardiac death. Swiss Med Wkly. Mar. 20. 2004;134(11-12):154-8. X-1,X-2,X-7,X-8. [pmid: 15106019].
519 Caputo M, Anis RR, Rogers CA, et al. Coronary collateral circulation: effect on early and midterm outcomes after off-pump coronary artery bypass surgery. Ann Thorac Surg. Jan. 2008;85(1):71-9. X-1,X-2,X-5,X-6,X-8. [pmid: 18154783].
520 Caputo M, Reeves BC, Rogers CA, et al. Monitoring the performance of residents during training in off-pump coronary surgery. J Thorac Cardiovasc Surg. Dec. 2004;128(6):907-15. X-1,X-2,X-8. [pmid: 15573076].
521 Carasso S, Sandach A, Beinart R, et al. Usefulness of four echocardiographic risk assessments in predicting 30-day outcome in acute myocardial infarction. Am J Cardiol. Jul. 1. 2005;96(1):25-30. X-1,X-8. [pmid: 15979427].
522 Caravalho J Jr, O'Donnell SD, Feuerstein IM, et al. Preoperative risk stratification using electron beam computed tomography in elective vascular surgery: relationship to clinical risk prediction and postoperative complications. Ann Vasc Surg. Sep. 2002;16(5):639-43. X-1,X-7. [pmid: 12219253].
523 Caravelli P, De Carlo M, Musumeci G, et al. P-wave signal-averaged electrocardiogram predicts atrial fibrillation after coronary artery bypass grafting. Ann Noninvasive Electrocardiol. Jul. 2002;7(3):198-203. X-1,X-6,X-7,X-8. [pmid: 12167179].
524 Cardinalli-Neto A, Bestetti RB, Cordeiro JA, et al. Predictors of all-cause mortality for patients with chronic Chagas' heart disease receiving implantable cardioverter defibrillator therapy. J Cardiovasc Electrophysiol. Dec. 2007;18(12):1236-40. X-1,X-2,X-6,X-7,X-8. [pmid: 17900257].
525 Cardoso CR, Salles GF, Deccache W. QTc interval prolongation is a predictor of future strokes in patients with type 2 diabetes mellitus. Stroke. Sep. 2003;34(9):2187-94. X-1,X-2. [pmid: 12893949].
526 Carey MG. Electrocardiographic predictors of sudden cardiac death. J Cardiovasc Nurs. Mar-Apr. 2008;23(2):175-82. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18382261].
527 Carlquist JF, Muhlestein JB, Anderson JL. Lipoprotein-associated phospholipase A2: a new biomarker for cardiovascular risk assessment and potential therapeutic target. Expert Rev Mol Diagn. Sep. 2007;7(5):511-7. X-1,X-2,X-4,X-5. [pmid: 17892360].
528 Carlsson AC, Wandell PE, de Faire U, et al. Risk factors associated with newly diagnosed high blood pressure in men and women. Am J Hypertens. Jul. 2008;21(7):771-7. X-1. [pmid: 18437125].
529 Carr JJ, Nelson JC, Wong ND, et al. Calcified coronary artery plaque measurement with cardiac CT in population-based studies: standardized protocol of Multi-Ethnic Study of Atherosclerosis (MESA) and Coronary Artery Risk Development in Young Adults (CARDIA) study. Radiology. Jan. 2005;234(1):35-43. X-1,X-4,X-5,X-6. [pmid: 15618373].
530 Carriere I, Dupuy AM, Lacroux A, et al. Biomarkers of inflammation and malnutrition associated with early death in healthy elderly people. J Am Geriatr Soc. May. 2008;56(5):840-6. X-1F,X-2, (France). [pmid: 18410327].
531 Carrio ML, Fortia C, Javierre C, et al. Selective prophylaxis of atrial fibrillation with amiodarone after cardiac surgery. Minerva Chir. Oct. 2006;61(5):403-8. X-1,X-2,X-6,X-8. [pmid: 17159748].
532 Carty CL, Cushman M, Jones D, et al. Associations between common fibrinogen gene polymorphisms and cardiovascular disease in older adults. The Cardiovascular Health Study. Thromb Haemost. Feb. 2008;99(2):388-95. X-1,X-2. [pmid: 18278190].
533 Casaleggio A, Maestri R, La Rovere MT, et al. Prediction of sudden death in heart failure patients: a novel perspective from the assessment of the peak ectopy rate. Europace. Jun. 2007;9(6):385-90. X-1. [pmid: 17437967].
534 Casella G, Pavesi PC, Niro MD, et al. Negative and positive predictive values of routine exercise testing in stable, medically-treated patients several years following a Q-wave myocardial infarction. Ital Heart J. Apr. 2001;2(4):271-9. X-1F,X-2,X-8. [pmid: 11374496].
535 Casiglia E, Tikhonoff V, Mazza A, et al. Pulse pressure and coronary mortality in elderly men and women from general population. J Hum Hypertens. Sep. 2002;16(9):611-20. X-1. [pmid: 12214256].
536 Cassidy AE, Bielak LF, Zhou Y, et al. Progression of subclinical coronary atherosclerosis: does obesity make a difference?. Circulation. Apr. 19. 2005;111(15):1877-82. X-1,X-6. [pmid: 15837939].
537 Castelvecchio S, Menicanti L, Ranucci M, et al. Impact of surgical ventricular restoration on diastolic function: implications of shape and residual ventricular size. Ann Thorac Surg. Dec. 2008;86(6):1849-54. X-1,X-6,X-7,X-8. [pmid: 19021992].
538 Cavanaugh KL, Merkin SS, Plantinga LC, et al. Accuracy of patients' reports of comorbid disease and their association with mortality in ESRD. Am J Kidney Dis. Jul. 2008;52(1):118-27. X-1,X-2,X-6,X-8. [pmid: 18589216].
539 Cavusoglu E, Ruwende C, Chopra V, et al. Tissue inhibitor of metalloproteinase-1 (TIMP-1) is an independent predictor of all-cause mortality, cardiac mortality, and myocardial infarction. Am Heart J. May. 2006;151(5):1101 e1-8. X-1A,X-1D,X-1F,X-2,X-8. [pmid: 16644343].
540 Celik T, Yuksel UC, Iyisoy A, et al. The impact of preinfarction angina on electrocardiographic ischemia grades in patients with acute myocardial infarction treated with primary percutaneous coronary intervention. Ann Noninvasive Electrocardiol. Jul. 2008;13(3):278-86. X-1,X-2,X-6,X-7,X-8. [pmid: 18713329].
541 Celis H, Fagard RH, Staessen JA, et al. Risk and benefit of treatment of isolated systolic hypertension in the elderly: evidence from the Systolic Hypertension in Europe Trial. Curr Opin Cardiol. Nov. 2001;16(6):342-8. X-1,X-2. [pmid: 11704703].
542 Ceriani L, Verna E, Giovanella L, et al. Diagnostic criteria for detection of postinfarction ischemia by quantitative analysis of stepwise dobutamine radionuclide ventriculography. J Nucl Cardiol. Sep-Oct. 1999;6(5):514-21. X-1,X-5,X-6,X-7. [pmid: 10548147].
543 Cervera A, Tassies D, Obach V, et al. The BC genotype of the VNTR polymorphism of platelet glycoprotein Ibalpha is overrepresented in patients with recurrent stroke regardless of aspirin therapy. Cerebrovasc Dis. 2007;24(2-3):242-6. X-1,X-2,X-7. [pmid: 17630485].
544 Chaix B, Rosvall M, Merlo J. Recent increase of neighborhood socioeconomic effects on ischemic heart disease mortality: a multilevel survival analysis of two large Swedish cohorts. Am J Epidemiol. Jan. 1. 2007;165(1):22-6. X-1,X-2. [pmid: 16973762].
545 Chambless LE, Folsom AR, Sharrett AR, et al. Coronary heart disease risk prediction in the Atherosclerosis Risk in Communities (ARIC) study. J Clin Epidemiol. Sep. 2003;56(9):880-90. X-1. [pmid: 14505774].
546 Champney KP, Veledar E, Klein M, et al. Sex-specific effects of diabetes on adverse outcomes after percutaneous coronary intervention: trends over time. Am Heart J. Jun. 2007;153(6):970-8. X-1,X-6,X-8. [pmid: 17540197].
547 Chan MR, Bedi S, Sanchez RJ, et al. Stent placement versus angioplasty improves patency of arteriovenous grafts and blood flow of arteriovenous fistulae. Clin J Am Soc Nephrol. May. 2008;3(3):699-705. X-1,X-2,X-6,X-7,X-8. [pmid: 18256373].
548 Chandy J, Nakai T, Lee RJ, et al. Increases in P-wave dispersion predict postoperative atrial fibrillation after coronary artery bypass graft surgery. Anesth Analg. Feb. 2004;98(2):303-10. table of contents. X-1B,X-2,X-5,X-8. [pmid: 14742359].
549 Chang AM, Mumma B, Sease KL, et al. Gender bias in cardiovascular testing persists after adjustment for presenting characteristics and cardiac risk. Acad Emerg Med. Jul. 2007;14(7):599-605. X-1,X-4,X-6,X-8. [pmid: 17538080].
550 Chang ST, Chen CL, Chu CM, et al. Ankle-arm index as a predictor of lesion morphology and risk classification for coronary artery disease undergoing angioplasty. Int J Cardiol. Nov. 18. 2006;113(3):385-90. X-1,X-2,X-5,X-6,X-8. [pmid: 16644037].
551 Chang WC, Boersma E, Granger CB, et al. Dynamic prognostication in non-ST-elevation acute coronary syndromes: insights from GUSTO-IIb and PURSUIT. Am Heart J. Jul. 2004;148(1):62-71. X-1,X-8. [pmid: 15215793].
552 Chang WC, Kaul P, Fu Y, et al. Forecasting mortality: dynamic assessment of risk in ST-segment elevation acute myocardial infarction. Eur Heart J. Feb. 2006;27(4):419-26. X-1,X-6,X-8. [pmid: 16407373].
553 Chaowalit N, Arruda AL, McCully RB, et al. Dobutamine stress echocardiography in patients with diabetes mellitus: enhanced prognostic prediction using a simple risk score. J Am Coll Cardiol. Mar. 7. 2006;47(5):1029-36. X-8. [pmid: 16516089].
554 Chaowalit N, McCully RB, Callahan MJ, et al. Outcomes after normal dobutamine stress echocardiography and predictors of adverse events: long-term follow-up of 3014 patients. Eur Heart J. Dec. 2006;27(24):3039-44. X-1,X-2. [pmid: 17132654].
555 Charlesworth DC, Likosky DS, Marrin CA, et al. Development and validation of a prediction model for strokes after coronary artery bypass grafting. Ann Thorac Surg. Aug. 2003;76(2):436-43. X-1,X-8. [pmid: 12902080].
556 Chase M, Brown AM, Robey JL, et al. Application of the TIMI risk score in ED patients with cocaine-associated chest pain. Am J Emerg Med. Nov. 2007;25(9):1015-8. X-1. [pmid: 18022495].
557 Chassot PG, Delabays A, Spahn DR. Preoperative evaluation of patients with, or at risk of, coronary artery disease undergoing non-cardiac surgery. Br J Anaesth. Nov. 2002;89(5):747-59. X-1,X-2,X-4,X-5,X-6. [pmid: 12393774].
558 Chau V, Poskitt KJ, Sargent MA, et al. Comparison of computer tomography and magnetic resonance imaging scans on the third day of life in term newborns with neonatal encephalopathy. Pediatrics. Jan. 2009;123(1):319-26. X-1,X-2,X-6,X-7,X-8. [pmid: 19117898].
559 Chaudhry FA, Qureshi EA, Yao SS, et al. Risk stratification and prognosis in octogenarians undergoing stress echocardiographic study. Echocardiography. Sep. 2007;24(8):851-9. X-1,X-1F,X-2,X-8. [pmid: 17767536].
560 Chaudhry FA, Tauke JT, Alessandrini RS, et al. Enhanced detection of ischemic myocardium by transesophageal dobutamine stress echocardiography: comparison with simultaneous transthoracic echocardiography. Echocardiography. Apr. 2000;17(3):241-53. X-1,X-6,X-7. [pmid: 10978988].
561 Chauhan VS, Selvaraj RJ. Utility of microvolt T-wave alternans to predict sudden cardiac death in patients with cardiomyopathy. Curr Opin Cardiol. Jan. 2007;22(1):25-32. X-1,X-2,X-4,X-5,X-6. [pmid: 17143041].
562 Chaves PH, Kuller LH, O'Leary DH, et al. Subclinical cardiovascular disease in older adults: insights from the Cardiovascular Health Study. Am J Geriatr Cardiol. May-Jun. 2004;13(3):137-51. X-1,X-2,X-4,X-5,X-6. [pmid: 15133417].
563 Chen CC, Chong CF, Kuo CD, et al. A risk score to predict silent myocardial ischemia in patients with coronary artery disease under aspirin therapy presenting with upper gastrointestinal hemorrhage. Am J Emerg Med. May. 2007;25(4):406-13. X-1,X-8. [pmid: 17499658].
564 Chen HJ, Bai CH, Yeh WT, et al. Influence of metabolic syndrome and general obesity on the risk of ischemic stroke. Stroke. Apr. 2006;37(4):1060-4. X-2,X-8. [pmid: 16514099].
565 Chen L, Peeters A, Magliano DJ, et al. Anthropometric measures and absolute cardiovascular risk estimates in the Australian Diabetes, Obesity and Lifestyle (AusDiab) Study. Eur J Cardiovasc Prev Rehabil. Dec. 2007;14(6):740-5. X-1,X-5,X-6. [pmid: 18043293].
566 Chen PC, Chien KL, Chang CW, et al. More hemorrhagic and severe events cause higher hospitalization care cost for childhood stroke in Taiwan. J Pediatr. Mar. 2008;152(3):388-93. X-1,X-2,X-5,X-6,X-8. [pmid: 18280847].
567 Chen SL, Zhang J, Yei F, et al. Clinical outcomes of contrast-induced nephropathy in patients undergoing percutaneous coronary intervention: a prospective, multicenter, randomized study to analyze the effect of hydration and acetylcysteine. Int J Cardiol. Jun. 6. 2008;126(3):407-13. X-1,X-6,X-8. [pmid: 17651830].
568 Chen SM, Li YG, Zhang HX, et al. Hypoxia-inducible factor-1alpha induces the coronary collaterals for coronary artery disease. Coron Artery Dis. May. 2008;19(3):173-9. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18418234].
569 Chen T, Kuwabara Y, Tsutsui H, et al. The usefulness of dipyridamole thallium-201 single photon emission computed tomography for predicting perioperative cardiac events in patients undergoing non-cardiac vascular surgery. Ann Nucl Med. Feb. 2002;16(1):45-53. X-1. [pmid: 11922208].
570 Chen W, Srinivasan SR, Bao W, et al. The magnitude of familial associations of cardiovascular risk factor variables between parents and offspring are influenced by age: the Bogalusa Heart Study. Ann Epidemiol. Nov. 2001;11(8):522-8. X-1,X-2,X-5,X-6. [pmid: 11709270].
571 Cheneau E, Leborgne L, Canos D, et al. Impact of intravascular ultrasound-guided direct stenting on clinical outcome of patients treated for native coronary disease. Cardiovasc Radiat Med. Jan-Mar. 2004;5(1):15-9. X-1,X-6,X-8. [pmid: 15275627].
572 Chen-Scarabelli C, Scarabelli TM. Chronic renal insufficiency is an independent predictor of mortality in implantable cardioverter-defibrillator recipients. Pacing Clin Electrophysiol. Mar. 2007;30(3):371-6. X-1,X-5,X-8. [pmid: 17367356].
573 Cherr GS, Wang J, Zimmerman PM, et al. Depression is associated with worse patency and recurrent leg symptoms after lower extremity revascularization. J Vasc Surg. Apr. 2007;45(4):744-50. X-1,X-6,X-8. [pmid: 17303367].
574 Cheung BM, Wat NM, Man YB, et al. Relationship between the metabolic syndrome and the development of hypertension in the Hong Kong Cardiovascular Risk Factor Prevalence Study-2 (CRISPS2). Am J Hypertens. Jan. 2008;21(1):17-22. X-1,X-6. [pmid: 18091739].
575 Cheung N, Bluemke DA, Klein R, et al. Retinal arteriolar narrowing and left ventricular remodeling: the multi-ethnic study of atherosclerosis. J Am Coll Cardiol. Jul. 3. 2007;50(1):48-55. X-5. [pmid: 17601545].
576 Cheung N, Wang JJ, Rogers SL, et al. Diabetic retinopathy and risk of heart failure. J Am Coll Cardiol. Apr. 22. 2008;51(16):1573-8. X-1,X-2,X-6. [pmid: 18420100].
577 Cheung PY, Barrington KJ, Finer NN, et al. Early childhood neurodevelopment in very low birth weight infants with predischarge apnea. Pediatr Pulmonol. Jan. 1999;27(1):14-20. X-1,X-6,X-8. [pmid: 10023786].
578 Cheung RT, Eliasziw M, Meldrum HE, et al. Risk, types, and severity of intracranial hemorrhage in patients with symptomatic carotid artery stenosis. Stroke. Aug. 2003;34(8):1847-51. X-1,X-6. [pmid: 12829862].
579 Cheung RT, Zou LY. Use of the original, modified, or new intracerebral hemorrhage score to predict mortality and morbidity after intracerebral hemorrhage. Stroke. Jul. 2003;34(7):1717-22. X-1,X-6. [pmid: 12805488].
580 Chew DK, Nguyen LL, Owens CD, et al. Comparative analysis of autogenous infrainguinal bypass grafts in African Americans and Caucasians: the association of race with graft function and limb salvage. J Vasc Surg. Oct. 2005;42(4):695-701. X-1,X-6,X-8. [pmid: 16242557].
581 Chew DP, Astley C, Molloy D, et al. Morbidity, mortality and economic burden of renal impairment in cardiac intensive care. Intern Med J. Mar. 2006;36(3):185-92. X-1,X-8. [pmid: 16503954].
582 Chew DP, Bhatt DL, Robbins MA, et al. Incremental prognostic value of elevated baseline C-reactive protein among established markers of risk in percutaneous coronary intervention. Circulation. Aug. 28. 2001;104(9):992-7. X-1,X-8. [pmid: 11524391].
583 Chiang HT, Lin SL, Hsu HC, et al. Prediction of in-hospital mortality in patients with myocardial infarction using APACHE II system. Zhonghua Yi Xue Za Zhi (Taipei). Sep. 2001;64(9):501-6. X-1,X-8. [pmid: 11768278].
584 Chien KL, Sung FC, Hsu HC, et al. Relative importance of atherosclerotic risk factors for coronary heart disease in Taiwan. Eur J Cardiovasc Prev Rehabil. Apr. 2005;12(2):95-101. X-1F,X-2,X-8(MI), (Taiwan). [pmid: 15785294].
585 Chien LY, Whyte R, Thiessen P, et al. Snap-II predicts severe intraventricular hemorrhage and chronic lung disease in the neonatal intensive care unit. J Perinatol. Jan. 2002;22(1):26-30. X-1. [pmid: 11840239].
586 Chieregato A, Marchi M, Compagnone C, et al. Estimated cerebral respiratory quotient and arteriovenous differences of CO2 in the ultra early detection of global ischemia in severe head injury. Acta Neurochir Suppl. 2005;95:67-71. X-1,X-6,X-7. [pmid: 16463823].
587 Chikamori T, Fujita H, Nanasato M, et al. Prognostic value of I-123 15-(p-iodophenyl)-3-(R,S) methylpentadecanoic acid myocardial imaging in patients with known or suspected coronary artery disease. J Nucl Cardiol. Mar-Apr. 2005;12(2):172-8. X-1,X-5,X-8. [pmid: 15812371].
588 Chiou KR, Huang WC, Lin SL, et al. Real-time dobutamine stress myocardial contrast echocardiography for detecting coronary artery disease: correlating abnormal wall motion and disturbed perfusion. Can J Cardiol. Oct. 2004;20(12):1237-43. X-1,X-6,X-7,X-8. [pmid: 15494776].
589 Chirinos JA, Veerani A, Zambrano JP, et al. Evaluation of comorbidity scores to predict all-cause mortality in patients with established coronary artery disease. Int J Cardiol. Apr. 12. 2007;117(1):97-102. X-8. [pmid: 16839629].
590 Chironi G, Simon A, Hugel B, et al. Circulating leukocyte-derived microparticles predict subclinical atherosclerosis burden in asymptomatic subjects. Arterioscler Thromb Vasc Biol. Dec. 2006;26(12):2775-80. X-1,X-2,X-5,X-6. [pmid: 17038634].
591 Chonchol MB, Aboyans V, Lacroix P, et al. Long-term outcomes after coronary artery bypass grafting: preoperative kidney function is prognostic. J Thorac Cardiovasc Surg. Sep. 2007;134(3):683-9. X-1,X-2,X-8. [pmid: 17723818].
592 Chong CF, Li YC, Wang TL, et al. Stratification of adverse outcomes by preoperative risk factors in coronary artery bypass graft patients: an artificial neural network prediction model. AMIA Annu Symp Proc. 2003:160-4. X-1,X-2,X-5,X-8.
593 Chou CY, Chien CW, Hsueh IP, et al. Developing a short form of the Berg Balance Scale for people with stroke. Phys Ther. Feb. 2006;86(2):195-204. X-1,X-6,X-8. [pmid: 16445333].
594 Chouraqui P, Livschitz S, Baron J, et al. The assessment of infarct size in postmyocardial infarction patients undergoing thallium-201 tomographic imaging is improved using attenuation correction. Clin Nucl Med. Jun. 2004;29(6):352-7. X-1,X-6,X-7,X-8. [pmid: 15166881].
595 Chowdhary S, Ivanov J, Mackie K, et al. The Toronto score for in-hospital mortality after percutaneous coronary interventions. Am Heart J. Jan. 2009;157(1):156-63. X-1,X-8. [pmid: 19081413].
596 Christensen H, Boysen G, Truelsen T. The Scandinavian stroke scale predicts outcome in patients with mild ischemic stroke. Cerebrovasc Dis. 2005;20(1):46-8. X-1,X-8. [pmid: 15942168].
597 Christenson RH, Leino EV, Giugliano RP, et al. Usefulness of prodromal unstable angina pectoris in predicting better survival and smaller infarct size in acute myocardial infarction (The InTIME-II Prodromal Symptoms Substudy). Am J Cardiol. Sep. 1. 2003;92(5):598-600. X-1,X-6,X-8. [pmid: 12943885].
598 Christianson TJ, Bryant SC, Weymiller AJ, et al. A pen-and-paper coronary risk estimator for office use with patients with type 2 diabetes. Mayo Clin Proc. May. 2006;81(5):632-6. X-2. [pmid: 16706261].
599 Christoforidis GA, Mohammad Y, Kehagias D, et al. Angiographic assessment of pial collaterals as a prognostic indicator following intra-arterial thrombolysis for acute ischemic stroke. AJNR Am J Neuroradiol. Aug. 2005;26(7):1789-97. X-1,X-5,X-7. [pmid: 16091531].
600 Chu D, Bakaeen FG, Wang XL, et al. The impact of peripheral vascular disease on long-term survival after coronary artery bypass graft surgery. Ann Thorac Surg. Oct. 2008;86(4):1175-80. X-1,X-2,X-8. [pmid: 18805156].
601 Chu WW, Dieter RS, Stone CK. Evolving clinical applications of cardiac markers: a review of the literature. WMJ. 2002;101(3):49-55. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12109202].
602 Chun AA, McGee SR. Bedside diagnosis of coronary artery disease: a systematic review. Am J Med. Sep. 1. 2004;117(5):334-43. X-1,X-6,X-8. [pmid: 15336583].
603 Chung CP, Oeser A, Avalos I, et al. Cardiovascular risk scores and the presence of subclinical coronary artery atherosclerosis in women with systemic lupus erythematosus. Lupus. 2006;15(9):562-9. X-2,X-5,X-6,X-7. [pmid: 17080910].
604 Chung SG, van Rey E, Bai Z, et al. Separate quantification of reflex and nonreflex components of spastic hypertonia in chronic hemiparesis. Arch Phys Med Rehabil. Apr. 2008;89(4):700-10. X-1,X-2,X-5,X-6,X-7. [pmid: 18374001].
605 Chung SH, Chu WS, Lee HA, et al. Peritoneal transport characteristics, comorbid diseases and survival in CAPD patients. Perit Dial Int. Sep-Oct. 2000;20(5):541-7. X-1,X-2,X-6. [pmid: 11117245].
606 Chung SH, Lindholm B, Lee HB. Is malnutrition an independent predictor of mortality in peritoneal dialysis patients?. Nephrol Dial Transplant. Oct. 2003;18(10):2134-40. X-1,X-7. [pmid: 13679492].
607 Church TS, LaMonte MJ, Barlow CE, et al. Cardiorespiratory fitness and body mass index as predictors of cardiovascular disease mortality among men with diabetes. Arch Intern Med. Oct. 10. 2005;165(18):2114-20. X-1F,X-2. [pmid: 16217001].
608 Church TS, Levine BD, McGuire DK, et al. Coronary artery calcium score, risk factors, and incident coronary heart disease events. Atherosclerosis. Jan. 2007;190(1):224-31. X-2. [pmid: 16540111].
609 Chyun D, Vaccarino V, Murillo J, et al. Acute myocardial infarction in the elderly with diabetes. Heart Lung. Sep-Oct. 2002;31(5):327-39. X-1,X-2,X-8. [pmid: 12487011].
610 Ciampi A, Courteau J, Niyonsenga T, et al. Family history and the risk of coronary heart disease: comparing predictive models. Eur J Epidemiol. 2001;17(7):609-20. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12086074].
611 Cicala S, Renzulli A, Galderisi M, et al. Transthoracic Doppler echocardiography of mammary artery grafts to assess graft function. Can J Cardiol. Jan. 2005;21(1):45-9. X-1,X-2,X-6,X-7,X-8. [pmid: 15685302].
612 Cirillo M, Amaducci A, Brunelli F, et al. Determinants of postinfarction remodeling affect outcome and left ventricular geometry after surgical treatment of ischemic cardiomyopathy. J Thorac Cardiovasc Surg. Jun. 2004;127(6):1648-56. X-1,X-2,X-6,X-7,X-8. [pmid: 15173719].
613 Citro R, Galderisi M, Guarini P, et al. Left bundle branch block with and without coronary artery disease: which value for a tissue Doppler-derived post-systolic motion?. Ital Heart J. Oct. 2003;4(10):706-12. X-1,X-2,X-6,X-7. [pmid: 14664284].
614 Claassen J, Bernardini GL, Kreiter K, et al. Effect of cisternal and ventricular blood on risk of delayed cerebral ischemia after subarachnoid hemorrhage: the Fisher scale revisited. Stroke. Sep. 2001;32(9):2012-20. X-1,X-6,X-8. [pmid: 11546890].
615 Clappers N, van Oijen MG, Sundaresan S, et al. The C50T polymorphism of the cyclooxygenase-1 gene and the risk of thrombotic events during low-dose therapy with acetyl salicylic acid. Thromb Haemost. Jul. 2008;100(1):70-5. X-1,X-6. [pmid: 18612540].
616 Clarke JL, Anderson JL, Carlquist JF, et al. Comparison of differing C-reactive protein assay methods and their impact on cardiovascular risk assessment. Am J Cardiol. Jan. 1. 2005;95(1):155-8. X-1E,X-1F,X-2,X-8. [pmid: 15619419].
617 Clarke JL, Johnston SC, Farrant M, et al. External validation of the ICH score. Neurocrit Care. 2004;1(1):53-60. X-1,X-7,X-8. [pmid: 16174898].
618 Classen S, Meuleman J, Garvan C, et al. Review of prescription medications in home-based older adults with stroke: a pilot study. Res Social Adm Pharm. Mar. 2007;3(1):104-22. X-1,X-5,X-6,X-7,X-8. [pmid: 17350560].
619 Cleary JD, Pearson M, Oliver J, et al. Association between Histoplasma exposure and stroke. J Stroke Cerebrovasc Dis. Sep. 2008;17(5):312-9. X-1,X-2,X-5,X-8. [pmid: 18755412].
620 Coffey CS, Hebert PR, Ritchie MD, et al. An application of conditional logistic regression and multifactor dimensionality reduction for detecting gene-gene interactions on risk of myocardial infarction: the importance of model validation. BMC Bioinformatics. Apr. 30. 2004;5:49. X-1,X-2,X-5,X-6. [pmid: 15119966].
621 Cohen MG, Kelly RV, Kong DF, et al. Pulmonary artery catheterization in acute coronary syndromes: insights from the GUSTO IIb and GUSTO III trials. Am J Med. May. 2005;118(5):482-8. X-1,X-8. [pmid: 15866250].
622 Cohen MG, Pascua JA, Garcia-Ben M, et al. A simple prediction rule for significant renal artery stenosis in patients undergoing cardiac catheterization. Am Heart J. Dec. 2005;150(6):1204-11. X-1,X-5,X-6,X-8. [pmid: 16338259].
623 Cojocaru IM, Cojocaru M, Musuroi C, et al. Study of anti-cardiolipin and anti-beta2-glycoprotein I antibodies in patients with ischemic stroke. Rom J Intern Med. 2003;41(2):189-204. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15526503].
624 Colivicchi F, Ammirati F, Melina D, et al. Development and prospective validation of a risk stratification system for patients with syncope in the emergency department: the OESIL risk score. Eur Heart J. May. 2003;24(9):811-9. X-1,X-5,X-6. [pmid: 12727148].
625 Collard CD, Shernan SK, Fox AA, et al. The MBL2 ‘LYQA secretor’ haplotype is an independent predictor of postoperative myocardial infarction in whites undergoing coronary artery bypass graft surgery. Circulation. Sep. 11. 2007;116(11 Suppl):I106-12. X-1,X-2,X-6,X-8. [pmid: 17846289].
626 Collet JP, Montalescot G, Vicaut E, et al. Acute release of plasminogen activator inhibitor-1 in ST-segment elevation myocardial infarction predicts mortality. Circulation. Jul. 29. 2003;108(4):391-4. X-1,X-2,X-7,X-8. [pmid: 12860898].
627 Colli A, Josa M, Pomar JL, et al. Heart fatty acid binding protein in the diagnosis of myocardial infarction: where do we stand today?. Cardiology. 2007;108(1):4-10. X-1,X-2. [pmid: 16960442].
628 Collinson J, Perez de Arenaza D, Flather MD, et al. Managing high-risk patients with acute coronary syndromes: the Prospective Registry of Acute Ischaemic Syndromes in the UK (PRAIS-UK). Clin Med. Jul-Aug. 2004;4(4):369-75. X-1,X-2,X-5,X-6,X-8. [pmid: 15372900].
629 Collinson PO. Testing for cardiac markers at the point of care. Clin Lab Med. Jun. 2001;21(2):351-62. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 11396088].
630 Colombet I, Jaulent MC, Degoulet P, et al. Logistic regression model: an assessment of variability of predictions. Stud Health Technol Inform. 2001;84(Pt 2):1314-8. X-1,X-2,X-4,X-5,X-6. [pmid: 11604940].
631 Colombet I, Ruelland A, Chatellier G, et al. Models to predict cardiovascular risk: comparison of CART, multilayer perceptron and logistic regression. Proc AMIA Symp. 2000:156-60. X-1,X-6.
632 Comeau A, Jensen L, Burton JR. Can symptom presentation predict unstable angina/non-ST-segment elevation myocardial infarction in a moderate-risk cohort?. Eur J Cardiovasc Nurs. Jun. 2006;5(2):127-36. X-1,X-7,X-8. [pmid: 16298162].
633 Comte A, Lalande A, Walker PM, et al. Visual estimation of the global myocardial extent of hyperenhancement on delayed contrast-enhanced MRI. Eur Radiol. Dec. 2004;14(12):2182-7. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15452664].
634 Conard SE, Bays HE, Leiter LA, et al. Efficacy and safety of ezetimibe added on to atorvastatin (20 mg) versus uptitration of atorvastatin (to 40 mg) in hypercholesterolemic patients at moderately high risk for coronary heart disease. Am J Cardiol. Dec. 1. 2008;102(11):1489-94. X-1,X-2,X-6,X-7. [pmid: 19026302].
635 Cook JW, Pierson LM, Herbert WG, et al. The influence of patient strength, aerobic capacity and body composition upon outcomes after coronary artery bypass grafting. Thorac Cardiovasc Surg. Apr. 2001;49(2):89-93. X-1,X-8. [pmid: 11339458].
636 Cook NR, Obarzanek E, Cutler JA, et al. Joint effects of sodium and potassium intake on subsequent cardiovascular disease: the Trials of Hypertension Prevention follow-up study. Arch Intern Med. Jan. 12. 2009;169(1):32-40. X-1,X-2. [pmid: 19139321].
637 Cooley DA. Early experience with cardiopulmonary bypass: reflections. J Card Surg. May-Jun. 2003;18(3):265-7. X-1 X-4. [pmid: 12809403].
638 Coolong A, Baim DS, Kuntz RE, et al. Saphenous vein graft stenting and major adverse cardiac events: a predictive model derived from a pooled analysis of 3958 patients. Circulation. Feb. 12. 2008;117(6):790-7. X-1,X-4,X-5,X-8. [pmid: 18212287].
639 Cooper HA, Domanski MJ, Rosenberg Y, et al. Acute ST-segment elevation myocardial infarction and prior stroke: an analysis from the Magnesium in Coronaries (MAGIC) trial. Am Heart J. Dec. 2004;148(6):1012-9. X-1,X-8. [pmid: 15632887].
640 Cooper JA, Miller GJ, Bauer KA, et al. Comparison of novel hemostatic factors and conventional risk factors for prediction of coronary heart disease. Circulation. Dec. 5. 2000;102(23):2816-22. X-1. [pmid: 11104738].
641 Cooper WA, O'Brien SM, Thourani VH, et al. Impact of renal dysfunction on outcomes of coronary artery bypass surgery: results from the Society of Thoracic Surgeons National Adult Cardiac Database. Circulation. Feb. 28. 2006;113(8):1063-70. X-1,X-8. [pmid: 16490821].
642 Coppola G, Rizzo M, Abrignani MG, et al. Fibrinogen as a predictor of mortality after acute myocardial infarction: a forty-two-month follow-up study. Ital Heart J. Apr. 2005;6(4):315-22. X-1,X-7,X-8. [pmid: 15902930].
643 Cordovil A, Junior WM, Andrade JL, et al. Role of dobutamine-atropine stress echocardiography in prognostic evaluation of 300 women. Echocardiography. Feb. 2004;21(2):113-8. X-1D,X-1E,X-1F,X-2,X-8(40%). [pmid: 14961788].
644 Corona AJ, Martinez DR, Avila MH, et al. Microalbuminuria as a predictor of myocardial infarction in a Mexican population: the Mexico City Diabetes Study. Kidney Int Suppl. Aug. 2005;(97):S34-9. X-1, Mexico. [pmid: 16014097].
645 Corrao G, Zambon A, Nicotra F, et al. Persistence with oral and transdermal hormone replacement therapy and hospitalisation for cardiovascular outcomes. Maturitas. Jul. 20. 2007;57(3):315-24. X-1,X-6. [pmid: 17485182].
646 Correa CR, Litt HI, Hwang WT, et al. Coronary artery findings after left-sided compared with right-sided radiation treatment for early-stage breast cancer. J Clin Oncol. Jul. 20. 2007;25(21):3031-7. X-1,X-6. [pmid: 17634481].
647 Correia LC, Lima JC, Rocha MS, et al. Does high-sensitivity C-reactive protein add prognostic value to the TIMI-Risk Score in individuals with non-ST elevation acute coronary syndromes?. Clin Chim Acta. Jan. 2007;375(1-2):124-8. X-1,X-6,X-7,X-8. [pmid: 16916502].
648 Correll CU, Frederickson AM, Kane JM, et al. Metabolic syndrome and the risk of coronary heart disease in 367 patients treated with second-generation antipsychotic drugs. J Clin Psychiatry. Apr. 2006;67(4):575-83. X-1,X-5,X-6. [pmid: 16669722].
649 Corson MA, Jones PH, Davidson MH. Review of the evidence for the clinical utility of lipoprotein-associated phospholipase A2 as a cardiovascular risk marker. Am J Cardiol. Jun. 16. 2008;101(12A):41F-50F. X-1,X-6.
650 Cortigiani L, Bigi R, Gigli G, et al. Prediction of mortality in patients with right bundle branch block referred for pharmacologic stress echocardiography. Am J Cardiol. Dec. 15. 2003;92(12):1429-33. X-1,X-5,X-6. [pmid: 14675579].
651 Cortigiani L, Bigi R, Gregori D, et al. Prognostic value of a multiparametric risk score in patients undergoing dipyridamole stress echocardiography. Am J Cardiol. Aug. 15. 2005;96(4):529-32. X-1. [pmid: 16098306].
652 Cortigiani L, Desideri A, Bigi R. Echocardiography for risk stratification of myocardial infarction in the reperfusion era. Clin Cardiol. Jan. 2005;28(1):3-7. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15704524].
653 Cortigiani L, Rigo F, Gherardi S, et al. Additional prognostic value of coronary flow reserve in diabetic and nondiabetic patients with negative dipyridamole stress echocardiography by wall motion criteria. J Am Coll Cardiol. Oct. 2. 2007;50(14):1354-61. X-1D,X-1F,X-2,X-8(30%). [pmid: 17903635].
654 Cortigiani L, Sicari R, Bigi R, et al. Usefulness of stress echocardiography for risk stratification of patients after percutaneous coronary intervention. Am J Cardiol. Nov. 1. 2008;102(9):1170-4. X-1,X-2,X-8. [pmid: 18940286].
655 Cosic Z, Tavcioski D, Jovelic A, et al. Late ventricular potentials in risk assessment of the occurrence of complex ventricular arrhythmia in patients with myocardial infarction and heart failure. Vojnosanit Pregl. Nov-Dec. 2004;61(6):589-97. X-1,X-7,X-8. [pmid: 15717719].
656 Costa MA, Carere RG, Lichtenstein SV, et al. Incidence, predictors, and significance of abnormal cardiac enzyme rise in patients treated with bypass surgery in the arterial revascularization therapies study (ARTS). Circulation. Nov. 27. 2001;104(22):2689-93. X-1,X-2,X-8. [pmid: 11723020].
657 Courivaud C, Kazory A, Simula-Faivre D, et al. Metabolic syndrome and atherosclerotic events in renal transplant recipients. Transplantation. Jun. 27. 2007;83(12):1577-81. X-1. [pmid: 17589340].
658 Courtis J, Rodes-Cabau J, Larose E, et al. Comparison of medical treatment and coronary revascularization in patients with moderate coronary lesions and borderline fractional flow reserve measurements. Catheter Cardiovasc Interv. Mar. 1. 2008;71(4):541-8. X-1,X-2,X-7,X-8. [pmid: 18307236].
659 Coutts SB, Eliasziw M, Hill MD, et al. An improved scoring system for identifying patients at high early risk of stroke and functional impairment after an acute transient ischemic attack or minor stroke. Int J Stroke. Feb. 2008;3(1):3-10. X-1,X-7,X-8. [pmid: 18705908].
660 Covin R, O'Brien M, Grunwald G, et al. Factors affecting transfusion of fresh frozen plasma, platelets, and red blood cells during elective coronary artery bypass graft surgery. Arch Pathol Lab Med. Apr. 2003;127(4):415-23. X-1,X-6. [pmid: 12683868].
661 Cowper PA, Peterson ED, DeLong ER, et al. The impact of statistical adjustment on economic profiles of interventional cardiologists. J Am Coll Cardiol. Nov. 1. 2001;38(5):1416-23. X-1,X-2,X-5,X-6,X-7. [pmid: 11691517].
662 Cramer GE, Kievit PC, Brouwer MA, et al. Lack of concordance between a rapid bedside and conventional laboratory method of cardiac troponin testing: impact on risk stratification of patients suspected of acute coronary syndrome. Clin Chim Acta. Jun. 2007;381(2):164-6. X-1C,X-1F,X-2,X-6,X-8(Unstable Angina). [pmid: 17467677].
663 Criqui MH, Denenberg JO, Bergan J, et al. Risk factors for chronic venous disease: the San Diego Population Study. J Vasc Surg. Aug. 2007;46(2):331-7. X-1,X-5,X-8. [pmid: 17600666].
664 Cronin L, Mehta SR, Zhao F, et al. Stroke in relation to cardiac procedures in patients with non-ST-elevation acute coronary syndrome: a study involving >18 000 patients. Circulation. Jul. 17. 2001;104(3):269-74. X-1,X-8. [pmid: 11457743].
665 Crow RS, Hannan PJ, Folsom AR. Prognostic significance of corrected QT and corrected JT interval for incident coronary heart disease in a general population sample stratified by presence or absence of wide QRS complex: the ARIC Study with 13 years of follow-up. Circulation. Oct. 21. 2003;108(16):1985-9. X-1F,X-2. [pmid: 14517173].
666 Crystal P, Zelingher J, Crystal E. Breast arterial calcifications as a cardiovascular risk marker in women. Expert Rev Cardiovasc Ther. Sep. 2004;2(5):753-60. X-1,X-4,X-5. [pmid: 15350176].
667 Cucchiara B, Tanne D, Levine SR, et al. A risk score to predict intracranial hemorrhage after recombinant tissue plasminogen activator for acute ischemic stroke. J Stroke Cerebrovasc Dis. Nov-Dec. 2008;17(6):331-3. X-1,X-8. [pmid: 18984422].
668 Cucchiara BL, Messe SR, Taylor RA, et al. Is the ABCD score useful for risk stratification of patients with acute transient ischemic attack?. Stroke. Jul. 2006;37(7):1710-4. X-1,X-7,X-8. [pmid: 16763186].
669 Cuculich PS, Sanchez JM, Kerzner R, et al. Poor prognosis for patients with chronic kidney disease despite ICD therapy for the primary prevention of sudden death. Pacing Clin Electrophysiol. Feb. 2007;30(2):207-13. X-1. [pmid: 17338717].
670 Cuddy TE, Tate RB. Sudden unexpected cardiac death as a function of time since the detection of electrocardiographic and clinical risk factors in apparently healthy men: the Manitoba Follow-Up Study, 1948 to 2004. Can J Cardiol. Mar. 1. 2006;22(3):205-11. X-1F,X-2,X-6. [pmid: 16520850].
671 Cui Y, Blumenthal RS, Flaws JA, et al. Non-high-density lipoprotein cholesterol level as a predictor of cardiovascular disease mortality. Arch Intern Med. Jun. 11. 2001;161(11):1413-9. X-1F,X-2. [pmid: 11386890].
672 Culleton BF, Larson MG, Kannel WB, et al. Serum uric acid and risk for cardiovascular disease and death: the Framingham Heart Study. Ann Intern Med. Jul. 6. 1999;131(1):7-13. X-1,X-6. [pmid: 10391820].
673 Cunningham EJ, Bond R, Mehta Z, et al. Long-term durability of carotid endarterectomy for symptomatic stenosis and risk factors for late postoperative stroke. Stroke. Nov. 2002;33(11):2658-63. X-1. [pmid: 12411657].
674 Curb JD, Abbott RD, Rodriguez BL, et al. C-reactive protein and the future risk of thromboembolic stroke in healthy men. Circulation. Apr. 22. 2003;107(15):2016-20. X-1,X-5. [pmid: 12681999].
675 Cury RC, Ferencik M, Hoffmann U, et al. Epidemiology and association of vascular and valvular calcium quantified by multidetector computed tomography in elderly asymptomatic subjects. Am J Cardiol. Aug. 1. 2004;94(3):348-51. X-1,X-5,X-6. [pmid: 15276102].
676 Cushman M, Arnold AM, Psaty BM, et al. C-reactive protein and the 10-year incidence of coronary heart disease in older men and women: the cardiovascular health study. Circulation. Jul. 5. 2005;112(1):25-31. X-2. [pmid: 15983251].
677 Cuspidi C, Meani S, Valerio C, et al. Age and target organ damage in essential hypertension: role of the metabolic syndrome. Am J Hypertens. Mar. 2007;20(3):296-303. X-1,X-6. [pmid: 17324743].
678 Cygankiewicz I, Zareba W, de Luna AB. Prognostic value of Holter monitoring in congestive heart failure. Cardiol J. 2008;15(4):313-23. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18698539].
679 Cygankiewicz I, Zareba W, Vazquez R, et al. Heart rate turbulence predicts all-cause mortality and sudden death in congestive heart failure patients. Heart Rhythm. Aug. 2008;5(8):1095-1102. X-1,X-2. [pmid: 18675217].
680 Czechowsky D, Hill MD. Neurological outcome and quality of life after stroke due to vertebral artery dissection. Cerebrovasc Dis. 2002;13(3):192-7. X-1,X-2,X-6,X-7,X-8. [pmid: 11914537].
681 Dabrowski A, Kramarz E, Piotrowicz R. Dispersion of QT interval following ventricular premature beats and mortality after myocardial infarction. Cardiology. 1999;91(2):75-80. X-1,X-6,X-7. [pmid: 10449876].
682 Dahl M, Tybjaerg-Hansen A, Sillesen H, et al. Blood pressure, risk of ischemic cerebrovascular and ischemic heart disease, and longevity in alpha(1)-antitrypsin deficiency: the Copenhagen City Heart Study. Circulation. Feb. 11. 2003;107(5):747-52. X-1,X-6,X-8. [pmid: 12578879].
683 Dai DF, Hwang JJ, Lin JL, et al. Joint effects of N-terminal pro-B-type-natriuretic peptide and C-reactive protein vs angiographic severity in predicting major adverse cardiovascular events and clinical restenosis after coronary angioplasty in patients with stable coronary artery disease. Circ J. Aug. 2008;72(8):1316-23. X-1,X-8. [pmid: 18654020].
684 Dakik HA, Hwang WS, Jafar A, et al. Prognostic value of quantitative stress myocardial perfusion imaging in unstable angina patients with negative cardiac enzymes and no new ischemic ECG changes. J Nucl Cardiol. Jan-Feb. 2005;12(1):32-6. X-1,X-7,X-8. [pmid: 15682363].
685 Dakik HA, Wendt JA, Kimball K, et al. Prognostic value of adenosine Tl-201 myocardial perfusion imaging after acute myocardial infarction: results of a prospective clinical trial. J Nucl Cardiol. May-Jun. 2005;12(3):276-83. X-1,X-7,X-8. [pmid: 15944532].
686 Dalager S, Falk E, Kristensen IB, et al. Plaque in superficial femoral arteries indicates generalized atherosclerosis and vulnerability to coronary death: an autopsy study. J Vasc Surg. Feb. 2008;47(2):296-302. X-1,X-2,X-5,X-7. [pmid: 18241752].
687 Dale RA, Jensen LH, Krantz MJ. Comparison of two point-of-care lipid analyzers for use in global cardiovascular risk assessments. Ann Pharmacother. May. 2008;42(5):633-9. X-1,X-2,X-5,X-6,X-7. [pmid: 18413684].
688 Daly CA, De Stavola B, Sendon JL, et al. Predicting prognosis in stable angina--results from the Euro heart survey of stable angina: prospective observational study. BMJ. Feb. 4. 2006;332(7536):262-7. X-1,X-8. [pmid: 16415069].
689 Daly CA, Stepinska J, Deptuch T, et al. Differences in presentation and management of stable angina from East to West in Europe: a comparison between Poland and the UK. Int J Cardiol. Apr. 25. 2008;125(3):311-8. X-1,X-6,X-8. [pmid: 17499372].
690 Daniels LB, Laughlin GA, Clopton P, et al. Minimally elevated cardiac troponin T and elevated N-terminal pro-B-type natriuretic peptide predict mortality in older adults: results from the Rancho Bernardo Study. J Am Coll Cardiol. Aug. 5. 2008;52(6):450-9. X-1,X-2,X-6,X-8. [pmid: 18672166].
691 Darabian S, Amirzadegan AR, Sadeghian H, et al. Ostial lesions of left main and right coronary arteries: demographic and angiographic features. Angiology. 2008 Dec-2009 Jan. 59(6):682-7. X-1,X-2,X-5,X-6,X-8. [pmid: 18388058].
692 Darwazah AK, Snaineh YA, Kiswani MO, et al. Off-pump coronary artery bypass in multi-vessel disease: effect of ejection fraction on early and midterm mortality and morbidity. J Cardiovasc Surg (Torino). Aug. 2008;49(4):519-26. X-1,X-2,X-7,X-8.
693 Das R, Dorsch MF, Lawrance RA, et al. External validation, extension and recalibration of Braunwald's simple risk index in a community-based cohort of patients with both STEMI and NSTEMI. Int J Cardiol. Mar. 8. 2006;107(3):327-32. X-1,X-8. [pmid: 15923049].
694 Dauerman HL, Frederick PD, Miller D, et al. Current incidence and clinical outcomes of bivalirudin administration among patients undergoing primary coronary intervention for stent thrombosis elevation acute myocardial infarction. Coron Artery Dis. Mar. 2007;18(2):141-8. X-1,X-8. [pmid: 17301606].
695 Daumit GL, Powe NR. Factors influencing access to cardiovascular procedures in patients with chronic kidney disease: race, sex, and insurance. Semin Nephrol. Jul. 2001;21(4):367-76. X-1,X-6. [pmid: 11455525].
696 Davar JI, Roberts EB, Coghlan JG, et al. Prognostic value of stress echocardiography in women with high (> or = 80%) probability of coronary artery disease. Postgrad Med J. Sep. 2001;77(911):573-7. X-7,X-8. [pmid: 11524515].
697 Davenport DL, Ferraris VA, Hosokawa P, et al. Multivariable predictors of postoperative cardiac adverse events after general and vascular surgery: results from the patient safety in surgery study. J Am Coll Surg. Jun. 2007;204(6):1199-210. X-1,X-8. [pmid: 17544078].
698 Davenport DL, Xenos ES, Hosokawa P, et al. The influence of body mass index obesity status on vascular surgery 30-day morbidity and mortality. J Vasc Surg. Jan. 2009;49(1):140-7. 147 e1. discussion 147. X-1,X-2,X-8. [pmid: 19028047].
699 Davidson KW, Haas DC, Shimbo D, et al. Standardizing the comparison of systolic blood pressure vs. pulse pressure for predicting coronary heart disease. J Clin Hypertens (Greenwich). Jun. 2006;8(6):411-3. X-1E,X-1F,X-2. [pmid: 16760679].
700 Daviglus ML, Pirzada A, Liu K, et al. Comparison of low risk and higher risk profiles in middle age to frequency and quantity of coronary artery calcium years later. Am J Cardiol. Aug. 1. 2004;94(3):367-9. X-1,X-5,X-6,X-7. [pmid: 15276108].
701 Daviglus ML, Stamler J, Pirzada A, et al. Favorable cardiovascular risk profile in young women and long-term risk of cardiovascular and all-cause mortality. JAMA. Oct. 6. 2004;292(13):1588-92. X-1E,X-1F,X-2. [pmid: 15467061].
702 Davila JA, Johnson CD, Behrenbeck TR, et al. Assessment of cardiovascular risk status at CT colonography. Radiology. Jul. 2006;240(1):110-5. X-1,X-2,X-5,X-8. [pmid: 16793974].
703 Davis BR, Arnett DK, Boerwinkle E, et al. Antihypertensive therapy, the alpha-adducin polymorphism, and cardiovascular disease in high-risk hypertensive persons: the Genetics of Hypertension-Associated Treatment Study. Pharmacogenomics J. Apr. 2007;7(2):112-22. X-1,X-2. [pmid: 16702981].
704 Davis DP, Robertson T, Imbesi SG. Diffusion-weighted magnetic resonance imaging versus computed tomography in the diagnosis of acute ischemic stroke. J Emerg Med. Oct. 2006;31(3):269-77. X-1,X-2,X-4,X-5. [pmid: 16982360].
705 Davis WJ 3rd, Vaynblat M, Chiavarelli M, et al. Open heart surgery in patients 85 years and older. J Card Surg. Jan-Feb. 2004;19(1):7-11. X-1,X-2,X-7,X-8. [pmid: 15108782].
706 Day D. Population-based screening with the Coronary Heart Disease Risk Factor Calculator. Adv Ther. Jan-Feb. 2001;18(1):21-32. X-1,X-2,X-5,X-6. [pmid: 11512530].
707 de Araujo Goncalves P, Ferreira J, Aguiar C, et al. TIMI, PURSUIT, and GRACE risk scores: sustained prognostic value and interaction with revascularization in NSTE-ACS. Eur Heart J. May. 2005;26(9):865-72. X-1,X-8. [pmid: 15764619].
708 de Belder AJ, Jewitt DE, Wainwright RJ, et al. Development and validation of a Bayesian index for predicting major adverse cardiac events with percutaneous transluminal coronary angioplasty. Heart. Jan. 2001;85(1):69-72. X-1D,X-1G,X-6,X-8(100%)(CABG)(Unstable Angina)(Stable Angina). [pmid: 11119467].
709 de Bree A, Verschuren WM, Blom HJ, et al. Coronary heart disease mortality, plasma homocysteine, and B-vitamins: a prospective study. Atherosclerosis. Feb. 2003;166(2):369-77. X-1,X-2,X-6. [pmid: 12535751].
710 de Bruyne MC, Hoes AW, Kors JA, et al. Prolonged QT interval predicts cardiac and all-cause mortality in the elderly. The Rotterdam Study. Eur Heart J. Feb. 1999;20(4):278-84. X-1,X-6. [pmid: 10099922].
711 De Castro S, Cartoni D, Fiorelli M, et al. Morphological and functional characteristics of patent foramen ovale and their embolic implications. Stroke. Oct. 2000;31(10):2407-13. X-1,X-5,X-7,X-8. [pmid: 11022072].
712 de Ferranti S, Rifai N. C-reactive protein and cardiovascular disease: a review of risk prediction and interventions. Clin Chim Acta. Mar. 2002;317(1-2):1-15. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 11814453].
713 De Ferrari GM, Sanzo A, Bertoletti A, et al. Baroreflex sensitivity predicts long-term cardiovascular mortality after myocardial infarction even in patients with preserved left ventricular function. J Am Coll Cardiol. Dec. 11. 2007;50(24):2285-90. X-1,X-8. [pmid: 18068036].
714 de Groot E, van Leuven SI, Duivenvoorden R, et al. Measurement of carotid intima-media thickness to assess progression and regression of atherosclerosis. Nat Clin Pract Cardiovasc Med. May. 2008;5(5):280-8. X-1,X-2. [pmid: 18332891].
715 De Henauw S, De Bacquer D, de Smet P, et al. Trends and regional differences in coronary risk factors in two areas in Belgium: final results from the MONICA Ghent-Charleroi Study. J Cardiovasc Risk. Oct. 2000;7(5):347-57. X-1. [pmid: 11143765].
716 de Jaegere PP, Suyker WJ. Off-pump coronary artery bypass surgery. Heart. Sep. 2002;88(3):313-8. X-1. [pmid: 12181233].
717 de la Torre MM, San Roman JA, Bermejo J, et al. Prognostic power of dobutamine echocardiography after uncomplicated acute myocardial infarction in the elderly. Chest. Oct. 2001;120(4):1200-5. X-1,X-7,X-8. [pmid: 11591561].
718 de Labriolle A, Giraudeau B, Pacouret G, et al. Revascularization algorithm in acute STEMI should take into account age. Cardiovasc Revasc Med. Apr-Jun. 2007;8(2):90-3. X-1,X-8. [pmid: 17574166].
719 de Labriolle A, Pacouret G, Giraudeau B, et al. Effect of time to treatment and age on one year mortality in acute STEMI: difference between thrombolysis and primary percutaneous coronary intervention. Arch Cardiovasc Dis. Jan. 2008;101(1):48-54. X-1,X-8. [pmid: 18391873].
720 de Lemos JA, Morrow DA, Sabatine MS, et al. Association between plasma levels of monocyte chemoattractant protein-1 and long-term clinical outcomes in patients with acute coronary syndromes. Circulation. Feb. 11. 2003;107(5):690-5. X-1,X-6,X-8. [pmid: 12578870].
721 De Lorenzo A, Hachamovitch R, Kang X, et al. Prognostic value of myocardial perfusion SPECT versus exercise electrocardiography in patients with ST-segment depression on resting electrocardiography. J Nucl Cardiol. Nov-Dec. 2005;12(6):655-61. X-1. [pmid: 16344227].
722 De Luca G, Suryapranata H, Ottervanger JP, et al. Postprocedural single-lead ST-segment deviation and long-term mortality in patients with ST-segment elevation myocardial infarction treated by primary angioplasty. Heart. Jan. 2008;94(1):44-7. X-1,X-2,X-8. [pmid: 17449501].
723 De Luca G, Suryapranata H, van 't Hof AW, et al. Prognostic assessment of patients with acute myocardial infarction treated with primary angioplasty: implications for early discharge. Circulation. Jun. 8. 2004;109(22):2737-43. X-1,X-8. [pmid: 15159293].
724 de Maat MP. Effects of diet, drugs, and genes on plasma fibrinogen levels. Ann N Y Acad Sci. 2001;936:509-21. X-1,X-6. [pmid: 11460508].
725 De Maria R, Mazzoni M, Parolini M, et al. Predictive value of EuroSCORE on long term outcome in cardiac surgery patients: a single institution study. Heart. Jun. 2005;91(6):779-84. X-1,X-8. [pmid: 15894777].
726 de Milliano PA, Tijssen JG, van Eck-Smit BL, et al. Cardiac 123 I-MIBG imaging and clinical variables in risk stratification in patients with heart failure treated with beta blockers. Nucl Med Commun. Jun. 2002;23(6):513-9. X-1,X-7,X-8. [pmid: 12029205].
727 De Muylder R, Tonglet R, Nackers F, et al. Randomised evaluation of a specific training of general practitioners in cardiovascular prevention. Acta Cardiol. Apr. 2005;60(2):199-205. X-1,X-5,X-6. [pmid: 15887477].
728 de Pouvourville G, Solesse A, Beillat M. Cost-effectiveness analysis of aldosterone blockade with eplerenone in patients with heart failure after acute myocardial infarction in the French context: the EPHESUS study. Arch Cardiovasc Dis. Sep. 2008;101(9):515-21. X-1,X-2,X-6,X-8. [pmid: 19041835].
729 De Reuck J, Proot P, Van Maele G. Chronic obstructive pulmonary disease as a risk factor for stroke-related seizures. Eur J Neurol. Sep. 2007;14(9):989-92. X-1,X-2,X-5,X-6,X-8. [pmid: 17718690].
730 de Ruijter W, Westendorp RG, Macfarlane PW, et al. The routine electrocardiogram for cardiovascular risk stratification in old age: the Leiden 85-plus study. J Am Geriatr Soc. Jun. 2007;55(6):872-7. X-1,X-6,X-8. [pmid: 17537087].
731 de Simone G, Kizer JR, Chinali M, et al. Normalization for body size and population-attributable risk of left ventricular hypertrophy: the Strong Heart Study. Am J Hypertens. Feb. 2005;18(2 Pt 1):191-6. X-1,X-2,X-5,X-6. [pmid: 15752946].
732 de Simone G, Wachtell K, Palmieri V, et al. Body build and risk of cardiovascular events in hypertension and left ventricular hypertrophy: the LIFE (Losartan Intervention For Endpoint reduction in hypertension) study. Circulation. Apr. 19. 2005;111(15):1924-31. X-1F,X-2. [pmid: 15837945].
733 De Socio GV, Parruti G, Quirino T, et al. Identifying HIV patients with an unfavorable cardiovascular risk profile in the clinical practice: results from the SIMONE study. J Infect. Jul. 2008;57(1):33-40. X-1,X-2,X-5,X-6. [pmid: 18436307].
734 de Sousa MR, Morillo CA, Rabelo FT, et al. Non-sustained ventricular tachycardia as a predictor of sudden cardiac death in patients with left ventricular dysfunction: a meta-analysis. Eur J Heart Fail. Oct. 2008;10(10):1007-14. X-1,X-8. [pmid: 18692437].
735 De Stavola BL, Meade TW. Long-term effects of hemostatic variables on fatal coronary heart disease: 30-year results from the first prospective Northwick Park Heart Study (NPHS-I). J Thromb Haemost. Mar. 2007;5(3):461-71. X-1,X-2. [pmid: 17137470].
736 de Vegt F, Dekker JM, Ruhe HG, et al. Hyperglycaemia is associated with all-cause and cardiovascular mortality in the Hoorn population: the Hoorn Study. Diabetologia. Aug. 1999;42(8):926-31. X-1F,X-2. [pmid: 10491751].
737 de Vincentiis C, Kunkl AB, Trimarchi S, et al. Aortic valve replacement in octogenarians: is biologic valve the unique solution?. Ann Thorac Surg. Apr. 2008;85(4):1296-301. X-1,X-2,X-6,X-8. [pmid: 18355513].
738 de Virgilio C, Toosie K, Elbassir M, et al. Dipyridamole-thallium/sestamibi before vascular surgery: a prospective blinded study in moderate-risk patients. J Vasc Surg. Jul. 2000;32(1):77-89. X-7. [pmid: 10876209].
739 de Virgilio C, Wall DB, Ephraim L, et al. An abnormal dipyridamole thallium/sestamibi fails to predict long-term cardiac events in vascular surgery patients. Ann Vasc Surg. Mar. 2001;15(2):267-71. X-7,X-8. [pmid: 11265096].
740 de Visser CL, Bilo HJ, Thomsen TF, et al. Prediction of coronary heart disease: a comparison between the Copenhagen risk score and the Framingham risk score applied to a Dutch population. J Intern Med. May. 2003;253(5):553-62. X-1,X-5. [pmid: 12702033].
741 de Zeeuw D, Bakker SJ. Does the metabolic syndrome add to the diagnosis and treatment of cardiovascular disease?. Nat Clin Pract Cardiovasc Med. Jul. 1. 2008;5:S10-4. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18580860].
742 Dean BB, Borenstein JE, Henning JM, et al. Can change in high-density lipoprotein cholesterol levels reduce cardiovascular risk?. Am Heart J. Jun. 2004;147(6):966-76. X-1,X-2,X-4,X-5. [pmid: 15199342].
743 Debing E, Van den Brande P. Chronic renal insufficiency and risk of early mortality in patients undergoing carotid endarterectomy. Ann Vasc Surg. Sep. 2006;20(5):609-13. X-1,X-8. [pmid: 16741650].
744 Decensi A, Maisonneuve P, Rotmensz N, et al. Effect of tamoxifen on venous thromboembolic events in a breast cancer prevention trial. Circulation. Feb. 8. 2005;111(5):650-6. X-1,X-6. [pmid: 15699284].
745 Deeb GM, Williams DM, Quint LE, et al. Risk analysis for aortic surgery using hypothermic circulatory arrest with retrograde cerebral perfusion. Ann Thorac Surg. Jun. 1999;67(6):1883-6. discussion 1891-4. X-1,X-5,X-6,X-7. [pmid: 10391332].
746 deFilippi C, Wasserman S, Rosanio S, et al. Cardiac troponin T and C-reactive protein for predicting prognosis, coronary atherosclerosis, and cardiomyopathy in patients undergoing long-term hemodialysis. JAMA. Jul. 16. 2003;290(3):353-9. X-1,X-2,X-8. [pmid: 12865376].
747 deFilippi CR, Rosanio S, Tocchi M, et al. Randomized comparison of a strategy of predischarge coronary angiography versus exercise testing in low-risk patients in a chest pain unit: in-hospital and long-term outcomes. J Am Coll Cardiol. Jun. 15. 2001;37(8):2042-9. X-1,X-2,X-6. [pmid: 11419885].
748 DeGeare VS, Boura JA, Grines LL, et al. Predictive value of the Killip classification in patients undergoing primary percutaneous coronary intervention for acute myocardial infarction. Am J Cardiol. May. 1. 2001;87(9):1035-8. X-5,X-8. [pmid: 11348598].
749 Dekker JM, Crow RS, Hannan PJ, et al. Heart rate-corrected QT interval prolongation predicts risk of coronary heart disease in black and white middle-aged men and women: the ARIC study. J Am Coll Cardiol. Feb. 18. 2004;43(4):565-71. X-1D,X-1E,X-1F,X-2,X-6. [pmid: 14975464].
750 del Sol AI, Moons KG, Hollander M, et al. Is carotid intima-media thickness useful in cardiovascular disease risk assessment? The Rotterdam Study. Stroke. Jul. 2001;32(7):1532-8. X-2. [pmid: 11441197].
751 Demaerschalk BM, Silver B, Wong E, et al. ASPECT scoring to estimate >1/3 middle cerebral artery territory infarction. Can J Neurol Sci. May. 2006;33(2):200-4. X-1,X-2,X-7,X-8. [pmid: 16736730].
752 Demchuk AM, Khan F, Hill MD, et al. Importance of leukoaraiosis on CT for tissue plasminogen activator decision making: evaluation of the NINDS rt-PA Stroke Study. Cerebrovasc Dis. 2008;26(2):120-5. X-1,X-2,X-8. [pmid: 18560214].
753 Demchuk E, Yucesoy B, Johnson VJ, et al. A statistical model for assessing genetic susceptibility as a risk factor in multifactorial diseases: lessons from occupational asthma. Environ Health Perspect. Feb. 2007;115(2):231-4. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 17384770].
754 Denarie N, Simon A, Chironi G, et al. Difference in carotid artery wall structure between Swedish and French men at low and high coronary risk. Stroke. Aug. 2001;32(8):1775-9. X-2,X-5,X-6. [pmid: 11486104].
755 Denollet J, Brutsaert DL. Reducing emotional distress improves prognosis in coronary heart disease:9-year mortality in a clinical trial of rehabilitation. Circulation. Oct. 23. 2001;104(17):2018-23. X-1,X-2,X-6,X-7,X-8. [pmid: 11673339].
756 Denvir MA, Lee AJ, Rysdale J, et al. Comparing performance between coronary intervention centres requires detailed case-mix adjusted analysis. J Public Health (Oxf). Jun. 2004;26(2):177-84. X-1,X-5,X-6,X-8. [pmid: 15284323].
757 Derdeyn CP, Videen TO, Grubb RL Jr, et al. Comparison of PET oxygen extraction fraction methods for the prediction of stroke risk. J Nucl Med. Aug. 2001;42(8):1195-7. X-7,X-8. [pmid: 11483680].
758 Dernellis J, Panaretou M. Assessment of cardiac risk before non-cardiac surgery: brain natriuretic peptide in 1590 patients. Heart. Nov. 2006;92(11):1645-50. X-1,X-2,X-8, (Greece). [pmid: 16709695].
759 Desai MY, Dalal D, Santos RD, et al. Association of body mass index, metabolic syndrome, and leukocyte count. Am J Cardiol. Mar. 15. 2006;97(6):835-8. X-1,X-5,X-6. [pmid: 16516585].
760 Desai MY, Nasir K, Braunstein JB, et al. Underlying risk factors incrementally add to the standard risk estimate in detecting subclinical atherosclerosis in low-and intermediate-risk middle-aged asymptomatic individuals. Am Heart J. Nov. 2004;148(5):871-7. X-1E,X-1F,X-2,X-5,X-6. [pmid: 15523320].
761 DeSilvey DL. Estimating risk for percutaneous interventions in the elderly. Am J Geriatr Cardiol. Jan-Feb. 2003;12(1):63-67. X-1. [pmid: 12502920].
762 Desmond DW, Moroney JT, Sano M, et al. Mortality in patients with dementia after ischemic stroke. Neurology. Aug. 27. 2002;59(4):537-43. X-1,X-6,X-8. [pmid: 12196645].
763 Dessein PH, Woodiwiss AJ, Joffe BI, et al. Aminotransferases are associated with insulin resistance and atherosclerosis in rheumatoid arthritis. BMC Cardiovasc Disord. 2007;7:31. X-7. [pmid: 17967187].
764 Devuyst G, Bogousslavsky J, Meuli R, et al. Stroke or transient ischemic attacks with basilar artery stenosis or occlusion: clinical patterns and outcome. Arch Neurol. Apr. 2002;59(4):567-73. X-1,X-2,X-6,X-7,X-8. [pmid: 11939891].
765 Dewey TM, Magee MJ, Acuff T, et al. Beating heart surgery reduces mortality in the reoperative bypass patient. Heart Surg Forum. 4. 2002;5:S301-16. X-1,X-6,X-8. [pmid: 12759205].
766 Dhingra R, Gona P, Nam BH, et al. C-reactive protein, inflammatory conditions, and cardiovascular disease risk. Am J Med. Dec. 2007;120(12):1054-62. X-1,X-2,X-5,X-6. [pmid: 18060926].
767 Di Castelnuovo A, Quacquaruccio G, Arnout J, et al. Cardiovascular risk factors and global risk of fatal cardiovascular disease are positively correlated between partners of 802 married couples from different European countries. Report from the IMMIDIET project. Thromb Haemost. Sep. 2007;98(3):648-55. X-1F,X-2,X-5,X-6. [pmid: 17849055].
768 Di Chiara A, Fresco C, Savonitto S, et al. Epidemiology of non-ST elevation acute coronary syndromes in the Italian cardiology network: the BLITZ-2 study. Eur Heart J. Feb. 2006;27(4):393-405. X-1,X-8. [pmid: 16219657].
769 Di Eusanio M, Schepens MA, Morshuis WJ, et al. Surgery for acute type A aortic dissection: the effect of antegrade selective cerebral perfusion on the early outcome of elderly patients. Ital Heart J. Apr. 2005;6(4):335-40. X-1,X-7,X-8. [pmid: 15902933].
770 Di Napoli M, Papa F. Inflammation, hemostatic markers, and antithrombotic agents in relation to long-term risk of new cardiovascular events in first-ever ischemic stroke patients. Stroke. Jul. 2002;33(7):1763-71. X-1,X-8. [pmid: 12105349].
771 Di Napoli M, Papa F. Angiotensin-converting enzyme inhibitor use is associated with reduced plasma concentration of C-reactive protein in patients with first-ever ischemic stroke. Stroke. Dec. 2003;34(12):2922-9. X-1,X-6,X-8. [pmid: 14605324].
772 Di Napoli M, Schwaninger M, Cappelli R, et al. Evaluation of C-reactive protein measurement for assessing the risk and prognosis in ischemic stroke: a statement for health care professionals from the CRP Pooling Project members. Stroke. Jun. 2005;36(6):1316-29. X-1,X-2,X-4,X-5. [pmid: 15879341].
773 Di Pasquale P, Cannizzaro S, Scalzo S, et al. Relationship between ACE-DD polymorphism and diastolic performance in healthy subjects. Scand Cardiovasc J. May. 2004;38(2):93-7. X-1,X-2,X-6. [pmid: 15204234].
774 Diaz LA, Brunken RC, Blackstone EH, et al. Independent contribution of myocardial perfusion defects to exercise capacity and heart rate recovery for prediction of all-cause mortality in patients with known or suspected coronary heart disease. J Am Coll Cardiol. May. 2001;37(6):1558-64. X-1D,X-2,X-6,X-8. [pmid: 11345365].
775 Dick P, Schillinger M, Minar E, et al. Haem oxygenase-1 genotype and cardiovascular adverse events in patients with peripheral artery disease. Eur J Clin Invest. Dec. 2005;35(12):731-7. X-1. [pmid: 16313248].
776 Diercks DB, Hollander JE, Sites F, et al. Derivation and validation of a risk stratification model to identify coronary artery disease in women who present to the emergency department with potential acute coronary syndromes. Acad Emerg Med. Jun. 2004;11(6):630-4. X-1,X-8. [pmid: 15175200].
777 Diercks DB, Kirk JD, Amsterdam EA. Can we identify those at risk for a nondiagnostic treadmill test in a chest pain observation unit?. Crit Pathw Cardiol. Mar. 2008;7(1):29-34. X-2,X-5,X-6,X-8. [pmid: 18458664].
778 Diercks GF, Hillege HL, van Boven AJ, et al. Microalbuminuria modifies the mortality risk associated with electrocardiographic ST-T segment changes. J Am Coll Cardiol. Oct. 16. 2002;40(8):1401. X-1F,X-2, (Netherlands). [pmid: 12392828].
779 Dixon SR, Grines CL, O'Neill WW. The year in interventional cardiology. J Am Coll Cardiol. Jul. 17. 2007;50(3):270-85. X-1,X-4. [pmid: 17631221].
780 Dixon T, Lim LL, Heller RF. Quality of life: an index for identifying high-risk cardiac patients. J Clin Epidemiol. Sep. 2001;54(9):952-60. X-1G,X-2,X-5,X-6,X-8. [pmid: 11520656].
781 Djaiani G, Phillips-Bute B, Podgoreanu M, et al. The association of patent foramen ovale and atrial fibrillation after coronary artery bypass graft surgery. Anesth Analg. Mar. 2004;98(3):585-9. table of contents. X-1,X-5,X-6,X-8. [pmid: 14980902].
782 Djousse L, Ellison RC, Beiser A, et al. Alcohol consumption and risk of ischemic stroke: The Framingham Study. Stroke. Apr. 2002;33(4):907-12. X-1E,X-1F,X-2,X-6. [pmid: 11935035].
783 Djousse L, Rothman KJ, Cupples LA, et al. Serum albumin and risk of myocardial infarction and all-cause mortality in the Framingham Offspring Study. Circulation. Dec. 3. 2002;106(23):2919-24. X-1F,X-2. [pmid: 12460872].
784 Doenst T, Borger MA, Weisel RD, et al. Relation between aortic cross-clamp time and mortality--not as straightforward as expected. Eur J Cardiothorac Surg. Apr. 2008;33(4):660-5. X-1,X-2,X-5,X-6,X-8. [pmid: 18272383].
785 Doenst T, Ivanov J, Borger MA, et al. Sex-specific long-term outcomes after combined valve and coronary artery surgery. Ann Thorac Surg. May. 2006;81(5):1632-6. X-1,X-2,X-8. [pmid: 16631648].
786 Doering LV, Esmailian F, Imperial-Perez F, et al. Determinants of intensive care unit length of stay after coronary artery bypass graft surgery. Heart Lung. Jan-Feb. 2001;30(1):9-17. X-1,X-6,X-7,X-8. [pmid: 11174363].
787 Doherty LS, Kiely JL, Swan V, et al. Long-term effects of nasal continuous positive airway pressure therapy on cardiovascular outcomes in sleep apnea syndrome. Chest. Jun. 2005;127(6):2076-84. X-1,X-7. [pmid: 15947323].
788 Dolan E, Stanton A, Thijs L, et al. Superiority of ambulatory over clinic blood pressure measurement in predicting mortality: the Dublin outcome study. Hypertension. Jul. 2005;46(1):156-61. X-1F,X-2,X-8(9.3-23.1%), (Ireland). [pmid: 15939805].
789 Domanski M, Mitchell G, Pfeffer M, et al. Pulse pressure and cardiovascular disease-related mortality: follow-up study of the Multiple Risk Factor Intervention Trial (MRFIT). JAMA. May. 22-29. 2002;287(20):2677-83. X-1F,X-2,X-6. [pmid: 12020303].
790 Domi T, Edgell DS, McCrindle BW, et al. Frequency, predictors, and neurologic outcomes of vaso-occlusive strokes associated with cardiac surgery in children. Pediatrics. Dec. 2008;122(6):1292-8. X-1,X-2,X-5,X-8. [pmid: 19047248].
791 Dondi M, Fagioli G, Salgarello M, et al. Myocardial SPECT: what do we gain from attenuation correction (and when)?. Q J Nucl Med Mol Imaging. Sep. 2004;48(3):181-7. X-1,X-6,X-8. [pmid: 15499291].
792 Doobay AV, Anand SS. Sensitivity and specificity of the ankle-brachial index to predict future cardiovascular outcomes: a systematic review. Arterioscler Thromb Vasc Biol. Jul. 2005;25(7):1463-9. X-1,X-2,X-4,X-5. [pmid: 15879302].
793 Dorfman TA, Iskandrian AE. Adenosine single photon emission computed tomography for assessing risk after myocardial infarction: recent developments. Curr Opin Cardiol. Sep. 2007;22(5):401-7. X-1,X-8. [pmid: 17762540].
794 Dormandy J, Heeck L, Vig S. The natural history of claudication: risk to life and limb. Semin Vasc Surg. Jun. 1999;12(2):123-37. X-1,X-2,X-4,X-5,X-6. [pmid: 10777239].
795 Dornelas EA, Sampson RA, Gray JF, et al. A randomized controlled trial of smoking cessation counseling after myocardial infarction. Prev Med. Apr. 2000;30(4):261-8. X-1,X-2,X-6,X-7,X-8. [pmid: 10731452].
796 Dorsch MF, Lawrance RA, Sapsford RJ, et al. A simple benchmark for evaluating quality of care of patients following acute myocardial infarction. Heart. Aug. 2001;86(2):150-4. X-1,X-6,X-8. [pmid: 11454829].
797 Dotsenko O, Chackathayil J, Patel JV, et al. Candidate circulating biomarkers for the cardiovascular disease continuum. Curr Pharm Des. 2008;14(24):2445-61. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18781994].
798 Douglas VC, Johnston CM, Elkins J, et al. Head computed tomography findings predict short-term stroke risk after transient ischemic attack. Stroke. Dec. 2003;34(12):2894-8. X-1,X-5,X-6. [pmid: 14615614].
799 Doyle F, McGee HM, De La Harpe D, et al. The Hospital Anxiety and Depression Scale depression subscale, but not the Beck Depression Inventory-Fast Scale, identifies patients with acute coronary syndrome at elevated risk of 1-year mortality. J Psychosom Res. May. 2006;60(5):461-7. X-1,X-8. [pmid: 16650586].
800 Dreau H, Colombet I, Degoulet P, et al. Identification of patients at high cardiovascular risk: a critical appraisal of applicability of statistical risk prediction models. Methods Inf Med. Mar. 2001;40(1):6-11. X-7. [pmid: 11310161].
801 Du R, Keyoung HM, Dowd CF, et al. The effects of diffuseness and deep perforating artery supply on outcomes after microsurgical resection of brain arteriovenous malformations. Neurosurgery. Apr. 2007;60(4):638-46. discussion 646-8. X-1,X-2,X-6. [pmid: 17415200].
802 Du X. Prevalence, treatment, control, and awareness of high blood pressure and the risk of stroke in Northwest England. Prev Med. Apr. 2000;30(4):288-94. X-1,X-2,X-5,X-6,X-8. [pmid: 10731457].
803 Dubin AM, Collins KK, Chiesa N, et al. Use of electrophysiologic testing to assess risk in children with Wolff-Parkinson-White syndrome. Cardiol Young. May. 2002;12(3):248-52. X-1,X-4,X-5. [pmid: 12365171].
804 Duffy VB, Lanier SA, Hutchins HL, et al. Food p questionnaire as a screening tool for assessing dietary risk of cardiovascular disease within health risk appraisals. J Am Diet Assoc. Feb. 2007;107(2):237-45. X-1,X-5,X-6. [pmid: 17258960].
805 Dunkelgrun M, Hoeks SE, Welten GM, et al. Anemia as an independent predictor of perioperative and long-term cardiovascular outcome in patients scheduled for elective vascular surgery. Am J Cardiol. Apr. 15. 2008;101(8):1196-200. X-1. [pmid: 18394458].
806 Dunkelgrun M, Welten GM, Goei D, et al. Association between serum uric acid and perioperative and late cardiovascular outcome in patients with suspected or definite coronary artery disease undergoing elective vascular surgery. Am J Cardiol. Oct. 1. 2008;102(7):797-801. X-1,X-2,X-8. [pmid: 18805100].
807 Dunne VG, Bhattachayya S, Besser M, et al. Metabolites from cerebrospinal fluid in aneurysmal subarachnoid haemorrhage correlate with vasospasm and clinical outcome: a pattern-recognition 1H NMR study. NMR Biomed. Feb. 2005;18(1):24-33. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15455468].
808 Duprez DA, Cohn JN. Identifying early cardiovascular disease to target candidates for treatment. J Clin Hypertens (Greenwich). Mar. 2008;10(3):226-31. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 18326965].
809 Duprez DA, Florea ND, Jones K, et al. Beneficial effects of valsartan in asymptomatic individuals with vascular or cardiac abnormalities: the DETECTIV Pilot Study. J Am Coll Cardiol. Aug. 28. 2007;50(9):835-9. X-1,X-2,X-6,X-7. [pmid: 17719468].
810 Dupuis J, Arsenault A, Meloche B, et al. Quantitative hyperemic reactivity in opposed limbs during myocardial perfusion imaging: a new marker of coronary artery disease. J Am Coll Cardiol. Oct. 6. 2004;44(7):1473-7. X-1,X-5,X-6,X-7,X-8. [pmid: 15464330].
811 Dziewas R, Ritter M, Kruger L, et al. C-reactive protein and fibrinogen in acute stroke patients with and without sleep apnea. Cerebrovasc Dis. 2007;24(5):412-7. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 17878721].
812 Dziewas R, Ritter M, Usta N, et al. Atherosclerosis and obstructive sleep apnea in patients with ischemic stroke. Cerebrovasc Dis. 2007;24(1):122-6. X-1,X-6,X-8. [pmid: 17565197].
813 Dziewas R, Warnecke T, Olenberg S, et al. Towards a basic endoscopic assessment of swallowing in acute stroke -development and evaluation of a simple dysphagia score. Cerebrovasc Dis. 2008;26(1):41-7. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18511871].
814 East MA, Jollis JG, Nelson CL, et al. The influence of left ventricular hypertrophy on survival in patients with coronary artery disease: do race and gender matter?. J Am Coll Cardiol. Mar. 19. 2003;41(6):949-54. X-1,X-6,X-8. [pmid: 12651039].
815 Ebrahim S, Montaner D, Lawlor DA. Clustering of risk factors and social class in childhood and adulthood in British women's heart and health study: cross sectional analysis. BMJ. Apr. 10. 2004;328(7444):861. X-1,X-2,X-5,X-6. [pmid: 15006898].
816 Ecochard R, Rabilloud M, Colin C, et al. Unjustified variations in patient management for acute myocardial infarction in the Rhone-Alpes region of France. PRIMA Group. Int J Technol Assess Health Care. Summer. 2000;16(3):885-95. X-1,X-6,X-8. [pmid: 11028143].
817 Eddinger J, Cohen MC. Advances in nuclear imaging for preoperative risk assessment. Curr Cardiol Rep. Mar. 2005;7(2):143-7. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15717962].
818 Edwards FH, Peterson ED, Coombs LP, et al. Prediction of operative mortality after valve replacement surgery. J Am Coll Cardiol. Mar. 1. 2001;37(3):885-92. X-1,X-6,X-8. [pmid: 11693766].
819 Edwards MS, Craven TE, Burke GL, et al. Renovascular disease and the risk of adverse coronary events in the elderly: a prospective, population-based study. Arch Intern Med. Jan. 24. 2005;165(2):207-13. X-1F,X-2, (Italy). [pmid: 15668368].
820 Efrati S, Cantor A, Goldfarb B, et al. The predictive value of exercise QRS duration changes for post-PTCA coronary events. Ann Noninvasive Electrocardiol. Jan. 2003;8(1):60-7. X-1,X-2,X-8. [pmid: 12848815].
821 Efstathiou SP, Tsioulos DI, Zacharos ID, et al. A new classification tool for clinical differentiation between haemorrhagic and ischaemic stroke. J Intern Med. Aug. 2002;252(2):121-9. X-1,X-8. [pmid: 12190887].
822 Efstratiadis S, Kennard ED, Kelsey SF, et al. Passive tobacco exposure may impair symptomatic improvement in patients with chronic angina undergoing enhanced external counterpulsation. BMC Cardiovasc Disord. 2008;8:23. X-1,X-2,X-6,X-8. [pmid: 18798998].
823 Eggers KM, Dellborg M, Oldgren J, et al. Risk prediction in chest pain patients by biochemical markers including estimates of renal function. Int J Cardiol. Aug. 18. 2008;128(2):207-13. X-1,X-2,X-6,X-8. [pmid: 17662484].
824 Eggers KM, Jaffe AS, Lind L, et al. Value of cardiac troponin I cutoff concentrations below the 99th percentile for clinical decision-making. Clin Chem. Jan. 2009;55(1):85-92. X-1,X-2,X-8. [pmid: 18988758].
825 Eguchi K, Pickering TG, Schwartz JE, et al. Short sleep duration as an independent predictor of cardiovascular events in Japanese patients with hypertension. Arch Intern Med. Nov. 10. 2008;168(20):2225-31. X-1,X-2. [pmid: 19001199].
826 Eichler K, Puhan MA, Steurer J, et al. Prediction of first coronary events with the Framingham score: a systematic review. Am Heart J. May. 2007;153(5):722-31. 731 e1. 8. X-4,X-5. [pmid: 17452145].
827 Eigel P, van Ingen G, Wagenpfeil S. Predictive value of perioperative cardiac troponin I for adverse outcome in coronary artery bypass surgery. Eur J Cardiothorac Surg. Sep. 2001;20(3):544-9. X-1,X-6,X-8. [pmid: 11509277].
828 Eisner MD, Wang Y, Haight TJ, et al. Secondhand smoke exposure, pulmonary function, and cardiovascular mortality. Ann Epidemiol. May. 2007;17(5):364-73. X-1. [pmid: 17300955].
829 Ekart R, Hojs R, Hojs-Fabjan T, et al. Predictive value of carotid intima media thickness in hemodialysis patients. Artif Organs. Aug. 2005;29(8):615-9. X-1,X-7. [pmid: 16048477].
830 El Baz N, Middel B, Van Dijk JP, et al. EuroSCORE predicts poor health-related physical functioning six month postcoronary artery bypass graft surgery. J Cardiovasc Surg (Torino). Oct. 2008;49(5):663-72. X-1,X-6,X-7,X-8.
831 Elahi M, Battula N, Swanevelder J. The use of the stroke risk index to predict neurological complications following coronary revascularisation on cardiopulmonary bypass. Anaesthesia. Jul. 2005;60(7):654-9. X-1,X-8. [pmid: 15960714].
832 Elahi MM, Haesey AM, Graham KC, et al. Leg wound infections following cardiac surgery: a scoring system for assessment and management. J Wound Care. Jul. 2005;14(7):337-40. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 16048221].
833 Elhendy A, Mahoney DW, Burger KN, et al. Prognostic value of exercise echocardiography in patients with classic angina pectoris. Am J Cardiol. Sep. 1. 2004;94(5):559-63. X-1. [pmid: 15342283].
834 Elhendy A, Mahoney DW, McCully RB, et al. Use of a scoring model combining clinical, exercise test, and echocardiographic data to predict mortality in patients with known or suspected coronary artery disease. Am J Cardiol. May. 15. 2004;93(10):1223-8. X-1. [pmid: 15135693].
835 Elhendy A, Schinkel AF, van Domburg RT, et al. Differential prognostic significance of peri-infarction versus remote myocardial ischemia on stress technetium-99m sestamibi tomography in patients with healed myocardial infarction. Am J Cardiol. Aug. 1. 2004;94(3):289-93. X-1,X-8. [pmid: 15276090].
836 Elhendy A, Schinkel AF, van Domburg RT, et al. Incidence and predictors of heart failure during long-term follow-up after stress Tc-99m sestamibi tomography in patients with suspected coronary artery disease. J Nucl Cardiol. Sep-Oct. 2004;11(5):527-33. X-1,X-8. [pmid: 15472637].
837 Elhendy A, Schinkel AF, van Domburg RT, et al. Prognostic value of stress 99mTc-tetrofosmin myocardial perfusion imaging in predicting all-cause mortality: a 6-year follow-up study. Eur J Nucl Med Mol Imaging. Oct. 2006;33(10):1157-61. X-1,X-8. [pmid: 16763814].
838 Elhendy A, Schinkel AF, van Domburg RT, et al. Prognostic value of stress Tc-99m tetrofosmin SPECT in patients with previous myocardial infarction: impact of scintigraphic extent of coronary artery disease. J Nucl Cardiol. Nov-Dec. 2004;11(6):704-9. X-1,X-8. [pmid: 15592194].
839 Elias MF, Sullivan LM, D'Agostino RB, et al. Framingham stroke risk profile and lowered cognitive performance. Stroke. Feb. 2004;35(2):404-9. X-1,X-2,X-5,X-6. [pmid: 14726556].
840 Elkeles R. Computed tomography imaging, coronary calcium and atherosclerosis. Expert Rev Cardiovasc Ther. Sep. 2008;6(8):1083-93. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18793111].
841 Elkeles RS, Dunlop A, Thompson GR, et al. Coronary calcification and predicted risk of coronary heart disease in asymptomatic men with hypercholesterolaemia. J Cardiovasc Risk. Dec. 2002;9(6):349-53. X-5,X-6. [pmid: 12478204].
842 Ellekjaer H, Holmen J, Vatten L. Blood pressure, smoking and body mass in relation to mortality from stroke and coronary heart disease in the elderly. A 10-year follow-up in Norway. Blood Press. 2001;10(3):156-63. X-1F,X-2. [pmid: 11688763].
843 Elliott P, Spirito P. Prevention of hypertrophic cardiomyopathy-related deaths: theory and practice. Heart. Oct. 2008;94(10):1269-75. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18653582].
844 Ellis SG, Bajzer CT, Bhatt DL, et al. Real-world bare metal stenting: identification of patients at low or very low risk of 9-month coronary revascularization. Catheter Cardiovasc Interv. Oct. 2004;63(2):135-40. X-1,X-6,X-8. [pmid: 15390245].
845 Ellis SG, Colombo A, Grube E, et al. Incidence, timing, and correlates of stent thrombosis with the polymeric paclitaxel drug-eluting stent: a TAXUS II, IV, V, and VI meta-analysis of 3,445 patients followed for up to 3 years. J Am Coll Cardiol. Mar. 13. 2007;49(10):1043-51. X-1,X-6,X-8. [pmid: 17349883].
846 Ellis SG, Guetta V, Miller D, et al. Relation between lesion characteristics and risk with percutaneous intervention in the stent and glycoprotein IIb/IIIa era: An analysis of results from 10,907 lesions and proposal for new classification scheme. Circulation. Nov. 9. 1999;100(19):1971-6. X-1,X-6,X-8. [pmid: 10556223].
847 El-Menyar A, Asaad N. T-wave alternans and sudden cardiac death. Crit Pathw Cardiol. Mar. 2008;7(1):21-8. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18458663].
848 El-Saed A, Kuller LH, Newman AB, et al. Factors associated with geographic variations in stroke incidence among older populations in four US communities. Stroke. Aug. 2006;37(8):1980-5. X-1F,X-2. [pmid: 16794204].
849 Elsayed EF, Sarnak MJ, Tighiouart H, et al. Waist-to-hip ratio, body mass index, and subsequent kidney disease and death. Am J Kidney Dis. Jul. 2008;52(1):29-38. X-1,X-2. [pmid: 18511168].
850 Elwert F, Christakis NA. The effect of widowhood on mortality by the causes of death of both spouses. Am J Public Health. Nov. 2008;98(11):2092-8. X-1,X-2. [pmid: 18511733].
851 Emberson JR, Ng LL, Armitage J, et al. N-terminal Pro-B-type natriuretic peptide, vascular disease risk, and cholesterol reduction among 20,536 patients in the MRC/BHF heart protection study. J Am Coll Cardiol. Jan. 23. 2007;49(3):311-9. X-1,X-2,X-6,X-8(22.2-60.9%). [pmid: 17239712].
852 Empana JP, Jouven X, Lemaitre R, et al. Marital status and risk of out-of-hospital sudden cardiac arrest in the population. Eur J Cardiovasc Prev Rehabil. Oct. 2008;15(5):577-82. X-1,X-2,X-5. [pmid: 18756177].
853 Endler G, Funk M, Haering D, et al. Is the factor XIII 34Val/Leu polymorphism a protective factor for cerebrovascular disease?. Br J Haematol. Jan. 2003;120(2):310-4. X-1,X-5. [pmid: 12542492].
854 Engblom H, Carlsson MB, Hedstrom E, et al. The endocardial extent of reperfused first-time myocardial infarction is more predictive of pathologic Q waves than is infarct transmurality: a magnetic resonance imaging study. Clin Physiol Funct Imaging. Mar. 2007;27(2):101-8. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 17309530].
855 Engblom H, Wagner GS, Setser RM, et al. Quantitative clinical assessment of chronic anterior myocardial infarction with delayed enhancement magnetic resonance imaging and QRS scoring. Am Heart J. Aug. 2003;146(2):359-66. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 12891208].
856 Engel G, Cho S, Ghayoumi A, et al. Prognostic significance of PVCs and resting heart rate. Ann Noninvasive Electrocardiol. Apr. 2007;12(2):121-9. X-1,X-6. [pmid: 17593180].
857 Engstrom G, Hedblad B, Janzon L, et al. Ventricular arrhythmias during 24-h ambulatory ECG recording: incidence, risk factors and prognosis in men with and without a history of cardiovascular disease. J Intern Med. Oct. 1999;246(4):363-72. X-6,X-8. [pmid: 10583707].
858 Engstrom G, Hedblad B, Janzon L, et al. Complement C3 and C4 in plasma and incidence of myocardial infarction and stroke: a population-based cohort study. Eur J Cardiovasc Prev Rehabil. Jun. 2007;14(3):392-7. X-1,X-6. [pmid: 17568238].
859 Engstrom G, Lind P, Hedblad B, et al. Long-term effects of inflammation-sensitive plasma proteins and systolic blood pressure on incidence of stroke. Stroke. Dec. 2002;33(12):2744-9. X-1. [pmid: 12468764].
860 Ennett CM, Frize M. Weight-elimination neural networks applied to coronary surgery mortality prediction. IEEE Trans Inf Technol Biomed. Jun. 2003;7(2):86-92. X-1,X-6,X-8. [pmid: 12834163].
861 Ennett CM, Frize M, Charette E. Improvement and automation of artificial neural networks to estimate medical outcomes. Med Eng Phys. May. 2004;26(4):321-8. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15121057].
862 Ensrud KE, Stock JL, Barrett-Connor E, et al. Effects of raloxifene on fracture risk in postmenopausal women: the Raloxifene Use for the Heart Trial. J Bone Miner Res. Jan. 2008;23(1):112-20. X-1,X-2,X-6,X-8. [pmid: 17892376].
863 Erblich J, Bovbjerg DH, Norman C, et al. It won't happen to me: lower perception of heart disease risk among women with family histories of breast cancer. Prev Med. Dec. 2000;31(6):714-21. X-1,X-2,X-7. [pmid: 11133339].
864 Erren M, Reinecke H, Junker R, et al. Systemic inflammatory parameters in patients with atherosclerosis of the coronary and peripheral arteries. Arterioscler Thromb Vasc Biol. Oct. 1999;19(10):2355-63. X-1,X-5,X-6,X-7. [pmid: 10521364].
865 Erzen B, Sabovic M, Sebestjen M, et al. Endothelial dysfunction, intima-media thickness, ankle-brachial pressure index, and pulse pressure in young post-myocardial infarction patients with various expressions of classical risk factors. Heart Vessels. Jul. 2007;22(4):215-22. X-1,X-6,X-7,X-8. [pmid: 17653514].
866 Espinola-Klein C, Rupprecht HJ, Bickel C, et al. Different calculations of ankle-brachial index and their impact on cardiovascular risk prediction. Circulation. Aug. 26. 2008;118(9):961-7. X-1,X-2,X-6,X-8. [pmid: 18697822].
867 Essink-Bot ML, Kruijshaar ME, Barendregt JJ, et al. Evidence-based guidelines, time-based health outcomes, and the Matthew effect. Eur J Public Health. Jun. 2007;17(3):314-7. X-1,X-2,X-5,X-6,X-7. [pmid: 17060334].
868 Etchells E, Meade M, Tomlinson G, et al. Semiquantitative dipyridamole myocardial stress perfusion imaging for cardiac risk assessment before noncardiac vascular surgery: a meta-analysis. J Vasc Surg. Sep. 2002;36(3):534-40. X-1,X-5. [pmid: 12218978].
869 Etienne PY, Papadatos S, Glineur D, et al. Reduced mortality in high-risk coronary patients operated off pump with preoperative intraaortic balloon counterpulsation. Ann Thorac Surg. Aug. 2007;84(2):498-502. X-1,X-6,X-8. [pmid: 17643622].
870 Evans CH, Harris G, Mendold V, et al. A basic approach to the interpretation of the exercise test. Prim Care. Mar. 2001;28(1):73-98. vi. X-4. [pmid: 11346499].
871 Evans JM, Wang J, Morris AD. Comparison of cardiovascular risk between patients with type 2 diabetes and those who had had a myocardial infarction: cross sectional and cohort studies. BMJ. Apr. 20. 2002;324(7343):939-42. X-8. [pmid: 11964337].
872 Everett BM, Kurth T, Buring JE, et al. The relative strength of C-reactive protein and lipid levels as determinants of ischemic stroke compared with coronary heart disease in women. J Am Coll Cardiol. Dec. 5. 2006;48(11):2235-42. X-1F,X-2. [pmid: 17161253].
873 Everett CJ, Mainous AG 3rd, Koopman RJ, et al. Multiple lipid scoring system for prediction of coronary heart disease risk: application to African Americans. J Natl Med Assoc. Nov. 2006;98(11):1740-5. X-2. [pmid: 17128681].
874 Everson SA, Lynch JW, Kaplan GA, et al. Stress-induced blood pressure reactivity and incident stroke in middle-aged men. Stroke. Jun. 2001;32(6):1263-70. X-1F,X-2. [pmid: 11387485].
875 Evrengul H, Dursunoglu D, Kaftan A, et al. Bilateral diagonal earlobe crease and coronary artery disease: a significant association. Dermatology. 2004;209(4):271-5. X-1,X-2,X-5,X-6,X-8. [pmid: 15539887].
876 Exner DV, Kavanagh KM, Slawnych MP, et al. Noninvasive risk assessment early after a myocardial infarction the REFINE study. J Am Coll Cardiol. Dec. 11. 2007;50(24):2275-84. X-1,X-8. [pmid: 18068035].
877 Extramiana F, Neyroud N, Huikuri HV, et al. QT interval and arrhythmic risk assessment after myocardial infarction. Am J Cardiol. Jan. 15. 1999;83(2):266-9. A6. X-1,X-5,X-6. [pmid: 10073834].
878 Ezekowitz JA, Theroux P, Welsh R, et al. Insights into the change in brain natriuretic peptide after ST-elevation myocardial infarction (STEMI): why should it be better than baseline?. Can J Physiol Pharmacol. Jan. 2007;85(1):173-8. X-1,X-5,X-6. [pmid: 17487257].
879 Faglia E, Clerici G, Caminiti M, et al. Advantages of myocardial revascularization after admission for critical limb ischemia in diabetic patients with coronary artery disease: data of a cohort of 564 consecutive patients. J Cardiovasc Med (Hagerstown). Oct. 2008;9(10):1030-6. X-1,X-2,X-8. [pmid: 18799966].
880 Falcone C, Minoretti P, D'Angelo A, et al. Markers of eosinophilic inflammation and risk prediction in patients with coronary artery disease. Eur J Clin Invest. Apr. 2006;36(4):211-7. X-1,X-8. [pmid: 16620281].
881 Falcoz PE, Chocron S, Stoica L, et al. Open heart surgery: one-year self-assessment of quality of life and functional outcome. Ann Thorac Surg. Nov. 2003;76(5):1598-604. discussion 1604. X-1,X-6,X-8. [pmid: 14602293].
882 Fallon UB, Virtamo J, Young I, et al. Homocysteine and cerebral infarction in finnish male smokers. Stroke. Jun. 2003;34(6):1359-63. X-1,X-5,X-6. [pmid: 12750538].
883 Falyar CR. Using transcranial Doppler sonography to augment the neurological examination after aneurysmal subarachnoid hemorrhage. J Neurosci Nurs. Oct. 1999;31(5):285-93. X-1,X-2,X-4,X-5,X-6,X-8. [pmid: 10633305].
884 Fang MC, Go AS, Chang Y, et al. Death and disability from warfarin-associated intracranial and extracranial hemorrhages. Am J Med. Aug. 2007;120(8):700-5. X-1,X-6. [pmid: 17679129].
885 Faraday N, Becker DM, Yanek LR, et al. Relation between atherosclerosis risk factors and aspirin resistance in a primary prevention population. Am J Cardiol. Sep. 15. 2006;98(6):774-9. X-1,X-2,X-6. [pmid: 16950183].
886 Faraday N, Martinez EA, Scharpf RB, et al. Platelet gene polymorphisms and cardiac risk assessment in vascular surgical patients. Anesthesiology. Dec. 2004;101(6):1291-7. X-1,X-7,X-8. [pmid: 15564935].
887 Farin A, Marshall LF. Lessons from epidemiologic studies in clinical trials of traumatic brain injury. Acta Neurochir Suppl. 2004;89:101-7. X-1,X-4,X-5. [pmid: 15335108].
888 Farkouh ME, Bansilal S, Mathew V. CRP has little incremental value over traditional cardiovascular risk factors in risk stratification. Nat Clin Pract Cardiovasc Med. Jun. 2007;4(6):290-1. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 17522718].
889 Farnier M, Garnier P, Yau C, et al. Prevalence of low HDL-cholesterol in patients with cardiovascular risk factors: The ECHOS (Etude du Cholesterol HDL en Observationnel) French Survey. Int J Clin Pract. Oct. 2006;60(10):1166-71. X-1,X-6. [pmid: 16942588].
890 Farrokhyar F, Wang X, Kent R, et al. Early mortality from off-pump and on-pump coronary bypass surgery in Canada: a comparison of the STS and the EuroSCORE risk prediction algorithms. Can J Cardiol. Sep. 2007;23(11):879-83. X-1,X-8. [pmid: 17876379].
891 Fatar M, Stroick M, Steffens M, et al. Single-nucleotide polymorphisms of MMP-2 gene in stroke subtypes. Cerebrovasc Dis. 2008;26(2):113-9. X-1,X-2,X-5,X-7,X-8. [pmid: 18560213].
892 Fateh-Moghadam S, Htun P, Tomandl B, et al. Hyperresponsiveness of platelets in ischemic stroke. Thromb Haemost. Jun. 2007;97(6):974-8. X-1,X-6,X-7. [pmid: 17549300].
893 Faulx MD, Storfer-Isser A, Kirchner HL, et al. Obstructive sleep apnea is associated with increased urinary albumin excretion. Sleep. Jul. 1. 2007;30(7):923-9. X-1,X-2,X-6. [pmid: 17682664].
894 Fayad ZA, Fuster V. Clinical imaging of the high-risk or vulnerable atherosclerotic plaque. Circ Res. Aug. 17. 2001;89(4):305-16. X-1,X-2,X-4,X-5,X-6. [pmid: 11509446].
895 Feinberg MS, Schwammenthal E, Shlizerman L, et al. Prognostic significance of mild mitral regurgitation by color Doppler echocardiography in acute myocardial infarction. Am J Cardiol. Nov. 1. 2000;86(9):903-7. X-1,X-8. [pmid: 11053696].
896 Felber Dietrich D, Schwartz J, Schindler C, et al. Effects of passive smoking on heart rate variability, heart rate and blood pressure: an observational study. Int J Epidemiol. Aug. 2007;36(4):834-40. X-1,X-2,X-5,X-6. [pmid: 17440032].
897 Feldman HA, Johannes CB, Derby CA, et al. Erectile dysfunction and coronary risk factors: prospective results from the Massachusetts male aging study. Prev Med. Apr. 2000;30(4):328-38. X-1,X-6. [pmid: 10731462].
898 Femia R, Natali A, L'Abbate A, et al. Coronary atherosclerosis and alcohol consumption: angiographic and mortality data. Arterioscler Thromb Vasc Biol. Jul. 2006;26(7):1607-12. X-1,X-8. [pmid: 16627806].
899 Ferguson TB Jr, Coombs LP, Peterson ED. Internal thoracic artery grafting in the elderly patient undergoing coronary artery bypass grafting: room for process improvement?. J Thorac Cardiovasc Surg. May. 2002;123(5):869-80. X-1,X-2,X-8. [pmid: 12019371].
900 Ferguson TS, Younger NO, Tulloch-Reid MK, et al. Prevalence of prehypertension and its relationship to risk factors for cardiovascular disease in Jamaica: analysis from a cross-sectional survey. BMC Cardiovasc Disord. 2008;8:20. X-1,X-2,X-5,X-6. [pmid: 18752689].
901 Feringa HH, Elhendy A, Karagiannis SE, et al. Improving risk assessment with cardiac testing in peripheral arterial disease. Am J Med. Jun. 2007;120(6):531-8. X-1F,X-2,X-8. [pmid: 17524756].
902 Feringa HH, Karagiannis SE, Schouten O, et al. Prognostic significance of declining ankle-brachial index values in patients with suspected or known peripheral arterial disease. Eur J Vasc Endovasc Surg. Aug. 2007;34(2):206-13. X-1F,X-2,X-8. [pmid: 17481930].
903 Feringa HH, Karagiannis SE, Vidakovic R, et al. Glycemic control, lipid-lowering treatment, and prognosis in diabetic patients with peripheral atherosclerotic disease. Ann Vasc Surg. Nov. 2007;21(6):780-9. X-1E,X-1F,X-1G,X-2. [pmid: 17980797].
904 Fernandez ML, Webb D. The LDL to HDL cholesterol ratio as a valuable tool to evaluate coronary heart disease risk. J Am Coll Nutr. Feb. 2008;27(1):1-5. X-4,X-5,X-6,X-7,X-8. [pmid: 18460475].
905 Fernandez-Miranda C, Yebra M, Aranda JL, et al. Effect of folic acid treatment on carotid intima-media thickness of patients with coronary disease. Int J Cardiol. Jun. 12. 2007;118(3):345-9. X-1,X-2,X-6,X-7,X-8. [pmid: 17052775].
906 Ferns GA. New and emerging risk factors for CVD. Proc Nutr Soc. May. 2008;67(2):223-31. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18412996].
907 Ferro D, Loffredo L, Polimeni L, et al. Soluble CD40 ligand predicts ischemic stroke and myocardial infarction in patients with nonvalvular atrial fibrillation. Arterioscler Thromb Vasc Biol. Dec. 2007;27(12):2763-8. X-1E,X-1F,X-2. [pmid: 17901373].
908 Ferroni P, Rosa A, Di Franco M, et al. Prognostic significance of interleukin-6 measurement in the diagnosis of acute myocardial infarction in emergency department. Clin Chim Acta. Jun. 2007;381(2):151-6. X-1,X-7,X-8. [pmid: 17408606].
909 Fesmire FM, Hughes AD, Stout PK, et al. Selective dual nuclear scanning in low-risk patients with chest pain to reliably identify and exclude acute coronary syndromes. Ann Emerg Med. Sep. 2001;38(3):207-15. X-1,X-2. [pmid: 11524638].
910 Filho JA, Salvetti XM, de Mello MT, et al. Coronary risk in a cohort of Paralympic athletes. Br J Sports Med. Nov. 2006;40(11):918-22. X-1,X-2,X-5,X-6,X-7. [pmid: 16950883].
911 Filipovic M, Jeger R, Probst C, et al. Heart rate variability and cardiac troponin I are incremental and independent predictors of one-year all-cause mortality after major noncardiac surgery in patients at risk of coronary artery disease. J Am Coll Cardiol. Nov. 19. 2003;42(10):1767-76. X-1,X-6X-8. [pmid: 14642686].
912 Filsoufi F, Jouan J, Chilkwe J, et al. Results and predictors of early and late outcome of coronary artery bypass graft surgery in patients with ejection fraction less than 20%. Arch Cardiovasc Dis. Sep. 2008;101(9):547-56. X-1,X-2,X-7,X-8. [pmid: 19041839].
913 Filsoufi F, Rahmanian PB, Castillo JG, et al. Excellent results of contemporary coronary artery bypass grafting with systematic application of modern perioperative strategies. Heart Surg Forum. 2007;10(5):E349-56. X-1,X-6,X-8. [pmid: 17855197].
914 Fink JN, Kumar S, Horkan C, et al. The stroke patient who woke up: clinical and radiological features, including diffusion and perfusion MRI. Stroke. Apr. 2002;33(4):988-93. X-1,X-2,X-6,X-8. [pmid: 11935049].
915 Finnie AK, Buchholz AC, Martin Ginis KA. Current coronary heart disease risk assessment tools may underestimate risk in community-dwelling persons with chronic spinal cord injury. Spinal Cord. Sep. 2008;46(9):608-15. X-1,X-2,X-5,X-6,X-7. [pmid: 18332887].
916 Fintel D, Joyce A, Mackell J, et al. Reduced mortality rates after intensive statin therapy in managed-care patients. Value Health. Mar-Apr. 2007;10(2):161-9. X-1,X-6,X-7,X-8. [pmid: 17391425].
917 Fiore LD, Ezekowitz MD, Brophy MT, et al. Department of Veterans Affairs Cooperative Studies Program Clinical Trial comparing combined warfarin and aspirin with aspirin alone in survivors of acute myocardial infarction: primary results of the CHAMP study. Circulation. Feb. 5. 2002;105(5):557-63. X-1,X-2,X-8. [pmid: 11827919].
918 Fitchett D, Goodman S, Langer A. New advances in the management of acute coronary syndromes: 1. Matching treatment to risk. CMAJ. May. 1. 2001;164(9):1309-16. X-1,X-8. [pmid: 11341143].
919 Fitzpatrick AL, Kronmal RA, Gardner JP, et al. Leukocyte telomere length and cardiovascular disease in the cardiovascular health study. Am J Epidemiol. Jan. 1. 2007;165(1):14-21. X-1E,X-1F,X-1G,X-2. [pmid: 17043079].
920 Flaker G, Greenspon A, Tardiff B, et al. Death in patients with permanent pacemakers for sick sinus syndrome. Am Heart J. Nov. 2003;146(5):887-93. X-1,X-6. [pmid: 14597940].
921 Fleming SM, Divilly M, Chakravarthi PI, et al. The role of cardiac troponin I in determining the necessity for exercise electrocardiography in low risk patients with chest pain. Ir J Med Sci. Jul-Sep. 2000;169(3):173-5. X-1,X-5,X-6,X-7,X-8. [pmid: 11272870].
922 Flint AJ, Rimm EB. Commentary: Obesity and cardiovascular disease risk among the young and old--is BMI the wrong benchmark?. Int J Epidemiol. Feb. 2006;35(1):187-9. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 16394117].
923 Florath I, Rosendahl UP, Mortasawi A, et al. Current determinants of operative mortality in 1400 patients requiring aortic valve replacement. Ann Thorac Surg. Jul. 2003;76(1):75-83. X-1,X-6. [pmid: 12842517].
924 Flores-Mateo G, Navas-Acien A, Pastor-Barriuso R, et al. Selenium and coronary heart disease: a meta-analysis. Am J Clin Nutr. Oct. 2006;84(4):762-73. X-1,X-2,X-4,X-5. [pmid: 17023702].
925 Flouris AD, Faught BE, Klentrou P. Cardiovascular disease risk in adolescent smokers: evidence of a ‘smoker lifestyle’. J Child Health Care. Sep. 2008;12(3):221-31. X-1,X-2,X-5,X-6,X-7. [pmid: 18678584].
926 Foguet Q, Rodriguez A, Saez M, et al. Usefulness of optic fundus examination with retinography in initial evaluation of hypertensive patients. Am J Hypertens. Apr. 2008;21(4):400-5. X-1,X-2,X-5,X-6. [pmid: 18369359].
927 Foley KA, Denke MA, Kamal-Bahl S, et al. The impact of physician attitudes and beliefs on treatment decisions: lipid therapy in high-risk patients. Med Care. May. 2006;44(5):421-8. X-1,X-2,X-5,X-6. [pmid: 16641660].
928 Foley RN, Murray AM, Li S, et al. Chronic kidney disease and the risk for cardiovascular disease, renal replacement, and death in the United States Medicare population, 1998 to 1999. J Am Soc Nephrol. Feb. 2005;16(2):489-95. X-1F,X-2,X-6,X-8. [pmid: 15590763].
929 Folkeringa N, Coppens M, Veeger NJ, et al. Absolute risk of venous and arterial thromboembolism in thrombophilic families is not increased by high thrombin-activatable fibrinolysis inhibitor (TAFI) levels. Thromb Haemost. Jul. 2008;100(1):38-44. X-1,X-6. [pmid: 18612536].
930 Folsom AR, Chambless LE, Ballantyne CM, et al. An assessment of incremental coronary risk prediction using C-reactive protein and other novel risk markers: the atherosclerosis risk in communities study. Arch Intern Med. Jul. 10. 2006;166(13):1368-73. X-1. [pmid: 16832001].
931 Folsom AR, Parker ED, Harnack LJ. Degree of concordance with DASH diet guidelines and incidence of hypertension and fatal cardiovascular disease. Am J Hypertens. Mar. 2007;20(3):225-32. X-1,X-2. [pmid: 17324731].
932 Fonarow GC, Adams KF Jr, Abraham WT, et al. Risk stratification for in-hospital mortality in acutely decompensated heart failure: classification and regression tree analysis. JAMA. Feb. 2. 2005;293(5):572-80. X-1,X-8. [pmid: 15687312].
933 Fonarow GC, Lukas MA, Robertson M, et al. Effects of carvedilol early after myocardial infarction: analysis of the first 30 days in Carvedilol Post-Infarct Survival Control in Left Ventricular Dysfunction (CAPRICORN). Am Heart J. Oct. 2007;154(4):637-44. X-1,X-2,X-8. [pmid: 17892984].
934 Fonseca A, Costa Jde R Jr, Abizaid A, et al. Intravascular ultrasound assessment of the novel AngioSculpt scoring balloon catheter for the treatment of complex coronary lesions. J Invasive Cardiol. Jan. 2008;20(1):21-7. X-1,X-2,X-5,X-6,X-7X-8. [pmid: 18174614].
935 Fontaine JM, Ofili EO, Adenaike MB, et al. Clinical assessment of the risk for sudden cardiac death in patients with sickle cell anemia. J Natl Med Assoc. Apr. 2008;100(4):360-8. X-1,X-5,X-6,X-7. [pmid: 18481474].
936 Foody JM, Ferdinand FD, Pearce GL, et al. HDL cholesterol level predicts survival in men after coronary artery bypass graft surgery: 20-year experience from The Cleveland Clinic Foundation. Circulation. Nov. 7. 2000;102(19 Suppl 3):III90-4. X-8. [pmid: 11082369].
937 Forbes TL, Steiner SH, Lawlor DK, et al. Risk-adjusted analysis of outcomes following elective open abdominal aortic aneurysm repair. Ann Vasc Surg. Mar. 2005;19(2):142-8. X-1D,X-2,X-8. [pmid: 15782273].
938 Ford ES. The metabolic syndrome and mortality from cardiovascular disease and all-causes: findings from the National Health and Nutrition Examination Survey II Mortality Study. Atherosclerosis. Apr. 2004;173(2):309-14. X-1,X-2. [pmid: 15064107].
939 Ford ES, Giles WH, Mokdad AH. The distribution of 10-Year risk for coronary heart disease among US adults: findings from the National Health and Nutrition Examination Survey III. J Am Coll Cardiol. May. 19. 2004;43(10):1791-6. X-1,X-2,X-5,X-6. [pmid: 15145101].
940 Forge BH, Briganti EM. Lipid lowering and coronary heart disease risk: how appropriate are the national guidelines?. Med J Aust. Nov. 5. 2001;175(9):471-5. X-1F,X-2,X-5,X-6,X-8. [pmid: 11758075].
941 Forshaw MJ, Strauss DC, Davies AR, et al. Is cardiopulmonary exercise testing a useful test before esophagectomy?. Ann Thorac Surg. Jan. 2008;85(1):294-9. X-1,X-2,X-6,X-7,X-8. [pmid: 18154826].
942 Fortescue EB, Bates DW, Chertow GM. Predicting acute renal failure after coronary bypass surgery: cross-validation of two risk-stratification algorithms. Kidney Int. Jun. 2000;57(6):2594-602. X-1,X-6,X-8. [pmid: 10844629].
943 Fortescue EB, Kahn K, Bates DW. Development and validation of a clinical prediction rule for major adverse outcomes in coronary bypass grafting. Am J Cardiol. Dec. 1. 2001;88(11):1251-8. X-1,X-8. [pmid: 11728352].
944 Fortmann SP, Ford E, Criqui MH, et al. CDC/AHA Workshop on Markers of Inflammation and Cardiovascular Disease: Application to Clinical and Public Health Practice: report from the population science discussion group. Circulation. Dec. 21. 2004;110(25):e554-9. X-1E,X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 15611381].
945 Foussas SG, Zairis MN, Lyras AG, et al. Early prognostic usefulness of C-reactive protein added to the Thrombolysis In Myocardial Infarction risk score in acute coronary syndromes. Am J Cardiol. Aug. 15. 2005;96(4):533-7. X-1,X-8. [pmid: 16098307].
946 Fowkes FG, Murray GD, Butcher I, et al. Ankle brachial index combined with Framingham Risk Score to predict cardiovascular events and mortality: a meta-analysis. JAMA. Jul. 9. 2008;300(2):197-208. X-1,X-5. [pmid: 18612117].
947 Fowler VG Jr, O'Brien SM, Muhlbaier LH, et al. Clinical predictors of major infections after cardiac surgery. Circulation. Aug. 30. 2005;112(9 Suppl):I358-65. X-1,X-6,X-8. [pmid: 16159846].
948 Fox CJ, Cullen DJ, Knuiman MW, et al. Effects of body iron stores and haemochromatosis genotypes on coronary heart disease outcomes in the Busselton health study. J Cardiovasc Risk. Oct. 2002;9(5):287-93. X-1,X-6. [pmid: 12394323].
949 Fox CS, Parise H, Vasan RS, et al. Mitral annular calcification is a predictor for incident atrial fibrillation. Atherosclerosis. Apr. 2004;173(2):291-4. X-1,X-2,X-6. [pmid: 15064104].
950 Fox ER, Han H, Taylor HA, et al. The prognostic value of the mitral diastolic filling velocity ratio for all-cause mortality and cardiovascular morbidity in African Americans: the Atherosclerotic Risks in Communities (ARIC) study. Am Heart J. Oct. 2006;152(4):749-55. X-1F,X-2. [pmid: 16996852].
951 Fox KA, Anderson FA Jr, Dabbous OH, et al. Intervention in acute coronary syndromes: do patients undergo intervention on the basis of their risk characteristics? The Global Registry of Acute Coronary Events (GRACE). Heart. Feb. 2007;93(2):177-82. X-1,X-2,X-8. [pmid: 16757543].
952 Fox KA, Anderson FA Jr, Goodman SG, et al. Time course of events in acute coronary syndromes: implications for clinical practice from the GRACE registry. Nat Clin Pract Cardiovasc Med. Sep. 2008;5(9):580-9. X-1,X-2,X-8. [pmid: 18665136].
953 Fox KA, Dabbous OH, Goldberg RJ, et al. Prediction of risk of death and myocardial infarction in the six months after presentation with acute coronary syndrome: prospective multinational observational study (GRACE). BMJ. Nov. 25. 2006;333(7578):1091. X-1,X-8. [pmid: 17032691].
954 Fracanzani AL, Burdick L, Raselli S, et al. Carotid artery intima-media thickness in nonalcoholic fatty liver disease. Am J Med. Jan. 2008;121(1):72-8. X-1,X-2,X-5,X-6. [pmid: 18187076].
955 Franco OH, Steyerberg EW, Hu FB, et al. Associations of diabetes mellitus with total life expectancy and life expectancy with and without cardiovascular disease. Arch Intern Med. Jun. 11. 2007;167(11):1145-51. X-1,X-2,X-8. [pmid: 17563022].
956 Franklin SS. Blood pressure and cardiovascular disease: what remains to be achieved?. J Hypertens Suppl. Sep. 2001;19(3):S3-8. X-1,X-4.
957 Fransson E, de Faire U, Ahlbom A, et al. The effect of leisure-time physical activity on the risk of acute myocardial infarction depending on body mass index: a population-based case-control study. BMC Public Health. 2006;6:296. X-1,X-2. [pmid: 17156418].
958 Fraser A, Harris R, Sattar N, et al. Gamma-glutamyltransferase is associated with incident vascular events independently of alcohol intake: analysis of the British Women's Heart and Health Study and Meta-Analysis. Arterioscler Thromb Vasc Biol. Dec. 2007;27(12):2729-35. X-1E,X-1F,X-2. [pmid: 17932318].
959 Fraser AG, Scragg RK, Cox B, et al. Helicobacter pylori, Chlamydia pneumoniae and myocardial infarction. Intern Med J. Jul. 2003;33(7):267-72. X-1,X-5,X-6. [pmid: 12823670].
960 Frazier L. Novel predictors of acute coronary syndrome outcomes. Biol Res Nurs. Jul. 2003;5(1):30-6. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12886668].
961 Freedman DS, Dietz WH, Srinivasan SR, et al. The relation of overweight to cardiovascular risk factors among children and adolescents: the Bogalusa Heart Study. Pediatrics. Jun. 1999;103(6 Pt 1):1175-82. X-1,X-8. [pmid: 10353925].
962 Freeman RV, Mehta RH, Al Badr W, et al. Influence of concurrent renal dysfunction on outcomes of patients with acute coronary syndromes and implications of the use of glycoprotein IIb/IIIa inhibitors. J Am Coll Cardiol. Mar. 5. 2003;41(5):718-24. X-1,X-6,X-8. [pmid: 12628712].
963 Freeman RV, O'Donnell M, Share D, et al. Nephropathy requiring dialysis after percutaneous coronary intervention and the critical role of an adjusted contrast dose. Am J Cardiol. Nov. 15. 2002;90(10):1068-73. X-1,X-2,X-6,X-8. [pmid: 12423705].
964 Freiberg MS, Pencina MJ, D'Agostino RB, et al. BMI vs. waist circumference for identifying vascular risk. Obesity (Silver Spring). Feb. 2008;16(2):463-9. X-1. [pmid: 18239660].
965 Frey N, Dietz A, Kurowski V, et al. Angiographic correlates of a positive troponin T test in patients with unstable angina. Crit Care Med. Jun. 2001;29(6):1130-6. X-1,X-6,X-7,X-8. [pmid: 11395586].
966 Friday G, Alter M, Lai SM. Control of hypertension and risk of stroke recurrence. Stroke. Nov. 2002;33(11):2652-7. X-1. [pmid: 12411656].
967 Fried LF, Katz R, Sarnak MJ, et al. Kidney function as a predictor of noncardiovascular mortality. J Am Soc Nephrol. Dec. 2005;16(12):3728-35. X-1,X-6. [pmid: 16251239].
968 Friedman AN, Groh WJ, Das M. A pilot study in hemodialysis of an electrophysiological tool to measure sudden cardiac death risk. Clin Nephrol. Sep. 2007;68(3):159-64. X-1,X-2,X-5,X-6,X-7. [pmid: 17915618].
969 Friedman ND, Bull AL, Russo PL, et al. Performance of the national nosocomial infections surveillance risk index in predicting surgical site infection in australia. Infect Control Hosp Epidemiol. Jan. 2007;28(1):55-9. X-1,X-6. [pmid: 17230388].
970 Friedman ND, Bull AL, Russo PL, et al. An alternative scoring system to predict risk for surgical site infection complicating coronary artery bypass graft surgery. Infect Control Hosp Epidemiol. Oct. 2007;28(10):1162-8. X-1,X-6,X-8. [pmid: 17828693].
971 Frijling BD, Lobo CM, Keus IM, et al. Perceptions of cardiovascular risk among patients with hypertension or diabetes. Patient Educ Couns. Jan. 2004;52(1):47-53. X-1,X-2,X-5,X-6. [pmid: 14729290].
972 Frimm CD, Trezza B, Gruppi C, et al. Left ventricular hypertrophy predicts outcome of hypertension regardless of the type of ventricular arrhythmia present. J Hum Hypertens. Sep. 1999;13(9):617-23. X-1,X-5,X-6,X-7. [pmid: 10482971].
973 Frioes F, Azevedo A, Castro A, et al. Impact of cardiovascular risk factors in an urban sample of Portuguese adults according to the Framingham risk prediction models. Rev Port Cardiol. Apr. 2003;22(4):511-20. X-1,X-2,X-5,X-6. [pmid: 12879643].
974 Froelicher V, Shetler K, Ashley E. Better decisions through science: exercise testing scores. Prog Cardiovasc Dis. Mar-Apr. 2002;44(5):395-414. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12024337].
975 Frontera JA, Parra A, Shimbo D, et al. Cardiac arrhythmias after subarachnoid hemorrhage: risk factors and impact on outcome. Cerebrovasc Dis. 2008;26(1):71-8. X-1,X-5,X-6,X-8. [pmid: 18525201].
976 Frontini MG, Srinivasan SR, Xu J, et al. Usefulness of childhood non-high density lipoprotein cholesterol levels versus other lipoprotein measures in predicting adult subclinical atherosclerosis: the Bogalusa Heart Study. Pediatrics. May. 2008;121(5):924-9. X-1,X-2,X-6. [pmid: 18450895].
977 Froom P, Cohen C, Rashcupkin J, et al. Referral to occupational medicine clinics and resumption of employment after myocardial infarction. J Occup Environ Med. Nov. 1999;41(11):943-7. X-1,X-6,X-7. [pmid: 10570498].
978 Frutkin AD, Mehta SK, Patel T, et al. Outcomes of 1,090 consecutive, elective, nonselected percutaneous coronary interventions at a community hospital without onsite cardiac surgery. Am J Cardiol. Jan. 1. 2008;101(1):53-7. X-1,X-2,X-5,X-6,X-8. [pmid: 18157965].
979 Fry DE, Pine M, Jordan HS, et al. Combining administrative and clinical data to stratify surgical risk. Ann Surg. Nov. 2007;246(5):875-85. X-1B,X-1F,X-2,X-5,X-6,X-7,X-8,X-9. [pmid: 17968182].
980 Fuchs I, Frossard M, Spiel A, et al. Platelet function in patients with acute coronary syndrome (ACS) predicts recurrent ACS. J Thromb Haemost. Dec. 2006;4(12):2547-52. X-1,X-2,X-6,X-8. [pmid: 17002662].
981 Fuchs S, Gruberg L, Singh S, et al. Prognostic value of cardiac troponin I re-elevation following percutaneous coronary intervention in high-risk patients with acute coronary syndromes. Am J Cardiol. Jul. 15. 2001;88(2):129-33. X-1,X-7,X-8. [pmid: 11448408].
982 Fukui T, Shibata T, Sasaki Y, et al. Long-term survival and functional recovery after isolated coronary artery bypass grafting in patients with severe left ventricular dysfunction. Gen Thorac Cardiovasc Surg. Oct. 2007;55(10):403-8. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18018603].
983 Fukui T, Shimokawa T, Manabe S, et al. Prior inferior myocardial infarction has worse early outcomes in patients undergoing coronary artery bypass grafting than prior anterior myocardial infarction. Ann Thorac Surg. Feb. 2009;87(2):475-80. X-1,X-2,X-8. [pmid: 19161763].
984 Fukuoka K, Nakao K, Morimoto H, et al. Glycated albumin levels predict long-term survival in diabetic patients undergoing haemodialysis. Nephrology (Carlton). Jun. 2008;13(4):278-83. X-1F,X-2,X-7. [pmid: 18476915].
985 Fuster RG, Argudo JA, Albarova OG, et al. Prognostic value of chronic obstructive pulmonary disease in coronary artery bypass grafting. Eur J Cardiothorac Surg. Feb. 2006;29(2):202-9. X-1,X-6,X-8. [pmid: 16376093].
986 Gabriel Steg P, Iung B, Feldman LJ, et al. Determinants of use and outcomes of invasive coronary procedures in acute coronary syndromes: results from ENACT. Eur Heart J. Apr. 2003;24(7):613-22. X-1,X-6,X-8. [pmid: 12657219].
987 Gaeta G, Cuomo S, Capozzi G, et al. Lipoprotein(a) levels are increased in healthy young subjects with parental history of premature myocardial infarction. Nutr Metab Cardiovasc Dis. Sep. 2008;18(7):492-6. X-1,X-2,X-5,X-6,X-7. [pmid: 17962002].
988 Gage BF, van Walraven C, Pearce L, et al. Selecting patients with atrial fibrillation for anticoagulation: stroke risk stratification in patients taking aspirin. Circulation. Oct. 19. 2004;110(16):2287-92. X-1,X-4,X-5,X-8. [pmid: 15477396].
989 Gage BF, Waterman AD, Shannon W, et al. Validation of clinical classification schemes for predicting stroke: results from the National Registry of Atrial Fibrillation. JAMA. Jun. 13. 2001;285(22):2864-70. X-2. [pmid: 11401607].
990 Galassi AR, Azzarelli S, Tomaselli A, et al. Incremental prognostic value of technetium-99m-tetrofosmin exercise myocardial perfusion imaging for predicting outcomes in patients with suspected or known coronary artery disease. Am J Cardiol. Jul. 15. 2001;88(2):101-6. X-1D,X-1F,X-2,X-8. [pmid: 11448403].
991 Gale CP, Manda SO, Batin PD, et al. Predictors of in-hospital mortality for patients admitted with ST-elevation myocardial infarction: a real-world study using the Myocardial Infarction National Audit Project (MINAP) database. Heart. Nov. 2008;94(11):1407-12. X-1,X-8. [pmid: 18070941].
992 Gale CR, Ashurst HE, Hall NF, et al. Size at birth and carotid atherosclerosis in later life. Atherosclerosis. Jul. 2002;163(1):141-7. X-1,X-2,X-8. [pmid: 12048132].
993 Galvani M, Ferrini D, Ottani F. Natriuretic peptides for risk stratification of patients with acute coronary syndromes. Eur J Heart Fail. Mar. 15. 2004;6(3):327-33. X-1,X-2,X-8. [pmid: 14987584].
994 Galvani M, Ottani F, Oltrona L, et al. N-terminal pro-brain natriuretic peptide on admission has prognostic value across the whole spectrum of acute coronary syndromes. Circulation. Jul. 13. 2004;110(2):128-34. X-1,X-8. [pmid: 15197143].
995 Game FL, Bartlett WA, Bayly GR, et al. Comparative accuracy of cardiovascular risk prediction methods in patients with diabetes mellitus. Diabetes Obes Metab. Aug. 2001;3(4):279-86. X-5,X-6. [pmid: 11520308].
996 Gandley RE, Rohland J, Zhou Y, et al. Increased myeloperoxidase in the placenta and circulation of women with preeclampsia. Hypertension. Aug. 2008;52(2):387-93. X-1,X-2,X-6,X-7. [pmid: 18591459].
997 Gang Y, Hnatkova K, Mandal K, et al. Preoperative electrocardiographic risk assessment of atrial fibrillation after coronary artery bypass grafting. J Cardiovasc Electrophysiol. Dec. 2004;15(12):1379-86. X-1,X-6,X-7,X-8. [pmid: 15610283].
998 Ganotakis ES, Vrentzos GE, Gazi IF, et al. Fibrinogen, lipoprotein (a), albumin and bilirubin (F-L-A-B) levels and cardiovascular risk calculated using the Framingham equation. In Vivo. Jul-Aug. 2007;21(4):685-94. X-2,X-5,X-6. [pmid: 17708367].
999 Gao SA, Johansson M, Hammaren A, et al. Reproducibility of methods for assessing baroreflex sensitivity and temporal QT variability in end-stage renal disease and healthy subjects. Clin Auton Res. Feb. 2005;15(1):21-8. X-1,X-2,X-5,X-6,X-7. [pmid: 15768198].
1000 Garcia JA, Romano PS, Chan BK, et al. Sociodemographic factors and the assignment of do-not-resuscitate orders in patients with acute myocardial infarctions. Med Care. Jun. 2000;38(6):670-8. X-1,X-2,X-5,X-6,X-8. [pmid: 10843314].
1001 Garcia S, Canoniero MJ, Chirinos JA, et al. Development of a score to predict the need for coronary artery bypass graft surgery in patients with non-ST segment elevation acute coronary syndromes. Ann Thorac Surg. Dec. 2004;78(6):2022-6. discussion 2026-7. X-1,X-6,X-8. [pmid: 15561024].
1002 Garcia-Pinilla JM, Espinosa-Caliani S, Jimenez-Navarro M, et al. Influence of 677 C-->T polymorphism of methylenetetrahydrofolate reductase on medium-term prognosis after acute coronary syndromes. Tex Heart Inst J. 2007;34(2):142-7. X-1,X-5,X-6,X-7. [pmid: 17622358].
1003 Gardemann A, Weidemann H, Philipp M, et al. The TT genotype of the methylenetetrahydrofolate reductase C677T gene polymorphism is associated with the extent of coronary atherosclerosis in patients at high risk for coronary artery disease. Eur Heart J. Apr. 1999;20(8):584-92. X-1,X-5,X-6. [pmid: 10337543].
1004 Garg AX, Prasad GV, Thiessen-Philbrook HR, et al. Cardiovascular disease and hypertension risk in living kidney donors: an analysis of health administrative data in Ontario, Canada. Transplantation. Aug. 15. 2008;86(3):399-406. X-2. [pmid: 18698242].
1005 Gasowski J, Li Y, Kuznetsova T, et al. Is “usual” blood pressure a proxy for 24-h ambulatory blood pressure in predicting cardiovascular outcomes?. Am J Hypertens. Sep. 2008;21(9):994-1000. X-1,X-2. [pmid: 18600212].
1006 Gasse C, Jacobsen J, Larsen AC, et al. Secondary medical prevention among Danish patients hospitalised with either peripheral arterial disease or myocardial infarction. Eur J Vasc Endovasc Surg. Jan. 2008;35(1):51-8. X-1,X-2,X-6. [pmid: 17923426].
1007 Gauss A, Rohm HJ, Schauffelen A, et al. Electrocardiographic exercise stress testing for cardiac risk assessment in patients undergoing noncardiac surgery. Anesthesiology. Jan. 2001;94(1):38-46. X-1. [pmid: 11135720].
1008 Gaw A, Packard CJ. At what level of coronary heart disease risk should a statin be prescribed?. Curr Opin Lipidol. Aug. 2000;11(4):363-7. X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 10945717].
1009 Gay J, Bergeron P. Can carotid stenting registries help in determining predictors of neurological outcome?. J Cardiovasc Surg (Torino). Apr. 2006;47(2):143-51. X-1,X-8.
1010 Gaynor SL, Schuessler RB, Bailey MS, et al. Surgical treatment of atrial fibrillation: predictors of late recurrence. J Thorac Cardiovasc Surg. Jan. 2005;129(1):104-11. X-1,X-2,X-8. [pmid: 15632831].
1011 Gaze DC. The role of existing and novel cardiac biomarkers for cardioprotection. Curr Opin Investig Drugs. Sep. 2007;8(9):711-7. X-1C,X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9.
1012 Geest TA, Engberg M, Lauritzen T. Discordance between self-evaluated health and doctor-evaluated health in relation to general health promotion. Scand J Prim Health Care. Sep. 2004;22(3):146-51. X-1,X-2,X-5,X-6. [pmid: 15370790].
1013 Gehi AK, Ali S, Na B, et al. Inducible ischemia and the risk of recurrent cardiovascular events in outpatients with stable coronary heart disease: the heart and soul study. Arch Intern Med. Jul. 14. 2008;168(13):1423-8. X-1,X-2,X-8. [pmid: 18625923].
1014 Geiger AM, Fischberg GM, Chen W, et al. Stroke risk and tamoxifen therapy for breast cancer. J Natl Cancer Inst. Oct. 20. 2004;96(20):1528-36. X-1,X-5,X-8. [pmid: 15494603].
1015 Geisler T, Schaeffeler E, Dippon J, et al. CYP2C19 and nongenetic factors predict poor responsiveness to clopidogrel loading dose after coronary stent implantation. Pharmacogenomics. Sep. 2008;9(9):1251-9. X-1,X-2,X-6,X-8. [pmid: 18781853].
1016 Geissler HJ, Holzl P, Marohl S, et al. Risk stratification in heart surgery: comparison of six score systems. Eur J Cardiothorac Surg. Apr. 2000;17(4):400-6. X-1,X-8. [pmid: 10773562].
1017 Gelber RP, Gaziano JM, Orav EJ, et al. Measures of obesity and cardiovascular risk among men and women. J Am Coll Cardiol. Aug. 19. 2008;52(8):605-15. X-1F,X-2. [pmid: 18702962].
1018 Gelsomino S, Lorusso R, Capecchi I, et al. Left ventricular reverse remodeling after undersized mitral ring annuloplasty in patients with ischemic regurgitation. Ann Thorac Surg. Apr. 2008;85(4):1319-30. X-1,X-2,X-6,X-8. [pmid: 18355519].
1019 Geluk CA, Dikkers R, Kors JA, et al. Measurement of coronary calcium scores or exercise testing as initial screening tool in asymptomatic subjects with ST-T changes on the resting ECG: an evaluation study. BMC Cardiovasc Disord. 2007;7:19. X-7. [pmid: 17629903].
1020 Georgiou D, Budoff MJ, Kaufer E, et al. Screening patients with chest pain in the emergency department using electron beam tomography: a follow-up study. J Am Coll Cardiol. Jul. 2001;38(1):105-10. X-7. [pmid: 11451257].
1021 Gerber A, Evers T, Haverkamp H, et al. Cost-benefit analysis of a plant sterol containing low-fat margarine for cholesterol reduction. Eur J Health Econ. Dec. 2006;7(4):247-54. X-1. [pmid: 16821072].
1022 Gerber Y, Goldbourt U, Drory Y. Interaction between income and education in predicting long-term survival after acute myocardial infarction. Eur J Cardiovasc Prev Rehabil. Oct. 2008;15(5):526-32. X-1,X-2,X-8. [pmid: 18622301].
1023 Gerber Y, McConnell JP, Jaffe AS, et al. Lipoprotein-associated phospholipase A2 and prognosis after myocardial infarction in the community. Arterioscler Thromb Vasc Biol. Nov. 2006;26(11):2517-22. X-1,X-6,X-8. [pmid: 16902161].
1024 Gerdtham UG, Johannesson M. A note on the effect of unemployment on mortality. J Health Econ. May. 2003;22(3):505-18. X-1,X-5,X-6. [pmid: 12683964].
1025 Gerdts E, Wachtell K, Omvik P, et al. Left atrial size and risk of major cardiovascular events during antihypertensive treatment: losartan intervention for endpoint reduction in hypertension trial. Hypertension. Feb. 2007;49(2):311-6. X-1,X-2,X-6,X-8(15%). [pmid: 17178978].
1026 Gersh BJ. Optimal management of acute myocardial infarction at the dawn of the next millennium. Am Heart J. Aug. 1999;138(2 Pt 2):S188-202. X-1,X-4,X-5,X-6. [pmid: 10426881].
1027 Gerward S, Tyden P, Hansen O, et al. Survival rate 28 days after hospital admission with first myocardial infarction. Inverse relationship with socio-economic circumstances. J Intern Med. Feb. 2006;259(2):164-72. X-1,X-6,X-8. [pmid: 16420545].
1028 Ghaffari S, Samadikhah J. Predictive value of thrombolysis in myocardial infarction risk score analysis for in-hospital and long term survival of patients with right ventricular infarction. Saudi Med J. Apr. 2006;27(4):553-5. X-1,X-8. [pmid: 16598340].
1029 Ghali WA, Quan H, Brant R. Risk adjustment using administrative data: impact of a diagnosis-type indicator. J Gen Intern Med. Aug. 2001;16(8):519-24. X-1,X-2,X-6,X-8. [pmid: 11556927].
1030 Ghanbarian A, Rashidi A, Madjid M, et al. Blood pressure measures and electrocardiogram-defined myocardial infarction in an Iranian population: Tehran Lipid and Glucose study. J Clin Hypertens (Greenwich). Feb. 2004;6(2):71-5. X-1,X-5,X-6,X-8. [pmid: 14872144].
1031 Ghuran A, Reid F, La Rovere MT, et al. Heart rate turbulence-based predictors of fatal and nonfatal cardiac arrest (The Autonomic Tone and Reflexes After Myocardial Infarction substudy). Am J Cardiol. Jan. 15. 2002;89(2):184-90. X-1,X-8. [pmid: 11792340].
1032 Giannitsis E, Kurz K, Katus HA. Multimarker strategy in acute coronary syndrome--pro-multimarker. Acute Card Care. 2007;9(1):6-9. X-1. [pmid: 17453533].
1033 Giannitsis E, Muller-Bardorff M, Kurowski V, et al. Independent prognostic value of cardiac troponin T in patients with confirmed pulmonary embolism. Circulation. Jul. 11. 2000;102(2):211-7. X-1,X-2,X-6,X-7,X-8. [pmid: 10889133].
1034 Giannuzzi P. Trends in cardiovascular rehabilitation. Monaldi Arch Chest Dis. Mar. 2006;66(1):44-7. X-5. [pmid: 17125044].
1035 Giavarina D, Barzon E, Cigolini M, et al. Comparison of methods to identify individuals at increased risk of cardiovascular disease in Italian cohorts. Nutr Metab Cardiovasc Dis. May. 2007;17(4):311-8. X-5,X-6. [pmid: 17434054].
1036 Gibbons RJ. Abnormal heart-rate recovery after exercise. Lancet. May. 4. 2002;359(9317):1536-7. X-1D,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 12047958].
1037 Gibbons RJ, Balady GJ, Bricker JT, et al. ACC/AHA 2002 guideline update for exercise testing: summary article: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Update the 1997 Exercise Testing Guidelines). Circulation. Oct. 1. 2002;106(14):1883-92. X-1,X-4,X-5,X-6,X-7,X-8. [pmid: 12356646].
1038 Gibson CM, Murphy SA, Pride YB, et al. Effects of pretreatment with clopidogrel on nonemergent percutaneous coronary intervention after fibrinolytic administration for ST-segment elevation myocardial infarction: a Clopidogrel as Adjunctive Reperfusion Therapy-Thrombolysis in Myocardial Infarction (CLARITY-TIMI) 28 study. Am Heart J. Jan. 2008;155(1):133-9. X-1,X-8. [pmid: 18082504].
1039 Gibson CM, Pinto DS, Murphy SA, et al. Association of creatinine and creatinine clearance on presentation in acute myocardial infarction with subsequent mortality. J Am Coll Cardiol. Nov. 5. 2003;42(9):1535-43. X-1,X-6,X-8. [pmid: 14607434].
1040 Gidding SS, McMahan CA, McGill HC, et al. Prediction of coronary artery calcium in young adults using the Pathobiological Determinants of Atherosclerosis in Youth (PDAY) risk score: the CARDIA study. Arch Intern Med. Nov. 27. 2006;166(21):2341-7. X-6. [pmid: 17130387].
1041 Gil VM. Coronary calcium does not accurately predict near-term future coronary events in high-risk adults. Rev Port Cardiol. Jun. 1999;18(6):659. X-3. [pmid: 10422465].
1042 Gilbert K, Larocque BJ, Patrick LT. Prospective evaluation of cardiac risk indices for patients undergoing noncardiac surgery. Ann Intern Med. Sep. 5. 2000;133(5):356-9. X-1. [pmid: 10979880].
1043 Giles MF, Flossman E, Rothwell PM. Patient behavior immediately after transient ischemic attack according to clinical characteristics, perception of the event, and predicted risk of stroke. Stroke. May. 2006;37(5):1254-60. X-1,X-2,X-5,X-6,X-8. [pmid: 16574923].
1044 Giles MF, Rothwell PM. Prediction and prevention of stroke after transient ischemic attack in the short and long term. Expert Rev Neurother. Mar. 2006;6(3):381-95. X-1,X-4,X-5,X-6,X-7,X-8. [pmid: 16533142].
1045 Giles MF, Rothwell PM. Risk prediction after TIA: the ABCD system and other methods. Geriatrics. Oct. 2008;63(10):10-3. 16. X-1,X-2,X-4,X-5,X-6,X-7,X-8.
1046 Gillett M, Davis WA, Jackson D, et al. Prospective evaluation of carotid bruit as a predictor of first stroke in type 2 diabetes: the Fremantle Diabetes Study. Stroke. Sep. 2003;34(9):2145-51. X-1,X-2. [pmid: 12907819].
1047 Gilligan AK, Markus R, Read S, et al. Baseline blood pressure but not early computed tomography changes predicts major hemorrhage after streptokinase in acute ischemic stroke. Stroke. Sep. 2002;33(9):2236-42. X-1,X-5,X-8. [pmid: 12215593].
1048 Gimelli A, L'Abbate A, Glauber M, et al. Cardiac imaging improves risk stratification in high-risk patients undergoing surgical revascularization. J Cardiovasc Med (Hagerstown). Jan. 2006;7(1):51-6. X-1,X-8. [pmid: 16645360].
1049 Giomarelli P, Scolletta S, Borrelli E, et al. Myocardial and lung injury after cardiopulmonary bypass: role of interleukin (IL)-10. Ann Thorac Surg. Jul. 2003;76(1):117-23. X-1,X-6,X-7,X-8. [pmid: 12842524].
1050 Giorda CB, Avogaro A, Maggini M, et al. Recurrence of cardiovascular events in patients with type 2 diabetes: epidemiology and risk factors. Diabetes Care. Nov. 2008;31(11):2154-9. X-1,X-2,X-8. [pmid: 18782902].
1051 Giordano SH, Kuo YF, Freeman JL, et al. Risk of cardiac death after adjuvant radiotherapy for breast cancer. J Natl Cancer Inst. Mar. 16. 2005;97(6):419-24. X-1C,X-1F,X-2,X-8. [pmid: 15770005].
1052 Giorgetti A, Rossi M, Stanislao M, et al. Feasibility and diagnostic accuracy of a gated SPECT early-imaging protocol: a multicenter study of the Myoview Imaging Optimization Group. J Nucl Med. Oct. 2007;48(10):1670-5. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 17873126].
1053 Giral P, Bruckert E, Dairou F, et al. Usefulness in predicting coronary artery disease by ultrasonic evaluation of the carotid arteries in asymptomatic hypercholesterolemic patients with positive exercise stress tests. Am J Cardiol. Jul. 1. 1999;84(1):14-7. X-1,X-5,X-6,X-7. [pmid: 10404844].
1054 Giral P, Jacob N, Dourmap C, et al. Elevated gamma-glutamyltransferase activity and perturbed thiol profile are associated with features of metabolic syndrome. Arterioscler Thromb Vasc Biol. Mar. 2008;28(3):587-93. X-1,X-2,X-5,X-6. [pmid: 18202323].
1055 Girish M, Trayner E Jr, Dammann O, et al. Symptom-limited stair climbing as a predictor of postoperative cardiopulmonary complications after high-risk surgery. Chest. Oct. 2001;120(4):1147-51. X-1,X-2,X-7. [pmid: 11591552].
1056 Girkin CA, Kannel WB, Friedman DS, et al. Glaucoma risk factor assessment and prevention: lessons from coronary heart disease. Am J Ophthalmol. Sep. 2004;138(3 Suppl):S11-8. X-1,X-2,X-4,X-5,X-6. [pmid: 15364048].
1057 Gitt AK, Wasserman K, Kilkowski C, et al. Exercise anaerobic threshold and ventilatory efficiency identify heart failure patients for high risk of early death. Circulation. Dec. 10. 2002;106(24):3079-84. X-1. [pmid: 12473555].
1058 Gjertsson P, Caidahl K, Oden A, et al. Diagnostic and referral delay in patients with aortic stenosis is common and negatively affects outcome. Scand Cardiovasc J. Jan. 2007;41(1):12-8. X-1,X-6. [pmid: 17365972].
1059 Glance LG, Dick A, Mukamel DB, et al. Are high-quality cardiac surgeons less likely to operate on high-risk patients compared to low-quality surgeons? Evidence from New York State. Health Serv Res. Feb. 2008;43(1 Pt 1):300-12. X-1,X-2,X-5,X-6,X-8. [pmid: 18211531].
1060 Glance LG, Osler TM. Comparing outcomes of coronary artery bypass surgery: Is the New York Cardiac Surgery Reporting System model sensitive to changes in case mix?. Crit Care Med. Nov. 2001;29(11):2090-6. X-1,X-2,X-5,X-6,X-8. [pmid: 11700401].
1061 Glance LG, Osler TM, Mukamel DB, et al. Effect of complications on mortality after coronary artery bypass grafting surgery: evidence from New York State. J Thorac Cardiovasc Surg. Jul. 2007;134(1):53-8. X-1,X-8. [pmid: 17599486].
1062 Glance LG, Osler TM, Mukamel DB, et al. Use of a matching algorithm to evaluate hospital coronary artery bypass grafting performance as an alternative to conventional risk adjustment. Med Care. Apr. 2007;45(4):292-9. X-1,X-5,X-6. [pmid: 17496712].
1063 Glaser R, Herrmann HC, Murphy SA, et al. Benefit of an early invasive management strategy in women with acute coronary syndromes. JAMA. Dec. 25. 2002;288(24):3124-9. X-1,X-2,X-8. [pmid: 12495392].
1064 Glickman ME, Kao MF. Apo-E genotypes and cardiovascular diseases: a sensitivity study using cross-validatory criteria. Biom J. Aug. 2005;47(4):541-53. X-1G,X-2. [pmid: 16161810].
1065 Glineur D, D'Hoore W, El Khoury G, et al. Angiographic predictors of 6-month patency of bypass grafts implanted to the right coronary artery a prospective randomized comparison of gastroepiploic artery and saphenous vein grafts. J Am Coll Cardiol. Jan. 15. 2008;51(2):120-5. X-1,X-2,X-6,X-7,X-8. [pmid: 18191734].
1066 Glower DD, Tuttle RH, Shaw LK, et al. Patient survival characteristics after routine mitral valve repair for ischemic mitral regurgitation. J Thorac Cardiovasc Surg. Apr. 2005;129(4):860-8. X-1,X-5. [pmid: 15821655].
1067 Glueck CJ, Wang P, Fontaine RN, et al. Estrogen replacement therapy, thrombophilia, and atherothrombosis. Metabolism. Jun. 2002;51(6):724-32. X-1,X-2,X-5,X-8. [pmid: 12037725].
1068 Glynn RJ, Chae CU, Guralnik JM, et al. Pulse pressure and mortality in older people. Arch Intern Med. Oct. 9. 2000;160(18):2765-72. X-1. [pmid: 11025786].
1069 Glynn RJ, L'Italien GJ, Sesso HD, et al. Development of predictive models for long-term cardiovascular risk associated with systolic and diastolic blood pressure. Hypertension. Jan. 2002;39(1):105-10. X-4,X-5. [pmid: 11799087].
1070 Glynn RJ, Rosner B. Methods to evaluate risks for composite end points and their individual components. J Clin Epidemiol. Feb. 2004;57(2):113-22. X-1,X-2,X-5,X-6,X-7. [pmid: 15125620].
1071 Gnasso A, Motti C, Irace C, et al. The Arg allele in position 192 of PON1 is associated with carotid atherosclerosis in subjects with elevated HDLs. Atherosclerosis. Oct. 2002;164(2):289-95. X-2,X-8. [pmid: 12204800].
1072 Godet G, Riou B, Bertrand M, et al. Does preoperative coronary angioplasty improve perioperative cardiac outcome?. Anesthesiology. Apr. 2005;102(4):739-46. X-1,X-5,X-8. [pmid: 15791102].
1073 Gold MR, Ip JH, Costantini O, et al. Role of microvolt T-wave alternans in assessment of arrhythmia vulnerability among patients with heart failure and systolic dysfunction: primary results from the T-wave alternans sudden cardiac death in heart failure trial substudy. Circulation. Nov. 11. 2008;118(20):2022-8. X-1,X-2,X-8. [pmid: 18955671].
1074 Goldberg A, Hammerman H, Petcherski S, et al. Prognostic importance of hyponatremia in acute ST-elevation myocardial infarction. Am J Med. Aug. 15. 2004;117(4):242-8. X-1,X-6,X-8. [pmid: 15308433].
1075 Goldberg A, Hammerman H, Petcherski S, et al. Inhospital and 1-year mortality of patients who develop worsening renal function following acute ST-elevation myocardial infarction. Am Heart J. Aug. 2005;150(2):330-7. X-1,X-8. [pmid: 16086939].
1076 Goldberg Arnold RJ, Akhras KS, Chen C, et al. Review of the development, validation, and application of predictive instruments in interventional cardiology. Heart Dis. Jul-Aug. 1999;1(3):138-48. X-1,X-2,X-4,X-5,X-8. [pmid: 11720617].
1077 Goldbourt U, Tanne D. Body height is associated with decreased long-term stroke but not coronary heart disease mortality?. Stroke. Mar. 2002;33(3):743-8. X-1. [pmid: 11872898].
1078 Goldenberg I, Jonas M, Tenenbaum A, et al. Current smoking, smoking cessation, and the risk of sudden cardiac death in patients with coronary artery disease. Arch Intern Med. Oct. 27. 2003;163(19):2301-5. X-1,X-6,X-8. [pmid: 14581249].
1079 Goldenberg I, Vyas AK, Hall WJ, et al. Risk stratification for primary implantation of a cardioverter-defibrillator in patients with ischemic left ventricular dysfunction. J Am Coll Cardiol. Jan. 22. 2008;51(3):288-96. X-1,X-6,X-8. [pmid: 18206738].
1080 Gonbert S, Malinsky S, Sposito AC, et al. Atorvastatin lowers lipoprotein(a) but not apolipoprotein(a) fragment levels in hypercholesterolemic subjects at high cardiovascular risk. Atherosclerosis. Oct. 2002;164(2):305-11. X-1,X-2,X-6,X-8. [pmid: 12204802].
1081 Gonzalez NR, Boscardin WJ, Glenn T, et al. Vasospasm probability index: a combination of transcranial doppler velocities, cerebral blood flow, and clinical risk factors to predict cerebral vasospasm after aneurysmal subarachnoid hemorrhage. J Neurosurg. Dec. 2007;107(6):1101-12. X-1,X-6. [pmid: 18077946].
1082 Goodney PP, Likosky DS, Cronenwett JL. Factors associated with stroke or death after carotid endarterectomy in Northern New England. J Vasc Surg. Nov. 2008;48(5):1139-45. X-1,X-8. [pmid: 18586446].
1083 Gopal A, Budoff MJ. Coronary calcium scanning. Am Heart Hosp J. Winter. 2006;4(1):43-50. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16470104].
1084 Gorelick PB. Lipoprotein-associated phospholipase A2 and risk of stroke. Am J Cardiol. Jun. 16. 2008;101(12A):34F-40F. X-1,X-2.
1085 Gormley K, Bevan S, Markus HS. Polymorphisms in genes of the renin-angiotensin system and cerebral small vessel disease. Cerebrovasc Dis. 2007;23(2-3):148-55. X-1,X-2,X-8. [pmid: 17124396].
1086 Gorter PM, Olijhoek JK, van der Graaf Y, et al. Prevalence of the metabolic syndrome in patients with coronary heart disease, cerebrovascular disease, peripheral arterial disease or abdominal aortic aneurysm. Atherosclerosis. Apr. 2004;173(2):363-9. X-1,X-2,X-5,X-6,X-8. [pmid: 15064114].
1087 Gossl M, Modder UI, Atkinson EJ, et al. Osteocalcin expression by circulating endothelial progenitor cells in patients with coronary atherosclerosis. J Am Coll Cardiol. Oct. 14. 2008;52(16):1314-25. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18929243].
1088 Gotoh F, Terayama Y, Amano T. Development of a novel, weighted, quantifiable stroke scale: Japan stroke scale. Stroke. Aug. 2001;32(8):1800-7. X-1,X-5,X-6,X-7,X-8. [pmid: 11486108].
1089 Gottlieb I, Lima JA. Screening high-risk patients with computed tomography angiography. Circulation. Mar. 11. 2008;117(10):1318-32. discussion 1332. X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 18332277].
1090 Grabowski M, Filipiak KJ, Malek LA, et al. Admission B-type natriuretic peptide assessment improves early risk stratification by Killip classes and TIMI risk score in patients with acute ST elevation myocardial infarction treated with primary angioplasty. Int J Cardiol. Feb. 14. 2007;115(3):386-90. X-1,X-8. [pmid: 16860415].
1091 Gracey M, Burke V, Martin DD, et al. Assessment of risks of “lifestyle” diseases including cardiovascular disease and type 2 diabetes by anthropometry in remote Australian Aborigines. Asia Pac J Clin Nutr. 2007;16(4):688-97. X-1C,X-1G,X-5,X-6. [pmid: 18042530].
1092 Grady D, Cauley JA, Geiger MJ, et al. Reduced incidence of invasive breast cancer with raloxifene among women at increased coronary risk. J Natl Cancer Inst. Jun. 18. 2008;100(12):854-61. X-1,X-6. [pmid: 18544744].
1093 Graham MM, Ghali WA, Faris PD, et al. Survival after coronary revascularization in the elderly. Circulation. May. 21. 2002;105(20):2378-84. X-1,X-8. [pmid: 12021224].
1094 Graham MM, Ghali WA, Faris PD, et al. Population rates of cardiac catheterization and yield of high-risk coronary artery disease. CMAJ. Jul. 5. 2005;173(1):35-9. X-1C,X-1F,X-2,X-5,X-6,X-8. [pmid: 15997042].
1095 Gramling R, Klein W, Roberts M, et al. Self-rated cardiovascular risk and 15-year cardiovascular mortality. Ann Fam Med. Jul-Aug. 2008;6(4):302-6. X-1F,X-2. [pmid: 18626029].
1096 Gravning J, Ueland T, Morkrid L, et al. Different prognostic importance of elevated troponin I after percutaneous coronary intervention in acute coronary syndrome and stable angina pectoris. Scand Cardiovasc J. Jun. 2008;42(3):214-21. X-1,X-2,X-8. [pmid: 18569954].
1097 Gray WA, Yadav JS, Verta P, et al. The CAPTURE registry: predictors of outcomes in carotid artery stenting with embolic protection for high surgical risk patients in the early post-approval setting. Catheter Cardiovasc Interv. Dec. 1. 2007;70(7):1025-33. X-1,X-8. [pmid: 18044758].
1098 Grayson AD, Moore RK, Jackson M, et al. Multivariate prediction of major adverse cardiac events after 9914 percutaneous coronary interventions in the north west of England. Heart. May. 2006;92(5):658-63. X-1,X-8. [pmid: 16159983].
1099 Grazuleviciene R, Dulskiene V. Risk factors for heart failure in survivors after first myocardial infarction. Medicina (Kaunas). 2006;42(10):810-6. X-1,X-2,X-6,X-8. [pmid: 17090980].
1100 Green M, Bjork J, Forberg J, et al. Comparison between neural networks and multiple logistic regression to predict acute coronary syndrome in the emergency room. Artif Intell Med. Nov. 2006;38(3):305-18. X-1,X-5,X-6,X-8. [pmid: 16962295].
1101 Greenberg JA. Removing confounders from the relationship between mortality risk and systolic blood pressure at low and moderately increased systolic blood pressure. J Hypertens. Jan. 2003;21(1):49-56. X-1F,X-2,X-8. [pmid: 12544435].
1102 Greenland P, Smith SC Jr, Grundy SM. Improving coronary heart disease risk assessment in asymptomatic people: role of traditional risk factors and noninvasive cardiovascular tests. Circulation. Oct. 9. 2001;104(15):1863-7. X-1F,X-1G,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 11591627].
1103 Greenson N, Macoviak J, Krishnaswamy P, et al. Usefulness of cardiac troponin I in patients undergoing open heart surgery. Am Heart J. Mar. 2001;141(3):447-55. X-1,X-2,X-7,X-8. [pmid: 11231444].
1104 Greenstein AJ, Chassin MR, Wang J, et al. Association between minor and major surgical complications after carotid endarterectomy: results of the New York Carotid Artery Surgery study. J Vasc Surg. Dec. 2007;46(6):1138-44. discussion 1145-6. X-1,X-2,X-8. [pmid: 18154989].
1105 Gregori D, Rosato R, Zecchin M, et al. Heart failure and sudden death in dilated cardiomyopathy: a hidden competition we should not forget about when modelling mortality. J Eval Clin Pract. Feb. 2008;14(1):53-8. X-1,X-2,X-5,X-7,X-8. [pmid: 18211644].
1106 Greil GF, Stuber M, Botnar RM, et al. Coronary magnetic resonance angiography in adolescents and young adults with kawasaki disease. Circulation. Feb. 26. 2002;105(8):908-11. X-1,X-2,X-6,X-7,X-8. [pmid: 11864916].
1107 Grewal J, Anand S, Islam S, et al. Prevalence and predictors of subclinical atherosclerosis among asymptomatic “low risk” individuals in a multiethnic population. Atherosclerosis. Mar. 2008;197(1):435-42. X-2,X-5. [pmid: 17675040].
1108 Grieve R, Hutton J, Green C. Selecting methods for the prediction of future events in cost-effectiveness models: a decision-framework and example from the cardiovascular field. Health Policy. Jun. 2003;64(3):311-24. X-1,X-4,X-5,X-6. [pmid: 12745170].
1109 Griffin M, Nicolaides AN, Belcaro G, et al. Cardiovascular risk assessment using ultrasound: the value of arterial wall changes including the presence, severity and character of plaques. Pathophysiol Haemost Thromb. Sep-Dec. 2002;32(5-6):367-70. X-1,X-2,X-5,X-8. [pmid: 13679678].
1110 Grimes DA, Lobo RA. Perspectives on the Women's Health Initiative trial of hormone replacement therapy. Obstet Gynecol. Dec. 2002;100(6):1344-53. X-1,X-2,X-4,X-5,X-6. [pmid: 12468183].
1111 Grimm W, Glaveris C, Hoffmann J, et al. Arrhythmia risk stratification in idiopathic dilated cardiomyopathy based on echocardiography and 12-lead, signal-averaged, and 24-hour holter electrocardiography. Am Heart J. Jul. 2000;140(1):43-51. X-1,X-2,X-6,X-8. [pmid: 10874262].
1112 Grimm W, Hoffmann J, Menz V, et al. Prediction of major arrhythmic events and sudden cardiac death in dilated cardiomyopathy. The Marburg Cardiomyopathy Study design and description of baseline clinical characteristics. Herz. May. 2000;25(3):189-99. X-1,X-8. [pmid: 10904838].
1113 Grimm W, Liedtke J, Muller HH. Prevalence of potential noninvasive arrhythmia risk predictors in healthy, middle-aged persons. Ann Noninvasive Electrocardiol. Jan. 2003;8(1):37-46. X-1,X-2,X-6,X-7. [pmid: 12848812].
1114 Grodstein F, Stampfer MJ, Falkeborn M, et al. Postmenopausal hormone therapy and risk of cardiovascular disease and hip fracture in a cohort of Swedish women. Epidemiology. Sep. 1999;10(5):476-80. X-1. [pmid: 10468418].
1115 Gromova HA, Gafarov VV, Gagulin IV. Depression and risk of cardiovascular diseases among males aged 25-64 (WHO MONICA--psychosocial). Alaska Med. 2007;49(2 Suppl):255-8. X-1E,X-1F,X-2. [pmid: 17929644].
1116 Gronholdt ML, Nordestgaard BG, Schroeder TV, et al. Ultrasonic echolucent carotid plaques predict future strokes. Circulation. Jul. 3. 2001;104(1):68-73. X-2,X-7,X-8. [pmid: 11435340].
1117 Groschel K, Ernemann U, Schnaudigel S, et al. A risk score to predict ischemic lesions after protected carotid artery stenting. J Neurol Sci. Oct. 15. 2008;273(1-2):112-5. X-1,X-2,X-6,X-7,X-8. [pmid: 18692206].
1118 Grossi E. How artificial intelligence tools can be used to assess individual patient risk in cardiovascular disease: problems with the current methods. BMC Cardiovasc Disord. 2006;6:20. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16672045].
1119 Grossman SA, Fischer C, Lipsitz LA, et al. Predicting adverse outcomes in syncope. J Emerg Med. Oct. 2007;33(3):233-9. X-1F,X-1G,X-2. [pmid: 17976548].
1120 Grover FL, Shroyer AL, Hammermeister K, et al. A decade's experience with quality improvement in cardiac surgery using the Veterans Affairs and Society of Thoracic Surgeons national databases. Ann Surg. Oct. 2001;234(4):464-72. discussion 472-4. X-1,X-2,X-5,X-6,X-8. [pmid: 11573040].
1121 Grover SA, Hemmelgarn B, Joseph L, et al. The role of global risk assessment in hypertension therapy. Can J Cardiol. May. 15. 2006;22(7):606-13. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16755316].
1122 Grubbs V, Bibbins-Domingo K, Fernandez A, et al. Acute myocardial infarction length of stay and hospital mortality are not associated with language p. J Gen Intern Med. Feb. 2008;23(2):190-4. X-1,X-2,X-5,X-6,X-8. [pmid: 18043984].
1123 Grunau GL, Sheps S, Goldner EM, et al. Specific comorbidity risk adjustment was a better predictor of 5-year acute myocardial infarction mortality than general methods. J Clin Epidemiol. Mar. 2006;59(3):274-80. X-1,X-8. [pmid: 16488358].
1124 Grzybowski M, Zalenski RJ, Ross MA, et al. A prediction model for prehospital triage of patients with suspected cardiac ischemia. J Electrocardiol. 2000;33(Suppl):253-8. X-1,X-5,X-8.
1125 Gu Q, Burt VL, Paulose-Ram R, et al. High blood pressure and cardiovascular disease mortality risk among U.S. adults: the third National Health and Nutrition Examination Survey mortality follow-up study. Ann Epidemiol. Apr. 2008;18(4):302-9. X-1E,X-2,X-6,X-8(2.4-20.4%). [pmid: 18261929].
1126 Guckelberger O, Byram A, Klupp J, et al. Coronary event rates in liver transplant recipients reflect the increased prevalence of cardiovascular risk-factors. Transpl Int. Aug. 2005;18(8):967-74. X-1. [pmid: 16008748].
1127 Guckelberger O, Mutzke F, Glanemann M, et al. Validation of cardiovascular risk scores in a liver transplant population. Liver Transpl. Mar. 2006;12(3):394-401. X-2. [pmid: 16498651].
1128 Gudmundsson LS, Johannsson M, Thorgeirsson G, et al. Risk profiles and prognosis of treated and untreated hypertensive men and women in a population-based longitudinal study: the Reykjavik Study. J Hum Hypertens. Sep. 2004;18(9):615-22. X-1,X-2. [pmid: 15071487].
1129 Gueret P, Khalife K, Jobic Y, et al. Echocardiographic assessment of the incidence of mechanical complications during the early phase of myocardial infarction in the reperfusion era: a French multicentre prospective registry. Arch Cardiovasc Dis. Jan. 2008;101(1):41-7. X-1,X-2,X-8. [pmid: 18391872].
1130 Gueyffier F, Boissel JP, Pocock S, et al. Identification of risk factors in hypertensive patients: contribution of randomized controlled trials through an individual patient database. Circulation. Nov. 2. 1999;100(18):e88-94. X-1F,X-2. [pmid: 10545441].
1131 Gugl A, Renner W, Seinost G, et al. Two polymorphisms in the fracalkine receptor CX3CR1 are not associated with peripheral arterial disease. Atherosclerosis. Feb. 2003;166(2):339-43. X-1,X-2,X-6. [pmid: 12535747].
1132 Gula LJ, Klein GJ, Hellkamp AS, et al. Ejection fraction assessment and survival: an analysis of the Sudden Cardiac Death in Heart Failure Trial (SCD-HeFT). Am Heart J. Dec. 2008;156(6):1196-200. X-1,X-2,X-8. [pmid: 19033019].
1133 Gulati M, Arnsdorf MF, Shaw LJ, et al. Prognostic value of the duke treadmill score in asymptomatic women. Am J Cardiol. Aug. 1. 2005;96(3):369-75. X-1. [pmid: 16054460].
1134 Gulati M, Patel S, Jaffe AS, et al. Impact of contemporary guideline compliance on risk stratification models for acute coronary syndromes in The Registry of Acute Coronary Syndromes. Am J Cardiol. Oct. 1. 2004;94(7):873-8. X-1,X-2,X-8. [pmid: 15464668].
1135 Gunarathne A, Patel JV, Hughes EA, et al. Measurement of stiffness index by digital volume pulse analysis technique: clinical utility in cardiovascular disease risk stratification. Am J Hypertens. Aug. 2008;21(8):866-72. X-1,X-5,X-6. [pmid: 18551104].
1136 Gunnarsson G, Eriksson P, Dellborg M. ECG criteria in diagnosis of acute myocardial infarction in the presence of left bundle branch block. Int J Cardiol. Apr. 2001;78(2):167-74. X-1,X-6,X-7,X-8. [pmid: 11334661].
1137 Guo G, Wu RH, Zhang YP, et al. Prediction of hemorrhagic transformation after acute ischemic stroke using hyperintense MCA sign. Conf Proc IEEE Eng Med Biol Soc. 2006;1:1881-4. X-1,X-5,X-6,X-7,X-8. [pmid: 17946485].
1138 Gur AY, Lampl Y, Gross B, et al. A new scale for assessing patients with vertebrobasilar stroke-the Israeli Vertebrobasilar Stroke Scale (IVBSS): inter-rater reliability and concurrent validity. Clin Neurol Neurosurg. May. 2007;109(4):317-22. X-1,X-5,X-6,X-7,X-8. [pmid: 17254701].
1139 Guthrie JR, Taffe JR, Lehert P, et al. Association between hormonal changes at menopause and the risk of a coronary event: a longitudinal study. Menopause. May-Jun. 2004;11(3):315-22. X-2,X-6. [pmid: 15167311].
1140 Guttormsen BN, Stein JH, McBride PE, et al. Rationale for targeted rather than population based screening with C-reactive protein using the National Health and Nutrition Examination Survey (1999 to 2002). Am J Cardiol. Oct. 1. 2007;100(7):1130-3. X-1F,X-2,X-6,X-8. [pmid: 17884376].
1141 Gyenes G, Shrive FM, Graham MM, et al. The prognostic importance of nonsignificant left main coronary artery disease in patients undergoing percutaneous coronary intervention. J Am Coll Cardiol. Jul. 18. 2006;48(2):276-80. X-8. [pmid: 16843175].
1142 Haapanen-Niemi N, Vuori I, Pasanen M. Public health burden of coronary heart disease risk factors among middle-aged and elderly men. Prev Med. Apr. 1999;28(4):343-8. X-1,X-6,X-8. [pmid: 10090863].
1143 Habil E, Faris R, Magid A, et al. Predictive model of coronary heart disease in Egypt (a disease with multiple risk factors). J Egypt Public Health Assoc. 1999;74(3-4):297-312. X-5. [pmid: 17219872].
1144 Hachamovitch R, Berman DS, Kiat H, et al. Value of stress myocardial perfusion single photon emission computed tomography in patients with normal resting electrocardiograms: an evaluation of incremental prognostic value and cost-effectiveness. Circulation. Feb. 19. 2002;105(7):823-9. X-1F,X-2,X-8. [pmid: 11854122].
1145 Hachamovitch R, Hayes S, Friedman JD, et al. Determinants of risk and its temporal variation in patients with normal stress myocardial perfusion scans: what is the warranty period of a normal scan?. J Am Coll Cardiol. Apr. 16. 2003;41(8):1329-40. X-1,X-6,X-7. [pmid: 12706929].
1146 Hachamovitch R, Hayes SW, Friedman JD, et al. A prognostic score for prediction of cardiac mortality risk after adenosine stress myocardial perfusion scintigraphy. J Am Coll Cardiol. Mar. 1. 2005;45(5):722-9. X-1C,X-2,X-8. [pmid: 15734617].
1147 Hacker M, Tausig A, Romuller B, et al. Dobutamine myocardial scintigraphy for the prediction of cardiac events after heart transplantation. Nucl Med Commun. Jul. 2005;26(7):607-12. X-1,X-6,X-7,X-8. [pmid: 15942481].
1148 Hackett ML, Anderson CS. Predictors of depression after stroke: a systematic review of observational studies. Stroke. Oct. 2005;36(10):2296-301. X-1,X-2,X-4,X-5,X-6,X-8. [pmid: 16179565].
1149 Hadaegh F, Esmaillzadeh A, Azizi F. Metabolic risks in individuals with normal body mass index and normal waist circumference. Eur J Cardiovasc Prev Rehabil. Apr. 2007;14(2):200-7. X-1,X-5,X-6. [pmid: 17446797].
1150 Hadley RD, Graber MA. Should we measure CRP levels to assess cardiovascular risk?. JAAPA. Jan. 2003;16(1):17-9. X-1.
1151 Haffner SM. Abdominal adiposity and cardiometabolic risk: do we have all the answers?. Am J Med. Sep. 2007;120(9 Suppl 1):S10-6. discussion S16-7. X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9.
1152 Haghjoo M, Arya A, Sadr-Ameli MA. Value of microvolt T-wave alternans for predicting patients who would benefit from implantable cardioverter-defibrillator therapy. Cardiol Rev. Jul-Aug. 2006;14(4):173-9. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16788329].
1153 Hahn KA, Strickland PA, Hamilton JL, et al. Hyperlipidemia guideline adherence and association with patient gender. J Womens Health (Larchmt). Nov. 2006;15(9):1009-13. X-1,X-2,X-5,X-6. [pmid: 17125419].
1154 Haidari M, Javadi E, Sadeghi B, et al. Evaluation of C-reactive protein, a sensitive marker of inflammation, as a risk factor for stable coronary artery disease. Clin Biochem. Jun. 2001;34(4):309-15. X-1,X-2,X-5,X-8. [pmid: 11440732].
1155 Haidari M, Javadi E, Sanati A, et al. Association of increased ferritin with premature coronary stenosis in men. Clin Chem. Sep. 2001;47(9):1666-72. X-5,X-8. [pmid: 11514401].
1156 Haim M, Tanne D, Boyko V, et al. Soluble intercellular adhesion molecule-1 and long-term risk of acute coronary events in patients with chronic coronary heart disease. Data from the Bezafibrate Infarction Prevention (BIP) Study. J Am Coll Cardiol. Apr. 3. 2002;39(7):1133-8. X-1,X-2,X-5,X-8. [pmid: 11923036].
1157 Hajat C, Dundas R, Stewart JA, et al. Cerebrovascular risk factors and stroke subtypes: differences between ethnic groups. Stroke. Jan. 2001;32(1):37-42. X-2,X-8. [pmid: 11136911].
1158 Hajek P, Macek M, Hladikova M, et al. Pregnancy-associated plasma protein A and proform eosinophilic major basic protein in the detection of different types of coronary artery disease. Physiol Res. 2008;57(1):23-32. X-1,X-2,X-5,X-7,X-8. [pmid: 17223728].
1159 Hajer GR, van der Graaf Y, Olijhoek JK, et al. Low plasma levels of adiponectin are associated with low risk for future cardiovascular events in patients with clinical evident vascular disease. Am Heart J. Oct. 2007;154(4):750 e1-7. X-1D,X-1F,X-2,X-5,X-8(MI, CAD, Stroke, Angina, 100%). [pmid: 17893004].
1160 Hajilooi M, Sanati A, Ahmadieh A, et al. Circulating ICAM-1, VCAM-1, E-selectin, P-selectin, and TNFalphaRII in patients with coronary artery disease. Immunol Invest. Nov. 2003;32(4):245-57. X-1,X-5,X-6,X-7,X-8. [pmid: 14603993].
1161 Hajilooi M, Sanati A, Ahmadieh A, et al. Circulating ICAM-1, VCAM-1, E-selectin, P-selectin, and TNFRII in patients with coronary artery disease. Immunol Invest. Aug. 2004;33(3):263-75. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15495786].
1162 Hak AE, Polderman KH, Westendorp IC, et al. Increased plasma homocysteine after menopause. Atherosclerosis. Mar. 2000;149(1):163-8. X-1,X-2,X-5,X-6,X-7. [pmid: 10704628].
1163 Hakeem A, Bhatti S, Dillie KS, et al. Predictive value of myocardial perfusion single-photon emission computed tomography and the impact of renal function on cardiac death. Circulation. Dec. 9. 2008;118(24):2540-9. X-1,X-2,X-8. [pmid: 19047585].
1164 Halamek J, Kara T, Jurak P, et al. Variability of phase shift between blood pressure and heart rate fluctuations: a marker of short-term circulation control. Circulation. Jul. 22. 2003;108(3):292-7. X-1,X-2,X-6,X-7,X-8. [pmid: 12860920].
1165 Halcox JP, Deanfield JE. Endothelial cell function testing: how does the method help us in evaluating vascular status?. Acta Paediatr Suppl. Dec. 2004;93(446):48-54. X-1,X-2,X-4,X-5,X-6,X-7,X-8.
1166 Halim AX, Singh V, Johnston SC, et al. Characteristics of brain arteriovenous malformations with coexisting aneurysms: a comparison of two referral centers. Stroke. Mar. 2002;33(3):675-9. X-1,X-2,X-5,X-8. [pmid: 11872886].
1167 Halkes PH, Gray LJ, Bath PM, et al. Dipyridamole plus aspirin versus aspirin alone in secondary prevention after TIA or stroke: a meta-analysis by risk. J Neurol Neurosurg Psychiatry. Nov. 2008;79(11):1218-23. X-1,X-2,X-4,X-5,X-8. [pmid: 18535024].
1168 Halkin A, Singh M, Nikolsky E, et al. Prediction of mortality after primary percutaneous coronary intervention for acute myocardial infarction: the CADILLAC risk score. J Am Coll Cardiol. May. 3. 2005;45(9):1397-405. X-1,X-8. [pmid: 15862409].
1169 Hall JA, French TK, Rasmusson KD, et al. The paradox of obesity in patients with heart failure. J Am Acad Nurse Pract. Dec. 2005;17(12):542-6. X-1,X-8. [pmid: 16293163].
1170 Haller C, Schulz J, Schmidt-Trucksass A, et al. Sequential based analysis of Intima-Media Thickness (IMT) in common carotid artery studies. Atherosclerosis. Dec. 2007;195(2):e203-9. X-1,X-2,X-5,X-6,X-8. [pmid: 17720168].
1171 Hallevi H, Albright KC, Martin-Schild S, et al. The complications of cardioembolic stroke: lessons from the VISTA database. Cerebrovasc Dis. 2008;26(1):38-40. X-1,X-2,X-8. [pmid: 18511870].
1172 Halperin RO, Sesso HD, Ma J, et al. Dyslipidemia and the risk of incident hypertension in men. Hypertension. Jan. 2006;47(1):45-50. X-1,X-6. [pmid: 16344375].
1173 Hamidon BB, Nabil I, Raymond AA. Risk factors and outcome of dysphagia after an acute ischaemic stroke. Med J Malaysia. Dec. 2006;61(5):553-7. X-1,X-6,X-7. [pmid: 17623955].
1174 Hamirani YS, Jibrin I, Abraham D, et al. Paclitaxel-eluting versus bare-metal stents in acute ST elevation myocardial infarction (STEMI). Crit Pathw Cardiol. Dec. 2008;7(4):232-8. X-1,X-2,X-7,X-8. [pmid: 19050419].
1175 Han B, Liu L, Aboud M, et al. Provisional stenting for multivessel PCI. Int J Cardiovasc Intervent. 2005;7(1):46-51. X-1,X-6,X-7,X-8. [pmid: 16019615].
1176 Han JH, Lindsell CJ, Hornung RW, et al. The elder patient with suspected acute coronary syndromes in the emergency department. Acad Emerg Med. Aug. 2007;14(8):732-9. X-1,X-6. [pmid: 17567963].
1177 Hanekom L, Jenkins C, Jeffries L, et al. Incremental value of strain rate analysis as an adjunct to wall-motion scoring for assessment of myocardial viability by dobutamine echocardiography: a follow-up study after revascularization. Circulation. Dec. 20. 2005;112(25):3892-900. X-1,X-6,X-7,X-8. [pmid: 16365209].
1178 Hankey GJ, Jamrozik K, Broadhurst RJ, et al. Long-term disability after first-ever stroke and related prognostic factors in the Perth Community Stroke Study, 1989-1990. Stroke. Apr. 2002;33(4):1034-40. X-1,X-6,X-8. [pmid: 11935057].
1179 Hankey GJ, Spiesser J, Hakimi Z, et al. Time frame and predictors of recovery from disability following recurrent ischemic stroke. Neurology. Jan. 16. 2007;68(3):202-5. X-1,X-2,X-6,X-8. [pmid: 17224574].
1180 Hannan EL, Wu C, Bennett EV, et al. Risk stratification of in-hospital mortality for coronary artery bypass graft surgery. J Am Coll Cardiol. Feb. 7. 2006;47(3):661-8. X-1,X-8. [pmid: 16458152].
1181 Hannan EL, Wu C, Bennett EV, et al. Risk index for predicting in-hospital mortality for cardiac valve surgery. Ann Thorac Surg. Mar. 2007;83(3):921-9. X-1,X-8. [pmid: 17307434].
1182 Hannan EL, Wu C, Ryan TJ, et al. Do hospitals and surgeons with higher coronary artery bypass graft surgery volumes still have lower risk-adjusted mortality rates?. Circulation. Aug. 19. 2003;108(7):795-801. X-1,X-2,X-5,X-6,X-8. [pmid: 12885743].
1183 Hansen HH, Joensen AM, Riahi S, et al. Short and long-term outcome in diabetic patients with acute myocardial infarction in the invasive era. Scand Cardiovasc J. Jan. 2007;41(1):19-24. X-1,X-8. [pmid: 17365973].
1184 Hansen TW, Thijs L, Boggia J, et al. Prognostic value of ambulatory heart rate revisited in 6928 subjects from 6 populations. Hypertension. Aug. 2008;52(2):229-35. X-1,X-2. [pmid: 18574073].
1185 Haq IU, Ramsay LE, Yeo WW, et al. Is the Framingham risk function valid for northern European populations? A comparison of methods for estimating absolute coronary risk in high risk men. Heart. Jan. 1999;81(1):40-6. X-5,X-7. [pmid: 10220543].
1186 Harats D, Leibovitz E, Maislos M, et al. Cardiovascular risk assessment and treatment to target low density lipoprotein levels in hospitalized ischemic heart disease patients: results of the HOLEM study. Isr Med Assoc J. Jun. 2005;7(6):355-9. X-1,X-2,X-6,X-8. [pmid: 15984375].
1187 Harawa NT, Morgenstern H, Beck J, et al. Correlates of knowledge of one's blood pressure and cholesterol levels among older members of a managed care plan. Aging (Milano). Apr. 2001;13(2):95-104. X-1,X-2,X-5,X-6. [pmid: 11405391].
1188 Harinstein ME, Flaherty JD, Ansari AH, et al. Predictive value of dobutamine stress echocardiography for coronary artery disease detection in liver transplant candidates. Am J Transplant. Jul. 2008;8(7):1523-8. X-1,X-5,X-6,X-7. [pmid: 18510630].
1189 Harrell L, Schunkert H, Palacios IF. Risk predictors in patients scheduled for percutaneous coronary revascularization. Catheter Cardiovasc Interv. Nov. 1999;48(3):253-60. X-1,X-6,X-8. [pmid: 10525222].
1190 Harriss LR, English DR, Hopper JL, et al. Alcohol consumption and cardiovascular mortality accounting for possible misclassification of intake: 11-year follow-up of the Melbourne Collaborative Cohort Study. Addiction. Oct. 2007;102(10):1574-85. X-1E,X-1F,X-2. [pmid: 17854334].
1191 Hart CL, Taylor MD, Davey Smith G, et al. Childhood IQ, social class, deprivation, and their relationships with mortality and morbidity risk in later life: prospective observational study linking the Scottish Mental Survey 1932 and the Midspan studies. Psychosom Med. Sep-Oct. 2003;65(5):877-83. X-1F,X-2,X-6. [pmid: 14508035].
1192 Hasdai D, Califf RM, Thompson TD, et al. Predictors of cardiogenic shock after thrombolytic therapy for acute myocardial infarction. J Am Coll Cardiol. Jan. 2000;35(1):136-43. X-1,X-6,X-8. [pmid: 10636271].
1193 Hasdai D, Holmes DR Jr, Califf RM, et al. Cardiogenic shock complicating acute myocardial infarction: predictors of death. GUSTO Investigators. Global Utilization of Streptokinase and Tissue-Plasminogen Activator for Occluded Coronary Arteries. Am Heart J. Jul. 1999;138(1 Pt 1):21-31. X-1,X-6,X-8. [pmid: 10385759].
1194 Hashimoto A, Nakata T, Wakabayashi T, et al. Validation of quantitative gated single photon emission computed tomography and an automated scoring system for the assessment of regional left ventricular systolic function. Nucl Med Commun. Sep. 2002;23(9):887-98. X-1,X-5,X-6,X-7,X-8. [pmid: 12195094].
1195 Hashimoto H, Kitagawa K, Hougaku H, et al. C-reactive protein predicts carotid atherosclerosis progression in mild to moderate risk and middle-aged patients. Clin Invest Med. Apr. 2006;29(2):77-82. X-7. [pmid: 16737083].
1196 Hassan A, Gormley K, O'sullivan M, et al. Endothelial nitric oxide gene haplotypes and risk of cerebral small-vessel disease. Stroke. Mar. 2004;35(3):654-9. X-1,X-5,X-6,X-8. [pmid: 14963277].
1197 Hassapoyannes CA, Giurgiutiu DV, Bagasra A, et al. Utilization efficacy of noninvasive and invasive cardiac testing among stable cardiac patients undergoing noncardiac surgery. Cardiovasc Revasc Med. Jan-Mar. 2006;7(1):12-8. X-1,X-8. [pmid: 16513518].
1198 Hassapoyannes CA, Giurgiutiu DV, Eaves G, et al. Apparent racial disparity in the utilization of invasive testing for risk assessment of cardiac patients undergoing noncardiac surgery. Cardiovasc Revasc Med. Apr-Jun. 2006;7(2):64-9. X-1,X-2,X-8. [pmid: 16757403].
1199 Hassapoyannes CA, McLaurin BT, Hornung CA, et al. Normokinesia adjacent to left ventricular aneurysm: a differential risk for sudden cardiac death. Eur J Heart Fail. Jan. 2002;4(1):33-40. X-1,X-7,X-8. [pmid: 11812663].
1200 Hata Y, Muratani H, Kimura Y, et al. Office blood pressure variability as a predictor of acute myocardial infarction in elderly patients receiving antihypertensive therapy. J Hum Hypertens. Feb. 2002;16(2):141-6. X-1,X-2,X-5,X-7,X-8. [pmid: 11850772].
1201 Hatfield J, Gulati S, Abdul Rahman MN, et al. Nurse-led risk assessment/management clinics reduce predicted cardiac morbidity and mortality in claudicants. J Vasc Nurs. Dec. 2008;26(4):118-22. X-1,X-2,X-6,X-7. [pmid: 19022170].
1202 Hatzinikolaou-Kotsakou E, Tziakas D, Hotidis A, et al. Could sustained monomorphic ventricular tachycardia in the early phase of a prime acute myocardial infarction affect patient outcome?. J Electrocardiol. Jan. 2007;40(1):72-7. X-1,X-2,X-6,X-7,X-8. [pmid: 17070829].
1203 Hauner H, Hanisch J, Bramlage P, et al. Prevalence of undiagnosed Type-2-diabetes mellitus and impaired fasting glucose in German primary care: data from the German Metabolic and Cardiovascular Risk Project (GEMCAS). Exp Clin Endocrinol Diabetes. Jan. 2008;116(1):18-25. X-1F,X-2,X-5,X-6,X-8(15%). [pmid: 17926235].
1204 Hayashi SY, Rohani M, Lindholm B, et al. Left ventricular function in patients with chronic kidney disease evaluated by colour tissue Doppler velocity imaging. Nephrol Dial Transplant. Jan. 2006;21(1):125-32. X-1,X-6,X-8. [pmid: 16221719].
1205 Hayashi T, Obi Y, Kimura T, et al. Cardiac troponin T predicts occult coronary artery stenosis in patients with chronic kidney disease at the start of renal replacement therapy. Nephrol Dial Transplant. Sep. 2008;23(9):2936-42. X-1,X-6,X-7,X-8. [pmid: 18403432].
1206 Hayashida K, Imanaka Y, Sekimoto M, et al. Evaluation of acute myocardial infarction in-hospital mortality using a risk-adjustment model based on Japanese administrative data. J Int Med Res. Sep-Oct. 2007;35(5):590-6. X-1,X-5,X-6,X-8. [pmid: 17900397].
1207 Hayden M, Pignone M, Phillips C, et al. Aspirin for the primary prevention of cardiovascular events: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Jan. 15. 2002;136(2):161-72. X-4. [pmid: 11790072].
1208 Hayes SW, De Lorenzo A, Hachamovitch R, et al. Prognostic implications of combined prone and supine acquisitions in patients with equivocal or abnormal supine myocardial perfusion SPECT. J Nucl Med. Oct. 2003;44(10):1633-40. X-1,X-8. [pmid: 14530478].
1209 He J, Whelton PK. Elevated systolic blood pressure and risk of cardiovascular and renal disease: overview of evidence from observational epidemiologic studies and randomized controlled trials. Am Heart J. Sep. 1999;138(3 Pt 2):211-9. X-4,X-5,X-6. [pmid: 10467215].
1210 Healy DG, Veerasingam D, Wood AE. EuroSCORE: useful in directing preoperative intra-aortic balloon pump placement in cardiac surgery?. Heart Surg Forum. 2006;9(6):E893-6. X-1,X-8. [pmid: 17599889].
1211 Heckbert SR, Hindorff LA, Edwards KL, et al. Beta2-adrenergic receptor polymorphisms and risk of incident cardiovascular events in the elderly. Circulation. Apr. 22. 2003;107(15):2021-4. X-1F,X-1G,X-2. [pmid: 12682000].
1212 Heeneman S, Donners MM, Bai L, et al. Drug-induced immunomodulation to affect the development and progression of atherosclerosis: a new opportunity?. Expert Rev Cardiovasc Ther. Mar. 2007;5(2):345-64. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 17338677].
1213 Heeschen C, Dimmeler S, Fichtlscherer S, et al. Prognostic value of placental growth factor in patients with acute chest pain. JAMA. Jan. 28. 2004;291(4):435-41. X-1,X-2,X-8. [pmid: 14747500].
1214 Heeschen C, Dimmeler S, Hamm CW, et al. Prognostic significance of angiogenic growth factor serum levels in patients with acute coronary syndromes. Circulation. Feb. 4. 2003;107(4):524-30. X-1,X-5,X-6. [pmid: 12566361].
1215 Heeschen C, Goldmann BU, Terres W, et al. Cardiovascular risk and therapeutic benefit of coronary interventions for patients with unstable angina according to the troponin T status. Eur Heart J. Jul. 2000;21(14):1159-66. X-1,X-8. [pmid: 10924299].
1216 Heggunje PS, Harjai KJ, Stone GW, et al. Procedural success versus clinical risk status in determining discharge of patients after primary angioplasty for acute myocardial infarction. J Am Coll Cardiol. Oct. 6. 2004;44(7):1400-7. X-1,X-8. [pmid: 15464319].
1217 Heijmans BT, Westendorp RG, Lagaay AM, et al. Common paraoxonase gene variants, mortality risk and fatal cardiovascular events in elderly subjects. Atherosclerosis. Mar. 2000;149(1):91-7. X-1,X-2. [pmid: 10704619].
1218 Heijmans JH, Maessen JG, Roekaerts PM. Risk stratification for adverse outcome in cardiac surgery. Eur J Anaesthesiol. Jul. 2003;20(7):515-27. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12884984].
1219 Heikkinen J, Biancari F, Satta J, et al. Predicting immediate and late outcome after surgery for mitral valve regurgitation with EuroSCORE. J Heart Valve Dis. Mar. 2007;16(2):116-21. X-1,X-6,X-8. [pmid: 17484456].
1220 Heine GH, Gerhart MK, Ulrich C, et al. Renal Doppler resistance indices are associated with systemic atherosclerosis in kidney transplant recipients. Kidney Int. Aug. 2005;68(2):878-85. X-1,X-6,X-7. [pmid: 16014069].
1221 Heiss G, Wallace R, Anderson GL, et al. Health risks and benefits 3 years after stopping randomized treatment with estrogen and progestin. JAMA. Mar. 5. 2008;299(9):1036-45. X-1F,X-2,X-6,X-8(7-8.8%). [pmid: 18319414].
1222 Heitzer T, Schlinzig T, Krohn K, et al. Endothelial dysfunction, oxidative stress, and risk of cardiovascular events in patients with coronary artery disease. Circulation. Nov. 27. 2001;104(22):2673-8. X-1,X-2,X-8. [pmid: 11723017].
1223 Heltai K, Kis Z, Burian K, et al. Elevated antibody levels against Chlamydia pneumoniae, human HSP60 and mycobacterial HSP65 are independent risk factors in myocardial infarction and ischaemic heart disease. Atherosclerosis. Apr. 2004;173(2):339-46. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15064111].
1224 Hemphill JC 3rd, Bonovich DC, Besmertis L, et al. The ICH score: a simple, reliable grading scale for intracerebral hemorrhage. Stroke. Apr. 2001;32(4):891-7. X-1,X-6,X-8. [pmid: 11283388].
1225 Hendler A, Kaluski E, Blatt A, et al. Percutaneous coronary intervention of unprotected left main coronary artery in the emergent/urgent setting. J Invasive Cardiol. May. 2007;19(5):202-6. X-1,X-7,X-8. [pmid: 17476033].
1226 Hendricks AS, Goodman B, Stein JH, et al. Gender differences in acute myocardial infarction: the University of Wisconsin experience. WMJ. Dec. 1999;98(8):30-3. 36. X-1,X-5,X-6,X-8.
1227 Hendrix SL, Wassertheil-Smoller S, Johnson KC, et al. Effects of conjugated equine estrogen on stroke in the Women's Health Initiative. Circulation. May. 23. 2006;113(20):2425-34. X-1F,X-2,X-8. [pmid: 16702472].
1228 Henley SJ, Thun MJ, Chao A, et al. Association between exclusive pipe smoking and mortality from cancer and other diseases. J Natl Cancer Inst. Jun. 2. 2004;96(11):853-61. X-1,X-2. [pmid: 15173269].
1229 Henley SJ, Thun MJ, Connell C, et al. Two large prospective studies of mortality among men who use snuff or chewing tobacco (United States). Cancer Causes Control. May. 2005;16(4):347-58. X-1F,X-2,X-8(6%). [pmid: 15953977].
1230 Henon H, Vroylandt P, Durieu I, et al. Leukoaraiosis more than dementia is a predictor of stroke recurrence. Stroke. Dec. 2003;34(12):2935-40. X-1,X-7,X-8. [pmid: 14631083].
1231 Henriksen T, Clausen T. The fetal origins hypothesis: placental insufficiency and inheritance versus maternal malnutrition in well-nourished populations. Acta Obstet Gynecol Scand. Feb. 2002;81(2):112-4. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 11942899].
1232 Henriques JP, Zijlstra F, Ottervanger JP, et al. Angiographic predictors of left ventricular ejection fraction after successful angioplasty in acute myocardial infarction: an angiographic risk score for use in the catheterization laboratory. Catheter Cardiovasc Interv. Mar. 2004;61(3):338-43. X-1,X-2,X-6,X-8. [pmid: 14988892].
1233 Hense HW, Koesters E, Wellmann J, et al. Evaluation of a recalibrated Systematic Coronary Risk Evaluation cardiovascular risk chart: results from Systematic Coronary Risk Evaluation Germany. Eur J Cardiovasc Prev Rehabil. Aug. 2008;15(4):409-15. X-5. [pmid: 18677164].
1234 Hergenc G, Onat A, Sari I, et al. Serum total and high-density lipoprotein phospholipid levels in a population-based study and relationship to risk of metabolic syndrome and coronary disease. Angiology. Feb-Mar. 2008;59(1):26-35. X-1,X-2,X-6. [pmid: 18319219].
1235 Herman C, Sullivan JA, Buth K, et al. Intraoperative graft flow measurements during coronary artery bypass surgery predict in-hospital outcomes. Interact Cardiovasc Thorac Surg. Aug. 2008;7(4):582-5. X-1,X-2,X-8. [pmid: 18467427].
1236 Hermann-Arnhof KM, Kastenbauer T, Publig T, et al. Initially elevated osteoprotegerin serum levels may predict a perioperative myocardial lesion in patients undergoing coronary artery bypass grafting. Crit Care Med. Jan. 2006;34(1):76-80. X-1,X-6,X-7,X-8. [pmid: 16374159].
1237 Hermida JS, Leenhardt A, Cauchemez B, et al. Decreased nocturnal standard deviation of averaged NN intervals. An independent marker to identify patients at risk in the Brugada Syndrome. Eur Heart J. Nov. 2003;24(22):2061-9. X-1,X-6,X-7. [pmid: 14613743].
1238 Herrmann W, Quast S, Wolter K, et al. Determination of free apolipoprotein(a) in serum by immunoassay and its significance for risk assessment in patients with coronary artery disease. Clin Chem Lab Med. Jan. 1999;37(1):21-8. X-1,X-5,X-6,X-8. [pmid: 10094374].
1239 Hertzer NR, Bena JF, Karafa MT. A personal experience with the influence of diabetes and other factors on the outcome of infrainguinal bypass grafts for occlusive disease. J Vasc Surg. Aug. 2007;46(2):271-279. X-1,X-6,X-8. [pmid: 17600656].
1240 Herwaldt LA, Cullen JJ, French P, et al. Preoperative risk factors for nasal carriage of Staphylococcus aureus. Infect Control Hosp Epidemiol. Jun. 2004;25(6):481-4. X-1,X-6. [pmid: 15242196].
1241 Herzog C, Britten M, Balzer JO, et al. Multidetector-row cardiac CT: diagnostic value of calcium scoring and CT coronary angiography in patients with symptomatic, but atypical, chest pain. Eur Radiol. Feb. 2004;14(2):169-77. X-1,X-5,X-6. [pmid: 14689229].
1242 Heuchan AM, Evans N, Henderson Smart DJ, et al. Perinatal risk factors for major intraventricular haemorrhage in the Australian and New Zealand Neonatal Network, 1995-97. Arch Dis Child Fetal Neonatal Ed. Mar. 2002;86(2):F86-90. X-1. [pmid: 11882549].
1243 Heuschmann PU, Kolominsky-Rabas PL, Misselwitz B, et al. Predictors of in-hospital mortality and attributable risks of death after ischemic stroke: the German Stroke Registers Study Group. Arch Intern Med. Sep. 13. 2004;164(16):1761-8. X-1,X-8. [pmid: 15364669].
1244 Heuschmann PU, Neureiter D, Gesslein M, et al. Association between infection with Helicobacter pylori and Chlamydia pneumoniae and risk of ischemic stroke subtypes: Results from a population-based case-control study. Stroke. Oct. 2001;32(10):2253-8. X-1,X-2,X-5,X-8. [pmid: 11588309].
1245 Hiatt WR, Money SR, Brass EP. Long-term safety of cilostazol in patients with peripheral artery disease: the CASTLE study (Cilostazol: A Study in Long-term Effects). J Vasc Surg. Feb. 2008;47(2):330-336. X-1,X-2,X-8. [pmid: 18155871].
1246 Hietanen H, Paakkonen R, Salomaa V. Ankle blood pressure as a predictor of total and cardiovascular mortality. BMC Cardiovasc Disord. 2008;8:3. X-1E,X-1F,X-2,X-8(4-54%). [pmid: 18267039].
1247 Higashikuni Y, Tanabe K, Tanimoto S, et al. Impact of culprit plaque composition on the no-reflow phenomenon in patients with acute coronary syndrome: an intravascular ultrasound radiofrequency analysis. Circ J. Aug. 2008;72(8):1235-41. X-1,X-2,X-6,X-7,X-8. [pmid: 18654006].
1248 Hildemann S, Karmann B, Pittrow D, et al. Predictors of uncontrolled hyperlipidaemia in high-risk ambulatory patients in primary care. Curr Med Res Opin. Jun. 2008;24(6):1659-68. X-1,X-4,X-5,X-6. [pmid: 18457604].
1249 Hill AB, Obrand D, O'Rourke K, et al. Hemispheric stroke following cardiac surgery: a case-control estimate of the risk resulting from ipsilateral asymptomatic carotid artery stenosis. Ann Vasc Surg. May. 2000;14(3):200-9. X-1,X-2,X-5,X-8. [pmid: 10796950].
1250 Hill DC, Ethans KD, MacLeod DA, et al. Exercise stress testing in subacute stroke patients using a combined upper- and lower-limb ergometer. Arch Phys Med Rehabil. Sep. 2005;86(9):1860-6. X-1,X-2,X-5,X-6X-7,X-8. [pmid: 16181955].
1251 Hill JM, Zalos G, Halcox JP, et al. Circulating endothelial progenitor cells, vascular function, and cardiovascular risk. N Engl J Med. Feb. 13. 2003;348(7):593-600. X-1,X-5,X-6,X-7. [pmid: 12584367].
1252 Hill MD, Yiannakoulias N, Jeerakathil T, et al. The high risk of stroke immediately after transient ischemic attack: a population-based study. Neurology. Jun. 8. 2004;62(11):2015-20. X-1,X-8. [pmid: 15184607].
1253 Hillsdon M, Thorogood M, Murphy M, et al. Can a simple measure of vigorous physical activity predict future mortality? Results from the OXCHECK study. Public Health Nutr. Jun. 2004;7(4):557-62. X-1,X-2. [pmid: 15153262].
1254 Hines GL, Feuerman M, Cappello D, et al. Results of carotid endarterectomy with pericardial patch angioplasty: rate and predictors of restenosis. Ann Vasc Surg. Nov. 2007;21(6):767-71. X-1,X-6,X-7,X-8. [pmid: 17980796].
1255 Hirakawa Y, Masuda Y, Kuzuya M, et al. Impact of gender on in-hospital mortality of patients with acute myocardial infarction undergoing percutaneous coronary intervention: an evaluation of the TAMIS-II data. Intern Med. 2007;46(7):363-6. X-1,X-8. [pmid: 17409598].
1256 Hirokawa K, Nagata C, Takatsuka N, et al. The relationships of a rationality/antiemotionality personality scale to mortalities of cancer and cardiovascular disease in a community population in Japan. J Psychosom Res. Jan. 2004;56(1):103-11. X-1F,X-2,X-5,X-6. [pmid: 14987971].
1257 Hirsch A, Nijveldt R, van der Vleuten PA, et al. Intracoronary infusion of autologous mononuclear bone marrow cells in patients with acute myocardial infarction treated with primary PCI: Pilot study of the multicenter HEBE trial. Catheter Cardiovasc Interv. Feb. 15. 2008;71(3):273-81. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18288734].
1258 Hirsch AT. Vascular disease, hypertension, and prevention: “from endothelium to clinical events”. J Am Coll Cardiol. Jul. 16. 2003;42(2):377-9. X-2,X-4. [pmid: 12875780].
1259 Hirtz D, Thurman DJ, Gwinn-Hardy K, et al. How common are the “common” neurologic disorders?. Neurology. Jan. 30. 2007;68(5):326-37. X-1,X-2,X-4,X-5. [pmid: 17261678].
1260 Hitman GA, Colhoun H, Newman C, et al. Stroke prediction and stroke prevention with atorvastatin in the Collaborative Atorvastatin Diabetes Study (CARDS). Diabet Med. Dec. 2007;24(12):1313-21. X-1F,X-2. [pmid: 17894827].
1261 Hiura Y, Fukushima Y, Yuno M, et al. Validation of the association of genetic variants on chromosome 9p21 and 1q41 with myocardial infarction in a Japanese population. Circ J. Aug. 2008;72(8):1213-7. X-1,X-2,X-5,X-8. [pmid: 18654002].
1262 Ho JE, Paultre F, Mosca L. Is diabetes mellitus a cardiovascular disease risk equivalent for fatal stroke in women? Data from the Women's Pooling Project. Stroke. Dec. 2003;34(12):2812-6. X-4. [pmid: 14657546].
1263 Ho KT, Miller TD, Hodge DO, et al. Use of a simple clinical score to predict prognosis of patients with normal or mildly abnormal resting electrocardiographic findings undergoing evaluation for coronary artery disease. Mayo Clin Proc. Jun. 2002;77(6):515-21. X-1,X-8. [pmid: 12059120].
1264 Hobbs FD, Erhardt LR, Rycroft C. The From The Heart study: a global survey of patient understanding of cholesterol management and cardiovascular risk, and physician-patient communication. Curr Med Res Opin. May. 2008;24(5):1267-78. X-1,X-2,X-5,X-6. [pmid: 18355420].
1265 Hobbs JB, Peterson DR, Moss AJ, et al. Risk of aborted cardiac arrest or sudden cardiac death during adolescence in the long-QT syndrome. JAMA. Sep. 13. 2006;296(10):1249-54. X-1D,X-1F,X-1G,X-2,X-5,X-8(100%),X-9. [pmid: 16968849].
1266 Hochadel M, Schneider S, Gottwik M, et al. Evaluation of hospitals regarding outcomes and baseline risk -- an application to percutaneous coronary intervention. Clin Res Cardiol. Jul. 2007;96(7):502-7. X-1,X-6,X-8. [pmid: 17534567].
1267 Hocher B, Ziebig R, Altermann C, et al. Different impact of biomarkers as mortality predictors among diabetic and nondiabetic patients undergoing hemodialysis. J Am Soc Nephrol. Sep. 2003;14(9):2329-37. X-1F,X-2. [pmid: 12937310].
1268 Hoefle G, Muendlein A, Saely CH, et al. The -11377 C>G promoter variant of the adiponectin gene, prevalence of coronary atherosclerosis, and incidence of vascular events in men. Thromb Haemost. Mar. 2007;97(3):451-7. X-1. [pmid: 17334513].
1269 Hoeks SE, Scholte Op, Reimer WJ, van Urk H, et al. Increase of 1-year mortality after perioperative beta-blocker withdrawal in endovascular and vascular surgery patients. Eur J Vasc Endovasc Surg. Jan. 2007;33(1):13-9. X-1,X-7. [pmid: 16935011].
1270 Hoenig MR. Implications of the obesity epidemic for lipid-lowering therapy: non-HDL cholesterol should replace LDL cholesterol as the primary therapeutic target. Vasc Health Risk Manag. 2008;4(1):143-56. X-2,X-4,X-5. [pmid: 18629364].
1271 Hoffmann U, Brady TJ, Muller J. Cardiology patient page. Use of new imaging techniques to screen for coronary artery disease. Circulation. Aug. 26. 2003;108(8):e50-3. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 12939244].
1272 Hoffmann U, Nagurney JT, Moselewski F, et al. Coronary multidetector computed tomography in the assessment of patients with acute chest pain. Circulation. Nov. 21. 2006;114(21):2251-60. X-1,X-2,X-6,X-7,X-8. [pmid: 17075011].
1273 Hogh AL, Joensen J, Lindholt JS, et al. C-reactive protein predicts future arterial and cardiovascular events in patients with symptomatic peripheral arterial disease. Vasc Endovascular Surg. Aug-Sep. 2008;42(4):341-7. X-1. [pmid: 18458051].
1274 Hognestad A, Endresen K, Wergeland R, et al. Inflammatory response and re-stenosis after percutaneous coronary intervention in heart transplant recipients and patients with native atherosclerosis. J Heart Lung Transplant. Aug. 2005;24(8):1026-32. X-1,X-2,X-6,X-7,X-8. [pmid: 16102437].
1275 Hoh J, Wille A, Zee R, et al. Selecting SNPs in two-stage analysis of disease association data: a model-free approach. Ann Hum Genet. Sep. 2000;64(Pt 5):413-7. X-1,X-8. [pmid: 11281279].
1276 Hoieggen A, Alderman MH, Kjeldsen SE, et al. The impact of serum uric acid on cardiovascular outcomes in the LIFE study. Kidney Int. Mar. 2004;65(3):1041-9. X-1E,X-1F,X-2. [pmid: 14871425].
1277 Hollander JE, Muttreja MR, Dalesandro MR, et al. Risk stratification of emergency department patients with acute coronary syndromes using P-selectin. J Am Coll Cardiol. Jul. 1999;34(1):95-105. X-1,X-6. [pmid: 10399997].
1278 Hollander JE, Sites FD, Pollack CV Jr, et al. Lack of utility of telemetry monitoring for identification of cardiac death and life-threatening ventricular dysrhythmias in low-risk patients with chest pain. Ann Emerg Med. Jan. 2004;43(1):71-6. X-1,X-5. [pmid: 14707944].
1279 Hollander M, Hak AE, Koudstaal PJ, et al. Comparison between measures of atherosclerosis and risk of stroke: the Rotterdam Study. Stroke. Oct. 2003;34(10):2367-72. X-1F,X-2. [pmid: 12958327].
1280 Holloman CH, Bortnick SM, Morara M, et al. A Bayesian hierarchical approach for relating PM(25) exposure to cardiovascular mortality in North Carolina. Environ Health Perspect. Sep. 2004;112(13):1282-8. X-1,X-2,X-5. [pmid: 15345340].
1281 Holmboe ES, Wang Y, Meehan TP, et al. Association between maintenance of certification examination scores and quality of care for medicare beneficiaries. Arch Intern Med. Jul. 14. 2008;168(13):1396-403. X-1,X-6. [pmid: 18625919].
1282 Holmes D, Velappan P, Kern MJ. Coronary pressure notch: an early non-hyperemic visual indicator of the physiologic significance of a coronary artery stenosis. J Invasive Cardiol. Nov. 2004;16(11):617-20. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15550728].
1283 Holscher B, Heitmeyer C, Fobker M, et al. Predictors for contrast media-induced nephropathy and long-term survival: prospectively assessed data from the randomized controlled Dialysis-Versus-Diuresis (DVD) trial. Can J Cardiol. Nov. 2008;24(11):845-50. X-1,X-2,X-6. [pmid: 18987758].
1284 Holubkov R, Pepine CJ, Rickens C, et al. Electrocardiogram abnormalities predict angiographic coronary artery disease in women with chest pain: results from the NHLBI WISE Study. Clin Cardiol. Dec. 2002;25(12):553-8. X-1,X-2,X-5,X-8. [pmid: 12492124].
1285 Holvoet P, Harris TB, Tracy RP, et al. Association of high coronary heart disease risk status with circulating oxidized LDL in the well-functioning elderly: findings from the Health, Aging, and Body Composition study. Arterioscler Thromb Vasc Biol. Aug. 1. 2003;23(8):1444-8. X-1,X-5,X-8. [pmid: 12791672].
1286 Honda O, Sugiyama S, Kugiyama K, et al. Echolucent carotid plaques predict future coronary events in patients with coronary artery disease. J Am Coll Cardiol. Apr. 7. 2004;43(7):1177-84. X-1,X-8. [pmid: 15063426].
1287 Hong MK, Mintz GS, Lee CW, et al. Late target lesion revascularization after implantation of sirolimus-eluting stent. Catheter Cardiovasc Interv. Feb. 15. 2008;71(3):299-303. X-1,X-6,X-8. [pmid: 17985380].
1288 Hong YJ, Jeong MH, Park OY, et al. The role of C-reactive protein on the long-term clinical outcome after primary or rescue percutaneous coronary intervention. Korean J Intern Med. Mar. 2003;18(1):29-34. X-1,X-6,X-8. [pmid: 12760265].
1289 Hongzong S, Tao W, Xiaojun Y, et al. Support vector machines classification for discriminating coronary heart disease patients from non-coronary heart disease. West Indian Med J. Oct. 2007;56(5):451-7. X-1,X-2,X-5,X-6,X-8. [pmid: 18303759].
1290 Honzikova N, Fiser B, Semrad B. Critical value of baroreflex sensitivity determined by spectral analysis in risk stratification after myocardial infarction. Pacing Clin Electrophysiol. Nov. 2000;23(11 Pt 2):1965-7. X-1,X-7,X-8. [pmid: 11139968].
1291 Hoogeveen EK, Kostense PJ, Valk GD, et al. Hyperhomocysteinaemia is not related to risk of distal somatic polyneuropathy: the Hoorn Study. J Intern Med. Dec. 1999;246(6):561-6. X-1,X-6. [pmid: 10620099].
1292 Hooning MJ, Dorresteijn LD, Aleman BM, et al. Decreased risk of stroke among 10-year survivors of breast cancer. J Clin Oncol. Dec. 1. 2006;24(34):5388-94. X-1,X-2. [pmid: 17088569].
1293 Hope SA, Antonis P, Adam D, et al. Arterial pulse wave velocity but not augmentation index is associated with coronary artery disease extent and severity: implications for arterial transfer function applicability. J Hypertens. Oct. 2007;25(10):2105-9. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 17885554].
1294 Hopkins PN, Heiss G, Ellison RC, et al. Coronary artery disease risk in familial combined hyperlipidemia and familial hypertriglyceridemia: a case-control comparison from the National Heart, Lung, and Blood Institute Family Heart Study. Circulation. Aug. 5. 2003;108(5):519-23. X-1,X-2,X-5,X-7. [pmid: 12847072].
1295 Horai T, Fukui T, Tabata M, et al. Early and mid-term results of off-pump coronary artery bypass grafting in patients with end stage renal disease: surgical outcomes after achievement of complete revascularization. Interact Cardiovasc Thorac Surg. Apr. 2008;7(2):218-21. X-1,X-2,X-5,X-6,X-7. [pmid: 18086692].
1296 Horan PG, Kamaruddin MS, Moore MJ, et al. Cardiovascular disease risk profiles among ‘healthy’ siblings of patients with early-onset cardiovascular disease: application of the new SCORE system. Eur J Cardiovasc Prev Rehabil. Aug. 2007;14(4):521-5. X-5,X-6. [pmid: 17667642].
1297 Horan PG, Leonard N, Herity NA. Progressively increasing operative risk among patients referred for coronary artery bypass surgery. Ulster Med J. May. 2006;75(2):136-40. X-1F,X-2. [pmid: 16755944].
1298 Horenstein RB, Smith DE, Mosca L. Cholesterol predicts stroke mortality in the Women's Pooling Project. Stroke. Jul. 2002;33(7):1863-8. X-4,X-5. [pmid: 12105367].
1299 Hori R, Hayano J, Monou H, et al. Coronary-prone behavior among Japanese men. Circ J. Feb. 2003;67(2):129-32. X-1,X-5,X-6. [pmid: 12547994].
1300 Horibe H, Yamada Y, Ichihara S, et al. Genetic risk for restenosis after coronary balloon angioplasty. Atherosclerosis. May. 2004;174(1):181-7. X-1,X-2,X-6,X-8. [pmid: 15135268].
1301 Horne BD, Anderson JL, John JM, et al. Which white blood cell subtypes predict increased cardiovascular risk?. J Am Coll Cardiol. May. 17. 2005;45(10):1638-43. X-1F,X-2,X-8(MI)(Unstable Angina)(Stable Angina). [pmid: 15893180].
1302 Horne BD, Muhlestein JB, Lappe DL, et al. Less affluent area of residence and lesser-insured status predict an increased risk of death or myocardial infarction after angiographic diagnosis of coronary disease. Ann Epidemiol. Feb. 2004;14(2):143-50. X-1F,X-2,X-8. [pmid: 15018888].
1303 Horwich TB, Patel J, MacLellan WR, et al. Cardiac troponin I is associated with impaired hemodynamics, progressive left ventricular dysfunction, and increased mortality rates in advanced heart failure. Circulation. Aug. 19. 2003;108(7):833-8. X-1,X-5,X-8. [pmid: 12912820].
1304 Hoshida S, Nishino M, Takeda T, et al. A persistent increase in C-reactive protein is a risk factor for restenosis in patients with stable angina who are not receiving statins. Atherosclerosis. Apr. 2004;173(2):285-90. X-1,X-2,X-6,X-8. [pmid: 15064103].
1305 Hossain A, Khan HT. Risk factors of coronary heart disease. Indian Heart J. Mar-Apr. 2007;59(2):147-51. X-1,X-2. [pmid: 19122248].
1306 Hougaku H, Fleg JL, Najjar SS, et al. Relationship between androgenic hormones and arterial stiffness, based on longitudinal hormone measurements. Am J Physiol Endocrinol Metab. Feb. 2006;290(2):E234-42. X-1,X-6. [pmid: 16159908].
1307 House A, Knapp P, Bamford J, et al. Mortality at 12 and 24 months after stroke may be associated with depressive symptoms at 1 month. Stroke. Mar. 2001;32(3):696-701. X-1,X-8. [pmid: 11239189].
1308 Houterman S, Janssen-Heijnen ML, Verheij CD, et al. Greater influence of age than co-morbidity on primary treatment and complications of prostate cancer patients: an in-depth population-based study. Prostate Cancer Prostatic Dis. 2006;9(2):179-84. X-1,X-6. [pmid: 16534509].
1309 Hoy A, Leininger-Muller B, Poirier O, et al. Myeloperoxidase polymorphisms in brain infarction. Association with infarct size and functional outcome. Atherosclerosis. Apr. 2003;167(2):223-30. X-1,X-5,X-6. [pmid: 12818404].
1310 Hoy W, Kelly A, Jacups S, et al. Stemming the tide: reducing cardiovascular disease and renal failure in Australian Aborigines. Aust N Z J Med. Jun. 1999;29(3):480-3. X-1,X-2,X-6. [pmid: 10868523].
1311 Hoyer D, Maestri R, La Rovere MT, et al. Autonomic response to cardiac dysfunction in chronic heart failure: a risk predictor based on autonomic information flow. Pacing Clin Electrophysiol. Feb. 2008;31(2):214-20. X-1,X-2,X-5,X-6,X-8. [pmid: 18233975].
1312 Hozawa A, Houston T, Steffes MW, et al. The association of cigarette smoking with self-reported disease before middle age: the Coronary Artery Risk Development in Young Adults (CARDIA) study. Prev Med. Mar. 2006;42(3):193-9. X-1. [pmid: 16480762].
1313 Hsia HH, Marchlinski FE. Electrophysiology studies in patients with dilated cardiomyopathies. Card Electrophysiol Rev. Dec. 2002;6(4):472-81. X-1,X-2,X-4,X-5,X-6. [pmid: 12438831].
1314 Hsia J, Barad D, Margolis K, et al. Usefulness of prior hysterectomy as an independent predictor of Framingham risk score (The Women's Health Initiative). Am J Cardiol. Aug. 1. 2003;92(3):264-9. X-1,X-2,X-5,X-6. [pmid: 12888128].
1315 Hsia J, Jablonski KA, Rice MM, et al. Sudden cardiac death in patients with stable coronary artery disease and preserved left ventricular systolic function. Am J Cardiol. Feb. 15. 2008;101(4):457-61. X-1,X-8. [pmid: 18312757].
1316 Hsia J, Klouj A, Prasad A, et al. Progression of coronary calcification in healthy postmenopausal women. BMC Cardiovasc Disord. Dec. 1. 2004;4:21. X-6. [pmid: 15574196].
1317 Hsia J, Simon JA, Lin F, et al. Peripheral arterial disease in randomized trial of estrogen with progestin in women with coronary heart disease: the Heart and Estrogen/Progestin Replacement Study. Circulation. Oct. 31. 2000;102(18):2228-32. X-1,X-8. [pmid: 11056097].
1318 Hsueh IP, Wang WC, Sheu CF, et al. Rasch analysis of combining two indices to assess comprehensive ADL function in stroke patients. Stroke. Mar. 2004;35(3):721-6. X-1,X-5,X-6,X-8. [pmid: 14963275].
1319 Hu G, Qiao Q, Tuomilehto J, et al. Prevalence of the metabolic syndrome and its relation to all-cause and cardiovascular mortality in nondiabetic European men and women. Arch Intern Med. May. 24. 2004;164(10):1066-76. X-1,X-2,X-4X-5. [pmid: 15159263].
1320 Hu G, Root MM. Building prediction models for coronary heart disease by synthesizing multiple longitudinal research findings. Eur J Cardiovasc Prev Rehabil. Oct. 2005;12(5):459-64. X-1. [pmid: 16210932].
1321 Hu G, Tuomilehto J, Borodulin K, et al. The joint associations of occupational, commuting, and leisure-time physical activity, and the Framingham risk score on the 10-year risk of coronary heart disease. Eur Heart J. Feb. 2007;28(4):492-8. X-5,X-6. [pmid: 17242011].
1322 Huang AL, Silver AE, Shvenke E, et al. Predictive value of reactive hyperemia for cardiovascular events in patients with peripheral arterial disease undergoing vascular surgery. Arterioscler Thromb Vasc Biol. Oct. 2007;27(10):2113-9. X-1F,X-2. [pmid: 17717291].
1323 Huang DT, Sesselberg HW, McNitt S, et al. Improved survival associated with prophylactic implantable defibrillators in elderly patients with prior myocardial infarction and depressed ventricular function: a MADIT-II substudy. J Cardiovasc Electrophysiol. Aug. 2007;18(8):833-8. X-1,X-6,X-8. [pmid: 17537209].
1324 Huang HW, Guo MH, Lin RJ, et al. Prevalence and risk factors of middle cerebral artery stenosis in asymptomatic residents in Rongqi County, Guangdong. Cerebrovasc Dis. 2007;24(1):111-5. X-1,X-5,X-6. [pmid: 17519553].
1325 Huang KC, Lee LT, Chen CY, et al. All-cause and cardiovascular disease mortality increased with metabolic syndrome in Taiwanese. Obesity (Silver Spring). Mar. 2008;16(3):684-9. X-1E,X-1F,X-2. [pmid: 18239592].
1326 Huang WF, Hsiao FY, Tsai YW, et al. Cardiovascular events associated with long-term use of celecoxib, rofecoxib and meloxicam in Taiwan: an observational study. Drug Saf. 2006;29(3):261-72. X-1,X-2. [pmid: 16524325].
1327 Hubacek J, Galbraith PD, Gao M, et al. External validation of a percutaneous coronary intervention mortality prediction model in patients with acute coronary syndromes. Am Heart J. Feb. 2006;151(2):308-15. X-1,X-6,X-8. [pmid: 16442892].
1328 Huddart RA, Norman A, Shahidi M, et al. Cardiovascular disease as a long-term complication of treatment for testicular cancer. J Clin Oncol. Apr. 15. 2003;21(8):1513-23. X-1F,X-1G. [pmid: 12697875].
1329 Hui AC, Wu B, Tang AS, et al. Lack of clinical utility of the Siriraj Stroke Score. Intern Med J. Jul. 2002;32(7):311-4. X-1,X-8. [pmid: 12088348].
1330 Huijskes RV, Rosseel PM, Tijssen JG. Outcome prediction in coronary artery bypass grafting and valve surgery in the Netherlands: development of the Amphiascore and its comparison with the Euroscore. Eur J Cardiothorac Surg. Nov. 2003;24(5):741-9. X-1,X-6,X-8. [pmid: 14583307].
1331 Huikuri HV, Mahaux V, Bloch-Thomsen PE. Cardiac arrhythmias and risk stratification after myocardial infarction: results of the CARISMA pilot study. Pacing Clin Electrophysiol. Jan. 2003;26(1 Pt 2):416-9. X-1,X-5,X-6. [pmid: 12687857].
1332 Huikuri HV, Makikallio TH, Raatikainen MJ, et al. Prediction of sudden cardiac death: appraisal of the studies and methods assessing the risk of sudden arrhythmic death. Circulation. Jul. 8. 2003;108(1):110-5. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12847054].
1333 Huittinen T, Leinonen M, Tenkanen L, et al. Autoimmunity to human heat shock protein 60, Chlamydia pneumoniae infection, and inflammation in predicting coronary risk. Arterioscler Thromb Vasc Biol. Mar. 1. 2002;22(3):431-7. X-5,X-8. [pmid: 11884286].
1334 Hula W, Doyle PJ, McNeil MR, et al. Rasch modeling of revised token test performance: validity and sensitivity to change. J Speech Lang Hear Res. Feb. 2006;49(1):27-46. X-1,X-6,X-7,X-8. [pmid: 16533071].
1335 Hulzebos EH, Van Meeteren NL, De Bie RA, et al. Prediction of postoperative pulmonary complications on the basis of preoperative risk factors in patients who had undergone coronary artery bypass graft surgery. Phys Ther. Jan. 2003;83(1):8-16. X-1,X-2,X-6,X-7,X-8. [pmid: 12495408].
1336 Humphries KH, Westendorp IC, Bots ML, et al. Parity and carotid artery atherosclerosis in elderly women: The Rotterdam Study. Stroke. Oct. 2001;32(10):2259-64. X-1,X-6. [pmid: 11588310].
1337 Humphries SE, Ridker PM, Talmud PJ. Genetic testing for cardiovascular disease susceptibility: a useful clinical management tool or possible misinformation?. Arterioscler Thromb Vasc Biol. Apr. 2004;24(4):628-36. X-1,X-2,X-4,X-5,X-6. [pmid: 14715642].
1338 Hundley WG, Morgan TM, Neagle CM, et al. Magnetic resonance imaging determination of cardiac prognosis. Circulation. Oct. 29. 2002;106(18):2328-33. X-1. [pmid: 12403662].
1339 Hung HC, Joshipura KJ, Jiang R, et al. Fruit and vegetable intake and risk of major chronic disease. J Natl Cancer Inst. Nov. 3. 2004;96(21):1577-84. X-1,X-2. [pmid: 15523086].
1340 Hung J, Beilby JP, Knuiman MW, et al. Folate and vitamin B-12 and risk of fatal cardiovascular disease: cohort study from Busselton, Western Australia. BMJ. Jan. 18. 2003;326(7381):131. X-1,X-2,X-8. [pmid: 12531843].
1341 Hung J, Knuiman MW, Divitini ML, et al. Prevalence and risk factor correlates of elevated C-reactive protein in an adult Australian population. Am J Cardiol. Jan. 15. 2008;101(2):193-8. X-1,X-2,X-5,X-6. [pmid: 18178405].
1342 Hung J, McQuillan BM, Nidorf M, et al. Angiotensin-converting enzyme gene polymorphism and carotid wall thickening in a community population. Arterioscler Thromb Vasc Biol. Aug. 1999;19(8):1969-74. X-1,X-5,X-6. [pmid: 10446079].
1343 Hung MJ, Cherng WJ, Cheng CW. Increased volume reduction of late left-atrial emptying for patients with pseudonormal mitral inflow: an analysis for differentiation between normal and pseudonormal mitral inflow. Echocardiography. Nov. 2003;20(8):703-9. X-1,X-5,X-6,X-7,X-8. [pmid: 14641374].
1344 Hunt KJ, Evans GW, Folsom AR, et al. Acoustic shadowing on B-mode ultrasound of the carotid artery predicts ischemic stroke: the Atherosclerosis Risk in Communities (ARIC) study. Stroke. May. 2001;32(5):1120-6. X-1F,X-2. [pmid: 11340220].
1345 Hunt ME, O'Malley PG, Feuerstein I, et al. The relationship between the ‘metabolic score’ and sub-clinical atherosclerosis detected with electron beam computed tomography. Coron Artery Dis. Jun. 2003;14(4):317-22. X-1,X-5,X-6. [pmid: 12826931].
1346 Hunt SC, Gwinn M, Adams TD. Family history assessment: strategies for prevention of cardiovascular disease. Am J Prev Med. Feb. 2003;24(2):136-42. X-1,X-4. [pmid: 12568819].
1347 Hunziker PR, Imsand C, Keller D, et al. Bedside quantification of atherosclerosis severity for cardiovascular risk stratification: a prospective cohort study. J Am Coll Cardiol. Feb. 20. 2002;39(4):702-9. X-1,X-2,X-8. [pmid: 11849872].
1348 Hur C, Simon LS, Gazelle GS. Analysis of aspirin-associated risks in healthy individuals. Ann Pharmacother. Jan. 2005;39(1):51-7. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15590881].
1349 Husmann L, Scheffel H, Valenta I, et al. Impact of hypertension on the diagnostic accuracy of coronary angiography with computed tomography. Int J Cardiovasc Imaging. Oct. 2008;24(7):763-70. X-1,X-2,X-6,X-7,X-8. [pmid: 18369738].
1350 Husmann L, Schepis T, Scheffel H, et al. Comparison of diagnostic accuracy of 64-slice computed tomography coronary angiography in patients with low, intermediate, and high cardiovascular risk. Acad Radiol. Apr. 2008;15(4):452-61. X-7. [pmid: 18342770].
1351 Hussain T, Burch M, Fenton MJ, et al. Positive pretransplantation cytomegalovirus serology is a risk factor for cardiac allograft vasculopathy in children. Circulation. Apr. 3. 2007;115(13):1798-805. X-1,X-5,X-6,X-7. [pmid: 17353448].
1352 Hutfless R, Kazanegra R, Madani M, et al. Utility of B-type natriuretic peptide in predicting postoperative complications and outcomes in patients undergoing heart surgery. J Am Coll Cardiol. May. 19. 2004;43(10):1873-9. X-1,X-7,X-8. [pmid: 15145114].
1353 Huxley R, Woodward M, Barzi F, et al. Does sex matter in the associations between classic risk factors and fatal coronary heart disease in populations from the Asia-Pacific region?. J Womens Health (Larchmt). Nov. 2005;14(9):820-8. X-4,X-5,X-8. [pmid: 16313209].
1354 Huynh BC, Rovner A, Rich MW. Long-term survival in elderly patients hospitalized for heart failure: 14-year follow-up from a prospective randomized trial. Arch Intern Med. Sep. 25. 2006;166(17):1892-8. X-1,X-6,X-8. [pmid: 17000947].
1355 Hwu CM, Fuh JL, Hsiao CF, et al. Waist circumference predicts metabolic cardiovascular risk in postmenopausal Chinese women. Menopause. Jan-Feb. 2003;10(1):73-80. X-1,X-5,X-6,X-8. [pmid: 12544680].
1356 Iacoviello M, Forleo C, Guida P, et al. Ventricular repolarization dynamicity provides independent prognostic information toward major arrhythmic events in patients with idiopathic dilated cardiomyopathy. J Am Coll Cardiol. Jul. 17. 2007;50(3):225-31. X-1,X-6,X-7. [pmid: 17631214].
1357 I'Allemand D, Wiegand S, Reinehr T, et al. Cardiovascular risk in 26,008 European overweight children as established by a multicenter database. Obesity (Silver Spring). Jul. 2008;16(7):1672-9. X-1,X-6. [pmid: 18451769].
1358 Ibanez J, Riera M, Saez de Ibarra JI, et al. Effect of preoperative mild renal dysfunction on mortality and morbidity following valve cardiac surgery. Interact Cardiovasc Thorac Surg. Dec. 2007;6(6):748-52. X-1,X-2,X-5,X-8. [pmid: 17890235].
1359 Idicula TT, Waje-Andreassen U, Brogger J, et al. The effect of physiologic derangement in patients with stroke treated with thrombolysis. J Stroke Cerebrovasc Dis. May-Jun. 2008;17(3):141-6. X-1,X-2,X-6,X-7,X-8. [pmid: 18436155].
1360 Idorn L, Hofsten DE, Wachtell K, et al. Prevalence and prognostic implications of ST-segment deviations from ambulatory Holter monitoring after ST-segment elevation myocardial infarction treated with either fibrinolysis or primary percutaneous coronary intervention (a Danish Trial in Acute Myocardial Infarction-2 Substudy). Am J Cardiol. Sep. 15. 2007;100(6):937-43. X-1,X-6,X-8. [pmid: 17826373].
1361 Idris I, Deepa R, Fernando DJ, et al. Relation between age and coronary heart disease (CHD) risk in Asian Indian patients with diabetes: A cross-sectional and prospective cohort study. Diabetes Res Clin Pract. Aug. 2008;81(2):243-9. X-1F,X-5. [pmid: 18495288].
1362 Ikeda A, Iso H, Kawachi I, et al. Type A behaviour and risk of coronary heart disease: the JPHC Study. Int J Epidemiol. Dec. 2008;37(6):1395-405. discussion 1406-7. X-1,X-2. [pmid: 18593749].
1363 Ikeda T, Yoshino H, Sugi K, et al. Predictive value of microvolt T-wave alternans for sudden cardiac death in patients with preserved cardiac function after acute myocardial infarction: results of a collaborative cohort study. J Am Coll Cardiol. Dec. 5. 2006;48(11):2268-74. X-1,X-2,X-6,X-8. [pmid: 17161258].
1364 Ilva T, Eriksson S, Lund J, et al. Improved early risk stratification and diagnosis of myocardial infarction, using a novel troponin I assay concept. Eur J Clin Invest. Feb. 2005;35(2):112-6. X-1,X-8. [pmid: 15667582].
1365 Imai Y, Morita H, Kurihara H, et al. Evidence for association between paraoxonase gene polymorphisms and atherosclerotic diseases. Atherosclerosis. Apr. 2000;149(2):435-42. X-1,X-2,X-5. [pmid: 10729395].
1366 Immer F, Habicht J, Nessensohn K, et al. Prospective evaluation of 3 risk stratification scores in cardiac surgery. Thorac Cardiovasc Surg. Jun. 2000;48(3):134-9. X-1,X-8. [pmid: 10903058].
1367 Imperatore G, Cadwell BL, Geiss L, et al. Thirty-year trends in cardiovascular risk factor levels among US adults with diabetes: National Health and Nutrition Examination Surveys, 1971-2000. Am J Epidemiol. Sep. 15. 2004;160(6):531-9. X-1,X-2,X-5,X-6. [pmid: 15353413].
1368 Inaba Y, Bergmann SR. Diagnostic accuracy of beta-methyl-p-[123I]-iodophenyl-pentadecanoic acid (BMIPP) imaging: a meta-analysis. J Nucl Cardiol. May-Jun. 2008;15(3):345-52. X-1,X-5. [pmid: 18513641].
1369 Inaguma D, Nagaya H, Hara K, et al. Relationship between serum 1,25-dihydroxyvitamin D and mortality in patients with pre-dialysis chronic kidney disease. Clin Exp Nephrol. Apr. 2008;12(2):126-31. X-1,X-2,X-8. [pmid: 18180871].
1370 Inama G, Pedrinazzi C, Durin O, et al. Microvolt T-wave alternans for risk stratification in athletes with ventricular arrhythmias: correlation with programmed ventricular stimulation. Ann Noninvasive Electrocardiol. Jan. 2008;13(1):14-21. X-1,X-2,X-6,X-7. [pmid: 18234002].
1371 Ingelsson E, Gona P, Larson MG, et al. Altered blood pressure progression in the community and its relation to clinical events. Arch Intern Med. Jul. 14. 2008;168(13):1450-7. X-1,X-2,X-6. [pmid: 18625926].
1372 Ingelsson E, Schaefer EJ, Contois JH, et al. Clinical utility of different lipid measures for prediction of coronary heart disease in men and women. JAMA. Aug. 15. 2007;298(7):776-85. X-1. [pmid: 17699011].
1373 Ingul CB, Stoylen A, Slordahl SA, et al. Automated analysis of myocardial deformation at dobutamine stress echocardiography: an angiographic validation. J Am Coll Cardiol. Apr. 17. 2007;49(15):1651-9. X-1,X-5,X-6,X-7. [pmid: 17433958].
1374 Inoue T, Matsunaga R, Morooka S, et al. Serum N-acetyl-beta-D-gulucosaminidase activity increases in association with insulin resistance in patients with coronary artery disease. Atherosclerosis. Mar. 2000;149(1):117-22. X-1,X-2,X-5,X-7. [pmid: 10704622].
1375 Ioannou GN, Weiss NS, Boyko EJ, et al. Elevated serum alanine aminotransferase activity and calculated risk of coronary heart disease in the United States. Hepatology. May. 2006;43(5):1145-51. X-1,X-5,X-6. [pmid: 16628637].
1376 Iqbal R, Anand S, Ounpuu S, et al. Dietary patterns and the risk of acute myocardial infarction in 52 countries: results of the INTERHEART study. Circulation. Nov. 4. 2008;118(19):1929-37. X-1,X-2,X-5,X-8. [pmid: 18936332].
1377 Irace C, Cortese C, Fiaschi E, et al. Wall shear stress is associated with intima-media thickness and carotid atherosclerosis in subjects at low coronary heart disease risk. Stroke. Feb. 2004;35(2):464-8. X-1,X-2,X-5,X-6. [pmid: 14726547].
1378 Iribarren C, Darbinian JA, Lo JC, et al. Value of the sagittal abdominal diameter in coronary heart disease risk assessment: cohort study in a large, multiethnic population. Am J Epidemiol. Dec. 15. 2006;164(12):1150-9. X-1F,X-2. [pmid: 17041127].
1379 Iribarren C, Go AS, Tolstykh I, et al. Breast vascular calcification and risk of coronary heart disease, stroke, and heart failure. J Womens Health (Larchmt). May. 2004;13(4):381-9. discussion 390-2. X-1,X-2. [pmid: 15186654].
1380 Iribarren JL, Sagasti FM, Jimenez JJ, et al. TNFbeta+250 polymorphism and hyperdynamic state in cardiac surgery with extracorporeal circulation. Interact Cardiovasc Thorac Surg. Dec. 2008;7(6):1071-4. X-1,X-2,X-6,X-7,X-8. [pmid: 18805892].
1381 Isaacs A, Sayed-Tabatabaei FA, Hofman A, et al. The cholesteryl ester transfer protein I405V polymorphism is associated with increased high-density lipoprotein levels and decreased risk of myocardial infarction: the Rotterdam Study. Eur J Cardiovasc Prev Rehabil. Jun. 2007;14(3):419-21. X-1,X-2,X-5,X-6,X-8. [pmid: 17568242].
1382 Isgum I, Rutten A, Prokop M, et al. Detection of coronary calcifications from computed tomography scans for automated risk assessment of coronary artery disease. Med Phys. Apr. 2007;34(4):1450-61. X-1,X-2,X-5,X-6,X-7. [pmid: 17500476].
1383 Ishani A, Grandits GA, Grimm RH, et al. Association of single measurements of dipstick proteinuria, estimated glomerular filtration rate, and hematocrit with 25-year incidence of end-stage renal disease in the multiple risk factor intervention trial. J Am Soc Nephrol. May. 2006;17(5):1444-52. X-1,X-6. [pmid: 16611715].
1384 Ishizaki T, Imanaka Y, Sekimoto M, et al. Comparisons of risk-adjusted clinical outcomes for patients with aneurysmal subarachnoid haemorrhage across eight teaching hospitals in Japan. J Eval Clin Pract. Jun. 2008;14(3):416-21. X-1,X-6,X-8. [pmid: 18373576].
1385 Ismeno G, Falco A, Tritto FP, et al. The use of “LAST” operation in high risk patient. Monaldi Arch Chest Dis. Mar. 2006;66(1):3-7. X-1,X-2,X-6,X-7,X-8. [pmid: 17125040].
1386 Ivanov J, Borger MA, Rao V, et al. The Toronto Risk Score for adverse events following cardiac surgery. Can J Cardiol. Mar. 1. 2006;22(3):221-7. X-1,X-8. [pmid: 16520853].
1387 Ivanov J, Tu JV, Naylor CD. Ready-made, recalibrated, or Remodeled? Issues in the use of risk indexes for assessing mortality after coronary artery bypass graft surgery. Circulation. Apr. 27. 1999;99(16):2098-104. X-1,X-4,X-5,X-6. [pmid: 10217648].
1388 Ivascu FA, Howells GA, Junn FS, et al. Predictors of mortality in trauma patients with intracranial hemorrhage on preinjury aspirin or clopidogrel. J Trauma. Oct. 2008;65(4):785-8. X-1,X-2,X-6,X-7. [pmid: 18849791].
1389 Ivey SL, Mehta KM, Fyr CL, et al. Prevalence and correlates of cardiovascular risk factors in South Asians: population-based data from two California surveys. Ethn Dis. Autumn. 2006;16(4):886-93. X-2,X-5,X-6. [pmid: 17061742].
1390 Iwashita M, Matsushita Y, Sasaki J, et al. Relation of serum total cholesterol and other risk factors to risk of coronary events in middle-aged and elderly Japanese men with hypercholesterolemia: the Kyushu Lipid Intervention Study. Circ J. May. 2004;68(5):405-9. X-1F,X-2. [pmid: 15118279].
1391 Ix JH, Mercado N, Shlipak MG, et al. Association of chronic kidney disease with clinical outcomes after coronary revascularization: the Arterial Revascularization Therapies Study (ARTS). Am Heart J. Mar. 2005;149(3):512-9. X-1,X-8. [pmid: 15864241].
1392 Jacob G, Noble JA, Behrenbruch C, et al. A shape-space-based approach to tracking myocardial borders and quantifying regional left-ventricular function applied in echocardiography. IEEE Trans Med Imaging. Mar. 2002;21(3):226-38. X-1,X-2,X-6,X-7. [pmid: 11989847].
1393 Jacoby DS, Mohler IE, Rader DJ. Noninvasive atherosclerosis imaging for predicting cardiovascular events and assessing therapeutic interventions. Curr Atheroscler Rep. Jan. 2004;6(1):20-6. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 14662104].
1394 Jafary FH, Arham AZ, Waqar F, et al. Survival of patients receiving fibrinolytic therapy for acute ST-segment elevation myocardial infarction in a developing country - patient characteristics and predictors of mortality. J Thromb Thrombolysis. Oct. 2008;26(2):147-9. X-1,X-2,X-6,X-8. [pmid: 17965962].
1395 Jaffe AS, Krumholz HM, Catellier DJ, et al. Prediction of medical morbidity and mortality after acute myocardial infarction in patients at increased psychosocial risk in the Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) study. Am Heart J. Jul. 2006;152(1):126-35. X-1,X-8. [pmid: 16824842].
1396 Jaffery Z, Hudson MP, Jacobsen G, et al. Modified thrombolysis in myocardial infarction (TIMI) risk score to risk stratify patients in the emergency department with possible acute coronary syndrome. J Thromb Thrombolysis. Oct. 2007;24(2):137-44. X-1F,X-8. [pmid: 17318424].
1397 Jager A, Kostense PJ, Ruhe HG, et al. Microalbuminuria and peripheral arterial disease are independent predictors of cardiovascular and all-cause mortality, especially among hypertensive subjects: five-year follow-up of the Hoorn Study. Arterioscler Thromb Vasc Biol. Mar. 1999;19(3):617-24. X-1,X-6. [pmid: 10073965].
1398 Jagsi R, Griffith KA, Koelling T, et al. Rates of myocardial infarction and coronary artery disease and risk factors in patients treated with radiation therapy for early-stage breast cancer. Cancer. Feb. 15. 2007;109(4):650-7. X-1. [pmid: 17238178].
1399 Jain D, Wegscheider K, Hartmann F, et al. Differential outcome after intracoronary radiation therapy is related to a simple classification based on lesion length and diameter. J Invasive Cardiol. May. 2005;17(5):256-61. X-1,X-6,X-8. [pmid: 15879605].
1400 Jain T, Peshock R, McGuire DK, et al. African Americans and Caucasians have a similar prevalence of coronary calcium in the Dallas Heart Study. J Am Coll Cardiol. Sep. 1. 2004;44(5):1011-7. X-1,X-2,X-5,X-6. [pmid: 15337212].
1401 Jakobsen MU, Overvad K, Dyerberg J, et al. Intake of ruminant trans fatty acids and risk of coronary heart disease. Int J Epidemiol. Feb. 2008;37(1):173-82. X-1G,X-2. [pmid: 18077475].
1402 James AL, Knuiman MW, Divitini ML, et al. Associations between white blood cell count, lung function, respiratory illness and mortality: the Busselton Health Study. Eur Respir J. May. 1999;13(5):1115-9. X-1,X-6. [pmid: 10414413].
1403 James PA, Li P, Ward MM. Myocardial infarction mortality in rural and urban hospitals: rethinking measures of quality of care. Ann Fam Med. Mar-Apr. 2007;5(2):105-11. X-1,X-2,X-6,X-8. [pmid: 17389533].
1404 James SK, Armstrong P, Barnathan E, et al. Troponin and C-reactive protein have different relations to subsequent mortality and myocardial infarction after acute coronary syndrome: a GUSTO-IV substudy. J Am Coll Cardiol. Mar. 19. 2003;41(6):916-24. X-1,X-6,X-8. [pmid: 12651034].
1405 James SK, Lindahl B, Armstrong P, et al. A rapid troponin I assay is not optimal for determination of troponin status and prediction of subsequent cardiac events at suspicion of unstable coronary syndromes. Int J Cardiol. Feb. 2004;93(2-3):113-20. X-1,X-2,X-5,X-6,X-8. [pmid: 14975536].
1406 James SK, Lindahl B, Siegbahn A, et al. N-terminal pro-brain natriuretic peptide and other risk markers for the separate prediction of mortality and subsequent myocardial infarction in patients with unstable coronary artery disease: a Global Utilization of Strategies To Open occluded arteries (GUSTO)-IV substudy. Circulation. Jul. 22. 2003;108(3):275-81. X-1,X-2,X-8. [pmid: 12847065].
1407 James SK, Lindahl B, Timmer JR, et al. Usefulness of biomarkers for predicting long-term mortality in patients with diabetes mellitus and non-ST-elevation acute coronary syndromes (a GUSTO IV substudy). Am J Cardiol. Jan. 15. 2006;97(2):167-72. X-1,X-6,X-8. [pmid: 16442356].
1408 James SK, Lindback J, Tilly J, et al. Troponin-T and N-terminal pro-B-type natriuretic peptide predict mortality benefit from coronary revascularization in acute coronary syndromes: a GUSTO-IV substudy. J Am Coll Cardiol. Sep. 19. 2006;48(6):1146-54. X-1,X-8. [pmid: 16978997].
1409 Jamieson WR, Edwards FH, Schwartz M, et al. Risk stratification for cardiac valve replacement. National Cardiac Surgery Database. Database Committee of The Society of Thoracic Surgeons. Ann Thorac Surg. Apr. 1999;67(4):943-51. X-1,X-6,X-8. [pmid: 10320233].
1410 Janardhan V, Wolf PA, Kase CS, et al. Anticardiolipin antibodies and risk of ischemic stroke and transient ischemic attack: the Framingham cohort and offspring study. Stroke. Mar. 2004;35(3):736-41. X-1,X-2. [pmid: 14764933].
1411 Janardhanan R, Kenchaiah S, Velazquez EJ, et al. Extent of coronary artery disease as a predictor of outcomes in acute myocardial infarction complicated by heart failure, left ventricular dysfunction, or both. Am Heart J. Jul. 2006;152(1):183-9. X-1,X-8. [pmid: 16824854].
1412 Janssen DP, Noyez L, van Druten JA, et al. Predictors of nephrological morbidity after coronary artery bypass surgery. Cardiovasc Surg. Jun. 2002;10(3):222-7. X-1,X-6,X-8. [pmid: 12044429].
1413 Janssen I, Katzmarzyk PT, Church TS, et al. The Cooper Clinic Mortality Risk Index: clinical score sheet for men. Am J Prev Med. Oct. 2005;29(3):194-203. X-6. [pmid: 16168868].
1414 Jansson L, Lavstedt S, Frithiof L. Relationship between oral health and mortality rate. J Clin Periodontol. Nov. 2002;29(11):1029-34. X-1,X-2,X-6. [pmid: 12472996].
1415 Janszky I, Ericson M, Mittleman MA, et al. Heart rate variability in long-term risk assessment in middle-aged women with coronary heart disease: The Stockholm Female Coronary Risk Study. J Intern Med. Jan. 2004;255(1):13-21. X-1,X-8. [pmid: 14687234].
1416 Januzzi JL Jr, Newby LK, Murphy SA, et al. Predicting a late positive serum troponin in initially troponin-negative patients with non-ST-elevation acute coronary syndrome: clinical predictors and validated risk score results from the TIMI IIIB and GUSTO IIA studies. Am Heart J. Feb. 2006;151(2):360-6. X-1,X-6,X-8. [pmid: 16442899].
1417 Jault F, Rama A, Bonnet N, et al. Cardiac surgery in patients receiving long term hemodialysis. Short and long term results. J Cardiovasc Surg (Torino). Dec. 2003;44(6):725-30. X-1,X-2,X-5,X-6,X-7,X-8.
1418 Jeetley P, Burden L, Greaves K, et al. Prognostic value of myocardial contrast echocardiography in patients presenting to hospital with acute chest pain and negative troponin. Am J Cardiol. May. 15. 2007;99(10):1369-73. X-1,X-7. [pmid: 17493462].
1419 Jegaden O, de Gevigney G, Farhat F, et al. Limits of arterial myocardial revascularization. J Card Surg. Mar-Apr. 2003;18(2):147-52. X-1,X-5,X-6. [pmid: 12757342].
1420 Jeger RV, Bonetti PO, Zellweger MJ, et al. Influence of revascularization on long-term outcome in patients > or =75 years of age with diabetes mellitus and angina pectoris. Am J Cardiol. Jul. 15. 2005;96(2):193-8. X-1,X-8. [pmid: 16018840].
1421 Jehkonen M, Ahonen JP, Dastidar P, et al. Visual neglect as a predictor of functional outcome one year after stroke. Acta Neurol Scand. Mar. 2000;101(3):195-201. X-1,X-6,X-7,X-8. [pmid: 10705943].
1422 Jensen BT, Abildstrom SZ, Larroude CE, et al. QT dynamics in risk stratification after myocardial infarction. Heart Rhythm. Apr. 2005;2(4):357-64. X-1,X-8. [pmid: 15851335].
1423 Jensen J, Eriksson SV, Lindvall B, et al. On-line vectorcardiography during elective coronary angioplasty indicates procedure-related myocardial infarction. Coron Artery Dis. Mar. 2000;11(2):161-9. X-1,X-2,X-7,X-8. [pmid: 10758818].
1424 Jensen L, Yang L. Risk factors for postoperative pulmonary complications in coronary artery bypass graft surgery patients. Eur J Cardiovasc Nurs. Sep. 2007;6(3):241-6. X-1,X-8. [pmid: 17347049].
1425 Jensen LO, Maeng M, Kaltoft A, et al. Stent thrombosis, myocardial infarction, and death after drug-eluting and bare-metal stent coronary interventions. J Am Coll Cardiol. Jul. 31. 2007;50(5):463-70. X-1,X-8. [pmid: 17662400].
1426 Jensen LO, Thayssen P, Kassis E, et al. Target vessel revascularization following percutaneous coronary intervention. A 10-year report from the Danish Percutaneous Transluminal Coronary Angioplasty Registry. Scand Cardiovasc J. Apr. 2005;39(1-2):30-5. X-1,X-6,X-8. [pmid: 16097411].
1427 Jensen MS, Thomsen JL, Jensen SE, et al. Electrocardiogram interpretation in general practice. Fam Pract. Feb. 2005;22(1):109-13. X-1,X-5,X-6,X-8. [pmid: 15528292].
1428 Jensen-Urstad M, Samad BA, Jensen-Urstad K, et al. Risk assessment in patients with acute myocardial infarction treated with thrombolytic therapy. J Intern Med. Jun. 2001;249(6):527-37. X-1,X-6,X-7,X-8. [pmid: 11422659].
1429 Jeon DS, Atar S, Brasch AV, et al. Association of mitral annulus calcification, aortic valve sclerosis and aortic root calcification with abnormal myocardial perfusion single photon emission tomography in subjects age < or =65 years old. J Am Coll Cardiol. Dec. 2001;38(7):1988-93. X-1,X-2,X-5,X-6. [pmid: 11738305].
1430 Jeon HW, Cha JK. Factors related to progression of middle cerebral artery stenosis determined using transcranial Doppler ultrasonograhy. J Thromb Thrombolysis. Jun. 2008;25(3):265-9. X-1,X-4,X-5,X-6,X-7,X-8. [pmid: 17541765].
1431 Jeppesen J, Hansen TW, Olsen MH, et al. C-reactive protein, insulin resistance and risk of cardiovascular disease: a population-based study. Eur J Cardiovasc Prev Rehabil. Oct. 2008;15(5):594-8. X-2. [pmid: 18753952].
1432 Jeppesen J, Hansen TW, Rasmussen S, et al. Insulin resistance, the metabolic syndrome, and risk of incident cardiovascular disease: a population-based study. J Am Coll Cardiol. May. 29. 2007;49(21):2112-9. X-1F,X-2. [pmid: 17531661].
1433 Jeppesen J, Hein HO, Suadicani P, et al. High triglycerides/low high-density lipoprotein cholesterol, ischemic electrocardiogram changes, and risk of ischemic heart disease. Am Heart J. Jan. 2003;145(1):103-8. X-2. [pmid: 12514661].
1434 Jernberg T, Cronblad J, Lindahl B, et al. Observer variability and optimal criteria of transient ischemia during ST monitoring with continuous 12-lead ECG. Ann Noninvasive Electrocardiol. Jul. 2002;7(3):181-90. X-1,X-7,X-8. [pmid: 12167177].
1435 Jernberg T, James S, Lindahl B, et al. Natriuretic peptides in unstable coronary artery disease. Eur Heart J. Sep. 2004;25(17):1486-93. X-1,X-2,X-4,X-5. [pmid: 15342167].
1436 Jernberg T, Lindahl B. A combination of troponin T and 12-lead electrocardiography: a valuable tool for early prediction of long-term mortality in patients with chest pain without ST-segment elevation. Am Heart J. Nov. 2002;144(5):804-10. X-1,X-8. [pmid: 12422148].
1437 Jha AK, Epstein AM. The predictive accuracy of the New York State coronary artery bypass surgery report-card system. Health Aff (Millwood). May-Jun. 2006;25(3):844-55. X-1,X-2,X-5,X-6,X-8. [pmid: 16684751].
1438 Jha HC, Vardhan H, Gupta R, et al. Higher incidence of persistent chronic infection of Chlamydia pneumoniae among coronary artery disease patients in India is a cause of concern. BMC Infect Dis. 2007;7:48. X-1,X-2,X-5,X-6,X-7. [pmid: 17537253].
1439 Jiang R, Schulze MB, Li T, et al. Non-HDL cholesterol and apolipoprotein B predict cardiovascular disease events among men with type 2 diabetes. Diabetes Care. Aug. 2004;27(8):1991-7. X-1F. [pmid: 15277429].
1440 Jiang WJ, Xu XT, Du B, et al. Comparison of elective stenting of severe vs moderate intracranial atherosclerotic stenosis. Neurology. Feb. 6. 2007;68(6):420-6. X-1,X-8. [pmid: 17283316].
1441 Jilcott SB, Keyserling TC, Samuel-Hodge CD, et al. Validation of a brief dietary assessment to guide counseling for cardiovascular disease risk reduction in an underserved population. J Am Diet Assoc. Feb. 2007;107(2):246-55. X-1,X-6. [pmid: 17258961].
1442 Jimenez-Candil J, Gonzalez IC, Gonzalez Matas JM, et al. Short- and long-term prognostic value of the corrected QT interval in the non-ST-elevation acute coronary syndrome. J Electrocardiol. Apr. 2007;40(2):180-7. X-1,X-8. [pmid: 17254595].
1443 Jin J, Huang L, Wang H, et al. Value of myocardial regional perfusion on long-term function in collateral-dependent myocardium. South Med J. Sep. 2008;101(9):894-9. X-1,X-2,X-6,X-8. [pmid: 18708956].
1444 Jin R, Grunkemeier GL, Starr A. Validation and refinement of mortality risk models for heart valve surgery. Ann Thorac Surg. Aug. 2005;80(2):471-9. X-1. [pmid: 16039188].
1445 Johannes CB, Koro CE, Quinn SG, et al. The risk of coronary heart disease in type 2 diabetic patients exposed to thiazolidinediones compared to metformin and sulfonylurea therapy. Pharmacoepidemiol Drug Saf. May. 2007;16(5):504-12. X-1. [pmid: 17245800].
1446 Johansen A, Hoilund-Carlsen PF, Christensen HW, et al. Observer variability in the evaluation of dual-isotope Tl-201/Tc-99m sestamibi rest/stress myocardial perfusion SPECT in men and women with known or suspected stable angina pectoris. J Nucl Cardiol. Nov-Dec. 2004;11(6):710-8. X-1X-5,X-6,X-8. [pmid: 15592195].
1447 Johanson P, Jernberg T, Gunnarsson G, et al. Prognostic value of ST-segment resolution-when and what to measure. Eur Heart J. Feb. 2003;24(4):337-45. X-1,X-5,X-6. [pmid: 12581681].
1448 Johnsen SH, Joakimsen O, Fosse E, et al. Sex differences in plaque morphology may explain the higher male prevalence of myocardial infarction compared to angina pectoris. The Tromso Study Scand Cardiovasc J. Apr. 2005;39(1-2):36-41. X-1,X-2,X-5.
1449 Johnsen SP, Overvad K, Sorensen HT, et al. Predictive value of stroke and transient ischemic attack discharge diagnoses in The Danish National Registry of Patients. J Clin Epidemiol. Jun. 2002;55(6):602-7. X-1,X-2,X-8. [pmid: 12063102].
1450 Johnston KC, Connors AF Jr, Wagner DP, et al. Risk adjustment effect on stroke clinical trials. Stroke. Feb. 2004;35(2):e43-5. X-1. [pmid: 14715975].
1451 Johnston KC, Wagner DP, Wang XQ, et al. Validation of an acute ischemic stroke model: does diffusion-weighted imaging lesion volume offer a clinically significant improvement in prediction of outcome?. Stroke. Jun. 2007;38(6):1820-5. X-1,X-5,X-6,X-8. [pmid: 17446421].
1452 Johnston SC, Rothwell PM, Nguyen-Huynh MN, et al. Validation and refinement of scores to predict very early stroke risk after transient ischaemic attack. Lancet. Jan. 27. 2007;369(9558):283-92. X-1,X-8. [pmid: 17258668].
1453 Johnston TC, Coory MD, Scott I, et al. Should we add clinical variables to administrative data?: The case of risk-adjusted case fatality rates after admission for acute myocardial infarction. Med Care. Dec. 2007;45(12):1180-5. X-1,X-5,X-6,X-8. [pmid: 18007168].
1454 Joki N, Hase H, Takahashi Y, et al. Angiographical severity of coronary atherosclerosis predicts death in the first year of hemodialysis. Int Urol Nephrol. 2003;35(2):289-97. X-1,X-2,X-5,X-7. [pmid: 15072511].
1455 Jokinen JJ, Mustonen PK, Hippelainen MJ, et al. Effects of coronary artery bypass related conduction defects: a 10-year follow-up study. Scand Cardiovasc J. Aug. 2004;38(4):235-9. X-1,X-2,X-7,X-8. [pmid: 15553935].
1456 Jonas M, Resnic FS, Levin AD, et al. Transition from bare metal to drug eluting stenting in contemporary US practice: effect on incidence and predictors of clinically driven target lesion revascularization. Catheter Cardiovasc Interv. Aug. 1. 2007;70(2):175-83. X-1. [pmid: 17630659].
1457 Jones AF, Walker J, Jewkes C, et al. Comparative accuracy of cardiovascular risk prediction methods in primary care patients. Heart. Jan. 2001;85(1):37-43. X-1,X-2,X-5,X-6,X-8. [pmid: 11119458].
1458 Jones RH. The year in cardiovascular surgery. J Am Coll Cardiol. May. 8. 2007;49(18):1887-98. X-1,X-2,X-4,X-5,X-6,X-7. [pmid: 17481449].
1459 Jorgensen L, Engstad T, Jacobsen BK. Bone mineral density in acute stroke patients: low bone mineral density may predict first stroke in women. Stroke. Jan. 2001;32(1):47-51. X-5,X-8. [pmid: 11136913].
1460 Jorgensen L, Engstad T, Jacobsen BK. Higher incidence of falls in long-term stroke survivors than in population controls: depressive symptoms predict falls after stroke. Stroke. Feb. 2002;33(2):542-7. X-1,X-2,X-5,X-6,X-8. [pmid: 11823667].
1461 Joseph A, Ad S, Srivastava A. PM(10) and its impacts on health - a case study in Mumbai. Int J Environ Health Res. Jun. 2003;13(2):207-14. X-1,X-5,X-6. [pmid: 12745340].
1462 Josephson SA, Sidney S, Pham TN, et al. Factors associated with the decision to hospitalize patients after transient ischemic attack before publication of prediction rules. Stroke. Feb. 2008;39(2):411-3. X-1D,X-2,X-5,X-6,X-8(100%). [pmid: 18096832].
1463 Jousilahti P, Tuomilehto J, Rastenyte D, et al. Headache and the risk of stroke: a prospective observational cohort study among 35,056 Finnish men and women. Arch Intern Med. May. 12. 2003;163(9):1058-62. X-1,X-6. [pmid: 12742803].
1464 Jousilahti P, Vartiainen E, Alho H, et al. Opposite associations of carbohydrate-deficient transferrin and gamma-glutamyltransferase with prevalent coronary heart disease. Arch Intern Med. Apr. 8. 2002;162(7):817-21. X-1,X-2,X-6,X-8. [pmid: 11926857].
1465 Jousilahti P, Vartiainen E, Korhonen HJ, et al. Is the effect of smoking on the risk for coronary heart disease even stronger than was previously thought?. J Cardiovasc Risk. Oct. 1999;6(5):293-8. X-1E,X-1F,X-2. [pmid: 10534130].
1466 Jungner I, Sniderman AD, Furberg C, et al. Does low-density lipoprotein size add to atherogenic particle number in predicting the risk of fatal myocardial infarction?. Am J Cardiol. Apr. 1. 2006;97(7):943-6. X-1F,X-2. [pmid: 16563891].
1467 Juonala M, Viikari JS, Ronnemaa T, et al. Elevated blood pressure in adolescent boys predicts endothelial dysfunction: the cardiovascular risk in young Finns study. Hypertension. Sep. 2006;48(3):424-30. X-6,X-7. [pmid: 16880344].
1468 Jurlander B, Clemmensen P, Wagner GS, et al. Very early diagnosis and risk stratification of patients admitted with suspected acute myocardial infarction by the combined evaluation of a single serum value of cardiac troponin-T, myoglobin, and creatine kinase MB(mass). Eur Heart J. Mar. 2000;21(5):382-9. X-1,X-2,X-7,X-8. [pmid: 10666352].
1469 Juutilainen A, Lehto S, Ronnemaa T, et al. Retinopathy predicts cardiovascular mortality in type 2 diabetic men and women. Diabetes Care. Feb. 2007;30(2):292-9. X-1F,X-1G,X-2. [pmid: 17259497].
1470 Juvela S. Prehemorrhage risk factors for fatal intracranial aneurysm rupture. Stroke. Aug. 2003;34(8):1852-7. X-1,X-6. [pmid: 12829865].
1471 Kabbani SS, Watkins MW, Ashikaga T, et al. Platelet reactivity characterized prospectively: a determinant of outcome 90 days after percutaneous coronary intervention. Circulation. Jul. 10. 2001;104(2):181-6. X-1,X-2,X-7,X-8. [pmid: 11447083].
1472 Kagansky N, Berner Y, Koren-Morag N, et al. Poor nutritional habits are predictors of poor outcome in very old hospitalized patients. Am J Clin Nutr. Oct. 2005;82(4):784-91. quiz 913-4. X-1,X-8. [pmid: 16210707].
1473 Kain K, Catto AJ, Young J, et al. Insulin resistance and elevated levels of tissue plasminogen activator in first-degree relatives of South Asian patients with ischemic cerebrovascular disease. Stroke. May. 2001;32(5):1069-73. X-1,X-5,X-6,X-7. [pmid: 11340211].
1474 Kaiser J. Air pollution risks. Software glitch threw off mortality estimates. Science. Jun. 14. 2002;296(5575):1945-7. X-1. [pmid: 12065806].
1475 Kakkos SK, Stevens JM, Nicolaides AN, et al. Texture analysis of ultrasonic images of symptomatic carotid plaques can identify those plaques associated with ipsilateral embolic brain infarction. Eur J Vasc Endovasc Surg. Apr. 2007;33(4):422-9. X-1,X-2,X-5,X-7. [pmid: 17161964].
1476 Kalahasti V, Nambi V, Martin DO, et al. QRS duration and prediction of mortality in patients undergoing risk stratification for ventricular arrhythmias. Am J Cardiol. Oct. 1. 2003;92(7):798-803. X-1,X-2,X-5. [pmid: 14516879].
1477 Kalinczuk L, Przyluski J, Karcz M, et al. Comparison of prognostic value of epicardial blood flow and early ST-segment resolution after primary coronary angioplasty. ANIN--Myocardial Infarction Registry. Kardiol Pol. Jan. 2007;65(1):1-10. discussion 11-2. X-1,X-8. [pmid: 17295155].
1478 Kalogeropoulos AP, Chiladakis JA, Sihlimiris I, et al. Predischarge QRS score and risk for heart failure after first ST-elevation myocardial infarction. J Card Fail. Apr. 2008;14(3):225-31. X-1,X-7,X-8. [pmid: 18381186].
1479 Kamalesh M, Sawada S, Humphreys A, et al. Prognostic value of negative transesophageal dobutamine stress echocardiography in men at high risk for coronary artery disease. Am J Cardiol. Jan. 1. 2000;85(1):41-4. X-7. [pmid: 11078234].
1480 Kamikawa S, Iwasaki K, Yamamoto K, et al. Significant correlation of recruitable coronary collateral blood flow determined by coronary wedge pressure with ST-segment elevation during coronary occlusion. Coron Artery Dis. Jun. 2005;16(4):231-6. X-1,X-6,X-7,X-8. [pmid: 15915075].
1481 Kammeraad JA, van Deurzen CH, Sreeram N, et al. Predictors of sudden cardiac death after Mustard or Senning repair for transposition of the great arteries. J Am Coll Cardiol. Sep. 1. 2004;44(5):1095-102. X-1,X-2,X-5,X-6,X-7. [pmid: 15337224].
1482 Kang X, Shaw LJ, Hayes SW, et al. Impact of body mass index on cardiac mortality in patients with known or suspected coronary artery disease undergoing myocardial perfusion single-photon emission computed tomography. J Am Coll Cardiol. Apr. 4. 2006;47(7):1418-26. X-1F,X-2,X-5,X-8. [pmid: 16580531].
1483 Kanis J, Oden A, Johnell O. Acute and long-term increase in fracture risk after hospitalization for stroke. Stroke. Mar. 2001;32(3):702-6. X-1,X-2,X-6,X-8. [pmid: 11239190].
1484 Kanjilal S, Rao VS, Mukherjee M, et al. Application of cardiovascular disease risk prediction models and the relevance of novel biomarkers to risk stratification in Asian Indians. Vasc Health Risk Manag. 2008;4(1):199-211. X-1G,X-2,X-5,X-6. [pmid: 18629375].
1485 Kannel WB, D'Agostino RB, Silbershatz H, et al. Profile for estimating risk of heart failure. Arch Intern Med. Jun. 14. 1999;159(11):1197-204. X-1,X-6,X-8. [pmid: 10371227].
1486 Kannel WB, Evans JC, Piper S, et al. Angina pectoris is a stronger indicator of diffuse vascular atherosclerosis than intermittent claudication: Framingham study. J Clin Epidemiol. Sep. 2008;61(9):951-7. X-1E,X-1F,X-2,X-8. [pmid: 18495425].
1487 Kannel WB, Vasan RS, Keyes MJ, et al. Usefulness of the triglyceride-high-density lipoprotein versus the cholesterol-high-density lipoprotein ratio for predicting insulin resistance and cardiometabolic risk (from the Framingham Offspring Cohort). Am J Cardiol. Feb. 15. 2008;101(4):497-501. X-1F. [pmid: 18312765].
1488 Kannel WB, Wilson PW, Nam BH, et al. A likely explanation for the J-curve of blood pressure cardiovascular risk. Am J Cardiol. Aug. 1. 2004;94(3):380-4. X-1. [pmid: 15276113].
1489 Kanwar M, Rosman HS, Fozo PK, et al. Usefulness of carotid ultrasound to improve the ability of stress testing to predict coronary artery disease. Am J Cardiol. May. 1. 2007;99(9):1196-200. X-1,X-5,X-6,X-7,X-8. [pmid: 17478140].
1490 Kapela A, Bezerianos A. A theoretical model of the high-frequency arrhythmogenic depolarization signal following myocardial infarction. IEEE Trans Biomed Eng. Nov. 2004;51(11):1915-22. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15536893].
1491 Kaplan RC, Heckbert SR, Furberg CD, et al. Predictors of subsequent coronary events, stroke, and death among survivors of first hospitalized myocardial infarction. J Clin Epidemiol. Jul. 2002;55(7):654-64. X-1,X-2,X-8. [pmid: 12160913].
1492 Kaplan RC, McGinn AP, Baird AE, et al. Inflammation and hemostasis biomarkers for predicting stroke in postmenopausal women: the Women's Health Initiative Observational Study. J Stroke Cerebrovasc Dis. Nov-Dec. 2008;17(6):344-55. X-5. [pmid: 18984425].
1493 Karalis IK, Alegakis AK, Kafatos AG, et al. Risk factors for ischaemic heart disease in a Cretan rural population: a twelve year follow-up study. BMC Public Health. 2007;7:351. X-2. [pmid: 18088432].
1494 Kardia SL, Modell SM, Peyser PA. Family-centered approaches to understanding and preventing coronary heart disease. Am J Prev Med. Feb. 2003;24(2):143-51. X-2,X-4.
1495 Kardys I, Kors JA, van der Meer IM, et al. Spatial QRS-T angle predicts cardiac death in a general population. Eur Heart J. Jul. 2003;24(14):1357-64. X-1,X-2. [pmid: 12871693].
1496 Karimi A, Ahmadi H, Davoodi S, et al. Early mortality predictors in coronary artery bypass grafting patients required intra-aortic balloon pump in perioperative and postoperative periods. J Cardiovasc Surg (Torino). Feb. 2008;49(1):103-11. X-1,X-2,X-5,X-8.
1497 Karjalainen J, Tikkanen H, Hernelahti M, et al. Muscle fiber-type distribution predicts weight gain and unfavorable left ventricular geometry: a 19 year follow-up study. BMC Cardiovasc Disord. 2006;6:2. X-1,X-6,X-7. [pmid: 16403232].
1498 Karkos CD, Thomson GJ, Hughes R, et al. Prediction of cardiac risk before abdominal aortic reconstruction: comparison of a revised Goldman Cardiac Risk Index and radioisotope ejection fraction. J Vasc Surg. May. 2002;35(5):943-9. X-1,X-7,X-8. [pmid: 12021711].
1499 Karkos CD, Thomson GJ, Hughes R, et al. Prediction of cardiac risk prior to elective abdominal aortic surgery: role of multiple gated acquisition scan. World J Surg. Oct. 2003;27(10):1085-92. X-1,X-5,X-7,X-8. [pmid: 12925903].
1500 Karlsson B, Lax I, Soderman M. Risk for hemorrhage during the 2-year latency period following gamma knife radiosurgery for arteriovenous malformations. Int J Radiat Oncol Biol Phys. Mar. 15. 2001;49(4):1045-51. X-1,X-2. [pmid: 11240246].
1501 Karnath BM. Preoperative cardiac risk assessment. Am Fam Physician. Nov. 15. 2002;66(10):1889-96. X-1,X-2,X-4,X-5,X-6. [pmid: 12469963].
1502 Karp I, Abrahamowicz M, Bartlett G, et al. Updated risk factor values and the ability of the multivariable risk score to predict coronary heart disease. Am J Epidemiol. Oct. 1. 2004;160(7):707-16. X-1. [pmid: 15383415].
1503 Karpansalo M, Manninen P, Lakka TA, et al. Physical workload and risk of early retirement: prospective population-based study among middle-aged men. J Occup Environ Med. Oct. 2002;44(10):930-9. X-1,X-6. [pmid: 12391772].
1504 Karthik S, Srinivasan AK, Grayson AD, et al. Limitations of additive EuroSCORE for measuring risk stratified mortality in combined coronary and valve surgery. Eur J Cardiothorac Surg. Aug. 2004;26(2):318-22. X-1,X-6,X-8. [pmid: 15296890].
1505 Kasai T, Miyauchi K, Kajimoto K, et al. Influence of diabetes on >10-year outcomes after percutaneous coronary intervention. Heart Vessels. May. 2008;23(3):149-54. X-1,X-2,X-8. [pmid: 18484156].
1506 Kasamatsu T, Hashimoto J, Iyatomi H, et al. Application of support vector machine classifiers to preoperative risk stratification with myocardial perfusion scintigraphy. Circ J. Nov. 2008;72(11):1829-35. X-1,X-8. [pmid: 18812675].
1507 Kasimir MT, Bialy J, Moidl R, et al. EuroSCORE predicts mid-term outcome after combined valve and coronary bypass surgery. J Heart Valve Dis. May. 2004;13(3):439-43. X-1,X-8. [pmid: 15222291].
1508 Kasiske BL, Maclean JR, Snyder JJ. Acute myocardial infarction and kidney transplantation. J Am Soc Nephrol. Mar. 2006;17(3):900-7. X-1D,X-2,X-8(100%). [pmid: 16481414].
1509 Kasliwal RR, Bansal M, Bhargava K, et al. Carotid intima-media thickness and brachial-ankle pulse wave velocity in patients with and without coronary artery disease. Indian Heart J. Mar-Apr. 2004;56(2):117-22. X-1,X-5,X-6,X-7. [pmid: 15377132].
1510 Kasner SE, Demchuk AM, Berrouschot J, et al. Predictors of fatal brain edema in massive hemispheric ischemic stroke. Stroke. Sep. 2001;32(9):2117-23. X-1,X-2,X-5,X-6,X-8. [pmid: 11546905].
1511 Kasner SE, Lynn MJ, Jackson BP, et al. Echocardiography in patients with symptomatic intracranial stenosis. J Stroke Cerebrovasc Dis. Sep-Oct. 2007;16(5):216-9. X-1,X-8. [pmid: 17845919].
1512 Kass-Hout TA, Moye LA, Smith MA, et al. A scoring system for ascertainment of incident stroke; the Risk Index Score (RISc). Methods Inf Med. 2006;45(1):27-36. X-1C,X-5,X-8. [pmid: 16482367].
1513 Kastrati A, Mehilli J, Dirschinger J, et al. Intracoronary stenting and angiographic results: strut thickness effect on restenosis outcome (ISAR-STEREO) trial. Circulation. Jun. 12. 2001;103(23):2816-21. X-1,X-2,X-6,X-8. [pmid: 11401938].
1514 Kastrati A, Pache J, Dirschinger J, et al. Primary intracoronary stenting in acute myocardial infarction: long-term clinical and angiographic follow-up and risk factor analysis. Am Heart J. Feb. 2000;139(2 Pt 1):208-16. X-1,X-2,X-8. [pmid: 10650292].
1515 Kathiresan S, Melander O, Anevski D, et al. Polymorphisms associated with cholesterol and risk of cardiovascular events. N Engl J Med. Mar. 20. 2008;358(12):1240-9. X-1G. [pmid: 18354102].
1516 Katrinchak C, Fritz K. Clinical implications of C-reactive protein as a predictor of vascular risk. J Am Acad Nurse Pract. Jul. 2007;19(7):335-40. X-2,X-4,X-5,X-7. [pmid: 17680898].
1517 Katz DA, Aufderheide TP, Bogner M, et al. The impact of unstable angina guidelines in the triage of emergency department patients with possible acute coronary syndrome. Med Decis Making. Nov-Dec. 2006;26(6):606-16. X-1,X-2,X-6,X-8. [pmid: 17099199].
1518 Katz DA, Dawson J, Beshansky JR, et al. Does concordance with guideline triage recommendations affect clinical care of patients with possible acute coronary syndrome?. Med Decis Making. Jul-Aug. 2007;27(4):423-37. X-1,X-6,X-8. [pmid: 17641142].
1519 Katzan IL, Cebul RD, Husak SH, et al. The effect of pneumonia on mortality among patients hospitalized for acute stroke. Neurology. Feb. 25. 2003;60(4):620-5. X-1,X-6. [pmid: 12601102].
1520 Kauffman AB, Delate T, Olson KL, et al. Relationship between haemoglobin A1C values and recurrent cardiac events: A retrospective, longitudinal cohort study. Clin Drug Investig. 2008;28(8):501-7. X-1,X-2,X-8.
1521 Kaufman ES, McNitt S, Moss AJ, et al. Risk of death in the long QT syndrome when a sibling has died. Heart Rhythm. Jun. 2008;5(6):831-6. X-1,X-2. [pmid: 18534367].
1522 Kauhanen L, Lakka HM, Lynch JW, et al. Social disadvantages in childhood and risk of all-cause death and cardiovascular disease in later life: a comparison of historical and retrospective childhood information. Int J Epidemiol. Aug. 2006;35(4):962-8. X-1F,X-2. [pmid: 16556645].
1523 Kaukiainen A, Riala R, Martikainen R, et al. Solvent-related health effects among construction painters with decreasing exposure. Am J Ind Med. Dec. 2004;46(6):627-36. X-1,X-2,X-5,X-6. [pmid: 15551367].
1524 Kaul P, Fu Y, Chang WC, et al. Prognostic value of ST segment depression in acute coronary syndromes: insights from PARAGON-A applied to GUSTO-IIb. PARAGON-A and GUSTO IIb Investigators. Platelet IIb/IIIa Antagonism for the Reduction of Acute Global Organization Network. J Am Coll Cardiol. Jul. 2001;38(1):64-71. X-1,X-8. [pmid: 11451297].
1525 Kavsak PA, Newman AM, Lustig V, et al. Long-term health outcomes associated with detectable troponin I concentrations. Clin Chem. Feb. 2007;53(2):220-7. X-1,X-2,X-8. [pmid: 17204519].
1526 Kawada T, Otsuka T. Relations of body mass index and coronary risk as estimated by the Framingham Risk Score. Percept Mot Skills. Feb. 2006;102(1):254-8. X-1,X-2,X-5,X-6. [pmid: 16671626].
1527 Kawaguchi R, Oshima S, Jingu M, et al. Usefulness of virtual histology intravascular ultrasound to predict distal embolization for ST-segment elevation myocardial infarction. J Am Coll Cardiol. Oct. 23. 2007;50(17):1641-6. X-1,X-2,X-6,X-7,X-8. [pmid: 17950144].
1528 Kawaguchi R, Tsurugaya H, Hoshizaki H, et al. Impact of lesion calcification on clinical and angiographic outcome after sirolimus-eluting stent implantation in real-world patients. Cardiovasc Revasc Med. Jan-Mar. 2008;9(1):2-8. X-1,X-2,X-8. [pmid: 18206630].
1529 Kawasaki T, Azuma A, Sawada T, et al. Electrocardiographic score as a predictor of mortality after subarachnoid hemorrhage. Circ J. Jun. 2002;66(6):567-70. X-1,X-2,X-7,X-8. [pmid: 12074275].
1530 Kazmierski R. Predictors of early mortality in patients with ischemic stroke. Expert Rev Neurother. Sep. 2006;6(9):1349-62. X-1,X-2,X-4,X-5,X-6. [pmid: 17009922].
1531 Kazui T, Osada H, Fujita H. An attempt to analyze the relation between hospital surgical volume and clinical outcome. Gen Thorac Cardiovasc Surg. Dec. 2007;55(12):483-92. X-1,X-2,X-5,X-6,X-8. [pmid: 18066639].
1532 Keavney B, Danesh J, Parish S, et al. Fibrinogen and coronary heart disease: test of causality by ‘Mendelian randomization’. Int J Epidemiol. Aug. 2006;35(4):935-43. X-1,X-5. [pmid: 16870675].
1533 Kechagias A, Perala J, Ylonen K, et al. Validation of the Finnvasc score in infrainguinal percutaneous transluminal angioplasty for critical lower limb ischemia. Ann Vasc Surg. Jul-Aug. 2008;22(4):547-51. X-1. [pmid: 18387781].
1534 Keeling D. Combined oral contraceptives and the risk of myocardial infarction. Ann Med. 2003;35(6):413-8. X-1,X-3,X-4,X-6,X-7,X-8. [pmid: 14572165].
1535 Keevil JG, Cullen MW, Gangnon R, et al. Implications of cardiac risk and low-density lipoprotein cholesterol distributions in the United States for the diagnosis and treatment of dyslipidemia: data from National Health and Nutrition Examination Survey 1999 to 2002. Circulation. Mar. 20. 2007;115(11):1363-70. X-1,X-5,X-6,X-8. [pmid: 17353444].
1536 Keezer MR, Yu AY, Zhu B, et al. Blood pressure and antihypertensive therapy as predictors of early outcome in acute ischemic stroke. Cerebrovasc Dis. 2008;25(3):202-8. X-1,X-2,X-5,X-6,X-8. [pmid: 18212508].
1537 Kelder SH, Osganian SK, Feldman HA, et al. Tracking of physical and physiological risk variables among ethnic subgroups from third to eighth grade: the Child and Adolescent Trial for Cardiovascular Health cohort study. Prev Med. Mar. 2002;34(3):324-33. X-1,X-2,X-6. [pmid: 11902849].
1538 Kelishadi R, Gharipour M, Sadri GH, et al. Cardiovascular disease risk factors, metabolic syndrome and obesity in an Iranian population. East Mediterr Health J. Sep-Oct. 2008;14(5):1070-9. X-1,X-2,X-5,X-6. [pmid: 19161079].
1539 Kelley-Hedgepeth A, Lloyd-Jones DM, Colvin A, et al. Ethnic differences in C-reactive protein concentrations. Clin Chem. Jun. 2008;54(6):1027-37. X-1,X-2,X-5,X-6. [pmid: 18403563].
1540 Kempf T, Bjorklund E, Olofsson S, et al. Growth-differentiation factor-15 improves risk stratification in ST-segment elevation myocardial infarction. Eur Heart J. Dec. 2007;28(23):2858-65. X-1,X-2,X-8. [pmid: 17977844].
1541 Kennedy BS. Does race predict stroke readmission? An analysis using the truncated negative binomial model. J Natl Med Assoc. May. 2005;97(5):699-713. X-1,X-8. [pmid: 15926648].
1542 Kennedy CR, Ayers S, Campbell MJ, et al. Randomized, controlled trial of acetazolamide and furosemide in posthemorrhagic ventricular dilation in infancy: follow-up at 1 year. Pediatrics. Sep. 2001;108(3):597-607. X-1,X-6,X-7,X-8. [pmid: 11533324].
1543 Kennon S, Timmis AD, Whitbourn R, et al. C reactive protein for risk stratification in acute coronary syndromes? Verdict: unproven. Heart. Nov. 2003;89(11):1288-90. X-1,X-4,X-5,X-8. [pmid: 14594879].
1544 Kent DM, Hill MD, Ruthazer R, et al. “Clinical-CT mismatch” and the response to systemic thrombolytic therapy in acute ischemic stroke. Stroke. Aug. 2005;36(8):1695-9. X-1,X-6,X-8. [pmid: 16002756].
1545 Kent DM, Langa KM, Selker HP. The potential use of ECG-based prognostic instruments in clinical trials and cost-effectiveness analyses of new therapies in acute cardiac ischemia. J Electrocardiol. 2000;33(Suppl):263-8. X-1,X-6,X-8. [pmid: 11265732].
1546 Kent DM, Ruthazer R, Griffith JL, et al. Comparison of mortality benefit of immediate thrombolytic therapy versus delayed primary angioplasty for acute myocardial infarction. Am J Cardiol. May. 15. 2007;99(10):1384-8. X-1,X-6,X-8. [pmid: 17493465].
1547 Kent DM, Ruthazer R, Selker HP. Are some patients likely to benefit from recombinant tissue-type plasminogen activator for acute ischemic stroke even beyond 3 hours from symptom onset?. Stroke. Feb. 2003;34(2):464-7. X-1,X-6. [pmid: 12574561].
1548 Kent DM, Selker HP, Ruthazer R, et al. Can multivariable risk-benefit profiling be used to select treatment-favorable patients for thrombolysis in stroke in the 3- to 6-hour time window?. Stroke. Dec. 2006;37(12):2963-9. X-1,X-2,X-6,X-8. [pmid: 17068306].
1549 Kerber KA, Whitman GT, Brown DL, et al. Increased risk of death in community-dwelling older people with white matter hyperintensities on MRI. J Neurol Sci. Dec. 1. 2006;250(1-2):33-8. X-1,X-5,X-6. [pmid: 16889799].
1550 Kernan WN, Viscoli CM, Inzucchi SE, et al. Prevalence of abnormal glucose tolerance following a transient ischemic attack or ischemic stroke. Arch Intern Med. Jan. 24. 2005;165(2):227-33. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15668371].
1551 Kertai MD, Boersma E, Westerhout CM, et al. A combination of statins and beta-blockers is independently associated with a reduction in the incidence of perioperative mortality and nonfatal myocardial infarction in patients undergoing abdominal aortic aneurysm surgery. Eur J Vasc Endovasc Surg. Oct. 2004;28(4):343-52. X-1. [pmid: 15350554].
1552 Kertai MD, Klein J, Bax JJ, et al. Predicting perioperative cardiac risk. Prog Cardiovasc Dis. Jan-Feb. 2005;47(4):240-57. X-1,X-4,X-8. [pmid: 15991153].
1553 Kessler M, Zannad F, Lehert P, et al. Predictors of cardiovascular events in patients with end-stage renal disease: an analysis from the Fosinopril in dialysis study. Nephrol Dial Transplant. Dec. 2007;22(12):3573-9. X-8. [pmid: 17611249].
1554 Kestenbaum B, Gillen DL, Sherrard DJ, et al. Calcium channel blocker use and mortality among patients with end-stage renal disease. Kidney Int. Jun. 2002;61(6):2157-64. X-1F,X-2,X-6,X-8. [pmid: 12028456].
1555 Kestler HA, Wohrle J, Hoher M. Cardiac vulnerability assessment from electrical microvariability of high-resolution electrocardiogram. Med Biol Eng Comput. Jan. 2000;38(1):88-92. X-1,X-5,X-6,X-7. [pmid: 10829396].
1556 Ketch TR, Turner SJ, Sacrinty MT, et al. Derived fibrinogen compared with C-reactive protein and brain natriuretic peptide for predicting events after myocardial infarction and coronary stenting. Am Heart J. Aug. 2008;156(2):234-40. X-1,X-2,X-8. [pmid: 18657651].
1557 Kettelkamp R, House J, Garg M, et al. Using the risk of restenosis as a guide to triaging patients between surgical and percutaneous coronary revascularization. Circulation. Sep. 14. 2004;110(11 Suppl 1):II50-4. X-1,X-5,X-6,X-8. [pmid: 15364838].
1558 Khan SQ, Dhillon O, Kelly D, et al. Plasma N-terminal B-Type natriuretic peptide as an indicator of long-term survival after acute myocardial infarction: comparison with plasma midregional pro-atrial natriuretic peptide: the LAMP (Leicester Acute Myocardial Infarction Peptide) study. J Am Coll Cardiol. May. 13. 2008;51(19):1857-64. X-1,X-8. [pmid: 18466800].
1559 Khan SQ, Dhillon O, Struck J, et al. C-terminal pro-endothelin-1 offers additional prognostic information in patients after acute myocardial infarction: Leicester Acute Myocardial Infarction Peptide (LAMP) Study. Am Heart J. Oct. 2007;154(4):736-42. X-1,X-6,X-8. [pmid: 17893002].
1560 Khan SQ, Quinn P, Davies JE, et al. N-terminal pro-B-type natriuretic peptide is better than TIMI risk score at predicting death after acute myocardial infarction. Heart. Jan. 2008;94(1):40-3. X-1,X-6,X-8. [pmid: 17488769].
1561 Khashoggi TY. Current trends in hormone replacement therapy. Saudi Med J. May. 2002;23(5):495-502. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12070567].
1562 Khaw AV, Mohr JP, Sciacca RR, et al. Association of infratentorial brain arteriovenous malformations with hemorrhage at initial presentation. Stroke. Mar. 2004;35(3):660-3. X-1,X-2,X-6,X-8. [pmid: 14752127].
1563 Khaw KT, Wareham N. Glycated hemoglobin as a marker of cardiovascular risk. Curr Opin Lipidol. Dec. 2006;17(6):637-43. X-2,X-4,X-5. [pmid: 17095908].
1564 Khera A, McGuire DK, Murphy SA, et al. Race and gender differences in C-reactive protein levels. J Am Coll Cardiol. Aug. 2. 2005;46(3):464-9. X-1,X-2,X-5,X-6. [pmid: 16053959].
1565 Khor LL, Muhlestein JB, Carlquist JF, et al. Sex- and age-related differences in the prognostic value of C-reactive protein in patients with angiographic coronary artery disease. Am J Med. Nov. 1. 2004;117(9):657-64. X-1,X-8. [pmid: 15501203].
1566 Khuseyinova N, Koenig W. Apolipoprotein A-I and risk for cardiovascular diseases. Curr Atheroscler Rep. Sep. 2006;8(5):365-73. X-1,X-2,X-4,X-5,X-6,X-7. [pmid: 16901406].
1567 Kiberd B, Keough-Ryan T, Panek R. Cardiovascular disease reduction in the outpatient kidney transplant clinic. Am J Transplant. Nov. 2003;3(11):1393-9. X-1,X-2,X-5,X-8. [pmid: 14525600].
1568 Kiberd B, Panek R. Cardiovascular outcomes in the outpatient kidney transplant clinic: the Framingham risk score revisited. Clin J Am Soc Nephrol. May. 2008;3(3):822-8. X-8,(28%). [pmid: 18322053].
1569 Kiechl S, Willeit J, Mayr M, et al. Oxidized phospholipids, lipoprotein(a), lipoprotein-associated phospholipase A2 activity, and 10-year cardiovascular outcomes: prospective results from the Bruneck study. Arterioscler Thromb Vasc Biol. Aug. 2007;27(8):1788-95. X-1F,X-2,X-8(8%). [pmid: 17541022].
1570 Kieltyka L, Urbina EM, Tang R, et al. Framingham risk score is related to carotid artery intima-media thickness in both white and black young adults: the Bogalusa Heart Study. Atherosclerosis. Sep. 2003;170(1):125-30. X-1F,X-2,X-5,X-6. [pmid: 12957690].
1571 Kikuya M, Ohkubo T, Asayama K, et al. Ambulatory blood pressure and 10-year risk of cardiovascular and noncardiovascular mortality: the Ohasama study. Hypertension. Feb. 2005;45(2):240-5. X-1E,X-1F,X-2,X-8(5.6%). [pmid: 15596571].
1572 Kilic T, Ural D, Ural E, et al. Relation between proinflammatory to anti-inflammatory cytokine ratios and long-term prognosis in patients with non-ST elevation acute coronary syndrome. Heart. Aug. 2006;92(8):1041-6. X-1,X-7,X-8. [pmid: 16547209].
1573 Kilkkinen A, Erlund I, Virtanen MJ, et al. Serum enterolactone concentration and the risk of coronary heart disease in a case-cohort study of Finnish male smokers. Am J Epidemiol. Apr. 15. 2006;163(8):687-93. X-1,X-5. [pmid: 16510545].
1574 Kim DW, Park SA, Kim CG, et al. Reversible defects on myocardial perfusion imaging early after coronary stent implantation: a predictor of late restenosis. Int J Cardiovasc Imaging. Jun. 2008;24(5):503-10. X-1,X-2,X-5,X-6X-7,X-8. [pmid: 18338236].
1575 Kim EY, Yoo E, Choi HY, et al. Thrombus volume comparison between patients with and without hyperattenuated artery sign on CT. AJNR Am J Neuroradiol. Feb. 2008;29(2):359-62. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 17974607].
1576 Kim H, Yang DH, Park Y, et al. Incremental prognostic value of C-reactive protein and N-terminal proB-type natriuretic peptide in acute coronary syndrome. Circ J. Nov. 2006;70(11):1379-84. X-1,X-2,X-8. [pmid: 17062957].
1577 Kim JS, Lee BH, Ko YG, et al. Comparison of sirolimus-eluting stent and paclitaxel-eluting stent for long-term cardiac adverse events in diabetic patients: the Korean Multicenter Angioplasty Team (KOMATE) Registry. Catheter Cardiovasc Interv. Nov. 1. 2008;72(5):601-7. X-1,X-2,X-8. [pmid: 18942123].
1578 Kim SB, Kwon S, Lee SK, et al. Association of atherosclerotic coronary artery disease and pulse pressure with renal disease progression. Ren Fail. Nov. 2003;25(6):1019-27. X-1,X-7. [pmid: 14669861].
1579 Kim SH, Chunawala L, Linde R, et al. Comparison of the 1997 and 2003 American Diabetes Association classification of impaired fasting glucose: impact on prevalence of impaired fasting glucose, coronary heart disease risk factors, and coronary heart disease in a community-based medical practice. J Am Coll Cardiol. Jul. 18. 2006;48(2):293-7. X-1,X-2,X-5,X-6. [pmid: 16843178].
1580 Kim WS, Lee J, Lee YT, et al. Total arterial revascularization in triple-vessel disease with off-pump and aortic no-touch technique. Ann Thorac Surg. Dec. 2008;86(6):1861-5. X-1,X-2,X-8. [pmid: 19021996].
1581 Kim YH, Ahn JM, Park DW, et al. EuroSCORE as a predictor of death and myocardial infarction after unprotected left main coronary stenting. Am J Cardiol. Dec. 15. 2006;98(12):1567-70. X-1,X-2,X-8. [pmid: 17145211].
1582 Kim YH, Lee KH, Chang HJ, et al. Depressed heart rate response to vasodilator stress for myocardial SPECT predicts mortality in patients after myocardial infarction. Int J Cardiovasc Imaging. Oct. 2006;22(5):663-70. X-1,X-7,X-8. [pmid: 16628384].
1583 Kini AS, Lee PC, Mitre CA, et al. Prediction of outcome after percutaneous coronary intervention for the acute coronary syndrome. Am J Med. Dec. 15. 2003;115(9):708-14. X-1,X-6,X-8. [pmid: 14693323].
1584 Kirton A, Deveber G, Pontigon AM, et al. Presumed perinatal ischemic stroke: vascular classification predicts outcomes. Ann Neurol. Apr. 2008;63(4):436-43. X-1,X-6,X-7. [pmid: 18306227].
1585 Kistorp C, Raymond I, Pedersen F, et al. N-terminal pro-brain natriuretic peptide, C-reactive protein, and urinary albumin levels as predictors of mortality and cardiovascular events in older adults. JAMA. Apr. 6. 2005;293(13):1609-16. X-1F,X-2. [pmid: 15811980].
1586 Kitagawa K, Hougaku H, Yamagami H, et al. Carotid intima-media thickness and risk of cardiovascular events in high-risk patients. Results of the Osaka Follow-Up Study for Carotid Atherosclerosis 2 (OSACA2 Study). Cerebrovasc Dis. 2007;24(1):35-42. X-1. [pmid: 17519542].
1587 Kittleson MM, Bead V, Fradley M, et al. Elevated uric acid levels predict allograft vasculopathy in cardiac transplant recipients. J Heart Lung Transplant. May. 2007;26(5):498-503. X-1,X-6,X-7. [pmid: 17449420].
1588 Kivimaki M, Ferrie JE, Brunner E, et al. Justice at work and reduced risk of coronary heart disease among employees: the Whitehall II Study. Arch Intern Med. Oct. 24. 2005;165(19):2245-51. X-1F,X-2,X-6. [pmid: 16246990].
1589 Kizer JR, Muttrej MR, Matthai WH, et al. Role of cardiac troponin T in the long-term risk stratification of patients undergoing percutaneous coronary intervention. Eur Heart J. Jul. 2003;24(14):1314-22. X-1,X-2,X-8. [pmid: 12871688].
1590 Klatsky AL, Friedman GD, Sidney S, et al. Risk of hemorrhagic stroke in Asian American ethnic groups. Neuroepidemiology. 2005;25(1):26-31. X-1E,X-1F,X-2,X-8. [pmid: 15855802].
1591 Klausen KP, Scharling H, Jensen G, et al. New definition of microalbuminuria in hypertensive subjects: association with incident coronary heart disease and death. Hypertension. Jul. 2005;46(1):33-7. X-1F,X-2. [pmid: 15928029].
1592 Kleikamp G, Maleszka A, Reiss N, et al. Determinants of mid- and long-term results in patients after surgical revascularization for ischemic cardiomyopathy. Ann Thorac Surg. May. 2003;75(5):1406-12. discussion 1412-3. X-1,X-6. [pmid: 12735554].
1593 Kleiman NS, Lakkis N, Cannon CP, et al. Prospective analysis of creatine kinase muscle-brain fraction and comparison with troponin T to predict cardiac risk and benefit of an invasive strategy in patients with non-ST-elevation acute coronary syndromes. J Am Coll Cardiol. Sep. 18. 2002;40(6):1044-50. X-1,X-8. [pmid: 12354426].
1594 Klein HU, Reek S. The MUSTT study: evaluating testing and treatment. J Interv Card Electrophysiol. Jan. 1. 2000;4:45-50. X-1,X-6,X-8. [pmid: 10590488].
1595 Klein JH, Hegele RA, Hackam DG, et al. Lipoprotein (a) is associated differentially with carotid stenosis, occlusion, and total plaque area. Arterioscler Thromb Vasc Biol. Oct. 2008;28(10):1851-6. X-1,X-2,X-6,X-8. [pmid: 18599799].
1596 Klein LW, Shaw RE, Krone RJ, et al. Mortality after emergent percutaneous coronary intervention in cardiogenic shock secondary to acute myocardial infarction and usefulness of a mortality prediction model. Am J Cardiol. Jul. 1. 2005;96(1):35-41. X-1,X-8. [pmid: 15979429].
1597 Klem I, Heitner JF, Shah DJ, et al. Improved detection of coronary artery disease by stress perfusion cardiovascular magnetic resonance with the use of delayed enhancement infarction imaging. J Am Coll Cardiol. Apr. 18. 2006;47(8):1630-8. X-1,X-6,X-7,X-8. [pmid: 16631001].
1598 Kline JA, Hernandez-Nino J, Newgard CD, et al. Use of pulse oximetry to predict in-hospital complications in normotensive patients with pulmonary embolism. Am J Med. Aug. 15. 2003;115(3):203-8. X-1,X-5,X-6. [pmid: 12935827].
1599 Klingenheben T, Hohnloser SH. Clinical value of T-wave alternans assessment. Card Electrophysiol Rev. Sep. 2002;6(3):323-8. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12114859].
1600 Klingenheben T, Hohnloser SH. Usefulness of risk stratification for future cardiac events in infarct survivors with severely depressed versus near-normal left ventricular function: results from a prospective long-term follow-up study. Ann Noninvasive Electrocardiol. Jan. 2003;8(1):68-74. X-1,X-2,X-8. [pmid: 12848816].
1601 Knobel H, Jerico C, Montero M, et al. Global cardiovascular risk in patients with HIV infection: concordance and differences in estimates according to three risk equations (Framingham, SCORE, and PROCAM). AIDS Patient Care STDS. Jul. 2007;21(7):452-7. X-2,X-5. [pmid: 17651026].
1602 Knollmann FD, Helmig K, Kapell S, et al. Coronary artery calcium scoring: diagnostic accuracy of different software implementations. Invest Radiol. Dec. 2003;38(12):761-8. X-1,X-5,X-6,X-7. [pmid: 14627893].
1603 Knopp RH, d'Emden M, Smilde JG, et al. Efficacy and safety of atorvastatin in the prevention of cardiovascular end points in subjects with type 2 diabetes: the Atorvastatin Study for Prevention of Coronary Heart Disease Endpoints in non-insulin-dependent diabetes mellitus (ASPEN). Diabetes Care. Jul. 2006;29(7):1478-85. X-1,X-2. [pmid: 16801565].
1604 Knuiman MW, Divitini ML, Olynyk JK, et al. Serum ferritin and cardiovascular disease: a 17-year follow-up study in Busselton, Western Australia. Am J Epidemiol. Jul. 15. 2003;158(2):144-9. X-1,X-2. [pmid: 12851227].
1605 Knuiman MW, James AL, Divitini ML, et al. Lung function, respiratory symptoms, and mortality: results from the Busselton Health Study. Ann Epidemiol. Jul. 1999;9(5):297-306. X-1,X-2,X-8(~10%). [pmid: 10976856].
1606 Knuiman MW, Watts GF, Divitini ML. Is sialic acid an independent risk factor for cardiovascular disease? A 17-year follow-up study in Busselton, Western Australia. Ann Epidemiol. Oct. 2004;14(9):627-32. X-1F,X-2,X-5,X-8, (Australia). [pmid: 15380792].
1607 Ko GT, Tang JS. Waist circumference and BMI cut-off based on 10-year cardiovascular risk: evidence for “central pre-obesity”. Obesity (Silver Spring). Nov. 2007;15(11):2832-9. X-1,X-2,X-5,X-6. [pmid: 18070775].
1608 Kober L, Swedberg K, McMurray JJ, et al. Previously known and newly diagnosed atrial fibrillation: a major risk indicator after a myocardial infarction complicated by heart failure or left ventricular dysfunction. Eur J Heart Fail. Oct. 2006;8(6):591-8. X-1,X-8. [pmid: 16507350].
1609 Koeijvoets KC, van der Net JB, van Rossum EF, et al. Two common haplotypes of the glucocorticoid receptor gene are associated with increased susceptibility to cardiovascular disease in men with familial hypercholesterolemia. J Clin Endocrinol Metab. Dec. 2008;93(12):4902-8. X-1,X-2. [pmid: 18812484].
1610 Koek HL, Soedamah-Muthu SS, Kardaun JW, et al. Short- and long-term mortality after acute myocardial infarction: comparison of patients with and without diabetes mellitus. Eur J Epidemiol. 2007;22(12):883-8. X-1,X-6,X-8. [pmid: 17926133].
1611 Koenig W. C-reactive protein: risk assessment in the primary prevention of atherosclerotic disease. Has the time come for including it in the risk profile?. Ital Heart J. Mar. 2001;2(3):157-63. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 11305526].
1612 Koenig W. Predicting risk and treatment benefit in atherosclerosis: the role of C-reactive protein. Int J Cardiol. Feb. 15. 2005;98(2):199-206. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15686768].
1613 Koenig W, Khuseyinova N, Baumert J, et al. Prospective study of high-sensitivity C-reactive protein as a determinant of mortality: results from the MONICA/KORA Augsburg Cohort Study, 1984-1998. Clin Chem. Feb. 2008;54(2):335-42. X-1E,X-2. [pmid: 18156284].
1614 Koenig W, Khuseyinova N, Lowel H, et al. Lipoprotein-associated phospholipase A2 adds to risk prediction of incident coronary events by C-reactive protein in apparently healthy middle-aged men from the general population: results from the 14-year follow-up of a large cohort from southern Germany. Circulation. Oct. 5. 2004;110(14):1903-8. X-1E,X-1F,X-2. [pmid: 15451783].
1615 Koga H, Takashima Y, Murakawa R, et al. Cognitive consequences of multiple lacunes and leukoaraiosis as vascular cognitive impairment in community-dwelling elderly individuals. J Stroke Cerebrovasc Dis. Jan. 2009;18(1):32-7. X-1,X-2,X-5,X-6. [pmid: 19110142].
1616 Koganei H, Kasanuki H, Ogawa H, et al. Association of glomerular filtration rate with unsuccessful primary percutaneous coronary intervention and subsequent mortality in patients with acute myocardial infarction: from the HIJAMI registry. Circ J. Feb. 2008;72(2):179-85. X-1,X-5,X-8. [pmid: 18219150].
1617 Koh KK, Quon MJ, Rosenson RS, et al. Vascular and metabolic effects of treatment of combined hyperlipidemia: focus on statins and fibrates. Int J Cardiol. Feb. 29. 2008;124(2):149-59. X-1,X-2,X-6. [pmid: 17658632].
1618 Kohsaka S, Goto M, Virani S, et al. Long-term clinical outcome of coronary artery stenting or coronary artery bypass grafting in patients with multiple-vessel disease. J Thorac Cardiovasc Surg. Aug. 2008;136(2):500-6. X-1,X-2,X-6,X-8. [pmid: 18692664].
1619 Kohsaka S, Menon V, Lowe AM, et al. Systemic inflammatory response syndrome after acute myocardial infarction complicated by cardiogenic shock. Arch Intern Med. Jul. 25. 2005;165(14):1643-50. X-1,X-5,X-6,X-8. [pmid: 16043684].
1620 Kokkinos P, Pittaras A, Narayan P, et al. Exercise capacity and blood pressure associations with left ventricular mass in prehypertensive individuals. Hypertension. Jan. 2007;49(1):55-61. X-1,X-2,X-5,X-6. [pmid: 17088448].
1621 Kolapo KO, Ogun SA, Danesi MA, et al. Validation study of the Siriraj Stroke score in African Nigerians and evaluation of the discriminant values of its parameters: a preliminary prospective CT scan study. Stroke. Aug. 2006;37(8):1997-2000. X-1,X-7,X-8. [pmid: 16794214].
1622 Kollen B, Kwakkel G, Lindeman E. Hemiplegic gait after stroke: is measurement of maximum speed required?. Arch Phys Med Rehabil. Mar. 2006;87(3):358-63. X-1,X-6,X-7,X-8. [pmid: 16500169].
1623 Kollen B, Kwakkel G, Lindeman E. Longitudinal robustness of variables predicting independent gait following severe middle cerebral artery stroke: a prospective cohort study. Clin Rehabil. Mar. 2006;20(3):262-8. X-1,X-6,X-7,X-8. [pmid: 16634346].
1624 Komorovsky R, Desideri A. Carotid ultrasound assessment of patients with coronary artery disease: a useful index for risk stratification. Vasc Health Risk Manag. 2005;1(2):131-6. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 17315399].
1625 Kon ZN, Brown EN, Tran R, et al. Simultaneous hybrid coronary revascularization reduces postoperative morbidity compared with results from conventional off-pump coronary artery bypass. J Thorac Cardiovasc Surg. Feb. 2008;135(2):367-75. X-1,X-2,X-6,X-7,X-8. [pmid: 18242270].
1626 Kondos GT, Hoff JA, Sevrukov A, et al. Electron-beam tomography coronary artery calcium and cardiac events: a 37-month follow-up of 5635 initially asymptomatic low- to intermediate-risk adults. Circulation. May. 27. 2003;107(20):2571-6. X-1F,X-2. [pmid: 12743005].
1627 Koomen EM, Hutten BA, Kelder JC, et al. Morbidity and mortality in patients waiting for coronary artery bypass surgery. Eur J Cardiothorac Surg. Mar. 2001;19(3):260-5. X-1,X-2,X-8. [pmid: 11251263].
1628 Kopp AF, Schroeder S, Baumbach A, et al. Non-invasive characterisation of coronary lesion morphology and composition by multislice CT: first results in comparison with intracoronary ultrasound. Eur Radiol. 2001;11(9):1607-11. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 11511879].
1629 Koren-Morag N, Goldbourt U, Tanne D. Renal dysfunction and risk of ischemic stroke or TIA in patients with cardiovascular disease. Neurology. Jul. 25. 2006;67(2):224-8. X-1,X-8. [pmid: 16864812].
1630 Korhonen P, Husa T, Tierala I, et al. QRS duration in high-resolution methods and standard ECG in risk assessment after first and recurrent myocardial infarctions. Pacing Clin Electrophysiol. Aug. 2006;29(8):830-6. X-1,X-6,X-7,X-8. [pmid: 16922998].
1631 Korhonen P, Tierala I, Simelius K, et al. Late QRS activity in signal-averaged magnetocardiography, body surface potential mapping, and orthogonal ECG in postinfarction ventricular tachycardia patients. Ann Noninvasive Electrocardiol. Oct. 2002;7(4):389-98. X-1,X-5,X-6,X-7,X-8. [pmid: 12431319].
1632 Kornowski R, Fuchs S, Hong MK, et al. Prognostic value of recurrent episodes of creatine kinase-MB elevation following repeated catheter-based coronary interventions. Catheter Cardiovasc Interv. Oct. 2000;51(2):131-7. X-1,X-8. [pmid: 11025563].
1633 Koro CE, Bowlin SJ, Stump TE, et al. The independent correlation between high-density lipoprotein cholesterol and subsequent major adverse coronary events. Am Heart J. Mar. 2006;151(3):755 e1-755 e6. X-2,X-8(MI, 9.2%)(CAD, 27%).
1634 Korosoglou G, Haars A, Humpert PM, et al. Evaluation of myocardial perfusion and deformation in patients with acute myocardial infarction treated with primary angioplasty and stent placement. Coron Artery Dis. Nov. 2008;19(7):497-506. X-1,X-6,X-7,X-8. [pmid: 18923246].
1635 Koschack J, Scherer M, Luers C, et al. Natriuretic peptide vs. clinical information for diagnosis of left ventricular systolic dysfunction in primary care. BMC Fam Pract. 2008;9:14. X-1,X-5,X-6,X-8. [pmid: 18298821].
1636 Kosiborod M. Blood glucose and its prognostic implications in patients hospitalised with acute myocardial infarction. Diab Vasc Dis Res. Nov. 2008;5(4):269-75. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18958836].
1637 Kosiborod M, Krumholz HM, Jones PG, et al. The relationship between anemia, change in hematocrit over time and change in health status in patients with heart failure after myocardial infarction. J Card Fail. Feb. 2008;14(1):27-34. X-1,X-2,X-6,X-8. [pmid: 18226770].
1638 Kosiborod M, Soto GE, Jones PG, et al. Identifying heart failure patients at high risk for near-term cardiovascular events with serial health status assessments. Circulation. Apr. 17. 2007;115(15):1975-81. X-1,X-8. [pmid: 17420346].
1639 Koski-Rahikkala H, Pouta A, Pietilainen K, et al. Does parity affect mortality among parous women?. J Epidemiol Community Health. Nov. 2006;60(11):968-73. X-1,X-2. [pmid: 17053286].
1640 Kosty T. Cerebral vasospasm after subarachnoid hemorrhage: an update. Crit Care Nurs Q. Apr-Jun. 2005;28(2):122-34. X-1,X-2,X-4,X-5,X-6,X-7. [pmid: 15875443].
1641 Koton S, Howard SC, Warlow CP, et al. Serum urate predicts long-term risk of acute coronary events in women after a transient ischaemic attack and stroke. Cerebrovasc Dis. 2008;26(5):517-24. X-1,X-2,X-8. [pmid: 18810239].
1642 Kouakam C, Guedon-Moreau L, Lucas C, et al. Long-term evaluation of autonomic tone in patients below 50 years of age with unexplained cerebral infarction: relation to atrial vulnerability. Europace. Oct. 2000;2(4):297-303. X-1,X-2,X-6,X-7,X-8. [pmid: 11194596].
1643 Kovar D, Cannon CP, Bentley JH, et al. Does initial and delayed heart rate predict mortality in patients with acute coronary syndromes?. Clin Cardiol. Feb. 2004;27(2):80-6. X-1,X-6,X-8. [pmid: 14979625].
1644 Kovari E, Gold G, Herrmann FR, et al. Cortical microinfarcts and demyelination significantly affect cognition in brain aging. Stroke. Feb. 2004;35(2):410-4. X-1,X-5,X-6. [pmid: 14707236].
1645 Kovesdy CP, Trivedi BK, Kalantar-Zadeh K, et al. Association of low blood pressure with increased mortality in patients with moderate to severe chronic kidney disease. Nephrol Dial Transplant. May. 2006;21(5):1257-62. X-1,X-6. [pmid: 16421161].
1646 Kowalczyk J, Lenarczyk R, Kowalski O, et al. Risk stratification according to the type of impaired renal function in patients with acute myocardial infarction treated with percutaneous coronary intervention. Kardiol Pol. Jun. 2007;65(6):635-43. discussion 644. X-1,X-8. [pmid: 17629825].
1647 Kowdley GC, Maithal S, Ahmed S, et al. Non-dialysis-dependent renal dysfunction and cardiac surgery-an assessment of perioperative risk factors. Curr Surg. Jan-Feb. 2005;62(1):64-70. X-1,X-2,X-6,X-7,X-8. [pmid: 15708149].
1648 Koz C, Baysan O, Hasimi A, et al. Conventional and non-conventional coronary risk factors in male premature coronary artery disease patients already having a low Framingham risk score. Acta Cardiol. Oct. 2008;63(5):623-8. X-1,X-7,X-8. [pmid: 19014007].
1649 Kozdag G, Ciftci E, Ural D, et al. Silent cerebral infarction in chronic heart failure: ischemic and nonischemic dilated cardiomyopathy. Vasc Health Risk Manag. 2008;4(2):463-9. X-1,X-5,X-7,X-8. [pmid: 18561522].
1650 Kozieradzka A, Kaminski K, Dobrzycki S, et al. TIMI Risk Score accurately predicts risk of death in 30-day and one-year follow-up in STEMI patients treated with primary percutaneous coronary interventions. Kardiol Pol. Jul. 2007;65(7):788-95. discussion 796-7. X-1,X-6,X-8. [pmid: 17694460].
1651 Kramer H, Toto R, Peshock R, et al. Association between chronic kidney disease and coronary artery calcification: the Dallas Heart Study. J Am Soc Nephrol. Feb. 2005;16(2):507-13. X-1,X-5,X-6. [pmid: 15601745].
1652 Krantz DS, Olson MB, Francis JL, et al. Anger, hostility, and cardiac symptoms in women with suspected coronary artery disease: the Women's Ischemia Syndrome Evaluation (WISE) Study. J Womens Health (Larchmt). Dec. 2006;15(10):1214-23. X-1,X-5,X-6,X-8. [pmid: 17199462].
1653 Krause KJ. C-reactive protein--a screening test for coronary disease?. J Insur Med. 2001;33(1):4-11. X-2,X-4,X-5,X-7,X-8. [pmid: 11317879].
1654 Krause KJ. Screening potential elderly preferred markers: exploratory analysis of Cardiovascular Health Study (CHS) data. J Insur Med. 2004;36(3):194-9. X-1F,X-2,X-6. [pmid: 15495435].
1655 Krause KJ. Mortality and prescription drug use: an analysis using the CHS limited access data. J Insur Med. 2007;39(1):24-7. X-1,X-5,X-6. [pmid: 17500353].
1656 Krauser DG, Devereux RB. Ventricular hypertrophy and hypertension: prognostic elements and implications for management. Herz. Jun. 2006;31(4):305-16. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16810470].
1657 Kraywinkel K, Heidrich J, Heuschmann PU, et al. Stroke risk perception among participants of a stroke awareness campaign. BMC Public Health. 2007;7:39. X-1,X-2,X-5,X-6. [pmid: 17371603].
1658 Krebs A, Krebs K, Keller F. Retrospective comparison of 5 different methods for long-term LDL-apheresis in 20 patients between 1986 and 2001. Int J Artif Organs. Feb. 2004;27(2):137-48. X-1,X-2,X-7. [pmid: 15061475].
1659 Kremers HM, Crowson CS, Therneau TM, et al. High ten-year risk of cardiovascular disease in newly diagnosed rheumatoid arthritis patients: a population-based cohort study. Arthritis Rheum. Aug. 2008;58(8):2268-74. X-1F,X-2. [pmid: 18668561].
1660 Krestan CR, Klein N, Fleischmann D, et al. Value of negative spiral CT angiography in patients with suspected acute PE: analysis of PE occurrence and outcome. Eur Radiol. Jan. 2004;14(1):93-8. X-1,X-6. [pmid: 12942280].
1661 Kreuz J, Lickfett LM, Schwab JO. Modern noninvasive risk stratification in primary prevention of sudden cardiac death. J Interv Card Electrophysiol. Oct. 2008;23(1):23-8. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18493844].
1662 Krishnan P, Balamurugan A, Urbina E, et al. Cardiovascular risk profile of asymptomatic healthy young adults with increased carotid artery intima-media thickness: the Bogalusa Heart Study. J La State Med Soc. May-Jun. 2003;155(3):165-9. X-1,X-2,X-6,X-8. [pmid: 12873105].
1663 Kristal-Boneh E, Harari G, Melamed S, et al. Association of physical activity at work with mortality in Israeli industrial employees: the CORDIS study. J Occup Environ Med. Feb. 2000;42(2):127-35. X-1E,X-1F,X-2. [pmid: 10693072].
1664 Kristen AV, Perz JB, Schonland SO, et al. Rapid progression of left ventricular wall thickness predicts mortality in cardiac light-chain amyloidosis. J Heart Lung Transplant. Dec. 2007;26(12):1313-9. X-1,X-5,X-6,X-7,X-8. [pmid: 18096484].
1665 Kroll D, Farah W, McKendall GR, et al. Prognostic value of stress-gated Tc-99m sestamibi SPECT after acute myocardial infarction. Am J Cardiol. Feb. 15. 2001;87(4):381-6. X-7,X-8. [pmid: 11179518].
1666 Kronenberg F, Neyer U, Lhotta K, et al. The low molecular weight apo(a) phenotype is an independent predictor for coronary artery disease in hemodialysis patients: a prospective follow-up. J Am Soc Nephrol. May. 1999;10(5):1027-36. X-1,X-8. [pmid: 10232689].
1667 Kronmal RA, Barzilay JI, Smith NL, et al. Mortality in pharmacologically treated older adults with diabetes: the Cardiovascular Health Study, 1989-2001. PLoS Med. Oct. 2006;3(10):e400. X-1,X-2. [pmid: 17048978].
1668 Kruk M, Karcz M, Przyluski J, et al. White blood cell count adds prognostic information to the thrombolysis in myocardial infarction risk index in patients following primary percutaneous coronary intervention (ANIN Myocardial Infarction Registry). Int J Cardiol. Apr. 4. 2007;116(3):376-82. X-1,X-5,X-8. [pmid: 16884793].
1669 Krumholz HM, Brindis RG, Brush JE, et al. Standards for statistical models used for public reporting of health outcomes: an American Heart Association Scientific Statement from the Quality of Care and Outcomes Research Interdisciplinary Writing Group: cosponsored by the Council on Epidemiology and Prevention and the Stroke Council. Endorsed by the American College of Cardiology Foundation. Circulation. Jan. 24. 2006;113(3):456-62. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16365198].
1670 Krumholz HM, Chen J, Wang Y, et al. Comparing AMI mortality among hospitals in patients 65 years of age and older: evaluating methods of risk adjustment. Circulation. Jun. 15. 1999;99(23):2986-92. X-1,X-6,X-8. [pmid: 10368115].
1671 Krumholz HM, Wang Y, Mattera JA, et al. An administrative claims model suitable for profiling hospital performance based on 30-day mortality rates among patients with an acute myocardial infarction. Circulation. Apr. 4. 2006;113(13):1683-92. X-1,X-8. [pmid: 16549637].
1672 Krzyzanowska K, Mittermayer F, Wolzt M, et al. Asymmetric dimethylarginine predicts cardiovascular events in patients with type 2 diabetes. Diabetes Care. Jul. 2007;30(7):1834-9. X-7. [pmid: 17456842].
1673 Kshirsagar AV, Bang H, Bomback AS, et al. A simple algorithm to predict incident kidney disease. Arch Intern Med. Dec. 8. 2008;168(22):2466-73. X-1,X-6. [pmid: 19064831].
1674 Kubal C, Srinivasan AK, Grayson AD, et al. Effect of risk-adjusted diabetes on mortality and morbidity after coronary artery bypass surgery. Ann Thorac Surg. May. 2005;79(5):1570-6. X-1,X-8. [pmid: 15854935].
1675 Kuch B, von Scheidt W, Kling B, et al. Differential impact of admission C-reactive protein levels on 28-day mortality risk in patients with ST-elevation versus non-ST-elevation myocardial infarction (from the Monitoring Trends and Determinants on Cardiovascular Diseases [MONICA]/Cooperative Health Research in the Region of Augsburg [KORA] Augsburg Myocardial Infarction Registry). Am J Cardiol. Nov. 1. 2008;102(9):1125-30. X-1,X-2,X-8. [pmid: 18940277].
1676 Kuettner A, Trabold T, Schroeder S, et al. Noninvasive detection of coronary lesions using 16-detector multislice spiral computed tomography technology: initial clinical results. J Am Coll Cardiol. Sep. 15. 2004;44(6):1230-7. X-1,X-5,X-6,X-7. [pmid: 15364324].
1677 Kuhan G, Gardiner ED, Abidia AF, et al. Risk modelling study for carotid endarterectomy. Br J Surg. Dec. 2001;88(12):1590-4. X-1,X-2,X-8. [pmid: 11736969].
1678 Kuijpers D, van Dijkman PR, Janssen CH, et al. Dobutamine stress MRI. Part II. Risk stratification with dobutamine cardiovascular magnetic resonance in patients suspected of myocardial ischemia. Eur Radiol. Nov. 2004;14(11):2046-52. X-1. [pmid: 15278416].
1679 Kuklinska AM, Sobkowicz B, Kaminski KA, et al. The benefits of repeated measurements of B-type natriuretic peptide in patients with first ST-elevation myocardial infarction treated with primary percutaneous coronary intervention. Int Heart J. Nov. 2006;47(6):843-54. X-1,X-2,X-7,X-8. [pmid: 17268119].
1680 Kuklinska AM, Sobkowicz B, Mroczko B, et al. Prognostic significance of the admission plasma B-type natriuretic peptide measurement in patients with first ST-elevation myocardial infarction in comparison with C-reactive protein and TIMI risk score. Clin Chim Acta. Jul. 2007;382(1-2):106-11. X-1,X-7,X-8. [pmid: 17482153].
1681 Kukulski T, Jamal F, Herbots L, et al. Identification of acutely ischemic myocardium using ultrasonic strain measurements. A clinical study in patients undergoing coronary angioplasty. J Am Coll Cardiol. Mar. 5. 2003;41(5):810-9. X-1,X-5,X-6,X-7. [pmid: 12628727].
1682 Kullo IJ, McConnell JP, Bailey KR, et al. Relation of C-reactive protein and fibrinogen to coronary artery calcium in subjects with systemic hypertension. Am J Cardiol. Jul. 1. 2003;92(1):56-8. X-1. [pmid: 12842247].
1683 Kumar A, Lloyd-Jones DM. Clinical significance of minor nonspecific ST-segment and T-wave abnormalities in asymptomatic subjects: a systematic review. Cardiol Rev. May-Jun. 2007;15(3):133-42. X-1,X-4,X-5. [pmid: 17438379].
1684 Kumar SS, Negassa A, Monrad ES, et al. The Mayo Clinic Risk Score predicts in-hospital mortality following primary angioplasty. J Invasive Cardiol. Oct. 2005;17(10):522-6. X-1,X-8. [pmid: 16204745].
1685 Kumar V, Sachdev HP, Khalil A. Noninvasive evaluation of endothelial function and arterial mechanics in overweight adolescents. Indian Pediatr. Nov. 2004;41(11):1105-14. X-1,X-2,X-5,X-6,X-7. [pmid: 15591660].
1686 Kumbhani DJ, Healey NA, Birjiniuk V, et al. Intraoperative regional myocardial acidosis predicts the need for inotropic support in cardiac surgery. Am J Surg. Nov. 2004;188(5):474-80. X-1,X-2,X-8. [pmid: 15546553].
1687 Kummerow FA, Olinescu RM, Fleischer L, et al. The relationship of oxidized lipids to coronary artery stenosis. Atherosclerosis. Mar. 2000;149(1):181-90. X-1,X-2,X-5,X-6,X-8. [pmid: 10704630].
1688 Kunadian B, Dunning J, Das R, et al. External validation of established risk adjustment models for procedural complications after percutaneous coronary intervention. Heart. Aug. 2008;94(8):1012-8. X-1,X-8. [pmid: 18032457].
1689 Kunadian B, Dunning J, Roberts AP, et al. Cumulative funnel plots for the early detection of interoperator variation: retrospective database analysis of observed versus predicted results of percutaneous coronary intervention. BMJ. Apr. 26. 2008;336(7650):931-4. X-1,X-8. [pmid: 18367500].
1690 Kupchak P, Wu AH, Ghani F, et al. Influence of imprecision on ROC curve analysis for cardiac markers. Clin Chem. Apr. 2006;52(4):752-3. X-1,X-4,X-5,X-6,X-8. [pmid: 16469856].
1691 Kuper H, Adami HO, Theorell T, et al. The socioeconomic gradient in the incidence of stroke: a prospective study in middle-aged women in Sweden. Stroke. Jan. 2007;38(1):27-33. X-1,X-2. [pmid: 17138948].
1692 Kupferwasser LI, Amorn AM, Kapoor N, et al. Comparison of drug-eluting stents with bare metal stents in unselected patients with acute myocardial infarction. Catheter Cardiovasc Interv. Jul. 1. 2007;70(1):1-8. X-1,X-8. [pmid: 17580366].
1693 Kuppuswamy V, Gupta S. Coronary heart disease in South Asians. Practitioner. Mar. 2003;247(1644):181-2. 186. 8. 190 passim. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 12640827].
1694 Kurki TS, Jarvinen O, Kataja MJ, et al. Performance of three preoperative risk indices; CABDEAL, EuroSCORE and Cleveland models in a prospective coronary bypass database. Eur J Cardiothorac Surg. Mar. 2002;21(3):406-10. X-1,X-8. [pmid: 11888755].
1695 Kurl S, Laukkanen JA, Rauramaa R, et al. Systolic blood pressure response to exercise stress test and risk of stroke. Stroke. Sep. 2001;32(9):2036-41. X-1F,X-2. [pmid: 11546894].
1696 Kurl S, Laukkanen JA, Tuomainen TP, et al. Association of exercise-induced, silent ST-segment depression with the risk of stroke and cardiovascular diseases in men. Stroke. Jul. 2003;34(7):1760-5. X-1,X-6. [pmid: 12829872].
1697 Kuroda S, Houkin K, Kamiyama H, et al. Long-term prognosis of medically treated patients with internal carotid or middle cerebral artery occlusion: can acetazolamide test predict it?. Stroke. Sep. 2001;32(9):2110-6. X-1,X-2,X-7,X-8. [pmid: 11546904].
1698 Kurpesa M, Trzos E, Rechcinski T, et al. The relationship between heart rate variability and heart rate turbulence dynamics after primary coronary angioplasty. Ann Noninvasive Electrocardiol. Jan. 2007;12(1):50-8. X-1,X-6,X-7,X-8. [pmid: 17286651].
1699 Kurth T, Kase CS, Berger K, et al. Smoking and risk of hemorrhagic stroke in women. Stroke. Dec. 2003;34(12):2792-5. X-1,X-6. [pmid: 14615625].
1700 Kuukasjarvi P, Nordhausen K, Malmivaara A. Reanalysis of systematic reviews: the case of invasive strategies for acute coronary syndromes. Int J Technol Assess Health Care. Fall. 2006;22(4):484-96. X-1,X-4,X-5,X-6,X-8. [pmid: 16984682].
1701 Kwakkel G, Kollen BJ, van der Grond J, et al. Probability of regaining dexterity in the flaccid upper limb: impact of severity of paresis and time since onset in acute stroke. Stroke. Sep. 2003;34(9):2181-6. X-1,X-2,X-6,X-7,X-8. [pmid: 12907818].
1702 Kwakkel G, van Dijk GM, Wagenaar RC. Accuracy of physical and occupational therapists' early predictions of recovery after severe middle cerebral artery stroke. Clin Rehabil. Feb. 2000;14(1):28-41. X-1,X-2,X-6,X-8. [pmid: 10688342].
1703 Kwiatkowski JL, Granger S, Brambilla DJ, et al. Elevated blood flow velocity in the anterior cerebral artery and stroke risk in sickle cell disease: extended analysis from the STOP trial. Br J Haematol. Aug. 2006;134(3):333-9. X-1,X-8. [pmid: 16848777].
1704 Kwon S, Hartzema AG, Duncan PW, et al. Disability measures in stroke: relationship among the Barthel Index, the Functional Independence Measure, and the Modified Rankin Scale. Stroke. Apr. 2004;35(4):918-23. X-1,X-2,X-6,X-8. [pmid: 14976324].
1705 Kwon SW, Yoon SJ, Kang TS, et al. Significance of small dense low-density lipoprotein as a risk factor for coronary artery disease and acute coronary syndrome. Yonsei Med J. Jun. 30. 2006;47(3):405-14. X-1,X-2,X-5,X-6,X-8. [pmid: 16807992].
1706 Kwong RY, Schussheim AE, Rekhraj S, et al. Detecting acute coronary syndrome in the emergency department with cardiac magnetic resonance imaging. Circulation. Feb. 4. 2003;107(4):531-7. X-1,X-5,X-6,X-7. [pmid: 12566362].
1707 La Rovere MT, Pinna GD, Maestri R, et al. Short-term heart rate variability strongly predicts sudden cardiac death in chronic heart failure patients. Circulation. Feb. 4. 2003;107(4):565-70. X-1,X-6,X-8. [pmid: 12566367].
1708 Laaksonen DE, Nyyssonen K, Niskanen L, et al. Prediction of cardiovascular mortality in middle-aged men by dietary and serum linoleic and polyunsaturated fatty acids. Arch Intern Med. Jan. 24. 2005;165(2):193-9. X-1. [pmid: 15668366].
1709 Labarre CA, Nelson DR, Pitts DE, et al. Immunohistochemical model to predict risk for coronary artery disease and failure in heart transplant patients. Am J Transplant. Sep. 2001;1(3):251-9. X-1,X-7,X-8. [pmid: 12102259].
1710 LaClair BJ, Reker DM, Duncan PW, et al. Stroke care: a method for measuring compliance with AHCPR guidelines. Am J Phys Med Rehabil. Mar. 2001;80(3):235-42. X-1,X-6,X-8. [pmid: 11237279].
1711 Ladwig KH, Marten-Mittag B, Lowel H, et al. C-reactive protein, depressed mood, and the prediction of coronary heart disease in initially healthy men: results from the MONICA-KORA Augsburg Cohort Study 1984-1998. Eur Heart J. Dec. 2005;26(23):2537-42. X-1E,X-2. [pmid: 16126719].
1712 LaFemina J, Sokal SM, Chang Y, et al. Effect of medical or surgical admission on outcome of patients with gallstone pancreatitis and common bile duct stones. J Gastrointest Surg. Sep. 2008;12(9):1554-60. X-1,X-2,X-6. [pmid: 18622658].
1713 Lagarde SM, Reitsma JB, Maris AK, et al. Preoperative prediction of the occurrence and severity of complications after esophagectomy for cancer with use of a nomogram. Ann Thorac Surg. Jun. 2008;85(6):1938-45. X-1,X-5,X-6. [pmid: 18498798].
1714 Lagares A, Gomez PA, Alen JF, et al. A comparison of different grading scales for predicting outcome after subarachnoid haemorrhage. Acta Neurochir (Wien). Jan. 2005;147(1):5-16. discussion 16. X-1D,X-1G,X-6,X-8. [pmid: 15565480].
1715 Laguna P, Martin A, Del Arco C, et al. Differences among clinical classification schemes for predicting stroke in atrial fibrillation: implications for therapy in daily practice. Acad Emerg Med. Sep. 2005;12(9):828-34. X-1D,X-1F,X-2,X-8(CAD, 20%)(Stroke, 16%)(Hypertension, 60%). [pmid: 16141016].
1716 Lahtinen J, Biancari F, Ala-Kokko T, et al. Pulmonary artery blood temperature at admission to the intensive care unit is predictive of outcome after on-pump coronary artery bypass surgery. Scand Cardiovasc J. May. 2004;38(2):104-12. X-1,X-6,X-8. [pmid: 15204236].
1717 Lai D, Hardy RJ. Potential gains in life expectancy or years of potential life lost: impact of competing risks of death. Int J Epidemiol. Oct. 1999;28(5):894-8. X-1,X-6. [pmid: 10597988].
1718 Lai S, Kaykha A, Yamazaki T, et al. Treadmill scores in elderly men. J Am Coll Cardiol. Feb. 18. 2004;43(4):606-15. X-1C,X-1D,X-1F,X-2. [pmid: 14975471].
1719 Lakkireddy D, Vacek J, Harris W, et al. Modified Mid America Heart Institute Coronary Care Unit scoring system--a new comprehensive prognostic index for Coronary Care Unit patients. Med Sci Monit. Mar. 2005;11(3):CR95-9. X-1,X-7,X-8. [pmid: 15735569].
1720 Lakkireddy DR, Bhakkad J, Korlakunta HL, et al. Prognostic value of the Duke Treadmill Score in diabetic patients. Am Heart J. Sep. 2005;150(3):516-21. X-1,X-2,X-5,X-8. [pmid: 16169334].
1721 Lakkireddy DR, Gowda MS, Murray CW, et al. Death certificate completion: how well are physicians trained and are cardiovascular causes overstated?. Am J Med. Oct. 1. 2004;117(7):492-8. X-1,X-2,X-5,X-6,X-8. [pmid: 15464706].
1722 Lakoski SG, Greenland P, Wong ND, et al. Coronary artery calcium scores and risk for cardiovascular events in women classified as “low risk” based on Framingham risk score: the multi-ethnic study of atherosclerosis (MESA). Arch Intern Med. Dec. 10. 2007;167(22):2437-42. X-2. [pmid: 18071165].
1723 Lakshminarayan K, Solid CA, Collins AJ, et al. Atrial fibrillation and stroke in the general medicare population: a 10-year perspective (1992 to 2002). Stroke. Aug. 2006;37(8):1969-74. X-1,X-2,X-8. [pmid: 16809573].
1724 Lam CS, Burnett JC Jr, Costello-Boerrigter L, et al. Alternate circulating pro-B-type natriuretic peptide and B-type natriuretic peptide forms in the general population. J Am Coll Cardiol. Mar. 20. 2007;49(11):1193-202. X-1,X-2,X-5,X-6,X-8. [pmid: 17367664].
1725 Lam TH, Liu LJ, Janus ED, et al. The relationship between fibrinogen and other coronary heart disease risk factors in a Chinese population. Atherosclerosis. Apr. 1999;143(2):405-13. X-1,X-5,X-6. [pmid: 10217371].
1726 Lamarche B, St-Pierre AC, Ruel IL, et al. A prospective, population-based study of low density lipoprotein particle size as a risk factor for ischemic heart disease in men. Can J Cardiol. Aug. 2001;17(8):859-65. X-1F,X-2, (Canada). [pmid: 11521128].
1727 Lamb SE, Ferrucci L, Volapto S, et al. Risk factors for falling in home-dwelling older women with stroke: the Women's Health and Aging Study. Stroke. Feb. 2003;34(2):494-501. X-1,X-6,X-7.
1728 Lamon-Fava S, Herrington DM, Reboussin DM, et al. Plasma levels of HDL subpopulations and remnant lipoproteins predict the extent of angiographically-defined coronary artery disease in postmenopausal women. Arterioscler Thromb Vasc Biol. Mar. 2008;28(3):575-9. X-1,X-2,X-5,X-6,X-8. [pmid: 18174456].
1729 Lampinen KH, Ronnback M, Groop PH, et al. A relationship between insulin sensitivity and vasodilation in women with a history of preeclamptic pregnancy. Hypertension. Aug. 2008;52(2):394-401. X-1,X-6,X-7. [pmid: 18574072].
1730 Lamy C, Domigo V, Semah F, et al. Early and late seizures after cryptogenic ischemic stroke in young adults. Neurology. Feb. 11. 2003;60(3):400-4. X-1,X-6,X-8. [pmid: 12578918].
1731 Lamy C, Giannesini C, Zuber M, et al. Clinical and imaging findings in cryptogenic stroke patients with and without patent foramen ovale: the PFO-ASA Study. Atrial Septal Aneurysm. Stroke. Mar. 2002;33(3):706-11. X-1,X-2,X-8. [pmid: 11872892].
1732 Lan TY, Chiu HC, Chang HY, et al. Clinical and laboratory predictors of all-cause mortality in older population. Arch Gerontol Geriatr. Nov-Dec. 2007;45(3):327-34. X-1,X-6. [pmid: 17383026].
1733 Lande MB, Pearson TA, Vermilion RP, et al. Elevated blood pressure, race/ethnicity, and C-reactive protein levels in children and adolescents. Pediatrics. Dec. 2008;122(6):1252-7. X-1,X-2,X-5,X-6. [pmid: 19047242].
1734 Landim MB, Victor EG. Framingham score for public transportation drivers in the city of Teresina, Piaui. Arq Bras Cardiol. Sep. 2006;87(3):315-20. X-2,X-5,X-6,X-7. [pmid: 17057932].
1735 Landoni C, Lucignani G, Paolini G, et al. Assessment of CABG-related risk in patients with CAD and LVD. Contribution of PET with [18F]FDG to the assessment of myocardial viability. J Cardiovasc Surg (Torino). Jun. 1999;40(3):363-72. X-1,X-6,X-8.
1736 Landrum MB, Normand SL. Applying Bayesian ideas to the development of medical guidelines. Stat Med. Jan. 30. 1999;18(2):117-37. X-1,X-4,X-5,X-6. [pmid: 10028134].
1737 Langsted A, Freiberg JJ, Nordestgaard BG. Fasting and nonfasting lipid levels: influence of normal food intake on lipids, lipoproteins, apolipoproteins, and cardiovascular risk prediction. Circulation. Nov. 11. 2008;118(20):2047-56. X-1,X-2,X-5,X-6. [pmid: 18955664].
1738 Lanktree M, Oh J, Hegele RA. Genetic testing for atherosclerosis risk: inevitability or pipe dream?. Can J Cardiol. Nov. 2008;24(11):851-4. X-1,X-2. [pmid: 18987759].
1739 LaRosa JC. What do the statins tell us?. Am Heart J. Dec. 2002;144(6 Suppl):S21-6. X-1,X-4,X-5. [pmid: 12486412].
1740 Larose E, Ganz P, Reynolds HG, et al. Right ventricular dysfunction assessed by cardiovascular magnetic resonance imaging predicts poor prognosis late after myocardial infarction. J Am Coll Cardiol. Feb. 27. 2007;49(8):855-62. X-1,X-7,X-8. [pmid: 17320743].
1741 Larrue V, von Kummer RR, Muller A, et al. Risk factors for severe hemorrhagic transformation in ischemic stroke patients treated with recombinant tissue plasminogen activator: a secondary analysis of the European-Australasian Acute Stroke Study (ECASS II). Stroke. Feb. 2001;32(2):438-41. X-1,X-6,X-8. [pmid: 11157179].
1742 Larson SL, Owens PL, Ford D, et al. Depressive disorder, dysthymia, and risk of stroke: thirteen-year follow-up from the Baltimore epidemiologic catchment area study. Stroke. Sep. 2001;32(9):1979-83. X-1F,X-2. [pmid: 11546884].
1743 Lasala JM, Cox DA, Dobies D, et al. Usage patterns and 2-year outcomes with the TAXUS express stent: results of the US ARRIVE 1 registry. Catheter Cardiovasc Interv. Oct. 1. 2008;72(4):433-45. X-1,X-2,X-6,X-8. [pmid: 18814217].
1744 Lassus J, Harjola VP, Sund R, et al. Prognostic value of cystatin C in acute heart failure in relation to other markers of renal function and NT-proBNP. Eur Heart J. Aug. 2007;28(15):1841-7. X-1,X-6,X-8. [pmid: 17289743].
1745 Laterza OF, Cameron SJ, Chappell D, et al. Evaluation of pregnancy-associated plasma protein A as a prognostic indicator in acute coronary syndrome patients. Clin Chim Acta. Oct. 2004;348(1-2):163-9. X-1D,X-1F,X-6,X-8. [pmid: 15369750].
1746 Lau EW, Griffith MJ, Pathmanathan RK, et al. The Midlands Trial of Empirical Amiodarone versus Electrophysiology-guided Interventions and Implantable Cardioverter-defibrillators (MAVERIC): a multi-centre prospective randomised clinical trial on the secondary prevention of sudden cardiac death. Europace. Jul. 2004;6(4):257-66. X-1,X-2. [pmid: 15172648].
1747 Lau GT, Ridley LJ, Schieb MC, et al. Coronary artery stenoses: detection with calcium scoring, CT angiography, and both methods combined. Radiology. May. 2005;235(2):415-22. X-1,X-5,X-6,X-7,X-8. [pmid: 15858083].
1748 Lau HK, Segev A, Hegele RA, et al. Thrombin-activatable fibrinolysis inhibitor (TAFI): a novel predictor of angiographic coronary restenosis. Thromb Haemost. Dec. 2003;90(6):1187-91. X-1,X-2,X-6,X-7,X-8. [pmid: 14652655].
1749 Lau KK, Chan YH, Yiu KH, et al. Incremental predictive value of vascular assessments combined with the Framingham Risk Score for prediction of coronary events in subjects of low-intermediate risk. Postgrad Med J. Mar. 2008;84(989):153-7. X-5,X-7,X-8. [pmid: 18372487].
1750 Lauer MS. Exercise electrocardiogram testing and prognosis. Novel markers and predictive instruments. Cardiol Clin. Aug. 2001;19(3):401-14. X-1G,X-2,X-4,X-5,X-6,X-7X-8,X-9. [pmid: 11570113].
1751 Lauer MS, Alexe S, Pothier Snader CE, et al. Use of the logical analysis of data method for assessing long-term mortality risk after exercise electrocardiography. Circulation. Aug. 6. 2002;106(6):685-90. X-6. [pmid: 12163428].
1752 Laukkanen JA, Kurl S, Rauramaa R, et al. Systolic blood pressure response to exercise testing is related to the risk of acute myocardial infarction in middle-aged men. Eur J Cardiovasc Prev Rehabil. Jun. 2006;13(3):421-8. X-1F,X-2. [pmid: 16926673].
1753 Laukkanen JA, Kurl S, Salonen R, et al. The predictive value of cardiorespiratory fitness for cardiovascular events in men with various risk profiles: a prospective population-based cohort study. Eur Heart J. Aug. 2004;25(16):1428-37. X-1F,X-2. [pmid: 15321701].
1754 Laukkanen JA, Rauramaa R, Kurl S. Exercise workload, coronary risk evaluation and the risk of cardiovascular and all-cause death in middle-aged men. Eur J Cardiovasc Prev Rehabil. Jun. 2008;15(3):285-92. X-2, (Finland). [pmid: 18525382].
1755 Laukkanen JA, Rauramaa R, Salonen JT, et al. The predictive value of cardiorespiratory fitness combined with coronary risk evaluation and the risk of cardiovascular and all-cause death. J Intern Med. Aug. 2007;262(2):263-72. X-1. [pmid: 17645594].
1756 Lavi S, Rihal CS, Yang EH, et al. The effect of drug eluting stents on cardiovascular events in patients with intermediate lesions and borderline fractional flow reserve. Catheter Cardiovasc Interv. Oct. 1. 2007;70(4):525-31. X-1,X-2,X-8. [pmid: 17896397].
1757 Lavine SJ. Prediction of heart failure post myocardial infarction: comparison of ejection fraction, transmitral filling parameters, and the index of myocardial performance. Echocardiography. Nov. 2003;20(8):691-701. X-1,X-7,X-8. [pmid: 14641373].
1758 Law MG, Friis-Moller N, El-Sadr WM, et al. The use of the Framingham equation to predict myocardial infarctions in HIV-infected patients: comparison with observed events in the D:A:D Study. HIV Med. May. 2006;7(4):218-30. X-2. [pmid: 16630034].
1759 Lawes CM, Rodgers A, Bennett DA, et al. Blood pressure and cardiovascular disease in the Asia Pacific region. J Hypertens. Apr. 2003;21(4):707-16. X-1F,X-2,X-4,X-5,X-7,X-8. [pmid: 12658016].
1760 Lawless CE, Best TM. Electrocardiograms in athletes: interpretation and diagnostic accuracy. Med Sci Sports Exerc. May. 2008;40(5):787-98. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18408622].
1761 Lawlor DA, Leon DA. Association of body mass index and obesity measured in early childhood with risk of coronary heart disease and stroke in middle age: findings from the aberdeen children of the 1950s prospective cohort study. Circulation. Apr. 19. 2005;111(15):1891-6. X-1F,X-2,X-6,X-9, (Scotland). [pmid: 15837941].
1762 Lawrance RA, Dorsch MF, Sapsford RJ, et al. Use of cumulative mortality data in patients with acute myocardial infarction for early detection of variation in clinical practice: observational study. BMJ. Aug. 11. 2001;323(7308):324-7. X-1,X-2,X-5,X-6. [pmid: 11498491].
1763 Le Grande MR, Elliott PC, Murphy BM, et al. Health related quality of life trajectories and predictors following coronary artery bypass surgery. Health Qual Life Outcomes. 2006;4:49. X-1. [pmid: 16904010].
1764 Ledue TB, Rifai N. High sensitivity immunoassays for C-reactive protein: promises and pitfalls. Clin Chem Lab Med. Nov. 2001;39(11):1171-6. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 11831635].
1765 Lee AJ, Price JF, Russell MJ, et al. Improved prediction of fatal myocardial infarction using the ankle brachial index in addition to conventional risk factors: the Edinburgh Artery Study. Circulation. Nov. 9. 2004;110(19):3075-80. X-1F. [pmid: 15477416].
1766 Lee CH, van Domburg RT, Hoye A, et al. Predictors of survival after contemporary percutaneous coronary revascularization for acute myocardial infarction in the real world. J Invasive Cardiol. Nov. 2004;16(11):627-31. X-1,X-2,X-8. [pmid: 15550731].
1767 Lee CR, North KE, Bray MS, et al. Cyclooxygenase polymorphisms and risk of cardiovascular events: the Atherosclerosis Risk in Communities (ARIC) study. Clin Pharmacol Ther. Jan. 2008;83(1):52-60. X-1,X-5,X-6,X-8. [pmid: 17495879].
1768 Lee CW, Suh J, Lee SW, et al. Factors predictive of cardiac events and restenosis after sirolimus-eluting stent implantation in small coronary arteries. Catheter Cardiovasc Interv. May. 1. 2007;69(6):821-5. X-1,X-2,X-8. [pmid: 17191211].
1769 Lee CY, Pellikka PA, McCully RB, et al. Nonexercise stress transthoracic echocardiography: transesophageal atrial pacing versus dobutamine stress. J Am Coll Cardiol. Feb. 1999;33(2):506-11. X-1,X-5,X-6,X-7. [pmid: 9973032].
1770 Lee KH, Cho SJ, Byun HS, et al. Triphasic perfusion computed tomography in acute middle cerebral artery stroke: a correlation with angiographic findings. Arch Neurol. Jul. 2000;57(7):990-9. X-1,X-2,X-6,X-7,X-8. [pmid: 10891981].
1771 Lee KW, Blann AD, Lip GY. Plasma markers of endothelial damage/dysfunction, inflammation and thrombogenesis in relation to TIMI risk stratification in acute coronary syndromes. Thromb Haemost. Nov. 2005;94(5):1077-83. X-1,X-7,X-8. [pmid: 16363252].
1772 Lee MS, Tseng CH, Barker CM, et al. Outcome after surgery and percutaneous intervention for cardiogenic shock and left main disease. Ann Thorac Surg. Jul. 2008;86(1):29-34. X-1,X-6,X-7,X-8. [pmid: 18573394].
1773 Lee SS, Singh S, Magder LS, et al. Predictors of high sensitivity C-reactive protein levels in patients with systemic lupus erythematosus. Lupus. 2008;17(2):114-23. X-1,X-2,X-6. [pmid: 18250134].
1774 Lee TC, O'Malley PG, Feuerstein I, et al. The prevalence and severity of coronary artery calcification on coronary artery computed tomography in black and white subjects. J Am Coll Cardiol. Jan. 1. 2003;41(1):39-44. X-1,X-5,X-6. [pmid: 12570942].
1775 Lee TH, Marcantonio ER, Mangione CM, et al. Derivation and prospective validation of a simple index for prediction of cardiac risk of major noncardiac surgery. Circulation. Sep. 7. 1999;100(10):1043-9. X-1,X-6,X-8. [pmid: 10477528].
1776 Lee YJ, Kim JK, Lee JH, et al. Association of serum gamma-glutamyltransferase with C-reactive protein levels and white blood cell count in Korean adults. Clin Chem Lab Med. 2008;46(10):1410-5. X-1,X-2,X-5,X-6. [pmid: 18844495].
1777 Legare JF, Buth KJ, Sullivan JA, et al. Composite arterial grafts versus conventional grafting for coronary artery bypass grafting. J Thorac Cardiovasc Surg. Jan. 2004;127(1):160-6. X-1,X-2,X-6,X-8. [pmid: 14752426].
1778 Lehrke S, Steen H, Sievers HH, et al. Cardiac troponin T for prediction of short- and long-term morbidity and mortality after elective open heart surgery. Clin Chem. Sep. 2004;50(9):1560-7. X-1,X-8. [pmid: 15217992].
1779 Leitha T, Bailer H, Gwechenberger M, et al. ROC analysis of three perfusion display options for ECG-gated perfusion SPECT in severe CAD. Nuklearmedizin. 1999;38(6):172-7. X-1,X-5,X-6. [pmid: 10510799].
1780 Lekakis JP, Papamichael C, Papaioannou TG, et al. Intima-media thickness score from carotid and femoral arteries predicts the extent of coronary artery disease: intima-media thickness and CAD. Int J Cardiovasc Imaging. Oct. 2005;21(5):495-501. X-1,X-5,X-6,X-8. [pmid: 16175437].
1781 Lekatsas I, Kranidis A, Ioannidis G, et al. Comparison of the extent and severity of coronary artery disease in patients with acute myocardial infarction with and without microalbuminuria. Am J Cardiol. Aug. 1. 2004;94(3):334-7. X-1,X-5,X-6,X-7,X-8. [pmid: 15276097].
1782 Lemesle G, Sudre A, Modine T, et al. High incidence of recurrent in stent thrombosis after successful treatment of a first in stent thrombosis. Catheter Cardiovasc Interv. Oct. 1. 2008;72(4):470-8. X-1X-2,X-6,X-8. [pmid: 18814219].
1783 Lemmer JH Jr, Metzdorff MT, Krause AH Jr, et al. Emergency coronary artery bypass graft surgery in abciximab-treated patients. Ann Thorac Surg. Jan. 2000;69(1):90-5. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 10654493].
1784 Lengele JP, Vinck WJ, De Plaen JF, et al. Cardiovascular risk assessment in hypertensive patients: major discrepancy according to ESH and SCORE strategies. J Hypertens. Apr. 2007;25(4):757-62. X-1,X-5,X-7. [pmid: 17351366].
1785 Lentine KL, Brennan DC, Schnitzler MA. Incidence and predictors of myocardial infarction after kidney transplantation. J Am Soc Nephrol. Feb. 2005;16(2):496-506. X-1D,X-1E,X-1F,X-2,X-8. [pmid: 15615820].
1786 Lentine KL, Rey LA, Kolli S, et al. Variations in the risk for cerebrovascular events after kidney transplant compared with experience on the waiting list and after graft failure. Clin J Am Soc Nephrol. Jul. 2008;3(4):1090-101. X-1F,X-2,X-8. [pmid: 18385393].
1787 Lentine KL, Rocca Rey LA, Kolli S, et al. Variations in the risk for cerebrovascular events after kidney transplant compared with experience on the waiting list and after graft failure. Clin J Am Soc Nephrol. Jul. 2008;3(4):1090-101. X-1,X-2. [pmid: 18385393].
1788 Leoncini G, Ratto E, Viazzi F, et al. Metabolic syndrome and ambulatory arterial stiffness index in non-diabetic patients with primary hypertension. J Hum Hypertens. Oct. 2007;21(10):802-7. X-1,X-2,X-6,X-7. [pmid: 17541383].
1789 Leoncini M, Bellandi F, Sciagra R, et al. Use of 99mTc-sestamibi gated SPECT to assess the influence of anterograde flow before primary coronary angioplasty on tissue salvage and functional recovery in acute myocardial infarction. Eur J Nucl Med Mol Imaging. Oct. 2004;31(10):1378-85. X-1,X-6,X-7,X-8. [pmid: 15221297].
1790 Leoncini M, Marcucci G, Sciagra R, et al. Usefulness of distinct activity thresholds according to baseline regional asynergy for predicting functional recovery in patients with chronic coronary artery disease and left ventricular dysfunction: a study with nitrate-enhanced sestamibi gated SPECT. J Nucl Cardiol. Sep-Oct. 2001;8(5):555-60. X-1,X-6,X-7,X-8. [pmid: 11593219].
1791 Leone N, Ducimetiere P, Gariepy J, et al. Distension of the carotid artery and risk of coronary events: the three-city study. Arterioscler Thromb Vasc Biol. Jul. 2008;28(7):1392-7. X-1F,X-2,X-8(12%). [pmid: 18421001].
1792 Leong T, Zylberstein D, Graham I, et al. Asymmetric dimethylarginine independently predicts fatal and nonfatal myocardial infarction and stroke in women: 24-year follow-up of the population study of women in Gothenburg. Arterioscler Thromb Vasc Biol. May. 2008;28(5):961-7. X-1. [pmid: 18292394].
1793 Leopold JA, Jacobs AK. Catheter-based revascularization strategies for acute coronary syndromes in women. Rev Cardiovasc Med. Fall. 2001;2(4):181-9. X-1,X-2,X-4,X-5,X-6. [pmid: 12439367].
1794 Lepper PM, Schumann C, Triantafilou K, et al. Association of lipopolysaccharide-binding protein and coronary artery disease in men. J Am Coll Cardiol. Jul. 3. 2007;50(1):25-31. X-1,X-5. [pmid: 17601541].
1795 Lerakis S, Kalogeropoulos AP, El-Chami MF, et al. Transthoracic dobutamine stress echocardiography in patients undergoing bariatric surgery. Obes Surg. Nov. 2007;17(11):1475-81. X-1,X-2. [pmid: 18219774].
1796 Lesage A, Ramakers M, Daubin C, et al. Complicated acute myocardial infarction requiring mechanical ventilation in the intensive care unit: prognostic factors of clinical outcome in a series of 157 patients. Crit Care Med. Jan. 2004;32(1):100-5. X-1,X-6,X-7,X-8. [pmid: 14707566].
1797 Leschka S, Scheffel H, Desbiolles L, et al. Combining dual-source computed tomography coronary angiography and calcium scoring: added value for the assessment of coronary artery disease. Heart. Sep. 2008;94(9):1154-61. X-1,X-5,X-6,X-7,X-8. [pmid: 18032458].
1798 Leslie WD, Tully SA, Yogendran MS, et al. Prognostic value of automated quantification of 99mTc-sestamibi myocardial perfusion imaging. J Nucl Med. Feb. 2005;46(2):204-11. X-1C,X-1F,X-2,X-8(26%). [pmid: 15695777].
1799 Lesperance F, Frasure-Smith N, Talajic M, et al. Five-year risk of cardiac mortality in relation to initial severity and one-year changes in depression symptoms after myocardial infarction. Circulation. Mar. 5. 2002;105(9):1049-53. X-1,X-2,X-8. [pmid: 11877353].
1800 Leung S, Gallup D, Mahaffey KW, et al. Smoking status and antithrombin therapy in patients with non-ST-segment elevation acute coronary syndrome. Am Heart J. Jul. 2008;156(1):177-84. X-1D,X-1F,X-2,X-8. [pmid: 18585514].
1801 Lev EI, Kornowski R, Vaknin-Assa H, et al. Comparison of the predictive value of four different risk scores for outcomes of patients with ST-elevation acute myocardial infarction undergoing primary percutaneous coronary intervention. Am J Cardiol. Jul. 1. 2008;102(1):6-11. X-1,X-6,X-8. [pmid: 18572028].
1802 Leviev I, Poirier O, Nicaud V, et al. High expressor paraoxonase PON1 gene promoter polymorphisms are associated with reduced risk of vascular disease in younger coronary patients. Atherosclerosis. Apr. 2002;161(2):463-7. X-1,X-5,X-8. [pmid: 11888532].
1803 Levine SK, Sachs GA, Jin L, et al. A prognostic model for 1-year mortality in older adults after hospital discharge. Am J Med. May. 2007;120(5):455-60. X-5,X-6. [pmid: 17466658].
1804 Levinson SS. Brief review and critical examination of the use of hs-CRP for cardiac risk assessment with the conclusion that it is premature to use this test. Clin Chim Acta. Jun. 2005;356(1-2):1-8. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15936299].
1805 Levitzky YS, Cupples LA, Murabito JM, et al. Prediction of intermittent claudication, ischemic stroke, and other cardiovascular disease by detection of abdominal aortic calcific deposits by plain lumbar radiographs. Am J Cardiol. Feb. 1. 2008;101(3):326-31. X-1. [pmid: 18237594].
1806 Lewis EF, Moye LA, Rouleau JL, et al. Predictors of late development of heart failure in stable survivors of myocardial infarction: the CARE study. J Am Coll Cardiol. Oct. 15. 2003;42(8):1446-53. X-1,X-6. [pmid: 14563590].
1807 Lewis EF, Velazquez EJ, Solomon SD, et al. Predictors of the first heart failure hospitalization in patients who are stable survivors of myocardial infarction complicated by pulmonary congestion and/or left ventricular dysfunction: a VALIANT study. Eur Heart J. Mar. 2008;29(6):748-56. X-1,X-2,X-6,X-8. [pmid: 18308687].
1808 Lewis JD, Schinnar R, Bilker WB, et al. Validation studies of the health improvement network (THIN) database for pharmacoepidemiology research. Pharmacoepidemiol Drug Saf. Apr. 2007;16(4):393-401. X-1,X-5,X-6. [pmid: 17066486].
1809 Lewis MS, Wilson RA, Walker K, et al. Factors in cardiac risk stratification of candidates for renal transplant. J Cardiovasc Risk. Aug. 1999;6(4):251-5. X-1,X-6. [pmid: 10501277].
1810 Lewis MS, Wilson RA, Walker KW, et al. Validation of an algorithm for predicting cardiac events in renal transplant candidates. Am J Cardiol. Apr. 1. 2002;89(7):847-50. X-1F,X-7(196),X-8. [pmid: 11909572].
1811 Lewis SL. After menopause: novel marker helps to identify women at risk for heart disease. J Fam Pract. Jul. 2004;(Suppl):S18-24. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9,X-1. [pmid: 15251109].
1812 Lewis WR. Echocardiography in the evaluation of patients in chest pain units. Cardiol Clin. Nov. 2005;23(4):531-9. vii. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16278122].
1813 Li B, Evans D, Faris P, et al. Risk adjustment performance of Charlson and Elixhauser comorbidities in ICD-9 and ICD-10 administrative databases. BMC Health Serv Res. 2008;8:12. X-1,X-6. [pmid: 18194561].
1814 Li C, Engstrom G, Berglund G, et al. Incidence of ischemic stroke in relation to asymptomatic carotid artery atherosclerosis in subjects with normal blood pressure. A prospective cohort study. Cerebrovasc Dis. 2008;26(3):297-303. X-1,X-2. [pmid: 18667810].
1815 Li CM, Zhang XH, Ma XJ, et al. Relation of corrected thrombolysis in myocardial infarction frame count and ST-segment resolution to myocardial tissue perfusion after acute myocardial infarction. Catheter Cardiovasc Interv. Feb. 15. 2008;71(3):312-7. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18288744].
1816 Li J, Hansen D, Mortensen PB, et al. Myocardial infarction in parents who lost a child: a nationwide prospective cohort study in Denmark. Circulation. Sep. 24. 2002;106(13):1634-9. X-1. [pmid: 12270855].
1817 Li R, Boerwinkle E, Olshan AF, et al. Glutathione S-transferase genotype as a susceptibility factor in smoking-related coronary heart disease. Atherosclerosis. Apr. 2000;149(2):451-62. X-1,X-6. [pmid: 10729397].
1818 Li WW, Froelicher ES. Predictors of smoking relapse in women with cardiovascular disease in a 30-month study: extended analysis. Heart Lung. Nov-Dec. 2008;37(6):455-65. X-1,X-2,X-6,X-8. [pmid: 18992629].
1819 Li Y, Glance LG, Cai X, et al. Are patients with coexisting mental disorders more likely to receive CABG surgery from low-quality cardiac surgeons? The experience in New York State. Med Care. Jul. 2007;45(7):587-93. X-1,X-8. [pmid: 17571006].
1820 Li YH, Teng JK, Tsai WC, et al. Prognostic significance of elevated hemostatic markers in patients with acute myocardial infarction. J Am Coll Cardiol. May. 1999;33(6):1543-8. X-1,X-6,X-7,X-8. [pmid: 10334421].
1821 Liao L, Smith WTt, Tuttle RH, et al. Prediction of death and nonfatal myocardial infarction in high-risk patients: a comparison between the Duke treadmill score, peak exercise radionuclide angiography, and SPECT perfusion imaging. J Nucl Med. Jan. 2005;46(1):5-11. X-1,X-2,X-8. [pmid: 15632026].
1822 Liao T, Park KW. Noninvasive tests of myocardial perfusion: stress tests and their values. Int Anesthesiol Clin. Fall. 2001;39(4):1-10. X-1G,X-2,X-4,X-5,X-6,X-7,X-8,X-9.
1823 Liapis CD, Kakisis JD, Kostakis AG. Carotid stenosis: factors affecting symptomatology. Stroke. Dec. 1. 2001;32(12):2782-6. X-1,X-8. [pmid: 11739973].
1824 Lichtman JH, Krumholz HM, Wang Y, et al. Risk and predictors of stroke after myocardial infarction among the elderly: results from the Cooperative Cardiovascular Project. Circulation. Mar. 5. 2002;105(9):1082-7. X-1,X-8. [pmid: 11877359].
1825 Licker MJ, Widikker I, Robert J, et al. Operative mortality and respiratory complications after lung resection for cancer: impact of chronic obstructive pulmonary disease and time trends. Ann Thorac Surg. May. 2006;81(5):1830-7. X-1. [pmid: 16631680].
1826 Liese AD, Hense HW, Brenner H, et al. Assessing the impact of classical risk factors on myocardial infarction by rate advancement periods. Am J Epidemiol. Nov. 1. 2000;152(9):884-8. X-2. [pmid: 11085401].
1827 Lietz K, John R, Kocher A, et al. Increased prevalence of autoimmune phenomena and greater risk for alloreactivity in female heart transplant recipients. Circulation. Sep. 18. 2001;104(12 Suppl 1):I177-83. X-1,X-2,X-6,X-8. [pmid: 11568052].
1828 Lievers KJ, Kluijtmans LA, Boers GH, et al. Influence of a glutamate carboxypeptidase II (GCPII) polymorphism (1561C-->T) on plasma homocysteine, folate and vitamin B(12) levels and its relationship to cardiovascular disease risk. Atherosclerosis. Oct. 2002;164(2):269-73. X-1,X-2,X-5,X-6,X-8. [pmid: 12204797].
1829 Liew D, McNeil JJ, Peeters A, et al. Epidemiological modelling (including economic modelling) and its role in preventive drug therapy. Med J Aust. Oct. 7. 2002;177(7):364-7. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12358579].
1830 Likosky DS, Dacey LJ, Baribeau YR, et al. Long-term survival of the very elderly undergoing coronary artery bypass grafting. Ann Thorac Surg. Apr. 2008;85(4):1233-7. X-1,X-2,X-8. [pmid: 18355501].
1831 Likosky DS, Leavitt BJ, Marrin CA, et al. Intra- and postoperative predictors of stroke after coronary artery bypass grafting. Ann Thorac Surg. Aug. 2003;76(2):428-34. discussion 435. X-1,X-2,X-8. [pmid: 12902078].
1832 Lim E, Ali ZA, Barlow CW, et al. A simple model to predict coronary disease in patients undergoing operation for mitral regurgitation. Ann Thorac Surg. Jun. 2003;75(6):1820-5. X-1,X-6. [pmid: 12822622].
1833 Lim HK, Chung N, Kim K, et al. Can magnetocardiography detect patients with non-ST-segment elevation myocardial infarction?. Ann Med. 2007;39(8):617-27. X-1,X-5,X-6,X-8. [pmid: 17852033].
1834 Lim J, Hawkins RC, Ng K, et al. A preliminary study of the utility of combined cardiac markers in the evaluation of patients presenting early with suspected acute coronary syndrome. Ann Acad Med Singapore. Nov. 2002;31(6):772-6. X-1,X-2,X-7,X-8. [pmid: 12520833].
1835 Lim P, Collet JP, Moutereau S, et al. Fetuin-A is an independent predictor of death after ST-elevation myocardial infarction. Clin Chem. Oct. 2007;53(10):1835-40. X-1,X-2,X-6,X-8. [pmid: 17702860].
1836 Lima RS, De Lorenzo A, Pantoja MR, et al. Incremental prognostic value of myocardial perfusion 99m-technetium-sestamibi SPECT in the elderly. Int J Cardiol. Feb. 2004;93(2-3):137-43. X-1. [pmid: 14975539].
1837 Limkakeng A Jr, Gibler WB, Pollack C, et al. Combination of Goldman risk and initial cardiac troponin I for emergency department chest pain patient risk stratification. Acad Emerg Med. Jul. 2001;8(7):696-702. X-1D,X-8. [pmid: 11435183].
1838 Limnell V, Pasternack R, Karjalainen J, et al. Seropositivity for Helicobacter pylori antibodies is associated with lower occurrence of venous bypass graft occlusion. Scand J Infect Dis. 2004;36(8):601-3. X-1,X-2,X-5,X-6,X-7. [pmid: 15370672].
1839 Lin F, Shaw LJ, Berman DS, et al. Multidetector computed tomography coronary artery plaque predictors of stress-induced myocardial ischemia by SPECT. Atherosclerosis. Apr. 2008;197(2):700-9. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 17720167].
1840 Lin J, Lee IM, Cook NR, et al. Plasma folate, vitamin B-6, vitamin B-12, and risk of breast cancer in women. Am J Clin Nutr. Mar. 2008;87(3):734-43. X-1,X-2,X-5,X-6. [pmid: 18326613].
1841 Lin J, Zhang SM, Cook NR, et al. Intakes of calcium and vitamin D and risk of colorectal cancer in women. Am J Epidemiol. Apr. 15. 2005;161(8):755-64. X-1,X-6,X-8. [pmid: 15800268].
1842 Lin K, Stewart D, Cooper S, et al. Pre-transplant cardiac testing for kidney-pancreas transplant candidates and association with cardiac outcomes. Clin Transplant. Aug. 2001;15(4):269-75. X-7. [pmid: 11683822].
1843 Lin KB, Shofer FS, McCusker C, et al. Predictive value of T-wave abnormalities at the time of emergency department presentation in patients with potential acute coronary syndromes. Acad Emerg Med. Jun. 2008;15(6):537-43. X-1. [pmid: 18616439].
1844 Lin PH, Bush RL, Lumsden AB. Carotid artery stenting: current status and future directions. Vasc Endovascular Surg. Sep-Oct. 2003;37(5):315-22. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 14528376].
1845 Lin YH, Juang JM, Jeng JS, et al. Symptomatic ostial vertebral artery stenosis treated with tubular coronary stents: clinical results and restenosis analysis. J Endovasc Ther. Dec. 2004;11(6):719-26. X-1,X-2,X-7,X-8. [pmid: 15615563].
1846 Lindberg G, Rastam L, Nilsson-Ehle P, et al. Serum sialic acid and sialoglycoproteins in asymptomatic carotid artery atherosclerosis. ARIC Investigators. Atherosclerosis Risk in Communities. Atherosclerosis. Sep. 1999;146(1):65-9. X-1,X-6,X-8. [pmid: 10487488].
1847 Linden PA, Bueno R, Colson YL, et al. Lung resection in patients with preoperative FEV1 < 35% predicted. Chest. Jun. 2005;127(6):1984-90. X-1,X-6,X-7. [pmid: 15951309].
1848 Lindholt JS. Relatively high pulmonary and cardiovascular mortality rates in screening-detected aneurysmal patients without previous hospital admissions. Eur J Vasc Endovasc Surg. Jan. 2007;33(1):94-9. X-1,X-6. [pmid: 16893664].
1849 Lindholt JS, Juul S, Henneberg EW. High-risk and low-risk screening for abdominal aortic aneurysm both reduce aneurysm-related mortality. A stratified analysis from a single-centre randomised screening trial. Eur J Vasc Endovasc Surg. Jul. 2007;34(1):53-8. X-1,X-6. [pmid: 17331750].
1850 Lindman AS, Selmer R, Tverdal A, et al. The SCORE risk model applied to recent population surveys in Norway compared to observed mortality in the general population. Eur J Cardiovasc Prev Rehabil. Oct. 2006;13(5):731-7. X-2,X-5,X-6,X-8(~10%). [pmid: 17001212].
1851 Lindsay J, Apple S, Pinnow EE, et al. Percutaneous coronary intervention-associated nephropathy foreshadows increased risk of late adverse events in patients with normal baseline serum creatinine. Catheter Cardiovasc Interv. Jul. 2003;59(3):338-43. X-1,X-6,X-8. [pmid: 12822153].
1852 Lindsay J Jr, Pinnow EE, Pichard AD. Frequency of major adverse cardiac events within one month of coronary angioplasty: a useful measure of operator performance. J Am Coll Cardiol. Dec. 1999;34(7):1916-23. X-1,X-8. [pmid: 10588204].
1853 Lip GY, Beevers DG. ACE inhibitors in vascular disease: some PROGRESS, more HOPE. J Hum Hypertens. Dec. 2001;15(12):833-5. X-1. [pmid: 11773984].
1854 Lisabeth LD, Smith MA, Sanchez BN, et al. Ethnic disparities in stroke and hypertension among women: the BASIC project. Am J Hypertens. Jul. 2008;21(7):778-83. X-1,X-2. [pmid: 18497733].
1855 Listi F, Candore G, Grimaldi MP, et al. Alpha1-antitrypsin heterozygosity plays a positive role in attainment of longevity. Biogerontology. Apr. 2007;8(2):139-45. X-1,X-2,X-5,X-6,X-8. [pmid: 17048073].
1856 L'Italien G, Ford I, Norrie J, et al. The cardiovascular event reduction tool (CERT)--a simplified cardiac risk prediction model developed from the West of Scotland Coronary Prevention Study (WOSCOPS). Am J Cardiol. Mar. 15. 2000;85(6):720-4. X-2. [pmid: 12000046].
1857 Little MP. Absence of evidence for differences in the dose-response for cancer and non-cancer endpoints by acute injury status in the Japanese atomic-bomb survivors. Int J Radiat Biol. Nov. 2002;78(11):1001-10. X-1,X-2,X-6. [pmid: 12456287].
1858 Liu J, Sempos CT, Donahue RP, et al. Non-high-density lipoprotein and very-low-density lipoprotein cholesterol and their risk predictive values in coronary heart disease. Am J Cardiol. Nov. 15. 2006;98(10):1363-8. X-1F,X-2,X-5C. [pmid: 17134630].
1859 Liu JF, Lin CH, Chua CH, et al. Outcome of off-pump coronary artery bypass in renal dialysis patients. Thorac Cardiovasc Surg. Oct. 2008;56(7):412-7. X-1,X-2,X-7,X-8. [pmid: 18810699].
1860 Liu S, Ma J, Ridker PM, et al. A prospective study of the association between APOE genotype and the risk of myocardial infarction among apparently healthy men. Atherosclerosis. Feb. 2003;166(2):323-9. X-1,X-2. [pmid: 12535745].
1861 Liu Y, Berthier-Schaad Y, Fallin MD, et al. IL-6 haplotypes, inflammation, and risk for cardiovascular disease in a multiethnic dialysis cohort. J Am Soc Nephrol. Mar. 2006;17(3):863-70. X-1D,X-2,X-8(49%)(32%). [pmid: 16467451].
1862 Liu Y, Yuan Z, Zhang J, et al. PPARgamma gene C161T substitution is associated with reduced risk of coronary artery disease and decreased proinflammatory cytokine expression. Am Heart J. Oct. 2007;154(4):718-24. X-1,X-2,X-5. [pmid: 17892998].
1863 Liukkonen T, Silvennoinen-Kassinen S, Jokelainen J, et al. The association between C-reactive protein levels and depression: Results from the northern Finland 1966 birth cohort study. Biol Psychiatry. Oct. 15. 2006;60(8):825-30. X-1,X-2,X-5,X-6. [pmid: 16616729].
1864 Liuzzo G, Biasucci LM, Trotta G, et al. Unusual CD4+CD28null T lymphocytes and recurrence of acute coronary events. J Am Coll Cardiol. Oct. 9. 2007;50(15):1450-8. X-1,X-2,X-7,X-8. [pmid: 17919564].
1865 Livingston EH, Chandalia M, Abate N. Do current body mass index criteria for obesity surgery reflect cardiovascular risk?. Surg Obes Relat Dis. Nov-Dec. 2007;3(6):577-85. X-5,X-6. [pmid: 17936086].
1866 Lloyd-Jones DM, Evans JC, Levy D. Hypertension in adults across the age spectrum: current outcomes and control in the community. JAMA. Jul. 27. 2005;294(4):466-72. X-1F,X-2,X-6. [pmid: 16046653].
1867 Lok CE, Allon M, Moist L, et al. Risk equation determining unsuccessful cannulation events and failure to maturation in arteriovenous fistulas (REDUCE FTM I). J Am Soc Nephrol. Nov. 2006;17(11):3204-12. X-1,X-6,X-8. [pmid: 16988062].
1868 Lokkegaard E, Jovanovic Z, Heitmann BL, et al. Increased risk of stroke in hypertensive women using hormone therapy: analyses based on the Danish Nurse Study. Arch Neurol. Oct. 2003;60(10):1379-84. X-1F,X-2. [pmid: 14568807].
1869 Lonn E. Use of carotid ultrasound to stratify risk. Can J Cardiol. May. A. 2001;17:22A-5A. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9.
1870 Lopez de Sa E, Lopez-Sendon J, Anguera I, et al. Prognostic value of clinical variables at presentation in patients with non-ST-segment elevation acute coronary syndromes: results of the Proyecto de Estudio del Pronostico de la Angina (PEPA). Medicine (Baltimore). Nov. 2002;81(6):434-42. X-1,X-2,X-8. [pmid: 12441900].
1871 Loponen P, Luther M, Nissinen J, et al. EuroSCORE predicts health-related quality of life after coronary artery bypass grafting. Interact Cardiovasc Thorac Surg. Aug. 2008;7(4):564-8. X-1,X-6,X-8. [pmid: 18390954].
1872 Loponen P, Taskinen P, Laakkonen E, et al. Peripheral vascular disease as predictor of outcome after coronary artery bypass grafting. Scand J Surg. 2002;91(2):160-5. X-1,X-7,X-8. [pmid: 12164516].
1873 Lorenzo C, Williams K, Hunt KJ, et al. The National Cholesterol Education Program -Adult Treatment Panel III, International Diabetes Federation, and World Health Organization definitions of the metabolic syndrome as predictors of incident cardiovascular disease and diabetes. Diabetes Care. Jan. 2007;30(1):8-13. X-1. [pmid: 17192325].
1874 Low AF, Ng WL, Lim YT, et al. The impact of diabetes mellitus on the prognostic value of a normal dobutamine stress echocardiogram in patients with intermediate to high cardiovascular risk. Singapore Med J. Apr. 2004;45(4):161-5. X-1,X-2,X-7. [pmid: 15094984].
1875 Low AF, Seow SC, Yeoh KG, et al. High-sensitivity C-reactive protein is predictive of medium-term cardiac outcome in high-risk Asian patients presenting with chest pain syndrome without myocardial infarction. Ann Acad Med Singapore. Jul. 2004;33(4):407-12. X-1. [pmid: 15329749].
1876 Lowel H, Doring A, Schneider A, et al. The MONICA Augsburg surveys--basis for prospective cohort studies. Gesundheitswesen. Aug. 1. 2005;67:S13-8. X-1,X-2,X-5,X-6. [pmid: 16032512].
1877 Lu M, Lyden PD, Brott TG, et al. Beyond subgroup analysis: improving the clinical interpretation of treatment effects in stroke research. J Neurosci Methods. Apr. 30. 2005;143(2):209-16. X-1,X-2,X-4,X-5,X-7,X-8. [pmid: 15814153].
1878 Lubinski A, Kornacewicz-Jach Z, Wnuk-Wojnar AM, et al. The terminal portion of the T wave: a new electrocardiographic marker of risk of ventricular arrhythmias. Pacing Clin Electrophysiol. Nov. 2000;23(11 Pt 2):1957-9. X-5,X-6,X-7,X-8. [pmid: 11139966].
1879 Ludman PF, Lazem F, Barbir M, et al. Incidence and clinical relevance of coronary calcification detected by electron beam computed tomography in heart transplant recipients. Eur Heart J. Feb. 1999;20(4):303-8. X-1,X-6,X-7. [pmid: 10099925].
1880 Lumley T, Kronmal RA, Cushman M, et al. A stroke prediction score in the elderly: validation and Web-based application. J Clin Epidemiol. Feb. 2002;55(2):129-36. X-2. [pmid: 11809350].
1881 Lumley T, Kronmal RA, Cushman M, et al. A stroke prediction score in the elderly: validation and Web-based application. J Clin Epidemiol. Feb. 2002;55(2):129-36. X-8. [pmid: 11809350].
1882 Lund J, Qin QP, Ilva T, et al. Circulating pregnancy-associated plasma protein a predicts outcome in patients with acute coronary syndrome but no troponin I elevation. Circulation. Oct. 21. 2003;108(16):1924-6. X-1,X-8. [pmid: 14530192].
1883 Lundgren-Nilsson A, Tennant A, Grimby G, et al. Cross-diagnostic validity in a generic instrument: an example from the Functional Independence Measure in Scandinavia. Health Qual Life Outcomes. 2006;4:55. X-1,X-6. [pmid: 16928268].
1884 Lupi-Herrera E, Chuquiure-Valenzuela E, Gonzalez-Pacheco H, et al. A proposed functional clinical classification predicts in-hospital and long-term survival in the setting of acute right ventricular infarction. Arch Cardiol Mex. Oct-Dec. 2008;78(4):369-78. X-1,X-8. [pmid: 19205544].
1885 Lykouras L, Rontos I, Rontos K, et al. Detecting alcohol-related problems among general hospital patients with heart disease. Psychother Psychosom. Jan-Feb. 2001;70(1):25-9. X-1,X-6,X-8. [pmid: 11150935].
1886 Lynch J, Smith GD. A life course approach to chronic disease epidemiology. Annu Rev Public Health. 2005;26:1-35. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15760279].
1887 Ma T, Jong GP, Ueng KC, et al. Establishing a prediction model for coronary angiography based on coronary risk factors. Int Heart J. Jan. 2005;46(1):57-68. X-1,X-6,X-8. [pmid: 15858937].
1888 Ma Y, Griffith JA, Chasan-Taber L, et al. Association between dietary fiber and serum C-reactive protein. Am J Clin Nutr. Apr. 2006;83(4):760-6. X-1,X-6. [pmid: 16600925].
1889 Maas R, Dentz L, Schwedhelm E, et al. Elevated plasma concentrations of the endogenous nitric oxide synthase inhibitor asymmetric dimethylarginine predict adverse events in patients undergoing noncardiac surgery. Crit Care Med. Aug. 2007;35(8):1876-81. X-1,X-6. [pmid: 17581491].
1890 Maas R, Wenske S, Zabel M, et al. Elevation of asymmetrical dimethylarginine (ADMA) and coronary artery disease in men with erectile dysfunction. Eur Urol. Dec. 2005;48(6):1004-11. discussion 1011-2. X-1,X-5,X-6,X-7,X-8. [pmid: 16139418].
1891 Maatz W, Kohler J, Botsios S, et al. Risk of stroke for carotid endarterectomy patients with contralateral carotid occlusion. Ann Vasc Surg. Jan. 2008;22(1):45-51. X-1,X-2,X-4,X-5,X-6. [pmid: 18083336].
1892 Mabuchi M, Kubo N, Morita K, et al. Prediction of functional recovery after coronary bypass surgery using quantitative gated myocardial perfusion SPECT. Nucl Med Commun. Jun. 2003;24(6):625-31. X-1,X-5,X-6. [pmid: 12766597].
1893 Macchi C, Lova RM, Miniati B, et al. Is the percentage of stenosis of the internal carotid artery a reliable measure of the risk of ischemic stroke? A morphometric study by duplex ultrasound of aortic arch branches in 500 normal adults. J Cardiovasc Surg (Torino). Feb. 2002;43(1):71-6. X-1,X-2,X-5,X-6.
1894 Mack M, Bachand D, Acuff T, et al. Improved outcomes in coronary artery bypass grafting with beating-heart techniques. J Thorac Cardiovasc Surg. Sep. 2002;124(3):598-607. X-1,X-2,X-8. [pmid: 12202877].
1895 Mack MJ, Pfister A, Bachand D, et al. Comparison of coronary bypass surgery with and without cardiopulmonary bypass in patients with multivessel disease. J Thorac Cardiovasc Surg. Jan. 2004;127(1):167-73. X-1,X-2,X-6,X-8. [pmid: 14752427].
1896 MacKenzie TA, Malenka DJ, Olmstead EM, et al. Prediction of survival after coronary revascularization: modeling short-term, mid-term, and long-term survival. Ann Thorac Surg. Feb. 2009;87(2):463-72. X-1,X-2,X-8. [pmid: 19161761].
1897 Mackey RH, Kuller LH, Sutton-Tyrrell K, et al. Lipoprotein subclasses and coronary artery calcium in postmenopausal women from the healthy women study. Am J Cardiol. Oct. 17. 2002;90(8A):71i-76i. X-1,X-5,X-6.
1898 Mackness B, Durrington P, McElduff P, et al. Low paraoxonase activity predicts coronary events in the Caerphilly Prospective Study. Circulation. Jun. 10. 2003;107(22):2775-9. X-1,X-5,X-6,X-7. [pmid: 12756158].
1899 Macleod J, Metcalfe C, Smith GD, et al. Does consideration of either psychological or material disadvantage improve coronary risk prediction? Prospective observational study of Scottish men. J Epidemiol Community Health. Sep. 2007;61(9):833-7. X-1, (Scotland). [pmid: 17699540].
1900 Madan M, Labinaz M, Cohen EA, et al. A comparison of clinical outcomes between Canadian and American patients after nonurgent coronary stenting. Can J Cardiol. Nov. 2004;20(13):1343-9. X-1,X-2,X-8. [pmid: 15570357].
1901 Madan P, Elayda MA, Lee VV, et al. Predicting major adverse cardiac events after percutaneous coronary intervention: the Texas Heart Institute risk score. Am Heart J. Jun. 2008;155(6):1068-74. X-1,X-8. [pmid: 18513521].
1902 Madans J, Reuben C, Rothwell S, et al. Differences in morbidity measures and risk factor identification using multiple data sources: the case of stroke. J Epidemiol Biostat. 1999;4(1):37-43. X-1. [pmid: 10613715].
1903 Madden E, Lee G, Kotler DP, et al. Association of antiretroviral therapy with fibrinogen levels in HIV-infection. AIDS. Mar. 30. 2008;22(6):707-15. X-1,X-2,X-6. [pmid: 18356600].
1904 Maddox TM. Preoperative cardiovascular evaluation for noncardiac surgery. Mt Sinai J Med. May. 2005;72(3):185-92. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15915313].
1905 Madjid M, Awan I, Willerson JT, et al. Leukocyte count and coronary heart disease: implications for risk assessment. J Am Coll Cardiol. Nov. 16. 2004;44(10):1945-56. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15542275].
1906 Madsen TE, Bledsoe J, Bossart P. Appropriately screened geriatric chest pain patients in an observation unit are not admitted at a higher rate than nongeriatric patients. Crit Pathw Cardiol. Dec. 2008;7(4):245-7. X-1,X-2,X-8. [pmid: 19050421].
1907 Magee MJ, Alexander JH, Hafley G, et al. Coronary artery bypass graft failure after on-pump and off-pump coronary artery bypass: findings from PREVENT IV. Ann Thorac Surg. Feb. 2008;85(2):494-9. discussion 499-500. X-1,X-6,X-8. [pmid: 18222251].
1908 Magee MJ, Herbert MA, Dewey TM, et al. Atrial fibrillation after coronary artery bypass grafting surgery: development of a predictive risk algorithm. Ann Thorac Surg. May. 2007;83(5):1707-12. discussion 1712. X-1,X-2,X-5,X-6,X-8. [pmid: 17462385].
1909 Mahaffey KW, Harrington RA, Simoons ML, et al. Stroke in patients with acute coronary syndromes: incidence and outcomes in the platelet glycoprotein IIb/IIIa in unstable angina. Receptor suppression using integrilin therapy (PURSUIT) trial. The PURSUIT Investigators. Circulation. May. 11. 1999;99(18):2371-7. X-1,X-6,X-8. [pmid: 10318656].
1910 Mahaffey KW, Yang Q, Pieper KS, et al. Prediction of one-year survival in high-risk patients with acute coronary syndromes: results from the SYNERGY trial. J Gen Intern Med. Mar. 2008;23(3):310-6. X-8. [pmid: 18196350].
1911 Mahenthiran J, Das MK, Bhakta D, et al. Prognostic importance of wall motion abnormalities in patients with ischemic cardiomyopathy and an implantable cardioverter-defibrillator. Am J Cardiol. Nov. 15. 2006;98(10):1301-6. X-1,X-2,X-7,X-8. [pmid: 17134618].
1912 Mahle WT, Campbell RM, Favaloro-Sabatier J. Myocardial infarction in adolescents. J Pediatr. Aug. 2007;151(2):150-4. X-5,X-8. [pmid: 17643766].
1913 Mahmarian JJ. Combining myocardial perfusion imaging with computed tomography for diagnosis of coronary artery disease. Curr Opin Cardiol. Sep. 2007;22(5):413-21. X-1,X-2. [pmid: 17762542].
1914 Mahmarian JJ, Shaw LJ, Olszewski GH, et al. Adenosine sestamibi SPECT post-infarction evaluation (INSPIRE) trial: A randomized, prospective multicenter trial evaluating the role of adenosine Tc-99m sestamibi SPECT for assessing risk and therapeutic outcomes in survivors of acute myocardial infarction. J Nucl Cardiol. Jul-Aug. 2004;11(4):458-69. X-1,X-8. [pmid: 15295415].
1915 Mahmud E, Shaw KD, Penny WF. Patients at low risk for periprocedural myocardial infarction can be identified by assessment immediately following percutaneous coronary intervention. J Invasive Cardiol. Jun. 2003;15(6):343-7. X-1,X-6,X-8. [pmid: 12777674].
1916 Mahoney LT, Burns TL, Stanford W, et al. Usefulness of the Framingham risk score and body mass index to predict early coronary artery calcium in young adults (Muscatine Study). Am J Cardiol. Sep. 1. 2001;88(5):509-15. X-6. [pmid: 11524059].
1917 Main ML, Magalski A, Kusnetzky LL, et al. Usefulness of myocardial contrast echocardiography in predicting global left ventricular functional recovery after anterior wall acute myocardial infarction. Am J Cardiol. Aug. 1. 2004;94(3):340-2. X-1,X-6,X-7,X-8. [pmid: 15276099].
1918 Mainous AG 3rd, Diaz VA, Everett CJ. Assessing risk for development of diabetes in young adults. Ann Fam Med. Sep-Oct. 2007;5(5):425-9. X-1G,X-6. [pmid: 17893384].
1919 Maitland-van der Zee AH, Boerwinkle E, Arnett DK, et al. Absence of an interaction between the angiotensin-converting enzyme insertion-deletion polymorphism and pravastatin on cardiovascular disease in high-risk hypertensive patients: the Genetics of Hypertension-Associated Treatment (GenHAT) study. Am Heart J. Jan. 2007;153(1):54-8. X-1,X-2. [pmid: 17174637].
1920 Majeed F, Miller M. Low high-density lipoprotein cholesterol: an important consideration in coronary heart disease risk assessment. Curr Opin Endocrinol Diabetes Obes. Apr. 2008;15(2):175-81. X-1,X-2,X-4,X-5. [pmid: 18316954].
1921 Majumdar SR, Gurwitz JH, Soumerai SB. Undertreatment of hyperlipidemia in the secondary prevention of coronary artery disease. J Gen Intern Med. Dec. 1999;14(12):711-7. X-1,X-5,X-6,X-8. [pmid: 10632815].
1922 Mak KH, Eisenberg MJ, Shaw J. Cost-efficacy modeling of functional testing with perfusion imaging to detect asymptomatic restenosis following percutaneous transluminal coronary angioplasty. Catheter Cardiovasc Interv. Dec. 1999;48(4):352-6. X-1,X-6. [pmid: 10559811].
1923 Makikallio AM, Makikallio TH, Korpelainen JT, et al. Heart rate dynamics predict poststroke mortality. Neurology. May. 25. 2004;62(10):1822-6. X-1,X-6,X-7. [pmid: 15159485].
1924 Malarcher AM, Giles WH, Croft JB, et al. Alcohol intake, type of beverage, and the risk of cerebral infarction in young women. Stroke. Jan. 2001;32(1):77-83. X-5,X-8. [pmid: 11136918].
1925 Malarstig A, Eriksson P, Hamsten A, et al. Raised interleukin-10 is an indicator of poor outcome and enhanced systemic inflammation in patients with acute coronary syndrome. Heart. Jun. 2008;94(6):724-9. X-5,X-8. [pmid: 17690160].
1926 Maleszka A, Kleikamp G, Zittermann A, et al. Simultaneous aortic and mitral valve replacement in octogenarians: a viable option?. Ann Thorac Surg. Dec. 2008;86(6):1804-8. X-1,X-2,X-7,X-8. [pmid: 19021981].
1927 Malik M, Hnatkova K, Batchvarov VN. Post infarction risk stratification using the 3-D angle between QRS complex and T-wave vectors. J Electrocardiol. 2004;37(Suppl):201-8. X-1,X-8.
1928 Mamode N, Docherty G, Lowe GD, et al. The role of myocardial perfusion scanning, heart rate variability and D-dimers in predicting the risk of perioperative cardiac complications after peripheral vascular surgery. Eur J Vasc Endovasc Surg. Dec. 2001;22(6):499-508. X-1,X-8. [pmid: 11735198].
1929 Manari A, Tomasi C, Guiducci V, et al. Time to treatment and ST-segment resolution in high-risk patients with acute myocardial infarction transferred from community hospitals for coronary angioplasty after pharmacological treatment. J Cardiovasc Med (Hagerstown). Jan. 2008;9(1):32-8. X-1,X-2,X-5,X-6,X-8. [pmid: 18268416].
1930 Mandegar MH, Yousefnia MA, Roshanali F, et al. Interaction between two predictors of functional outcome after revascularization in ischemic cardiomyopathy: left ventricular volume and amount of viable myocardium. J Thorac Cardiovasc Surg. Oct. 2008;136(4):930-6. X-1,X-2,X-6,X-7,X-8. [pmid: 18954632].
1931 Mandolini C, Tornini A, Borgia MC. About cardiovascular risk in non-cardiac surgery. Ann Ital Med Int. Oct-Dec. 2004;19(4):262-8. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15678706].
1932 Manenti ER, Bodanese LC, Camey SA, et al. Prognostic value of serum biomarkers in association with TIMI risk score for acute coronary syndromes. Clin Cardiol. Sep. 2006;29(9):405-10. X-1D,X-7(172),X-8. [pmid: 17007172].
1933 Maniar HS, Barner HB, Bailey MS, et al. Radial artery patency: are aortocoronary conduits superior to composite grafting?. Ann Thorac Surg. Nov. 2003;76(5):1498-503. discussion 1503-4. X-1,X-5,X-6,X-8. [pmid: 14602275].
1934 Maor Y, Cohen Y, Olmer L, et al. Factors associated with health indicators in patients undergoing coronary artery bypass surgery. Chest. Dec. 1999;116(6):1570-4. X-1,X-8. [pmid: 10593778].
1935 Marcassa C, Galli M, Paino A, et al. Electrocardiographic evolution after Q-wave anterior myocardial infarction: correlations between QRS score and changes in left ventricular perfusion and function. J Nucl Cardiol. Sep-Oct. 2001;8(5):561-7. X-1,X-2,X-6,X-7,X-8. [pmid: 11593220].
1936 Marcheix B, Vanden Eynden F, Demers P, et al. Influence of diabetes mellitus on long-term survival in systematic off-pump coronary artery bypass surgery. Ann Thorac Surg. Oct. 2008;86(4):1181-8. X-1,X-2,X-8. [pmid: 18805157].
1937 Marchioli R, Avanzini F, Barzi F, et al. Assessment of absolute risk of death after myocardial infarction by use of multiple-risk-factor assessment equations: GISSI-Prevenzione mortality risk chart. Eur Heart J. Nov. 2001;22(22):2085-103. X-1,X-6,X-8. [pmid: 11686666].
1938 Marcin JP, Li Z, Kravitz RL, et al. The CABG surgery volume-outcome relationship: temporal trends and selection effects in California, 1998-2004. Health Serv Res. Feb. 2008;43(1 Pt 1):174-92. X-1,X-2,X-5,X-6,X-8. [pmid: 18211524].
1939 Marenzi G, Moltrasio M, Assanelli E, et al. Impact of cardiac and renal dysfunction on inhospital morbidity and mortality of patients with acute myocardial infarction undergoing primary angioplasty. Am Heart J. May. 2007;153(5):755-62. X-1,X-6,X-8. [pmid: 17452149].
1940 Marin A, Medrano MJ, Gonzalez J, et al. Risk of ischaemic heart disease and acute myocardial infarction in a Spanish population: observational prospective study in a primary-care setting. BMC Public Health. 2006;6(38). X-2,X-8.
1941 Mark DB. Risk stratification in patients with chest pain. Prim Care. Mar. 2001;28(1):99-118. vii. X-2,X-4,X-5,X-7,X-8. [pmid: 11346500].
1942 Marmur JD, Poludasu S, Agarwal A, et al. Bolus-only platelet glycoprotein IIb-IIIa inhibition during percutaneous coronary intervention. J Invasive Cardiol. Nov. 2006;18(11):521-6. X-1,X-2,X-8. [pmid: 17090813].
1943 Marques-Vidal P, Rodondi N, Bochud M, et al. Predictive accuracy and usefulness of calibration of the ESC SCORE in Switzerland. Eur J Cardiovasc Prev Rehabil. Aug. 2008;15(4):402-8. X-1,X-5,X-6. [pmid: 18677163].
1944 Marquezine GF, Pereira AC, Sousa AG, et al. TCF7L2 variant genotypes and type 2 diabetes risk in Brazil: significant association, but not a significant tool for risk stratification in the general population. BMC Med Genet. 2008;9(106). X-1,X-6,X-8.
1945 Marrugat J, D'Agostino R, Sullivan L, et al. An adaptation of the Framingham coronary heart disease risk function to European Mediterranean areas. J Epidemiol Community Health. Aug. 2003;57(8):634-8. X-1,X-5, (Spain). [pmid: 12883073].
1946 Marsboom G, Janssens S. Endothelial progenitor cells: new perspectives and applications in cardiovascular therapies. Expert Rev Cardiovasc Ther. Jun. 2008;6(5):687-701. X-1,X-2. [pmid: 18510485].
1947 Marschke LM, Allen GJ, Coble DA, et al. Cardiovascular health status and health risk assessment method of p among worksite employees. J Prim Prev. Jan. 2006;27(1):67-79. X-7. [pmid: 16421655].
1948 Marschner IC, Simes RJ, Keech A. Biases in the identification of risk factor thresholds and J-curves. Am J Epidemiol. Oct. 1. 2007;166(7):824-31. X-1,X-2,X-5. [pmid: 17644824].
1949 Marshall NS, Wong KK, Liu PY, et al. Sleep apnea as an independent risk factor for all-cause mortality: the Busselton Health Study. Sleep. Aug. 1. 2008;31(8):1079-85. X-1,X-2,X-6. [pmid: 18714779].
1950 Marshall T. Identification of patients for clinical risk assessment by prediction of cardiovascular risk using default risk factor values. BMC Public Health. 2008;8:25. X-1G,X-5,X-6. [pmid: 18215252].
1951 Marshall T, Rouse A. Resource implications and health benefits of primary prevention strategies for cardiovascular disease in people aged 30 to 74: mathematical modelling study. BMJ. Jul. 27. 2002;325(7357):197. X-1,X-4,X-5,X-7,X-8. [pmid: 12142309].
1952 Marte T, Saely CH, Schmid F, et al. Effectiveness of atrial fibrillation as an independent predictor of death and coronary events in patients having coronary angiography. Am J Cardiol. Jan. 1. 2009;103(1):36-40. X-2. [pmid: 19101226].
1953 Marti-Fabregas J, Bravo Y, Cocho D, et al. Frequency and predictors of symptomatic intracerebral hemorrhage in patients with ischemic stroke treated with recombinant tissue plasminogen activator outside clinical trials. Cerebrovasc Dis. 2007;23(2-3):85-90. X-1,X-2,X-8. [pmid: 17114877].
1954 Martin C, Vanderpump M, French J. Description and validation of a Markov model of survival for individuals free of cardiovascular disease that uses Framingham risk factors. BMC Med Inform Decis Mak. May. 24. 2004;4:6. X-5,X-6. [pmid: 15157279].
1955 Martin RM, Smith GD, Frankel S, et al. Parents' growth in childhood and the birth weight of their offspring. Epidemiology. May. 2004;15(3):308-16. X-1,X-2,X-6. [pmid: 15097011].
1956 Martinelli N, Trabetti E, Bassi A, et al. The -1131 T>C and S19W APOA5 gene polymorphisms are associated with high levels of triglycerides and apolipoprotein C-III, but not with coronary artery disease: an angiographic study. Atherosclerosis. Apr. 2007;191(2):409-17. X-1,X-2,X-5,X-6,X-8. [pmid: 16682041].
1957 Martinez A, Taeusch HW, Yu V, et al. Variation in mortality and intraventricular haemorrhage in occupants of Pacific Rim nurseries. J Paediatr Child Health. Jun. 2002;38(3):235-40. X-1,X-2,X-8. [pmid: 12047689].
1958 Martinez-Selles M, Barrio JM, Hortal J, et al. Prevalence of peripheral arterial disease and prior stroke in octogenarians with symptomatic severe aortic stenosis or severe coronary artery disease: influence in management and outcome. Int Angiol. Mar. 2007;26(1):33-7. X-1,X-6,X-7,X-8. [pmid: 17353886].
1959 Maruyama K, Shin M, Tago M, et al. Radiosurgery to reduce the risk of first hemorrhage from brain arteriovenous malformations. Neurosurgery. Mar. 2007;60(3):453-8. discussion 458-9. X-1,X-6,X-8. [pmid: 17327789].
1960 Marwick TH. Cost-effectiveness of stress echocardiography for assessment of coronary artery disease: what we know and what we need to know. Eur J Echocardiogr. Mar. 2000;1(1):22-31. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 11916582].
1961 Marwick TH, Case C, Leano R, et al. Use of tissue Doppler imaging to facilitate the prediction of events in patients with abnormal left ventricular function by dobutamine echocardiography. Am J Cardiol. Jan. 15. 2004;93(2):142-6. X-1,X-8. [pmid: 14715337].
1962 Marwick TH, Case C, Poldermans D, et al. A clinical and echocardiographic score for assigning risk of major events after dobutamine echocardiograms. J Am Coll Cardiol. Jun. 2. 2004;43(11):2102-7. X-1. [pmid: 15172420].
1963 Marwick TH, Case C, Sawada S, et al. Prediction of mortality using dobutamine echocardiography. J Am Coll Cardiol. Mar. 1. 2001;37(3):754-60. X-1F,X-1G,X-2,X-8. [pmid: 11693748].
1964 Marwick TH, Case C, Sawada S, et al. Use of stress echocardiography to predict mortality in patients with diabetes and known or suspected coronary artery disease. Diabetes Care. Jun. 2002;25(6):1042-8. X-1,X-8. [pmid: 12032112].
1965 Mas JL, Trinquart L, Leys D, et al. Endarterectomy Versus Angioplasty in Patients with Symptomatic Severe Carotid Stenosis (EVA-3S) trial: results up to 4 years from a randomised, multicentre trial. Lancet Neurol. Oct. 2008;7(10):885-92. X-1,X-2,X-8. [pmid: 18774745].
1966 Maseri A. C-reactive protein in cardiovascular risk prediction. Zooming in and zooming out. Ital Heart J. Mar. 2001;2(3):155-6. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 11305525].
1967 Masip J, Paez J, Merino M, et al. Risk factors for intubation as a guide for noninvasive ventilation in patients with severe acute cardiogenic pulmonary edema. Intensive Care Med. Nov. 2003;29(11):1921-8. X-1,X-6,X-7. [pmid: 13680119].
1968 Masley SC, Phillips SE, Schocken DD. Blood pressure as a predictor of cardiovascular events in the elderly: the William Hale Research Program. J Hum Hypertens. Jun. 2006;20(6):392-7. X-1E,X-1F,X-2. [pmid: 16543911].
1969 Mason NA, Bailie GR, Satayathum S, et al. HMG-coenzyme a reductase inhibitor use is associated with mortality reduction in hemodialysis patients. Am J Kidney Dis. Jan. 2005;45(1):119-26. X-1,X-2. [pmid: 15696451].
1970 Massy ZA, Taupin P, Jungers P, et al. Prediction model of coronary heart disease in patients with chronic kidney disease: role of plasma fibrinogen as a new prognostic variable. Prilozi. Dec. 2005;26(2):63-77. X-7. [pmid: 16400230].
1971 Matanoski GM, Tao XG. Styrene exposure and ischemic heart disease: a case-cohort study. Am J Epidemiol. Nov. 15. 2003;158(10):988-95. X-1,X-6,X-8. [pmid: 14607807].
1972 Matheny ME, Ohno-Machado L, Resnic FS. Discrimination and calibration of mortality risk prediction models in interventional cardiology. J Biomed Inform. Oct. 2005;38(5):367-75. X-1,X-8. [pmid: 16198996].
1973 Mathew JP, Fontes ML, Tudor IC, et al. A multicenter risk index for atrial fibrillation after cardiac surgery. JAMA. Apr. 14. 2004;291(14):1720-9. X-1,X-8. [pmid: 15082699].
1974 Mathew JP, Grocott HP, Phillips-Bute B, et al. Lower endotoxin immunity predicts increased cognitive dysfunction in elderly patients after cardiac surgery. Stroke. Feb. 2003;34(2):508-13. X-1,X-6,X-8. [pmid: 12574568].
1975 Mathew V, Farkouh M, Grill DE, et al. Clinical risk stratification correlates with the angiographic extent of coronary artery disease in unstable angina. J Am Coll Cardiol. Jun. 15. 2001;37(8):2053-8. X-1,X-2,X-5. [pmid: 11419887].
1976 Mathisen L, Andersen MH, Hol PK, et al. Preoperative cerebral ischemic lesions predict physical health status after on-pump coronary artery bypass surgery. J Thorac Cardiovasc Surg. Dec. 2005;130(6):1691-7. X-1,X-6,X-7,X-8. [pmid: 16308017].
1977 Matsumoto N, Sato Y, Suzuki Y, et al. Prognostic value of myocardial perfusion single-photon emission computed tomography for the prediction of future cardiac events in a Japanese population: a middle-term follow-up study. Circ J. Oct. 2007;71(10):1580-5. X-1,X-2,X-8. [pmid: 17895555].
1978 Matsunari I, Kanayama S, Yoneyama T, et al. Electrocardiographic-gated dual-isotope simultaneous acquisition SPECT using 18F-FDG and 99mTc-sestamibi to assess myocardial viability and function in a single study. Eur J Nucl Med Mol Imaging. Feb. 2005;32(2):195-202. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15449050].
1979 Matsushita K, Yatsuya H, Tamakoshi K, et al. High-sensitivity C-reactive protein is quite low in Japanese men at high coronary risk. Circ J. Jun. 2007;71(6):820-5. X-5. [pmid: 17526975].
1980 Matthews KA, Gump BB. Chronic work stress and marital dissolution increase risk of posttrial mortality in men from the Multiple Risk Factor Intervention Trial. Arch Intern Med. Feb. 11. 2002;162(3):309-15. X-1F,X-2. [pmid: 11822923].
1981 Matthews KA, Kuller LH, Sutton-Tyrrell K, et al. Changes in cardiovascular risk factors during the perimenopause and postmenopause and carotid artery atherosclerosis in healthy women. Stroke. May. 2001;32(5):1104-11. X-1,X-6. [pmid: 11340217].
1982 Maury P, Zimmermann M, Metzger J, et al. Amiodarone therapy for sustained ventricular tachycardia after myocardial infarction: long-term follow-up, risk assessment and predictive value of programmed ventricular stimulation. Int J Cardiol. Nov-Dec. 2000;76(2-3):199-210. X-1,X-7,X-8. [pmid: 11104875].
1983 May A, Wang TJ. Evaluating the role of biomarkers for cardiovascular risk prediction: focus on CRP, BNP and urinary microalbumin. Expert Rev Mol Diagn. Nov. 2007;7(6):793-804. X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 18020909].
1984 May M, Sterne JA, Shipley M, et al. A coronary heart disease risk model for predicting the effect of potent antiretroviral therapy in HIV-1 infected men. Int J Epidemiol. Dec. 2007;36(6):1309-18. X-2, (Various Countries). [pmid: 17652317].
1985 Mazur W, Rivera JM, Khoury AF, et al. Prognostic value of exercise echocardiography: validation of a new risk index combining echocardiographic, treadmill, and exercise electrocardiographic parameters. J Am Soc Echocardiogr. Apr. 2003;16(4):318-25. X-1,X-6. [pmid: 12712013].
1986 McAvoy NC, Kochar N, McKillop G, et al. Prevalence of coronary artery calcification in patients undergoing assessment for orthotopic liver transplantation. Liver Transpl. Dec. 2008;14(12):1725-31. X-1,X-2,X-6,X-7. [pmid: 19025916].
1987 McBane RD, Hodge DO, Wysokinski WE. Clinical and echocardiographic measures governing thromboembolism destination in atrial fibrillation. Thromb Haemost. May. 2008;99(5):951-5. X-1,X-6,X-7,X-8. [pmid: 18449427].
1988 McCarron P, Smith GD, Okasha M, et al. Smoking in adolescence and young adulthood and mortality in later life: prospective observational study. J Epidemiol Community Health. May. 2001;55(5):334-5. X-1F,X-2. [pmid: 11297653].
1989 McClelland RL, Nasir K, Budoff M, et al. Arterial age as a function of coronary artery calcium (from the Multi-Ethnic Study of Atherosclerosis [MESA]). Am J Cardiol. Jan. 1. 2009;103(1):59-63. X-1. [pmid: 19101230].
1990 McConnell MV. Imaging techniques to predict cardiovascular risk. Curr Cardiol Rep. Jul. 2000;2(4):300-7. X-1C,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 10953263].
1991 McCrath DJ, Cerboni E, Frumento RJ, et al. Thromboelastography maximum amplitude predicts postoperative thrombotic complications including myocardial infarction. Anesth Analg. Jun. 2005;100(6):1576-83. X-1F,X-1G,X-2,X-8. [pmid: 15920177].
1992 McCullough PA, Henry TD, Kennard ED, et al. Residual high-grade angina after enhanced external counterpulsation therapy. Cardiovasc Revasc Med. Jul-Sep. 2007;8(3):161-5. X-1F,X-2,X-8(Unstable Angina)(Stable Angina). [pmid: 17765644].
1993 McCullough PA, Sandberg KR, Borzak S, et al. Benefits of aspirin and beta-blockade after myocardial infarction in patients with chronic kidney disease. Am Heart J. Aug. 2002;144(2):226-32. X-1,X-2,X-8. [pmid: 12177638].
1994 McDermott S, Moran R, Platt T, et al. Depression in adults with disabilities, in primary care. Disabil Rehabil. Feb. 4. 2005;27(3):117-23. X-1,X-5,X-6. [pmid: 15823993].
1995 McGeechan K, Liew G, Macaskill P, et al. Risk prediction of coronary heart disease based on retinal vascular caliber (from the Atherosclerosis Risk In Communities [ARIC] Study). Am J Cardiol. Jul. 1. 2008;102(1):58-63. X-1. [pmid: 18572036].
1996 McGeechan K, Macaskill P, Irwig L, et al. Assessing new biomarkers and predictive models for use in clinical practice: a clinician's guide. Arch Intern Med. Nov. 24. 2008;168(21):2304-10. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 19029492].
1997 McKhann GM, Selnes OA, Grega MA, et al. Subjective memory symptoms in surgical and nonsurgical coronary artery patients: 6-year follow-up. Ann Thorac Surg. Jan. 2009;87(1):27-34. X-1,X-2,X-6,X-8. [pmid: 19101263].
1998 McLaughlin T, Reaven G, Abbasi F, et al. Is there a simple way to identify insulin-resistant individuals at increased risk of cardiovascular disease?. Am J Cardiol. Aug. 1. 2005;96(3):399-404. X-1,X-6. [pmid: 16054467].
1999 McMahan CA, Gidding SS, Fayad ZA, et al. Risk scores predict atherosclerotic lesions in young people. Arch Intern Med. Apr. 25. 2005;165(8):883-90. X-1,X-5,X-6. [pmid: 15851639].
2000 McMahan CA, Gidding SS, Viikari JS, et al. Association of Pathobiologic Determinants of Atherosclerosis in Youth risk score and 15-year change in risk score with carotid artery intima-media thickness in young adults (from the Cardiovascular Risk in Young Finns Study). Am J Cardiol. Oct. 1. 2007;100(7):1124-9. X-2,X-6,X-9. [pmid: 17884375].
2001 McMurtray A, Nakamoto B, Shikuma C, et al. Small-vessel vascular disease in human immunodeficiency virus infection: the Hawaii aging with HIV cohort study. Cerebrovasc Dis. 2007;24(2-3):236-41. X-1,X-2,X-5,X-6,X-7. [pmid: 17630484].
2002 McNeil JJ, Peeters A, Liew D, et al. A model for predicting the future incidence of coronary heart disease within percentiles of coronary heart disease risk. J Cardiovasc Risk. Feb. 2001;8(1):31-7. X-2,X-5. [pmid: 11234724].
2003 McPhee JT, Hill JS, Ciocca RG, et al. Carotid endarterectomy was performed with lower stroke and death rates than carotid artery stenting in the United States in 2003 and 2004. J Vasc Surg. Dec. 2007;46(6):1112-1118. X-1,X-2,X-5,X-6,X-8. [pmid: 18154987].
2004 McPherson K. Where are we now with hormone replacement therapy?. Reprod Health Matters. Nov. 2004;12(24):200-3. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15626210].
2005 McQueen MJ, Gerstein HC, Pogue J, et al. Reevaluation by high-performance liquid chromatography: clinical significance of microalbuminuria in individuals at high risk of cardiovascular disease in the Heart Outcomes Prevention Evaluation (HOPE) Study. Am J Kidney Dis. Dec. 2006;48(6):889-96. X-1. [pmid: 17162143].
2006 McTigue K, Larson JC, Valoski A, et al. Mortality and cardiac and vascular outcomes in extremely obese women. JAMA. Jul. 5. 2006;296(1):79-86. X-1F,X-2,X-8. [pmid: 16820550].
2007 McWhorter VC, Ford LC, Butch AW. Analytical performance of the Synchron LX20 Pro, BN trade mark II and IMMAGE high sensitivity C-reactive protein assays and concordance in cardiovascular risk stratification. Clin Chim Acta. Sep. 2004;347(1-2):71-9. X-1,X-5,X-6. [pmid: 15313143].
2008 Meaume S, Benetos A, Henry OF, et al. Aortic pulse wave velocity predicts cardiovascular mortality in subjects >70 years of age. Arterioscler Thromb Vasc Biol. Dec. 2001;21(12):2046-50. X-7. [pmid: 11742883].
2009 Meco M, Biraghi T, Panisi P, et al. Aortocoronary bypass grafting in high-risk patients over 75 years. Propensity score analysis of on versus off-pump, early and midterm results. J Cardiovasc Surg (Torino). Jun. 2007;48(3):339-47. X-1,X-6,X-7,X-8.
2010 Meco M, Gramegna G, Yassini A, et al. Mortality and morbidity from intra-aortic balloon pumps. Risk analysis. J Cardiovasc Surg (Torino). Feb. 2002;43(1):17-23. X-1,X-6,X-7,X-8.
2011 Meerwaldt R, Hartog JW, Graaff R, et al. Skin autofluorescence, a measure of cumulative metabolic stress and advanced glycation end products, predicts mortality in hemodialysis patients. J Am Soc Nephrol. Dec. 2005;16(12):3687-93. X-1,X-7,X-8. [pmid: 16280473].
2012 Meerwaldt R, Lutgers HL, Links TP, et al. Skin autofluorescence is a strong predictor of cardiac mortality in diabetes. Diabetes Care. Jan. 2007;30(1):107-12. X-1,X-2,X-7. [pmid: 17192342].
2013 Mega JL, Morrow DA, de Lemos JA, et al. Thrombus precursor protein and clinical outcomes in patients with acute coronary syndromes. J Am Coll Cardiol. Jun. 24. 2008;51(25):2422-9. X-6,X-8. [pmid: 18565400].
2014 Mega JL, Morrow DA, De Lemos JA, et al. B-type natriuretic peptide at presentation and prognosis in patients with ST-segment elevation myocardial infarction: an ENTIRE-TIMI-23 substudy. J Am Coll Cardiol. Jul. 21. 2004;44(2):335-9. X-1,X-7,X-8. [pmid: 15261928].
2015 Mega JL, Morrow DA, Sabatine MS, et al. Correlation between the TIMI risk score and high-risk angiographic findings in non-ST-elevation acute coronary syndromes: observations from the Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms (PRISM-PLUS) trial. Am Heart J. May. 2005;149(5):846-50. X-1,X-8. [pmid: 15894966].
2016 Megnien JL, Denarie N, Cocaul M, et al. Predictive value of waist-to-hip ratio on cardiovascular risk events. Int J Obes Relat Metab Disord. Jan. 1999;23(1):90-7. X-1,X-5. [pmid: 10094583].
2017 Mehran R, Aymong ED, Nikolsky E, et al. A simple risk score for prediction of contrast-induced nephropathy after percutaneous coronary intervention: development and initial validation. J Am Coll Cardiol. Oct. 6. 2004;44(7):1393-9. X-1,X-6. [pmid: 15464318].
2018 Mehta RH, Grab JD, O'Brien SM, et al. Bedside tool for predicting the risk of postoperative dialysis in patients undergoing cardiac surgery. Circulation. Nov. 21. 2006;114(21):2208-16. quiz 2208. X-1,X-2,X-6,X-8. [pmid: 17088458].
2019 Mehta RH, Grab JD, O'Brien SM, et al. Clinical characteristics and in-hospital outcomes of patients with cardiogenic shock undergoing coronary artery bypass surgery: insights from the Society of Thoracic Surgeons National Cardiac Database. Circulation. Feb. 19. 2008;117(7):876-85. X-1,X-6,X-8. [pmid: 18250266].
2020 Mehta RH, Honeycutt E, Shaw LK, et al. Clinical characteristics associated with poor long-term survival among patients with diabetes mellitus undergoing saphenous vein graft interventions. Am Heart J. Oct. 2008;156(4):728-35. X-1,X-2,X-6,X-8. [pmid: 18926154].
2021 Meijboom WB, van Mieghem CA, Mollet NR, et al. 64-slice computed tomography coronary angiography in patients with high, intermediate, or low pretest probability of significant coronary artery disease. J Am Coll Cardiol. Oct. 9. 2007;50(15):1469-75. X-1,X-5,X-6,X-8. [pmid: 17919567].
2022 Meisinger C, Doring A, Thorand B, et al. Body fat distribution and risk of type 2 diabetes in the general population: are there differences between men and women? The MONICA/KORA Augsburg cohort study. Am J Clin Nutr. Sep. 2006;84(3):483-9. X-1G,X-2,X-6,X-8. [pmid: 16960160].
2023 Melchior M, Berkman LF, Kawachi I, et al. Lifelong socioeconomic trajectory and premature mortality (35-65 years) in France: findings from the GAZEL Cohort Study. J Epidemiol Community Health. Nov. 2006;60(11):937-44. X-1,X-2,X-6. [pmid: 17053282].
2024 Melchior T, Kober L, Madsen CR, et al. Accelerating impact of diabetes mellitus on mortality in the years following an acute myocardial infarction. TRACE Study Group Trandolapril Cardiac Evaluation. Eur Heart J. Jul. 1999;20(13):973-8. X-1,X-8. [pmid: 10361050].
2025 Melikian N, Kearney MT, Thomas MR, et al. A simple thermodilution technique to assess coronary endothelium-dependent microvascular function in humans: validation and comparison with coronary flow reserve. Eur Heart J. Sep. 2007;28(18):2188-94. X-1,X-6. [pmid: 17644509].
2026 Mendes LA, Picard MH, Sleeper LA, et al. Cardiogenic shock: predictors of outcome based on right and left ventricular size and function at presentation. Coron Artery Dis. Jun. 2005;16(4):209-15. X-1,X-6,X-7,X-8. [pmid: 15915072].
2027 Menotti A, Kromhout D, Blackburn H, et al. Forty-year mortality from cardiovascular diseases and all causes of death in the US Railroad cohort of the Seven Countries Study. Eur J Epidemiol. 2004;19(5):417-24. X-1. [pmid: 15233313].
2028 Menotti A, Lanti M, Agabiti-Rosei E, et al. Riskard 2005. New tools for prediction of cardiovascular disease risk derived from Italian population studies. Nutr Metab Cardiovasc Dis. Dec. 2005;15(6):426-40. X-4,X-5. [pmid: 16314229].
2029 Menotti A, Lanti M, Kromhout D, et al. Short and long term association of a single serum cholesterol measurement in middle-aged men in prediction of fatal coronary and other cardiovascular events: a cross-cultural comparison through Europe. Eur J Epidemiol. 2005;20(7):597-604. X-1D,X-1F,X-2. [pmid: 16119433].
2030 Menotti A, Lanti M, Maiani G, et al. Forty-year mortality from cardiovascular diseases and their risk factors in men of the Italian rural areas of the Seven Countries Study. Acta Cardiol. Oct. 2005;60(5):521-31. X-1F,X-2. [pmid: 16261784].
2031 Menotti A, Lanti M, Nedeljkovic S, et al. The relationship of age, blood pressure, serum cholesterol and smoking habits with the risk of typical and atypical coronary heart disease death in the European cohorts of the Seven Countries Study. Int J Cardiol. Jan. 13. 2006;106(2):157-63. X-1F,X-2. [pmid: 16321686].
2032 Menotti A, Lanti M, Puddu PE, et al. An Italian chart for cardiovascular risk prediction. Its scientific basis. Ann Ital Med Int. Oct-Dec. 2001;16(4):240-51. X-4,X-5. [pmid: 11799632].
2033 Menotti A, Lanti M, Puddu PE, et al. The risk functions incorporated in Riscard 2002: a software for the prediction of cardiovascular risk in the general population based on Italian data. Ital Heart J. Feb. 2002;3(2):114-21. X-4,X-5. [pmid: 11926009].
2034 Menotti A, Lanti M, Puddu PE, et al. Coronary heart disease incidence in northern and southern European populations: a reanalysis of the seven countries study for a European coronary risk chart. Heart. Sep. 2000;84(3):238-44. X-1. [pmid: 10956281].
2035 Menotti A, Lanti M, Puddu PE, et al. First risk functions for prediction of coronary and cardiovascular disease incidence in the Gubbio Population Study. Ital Heart J. Jun. 2000;1(6):394-9. X-2. [pmid: 10929739].
2036 Menotti A, Puddu PE, Lanti M. Comparison of the Framingham risk function-based coronary chart with risk function from an Italian population study. Eur Heart J. Mar. 2000;21(5):365-70. X-2. [pmid: 10666350].
2037 Menotti A, Puddu PE, Lanti M. The estimate of cardiovascular risk. Theory, tools and problems. Ann Ital Med Int. Apr-Jun. 2002;17(2):81-94. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12150050].
2038 Menown IB, Allen J, Anderson JM, et al. ST depression only on the initial 12-lead ECG: early diagnosis of acute myocardial infarction. Eur Heart J. Feb. 2001;22(3):218-27. X-1,X-7,X-8. [pmid: 11161933].
2039 Menown IB, Mackenzie G, Adgey AA. Optimizing the initial 12-lead electrocardiographic diagnosis of acute myocardial infarction. Eur Heart J. Feb. 2000;21(4):275-83. X-1,X-5,X-8. [pmid: 10653675].
2040 Mercie P, Thiebaut R, Lavignolle V, et al. Evaluation of cardiovascular risk factors in HIV-1 infected patients using carotid intima-media thickness measurement. Ann Med. 2002;34(1):55-63. X-1,X-5,X-6. [pmid: 12014436].
2041 Merello L, Riesle E, Alburquerque J, et al. Risk scores do not predict high mortality after coronary artery bypass surgery in the presence of diastolic dysfunction. Ann Thorac Surg. Apr. 2008;85(4):1247-55. X-1,X-7,X-8. [pmid: 18355505].
2042 Merino J, Planas A, De Moner A, et al. The association of peripheral arterial occlusive disease with major coronary events in a mediterranean population with low coronary heart disease incidence. Eur J Vasc Endovasc Surg. Jul. 2008;36(1):71-6. X-1F,X-2,X-8(14%). [pmid: 18396072].
2043 Metcalf PA, Wells S, Scragg RK, et al. Comparison of three different methods of assessing cardiovascular disease risk in New Zealanders with Type 2 diabetes mellitus. N Z Med J. Sep. 5. 2008;121(1281):49-57. X-2,X-5,X-6. [pmid: 18797484].
2044 Metz LD, Beattie M, Hom R, et al. The prognostic value of normal exercise myocardial perfusion imaging and exercise echocardiography: a meta-analysis. J Am Coll Cardiol. Jan. 16. 2007;49(2):227-37. X-1,X-4,X-5. [pmid: 17222734].
2045 Meuwissen M, Chamuleau SA, Siebes M, et al. The prognostic value of combined intracoronary pressure and blood flow velocity measurements after deferral of percutaneous coronary intervention. Catheter Cardiovasc Interv. Feb. 15. 2008;71(3):291-7. X-1,X-2,X-5X-7,X-8. [pmid: 18288725].
2046 Meyer A, Bunzemeier H, Hausberg M, et al. Impact of different stages of chronic kidney disease on in-hospital costs in patients with coronary heart disease. Nephrol Dial Transplant. Jun. 2008;23(6):1955-60. X-1,X-5,X-6,X-8. [pmid: 18083761].
2047 Meyer JW, Schultz JS, O'Donnell JC, et al. Patterns and effectiveness of lipid-lowering therapies in a managed care environment. Value Health. Sep-Oct. 2005;8(5):601-12. X-1,X-6,X-8. [pmid: 16176498].
2048 Michaelides AP, Aigyprladou MN, Andrikopoulos GK, et al. The prognostic value of a QRS score during exercise testing. Clin Cardiol. Aug. 2005;28(8):375-80. X-1,X-8. [pmid: 16144213].
2049 Michel P, Roques F, Nashef SA. Logistic or additive EuroSCORE for high-risk patients?. Eur J Cardiothorac Surg. May. 2003;23(5):684-7. discussion 687. X-1,X-6,X-8. [pmid: 12754018].
2050 Michelucci A, Mortara D, Lazzeri C, et al. Simultaneous assessment of electrocardiographic parameters for risk stratification: validation in healthy subjects. Ital Heart J. May. 2002;3(5):308-17. X-1F,X-2,X-5,X-6,X-7, (Italy). [pmid: 12066563].
2051 Michielon G, Di Carlo D, Brancaccio G, et al. Anomalous coronary artery origin from the pulmonary artery: correlation between surgical timing and left ventricular function recovery. Ann Thorac Surg. Aug. 2003;76(2):581-8. discussion 588. X-1,X-2,X-6,X-7,X-8. [pmid: 12902108].
2052 Mieszczanska H, Pietrasik G, Piotrowicz K, et al. Gender-related differences in electrocardiographic parameters and their association with cardiac events in patients after myocardial infarction. Am J Cardiol. Jan. 1. 2008;101(1):20-4. X-1,X-2,X-8. [pmid: 18157959].
2053 Migliaresi P, Celentano A, Palmieri V, et al. Knowledge of cardiovascular risk factors and awareness of non-pharmacological approach for risk prevention in young survivors of acute myocardial infarction. The cardiovascular risk prevention project “Help Your Heart Stay Young”. Nutr Metab Cardiovasc Dis. Jul. 2007;17(6):468-72. X-1,X-2,X-5,X-6,X-8. [pmid: 17379491].
2054 Migliorini A, Moschi G, Giurlani L, et al. Drug-eluting stent supported percutaneous coronary intervention for unprotected left main disease. Catheter Cardiovasc Interv. Aug. 2006;68(2):225-30. X-1,X-7,X-8. [pmid: 16817178].
2055 Millen BE, Quatromoni PA, Copenhafer DL, et al. Validation of a dietary pattern approach for evaluating nutritional risk: the Framingham Nutrition Studies. J Am Diet Assoc. Feb. 2001;101(2):187-94. X-1,X-6. [pmid: 11271691].
2056 Miller CD, Lindsell CJ, Anantharaman V, et al. Performance of a population-based cardiac risk stratification tool in Asian patients with chest pain. Acad Emerg Med. May. 2005;12(5):423-30. X-1,X-8. [pmid: 15863398].
2057 Miller CD, Roe MT, Mulgund J, et al. Impact of acute beta-blocker therapy for patients with non-ST-segment elevation myocardial infarction. Am J Med. Aug. 2007;120(8):685-92. X-1,X-6,X-8. [pmid: 17679127].
2058 Miller DD, Shaw LJ. Coronary artery disease: diagnostic and prognostic models for reducing patient risk. J Cardiovasc Nurs. Nov-Dec. 2006;21(6 Suppl 1):S2-16. quiz S17-9. X-1,X-2,X-4,X-5,X-6,X-7,X-8.
2059 Miller JM, Rochitte CE, Dewey M, et al. Diagnostic performance of coronary angiography by 64-row CT. N Engl J Med. Nov. 27. 2008;359(22):2324-36. X-1,X-6,X-8. [pmid: 19038879].
2060 Miller M. Differentiating the effects of raising low levels of high-density lipoprotein cholesterol versus lowering normal triglycerides: further insights from the Veterans Affairs High-Density Lipoprotein Intervention Trial. Am J Cardiol. Dec. 21. 2000;86(12A):23L-27L. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9.
2061 Miller M, Cannon CP, Murphy SA, et al. Impact of triglyceride levels beyond low-density lipoprotein cholesterol after acute coronary syndrome in the PROVE IT-TIMI 22 trial. J Am Coll Cardiol. Feb. 19. 2008;51(7):724-30. X-1,X-2,X-8. [pmid: 18279736].
2062 Miller TD, Roger VL, Hodge DO, et al. A simple clinical score accurately predicts outcome in a community-based population undergoing stress testing. Am J Med. Aug. 2005;118(8):866-72. X-1,X-8. [pmid: 16084179].
2063 Miller WL, Wright RS, Grill JP, et al. Improved survival after acute myocardial infarction in patients with advanced Killip class. Clin Cardiol. Oct. 2000;23(10):751-8. X-1,X-8. [pmid: 11061053].
2064 Milne R, Gamble G, Whitlock G, et al. Framingham Heart Study risk equation predicts first cardiovascular event rates in New Zealanders at the population level. N Z Med J. Nov. 7. 2003;116(1185):U662. X-2, (New Zealand). [pmid: 14615804].
2065 Min JK, Williams KA, Okwuosa TM, et al. Prediction of coronary heart disease by erectile dysfunction in men referred for nuclear stress testing. Arch Intern Med. Jan. 23. 2006;166(2):201-6. X-1,X-2,X-5,X-6,X-8. [pmid: 16432089].
2066 Minoretti P, Falcone C, Calcagnino M, et al. Prognostic significance of plasma osteopontin levels in patients with chronic stable angina. Eur Heart J. Apr. 2006;27(7):802-7. X-1,X-8. [pmid: 16421174].
2067 Mirbagheri SA, Rashidi A, Abdi S, et al. Liver: an alarm for the heart?. Liver Int. Sep. 2007;27(7):891-4. X-5,X-6. [pmid: 17696926].
2068 Mishkel GJ, Moore AL, Markwell S, et al. Correlates of late and very late thrombosis of drug eluting stents. Am Heart J. Jul. 2008;156(1):141-7. X-1,X-2,X-6,X-8. [pmid: 18585509].
2069 Mistiaen W, Van Cauwelaert P, Sys SU, et al. Role of age, gender and association of CABG on long-term results after aortic valve replacement with a Carpentier-Edwards bioprosthesis in the elderly. J Cardiovasc Surg (Torino). Dec. 2003;44(6):701-6. X-1,X-2,X-5,X-8.
2070 Mistiaen W, Vissers D. The risk of postoperative pulmonary or pleural complications after aortic valve replacement is low in elderly patients: an observational study. Aust J Physiother. 2008;54(2):119-24. X-1,X-6,X-8. [pmid: 18492003].
2071 Mitka M. Biomarkers for coronary heart disease: predictive value or noise?. JAMA. Dec. 15. 2004;292(23):2824-5. X-1C,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 15598900].
2072 Mittal TK, Barbir M, Rubens M. Role of computed tomography in risk assessment for coronary heart disease. Postgrad Med J. Oct. 2006;82(972):664-71. X-1,X-2,X-4,X-5,X-6. [pmid: 17068277].
2073 Miura K, Daviglus ML, Dyer AR, et al. Relationship of blood pressure to 25-year mortality due to coronary heart disease, cardiovascular diseases, and all causes in young adult men: the Chicago Heart Association Detection Project in Industry. Arch Intern Med. Jun. 25. 2001;161(12):1501-8. X-1F,X-2. [pmid: 11427097].
2074 Miyahara K, Matsuura A, Takemura H, et al. On-pump beating-heart coronary artery bypass grafting after acute myocardial infarction has lower mortality and morbidity. J Thorac Cardiovasc Surg. Mar. 2008;135(3):521-6. X-1,X-2,X-6,X-7,X-8. [pmid: 18329463].
2075 Miyata H, Motomura N, Ueda Y, et al. Effect of procedural volume on outcome of coronary artery bypass graft surgery in Japan: implication toward public reporting and minimal volume standards. J Thorac Cardiovasc Surg. Jun. 2008;135(6):1306-12. X-1,X-6,X-8. [pmid: 18544377].
2076 Mizutani S, Matsuura A, Miyahara K, et al. On-pump beating-heart coronary artery bypass: a propensity matched analysis. Ann Thorac Surg. Apr. 2007;83(4):1368-73. X-1,X-7,X-8. [pmid: 17383341].
2077 Mo VY, De Lemos JA. Individualizing therapy in acute coronary syndromes: using a multiple biomarker approach for diagnosis, risk stratification, and guidance of therapy. Curr Cardiol Rep. Jul. 2004;6(4):273-8. X-1,X-2,X-4,X-5,X-6. [pmid: 15182604].
2078 Mobasseri S, Hendel RC. Cardiac imaging in women: use of radionuclide myocardial perfusion imaging and echocardiography for acute chest pain. Cardiol Rev. May-Jun. 2002;10(3):149-60. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12047793].
2079 Mochari H, Grbic JT, Mosca L. Usefulness of self-reported periodontal disease to identify individuals with elevated inflammatory markers at risk of cardiovascular disease. Am J Cardiol. Dec. 1. 2008;102(11):1509-13. X-1,X-5,X-6. [pmid: 19026305].
2080 Mockel M, Gerhardt W, Heller G Jr, et al. Validation of NACB and IFCC guidelines for the use of cardiac markers for early diagnosis and risk assessment in patients with acute coronary syndromes. Clin Chim Acta. Jan. 2001;303(1-2):167-79. X-1. [pmid: 11163037].
2081 Mockel M, Muller R, Vollert JO, et al. Lipoprotein-associated phospholipase A2 for early risk stratification in patients with suspected acute coronary syndrome: a multi-marker approach: the North Wuerttemberg and Berlin Infarction Study-II (NOBIS-II). Clin Res Cardiol. Sep. 2007;96(9):604-12. X-1,X-5. [pmid: 17593313].
2082 Mohlenkamp S, Lehmann N, Breuckmann F, et al. Running: the risk of coronary events : Prevalence and prognostic relevance of coronary atherosclerosis in marathon runners. Eur Heart J. Aug. 2008;29(15):1903-10. X-2,X-7. [pmid: 18426850].
2083 Mohlenkamp S, Schmermund A, Kroger K, et al. Coronary atherosclerosis and cardiovascular risk in masters male marathon runners. Rationale and design of the “marathon study”. Herz. Sep. 2006;31(6):575-85. X-1G,X-2,X-4,X-5,X-6,X-7. [pmid: 17036189].
2084 Molina CA, Alvarez-Sabin J, Montaner J, et al. Thrombolysis-related hemorrhagic infarction: a marker of early reperfusion, reduced infarct size, and improved outcome in patients with proximal middle cerebral artery occlusion. Stroke. Jun. 2002;33(6):1551-6. X-1,X-2,X-6,X-7,X-8. [pmid: 12052990].
2085 Molina CA, Montaner J, Abilleira S, et al. Timing of spontaneous recanalization and risk of hemorrhagic transformation in acute cardioembolic stroke. Stroke. May. 2001;32(5):1079-84. X-1,X-6,X-7,X-8. [pmid: 11340213].
2086 Moller J, Ahlbom A, Hulting J, et al. Sexual activity as a trigger of myocardial infarction. A case-crossover analysis in the Stockholm Heart Epidemiology Programme (SHEEP). Heart. Oct. 2001;86(4):387-90. X-1,X-8. [pmid: 11559674].
2087 Moller JE, Hillis GS, Oh JK, et al. Prognostic importance of secondary pulmonary hypertension after acute myocardial infarction. Am J Cardiol. Jul. 15. 2005;96(2):199-203. X-1,X-8. [pmid: 16018841].
2088 Moller JE, Hillis GS, Oh JK, et al. Wall motion score index and ejection fraction for risk stratification after acute myocardial infarction. Am Heart J. Feb. 2006;151(2):419-25. X-1,X-6,X-8. [pmid: 16442909].
2089 Molon G, Targher G, Costa A, et al. Measurement of microvolt T-wave alternans, a new arrhythmic risk stratification test, in Type 2 diabetic patients without clinical cardiovascular disease. Diabet Med. Feb. 2006;23(2):207-10. X-5,X-6,X-7. [pmid: 16433721].
2090 Mondillo S, Agricola E, Ammaturo T, et al. Prognostic value of dipyridamole stress echocardiography in hypertensive patients with left ventricular hypertrophy, chest pain and resting electrocardiographic repolarization abnormalities. Can J Cardiol. May. 2001;17(5):571-7. X-7,X-8. [pmid: 11381279].
2091 Mondillo S, Ballo P, Agricola E, et al. Noninvasive tests for risk stratification in major vascular surgery. Vasa. Aug. 2002;31(3):195-201. X-1,X-7. [pmid: 12236025].
2092 Monnig G, Eckardt L, Wedekind H, et al. Electrocardiographic risk stratification in families with congenital long QT syndrome. Eur Heart J. Sep. 2006;27(17):2074-80. X-1,X-5,X-6. [pmid: 16882679].
2093 Monserrat L, Elliott PM, Gimeno JR, et al. Non-sustained ventricular tachycardia in hypertrophic cardiomyopathy: an independent marker of sudden death risk in young patients. J Am Coll Cardiol. Sep. 3. 2003;42(5):873-9. X-1F,X-2,X-6. [pmid: 12957435].
2094 Montaner J, Alvarez-Sabin J, Molina CA, et al. Matrix metalloproteinase expression is related to hemorrhagic transformation after cardioembolic stroke. Stroke. Dec. 1. 2001;32(12):2762-7. X-1,X-2,X-6,X-7,X-8. [pmid: 11739970].
2095 Montgomery AA, Fahey T, MacKintosh C, et al. Estimation of cardiovascular risk in hypertensive patients in primary care. Br J Gen Pract. Feb. 2000;50(451):127-8. X-1. [pmid: 10750210].
2096 Moon JC, McKenna WJ, McCrohon JA, et al. Toward clinical risk assessment in hypertrophic cardiomyopathy with gadolinium cardiovascular magnetic resonance. J Am Coll Cardiol. May. 7. 2003;41(9):1561-7. X-1,X-5,X-6. [pmid: 12742298].
2097 Moore DF, Li H, Jeffries N, et al. Using peripheral blood mononuclear cells to determine a gene expression profile of acute ischemic stroke: a pilot investigation. Circulation. Jan. 18. 2005;111(2):212-21. X-1,X-5,X-6,X-7,X-8. [pmid: 15630028].
2098 Moore WS. For severe carotid stenosis found on ultrasound, further arterial evaluation is unnecessary. Stroke. Jul. 2003;34(7):1816-7. discussion 1819. X-1. [pmid: 12829871].
2099 Mora S, Redberg RF, Cui Y, et al. Ability of exercise testing to predict cardiovascular and all-cause death in asymptomatic women: a 20-year follow-up of the lipid research clinics prevalence study. JAMA. Sep. 24. 2003;290(12):1600-7. X-1F,X-2. [pmid: 14506119].
2100 Mora S, Redberg RF, Sharrett AR, et al. Enhanced risk assessment in asymptomatic individuals with exercise testing and Framingham risk scores. Circulation. Sep. 13. 2005;112(11):1566-72. X-1F,X-2. [pmid: 16144993].
2101 Mora S, Rifai N, Buring JE, et al. Additive value of immunoassay-measured fibrinogen and high-sensitivity C-reactive protein levels for predicting incident cardiovascular events. Circulation. Aug. 1. 2006;114(5):381-7. X-1F,X-2. [pmid: 16864722].
2102 Mora S, Yanek LR, Moy TF, et al. Interaction of body mass index and framingham risk score in predicting incident coronary disease in families. Circulation. Apr. 19. 2005;111(15):1871-6. X-2. [pmid: 15837938].
2103 Moran PJ, Ghidella T, Power G, et al. The use of Lee and co-workers' index to assist a risk adjusted audit of perioperative cardiac outcome. Anaesth Intensive Care. Mar. 2008;36(2):167-73. X-1. [pmid: 18361006].
2104 Morange PE, Blankenberg S, Alessi MC, et al. Prognostic value of plasma tissue factor and tissue factor pathway inhibitor for cardiovascular death in patients with coronary artery disease: the AtheroGene study. J Thromb Haemost. Mar. 2007;5(3):475-82. X-1,X-8. [pmid: 17204132].
2105 Moretti EW, Newman MF, Muhlbaier LH, et al. Effects of decreased preoperative endotoxin core antibody levels on long-term mortality after coronary artery bypass graft surgery. Arch Surg. Jul. 2006;141(7):637-41. discussion 642. X-1,X-8. [pmid: 16847232].
2106 Morgenstern LB, Viscoli CM, Kernan WN, et al. Use of Ephedra-containing products and risk for hemorrhagic stroke. Neurology. Jan. 14. 2003;60(1):132-5. X-1,X-2,X-5,X-7. [pmid: 12525737].
2107 Morikawa Y, Ohashi Y, Harada K, et al. Coronary risks after high-dose gamma-globulin in children with Kawasaki disease. Pediatr Int. Oct. 2000;42(5):464-9. X-1. [pmid: 11059532].
2108 Morise A, Evans M, Jalisi F, et al. A pretest prognostic score to assess patients undergoing exercise or pharmacological stress testing. Heart. Feb. 2007;93(2):200-4. X-1,X-5,X-8. [pmid: 17228070].
2109 Morise AP. Comparison of the Diamond-Forrester method and a new score to estimate the pretest probability of coronary disease before exercise testing. Am Heart J. Oct. 1999;138(4 Pt 1):740-5. X-1,X-6,X-7,X-8. [pmid: 10502221].
2110 Morris RW, Walker M, Lennon LT, et al. Hard drinking water does not protect against cardiovascular disease: new evidence from the British Regional Heart Study. Eur J Cardiovasc Prev Rehabil. Apr. 2008;15(2):185-9. X-1,X-2. [pmid: 18391646].
2111 Morris RW, Whincup PH, Papacosta O, et al. Inequalities in coronary revascularisation during the 1990s: evidence from the British regional heart study. Heart. May. 2005;91(5):635-40. X-1,X-8. [pmid: 15831650].
2112 Morrison AC, Bare LA, Chambless LE, et al. Prediction of coronary heart disease risk using a genetic risk score: the Atherosclerosis Risk in Communities Study. Am J Epidemiol. Jul. 1. 2007;166(1):28-35. X-1. [pmid: 17443022].
2113 Morrow DA, Antman EM, Charlesworth A, et al. TIMI risk score for ST-elevation myocardial infarction: A convenient, bedside, clinical score for risk assessment at presentation: An intravenous nPA for treatment of infarcting myocardium early II trial substudy. Circulation. Oct. 24. 2000;102(17):2031-7. X-1,X-8. [pmid: 11044416].
2114 Morrow DA, Antman EM, Murphy SA, et al. The Risk Score Profile: a novel approach to characterising the risk of populations enrolled in clinical studies. Eur Heart J. Jul. 2004;25(13):1139-45. X-1,X-5,X-6. [pmid: 15231372].
2115 Morrow DA, Antman EM, Parsons L, et al. Application of the TIMI risk score for ST-elevation MI in the National Registry of Myocardial Infarction 3. JAMA. Sep. 19. 2001;286(11):1356-9. X-1,X-8. [pmid: 11560541].
2116 Morrow DA, Antman EM, Snapinn SM, et al. An integrated clinical approach to predicting the benefit of tirofiban in non-ST elevation acute coronary syndromes. Application of the TIMI Risk Score for UA/NSTEMI in PRISM-PLUS. Eur Heart J. Feb. 2002;23(3):223-9. X-1,X-8. [pmid: 11792137].
2117 Morrow DA, de Lemos JA, Blazing MA, et al. Prognostic value of serial B-type natriuretic peptide testing during follow-up of patients with unstable coronary artery disease. JAMA. Dec. 14. 2005;294(22):2866-71. X-1,X-6,X-8. [pmid: 16352794].
2118 Morrow DA, de Lemos JA, Sabatine MS, et al. Evaluation of B-type natriuretic peptide for risk assessment in unstable angina/non-ST-elevation myocardial infarction: B-type natriuretic peptide and prognosis in TACTICS-TIMI 18. J Am Coll Cardiol. Apr. 16. 2003;41(8):1264-72. X-1,X-6,X-8. [pmid: 12706919].
2119 Morrow DA, Sabatine MS, Brennan ML, et al. Concurrent evaluation of novel cardiac biomarkers in acute coronary syndrome: myeloperoxidase and soluble CD40 ligand and the risk of recurrent ischaemic events in TACTICS-TIMI 18. Eur Heart J. May. 2008;29(9):1096-102. X-1,X-2,X-8. [pmid: 18339606].
2120 Mosca L. Absolute risk assessment in the clinical setting. Am J Med. Aug. 23. 1999;107(2A):7S-9S. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9.
2121 Moscucci M, Eagle KA, Share D, et al. Public reporting and case selection for percutaneous coronary interventions: an analysis from two large multicenter percutaneous coronary intervention databases. J Am Coll Cardiol. Jun. 7. 2005;45(11):1759-65. X-1,X-8. [pmid: 15936602].
2122 Moscucci M, Kline-Rogers E, Share D, et al. Simple bedside additive tool for prediction of in-hospital mortality after percutaneous coronary interventions. Circulation. Jul. 17. 2001;104(3):263-8. X-1,X-8. [pmid: 11457742].
2123 Moscucci M, Muller DW, Watts CM, et al. Reducing costs and improving outcomes of percutaneous coronary interventions. Am J Manag Care. May. 2003;9(5):365-72. X-1,X-8. [pmid: 12744298].
2124 Moscucci M, O'Connor GT, Ellis SG, et al. Validation of risk adjustment models for in-hospital percutaneous transluminal coronary angioplasty mortality on an independent data set. J Am Coll Cardiol. Sep. 1999;34(3):692-7. X-1,X-8. [pmid: 10483949].
2125 Moser KW, O'Keefe JH Jr, Bateman TM, et al. Coronary calcium screening in asymptomatic patients as a guide to risk factor modification and stress myocardial perfusion imaging. J Nucl Cardiol. Nov-Dec. 2003;10(6):590-8. X-1,X-6. [pmid: 14668770].
2126 Mosley WJ 2nd, Greenland P, Garside DB, et al. Predictive utility of pulse pressure and other blood pressure measures for cardiovascular outcomes. Hypertension. Jun. 2007;49(6):1256-64. X-1F. [pmid: 17420336].
2127 Moss AJ. MADIT-I and MADIT-II. J Cardiovasc Electrophysiol. Sep. 2003;14(9 Suppl):S96-8. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12950528].
2128 Moss AJ, Daubert J, Zareba W. MADIT-II: clinical implications. Card Electrophysiol Rev. Dec. 2002;6(4):463-5. X-1,X-2,X-4,X-5,X-6. [pmid: 12438829].
2129 Moss AJ, Fadl Y, Zareba W, et al. Survival benefit with an implanted defibrillator in relation to mortality risk in chronic coronary heart disease. Am J Cardiol. Sep. 1. 2001;88(5):516-20. X-1,X-8. [pmid: 11524060].
2130 Moss AJ, Ryan D, Oakes D, et al. Atherosclerotic risk genotypes and recurrent coronary events after myocardial infarction. Am J Cardiol. Jul. 15. 2005;96(2):177-82. X-1,X-8. [pmid: 16018837].
2131 Moss SE, Klein R, Klein BE. Association of cigarette smoking with diabetic retinopathy. Diabetes Care. Feb. 1991;14(2):119-26. X-1. [pmid: 2060413].
2132 Motomura N, Miyata H, Tsukihara H, et al. First report on 30-day and operative mortality in risk model of isolated coronary artery bypass grafting in Japan. Ann Thorac Surg. Dec. 2008;86(6):1866-72. X-1,X-8. [pmid: 19021998].
2133 Motomura N, Miyata H, Tsukihara H, et al. Risk model of thoracic aortic surgery in 4707 cases from a nationwide single-race population through a web-based data entry system: the first report of 30-day and 30-day operative outcome risk models for thoracic aortic surgery. Circulation. Sep. 30. 2008;118(14 Suppl):S153-9. X-1,X-8. [pmid: 18824747].
2134 Mousa A, Yilmaz A. Comparative analysis on wavelet-based detection of finite duration low-amplitude signals related to ventricular late potentials. Physiol Meas. Dec. 2004;25(6):1443-57. X-1. [pmid: 15712723].
2135 Mouzopoulos G, Kouvaris C, Antonopoulos D, et al. Perioperative creatine phosphokinase (CPK) and troponin I trends after elective hip surgery. J Trauma. Aug. 2007;63(2):388-93. X-1,X-6. [pmid: 17693841].
2136 Mowatt G, Brazzelli M, Gemmell H, et al. Systematic review of the prognostic effectiveness of SPECT myocardial perfusion scintigraphy in patients with suspected or known coronary artery disease and following myocardial infarction. Nucl Med Commun. Mar. 2005;26(3):217-29. X-1,X-4,X-5,X-8. [pmid: 15722902].
2137 Mozaffarian D, Anker SD, Anand I, et al. Prediction of mode of death in heart failure: the Seattle Heart Failure Model. Circulation. Jul. 24. 2007;116(4):392-8. X-1,X-8. [pmid: 17620506].
2138 Mozaffarian D, Kamineni A, Prineas RJ, et al. Metabolic syndrome and mortality in older adults: the Cardiovascular Health Study. Arch Intern Med. May. 12. 2008;168(9):969-78. X-1F,X-2. [pmid: 18474761].
2139 Mozaffarian D, Longstreth WT Jr, Lemaitre RN, et al. Fish consumption and stroke risk in elderly individuals: the cardiovascular health study. Arch Intern Med. Jan. 24. 2005;165(2):200-6. X-1,X-2. [pmid: 15668367].
2140 Mozumdar A, Roy SK. Validity of an alternative anthropometric trait as cardiovascular diseases risk factor: example from individuals with traumatic lower extremity amputation. Eur J Clin Nutr. Oct. 2006;60(10):1180-8. X-1,X-6. [pmid: 16708069].
2141 Mrowka R, Persson PB, Theres H, et al. Blunted arterial baroreflex causes “pathological” heart rate turbulence. Am J Physiol Regul Integr Comp Physiol. Oct. 2000;279(4):R1171-5. X-1. [pmid: 11003980].
2142 Mueller O, Chang E, Deng D, et al. PROCAM Study: risk prediction for myocardial infarction using microfluidic high-density lipoprotein (HDL) subfractionation is independent of HDL cholesterol. Clin Chem Lab Med. 2008;46(4):490-8. X-1. [pmid: 18605933].
2143 Muhlestein JB, Horne BD, Carlquist JF, et al. Cytomegalovirus seropositivity and C-reactive protein have independent and combined predictive value for mortality in patients with angiographically demonstrated coronary artery disease. Circulation. Oct. 17. 2000;102(16):1917-23. X-1,X-7,X-8. [pmid: 11034939].
2144 Mujahid MS, Diez Roux AV, Morenoff JD, et al. Assessing the measurement properties of neighborhood scales: from psychometrics to ecometrics. Am J Epidemiol. Apr. 15. 2007;165(8):858-67. X-1,X-5,X-7. [pmid: 17329713].
2145 Mukaddirov M, Frapier JM, Demaria RG, et al. Surgical treatment of postinfarction anterior left ventricular aneurysms: linear vs. patch plasty repair. Interact Cardiovasc Thorac Surg. Apr. 2008;7(2):256-61. X-1,X-2,X-6,X-7,X-8. [pmid: 18086691].
2146 Mukamal KJ, Cushman M, Mittleman MA, et al. Alcohol consumption and inflammatory markers in older adults: the Cardiovascular Health Study. Atherosclerosis. Mar. 2004;173(1):79-87. X-1,X-5,X-6. [pmid: 15177126].
2147 Mukamal KJ, Kronmal RA, Tracy RP, et al. Traditional and novel risk factors in older adults: cardiovascular risk assessment late in life. Am J Geriatr Cardiol. Mar-Apr. 2004;13(2):69-80. X-1,X-5,X-6. [pmid: 15010653].
2148 Mukamal KJ, Maclure M, Muller JE, et al. Caffeinated coffee consumption and mortality after acute myocardial infarction. Am Heart J. Jun. 2004;147(6):999-1004. X-1,X-2,X-6,X-8. [pmid: 15199347].
2149 Mule G, Cerasola G. The metabolic syndrome and its relationship to hypertensive target organ damage. J Clin Hypertens (Greenwich). Mar. 2006;8(3):195-201. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16522997].
2150 Mullenix PS, Steele SR, Martin MJ, et al. C-reactive protein level and traditional vascular risk factors in the prediction of carotid stenosis. Arch Surg. Nov. 2007;142(11):1066-71. X-2,X-5,X-6,X-7. [pmid: 18025335].
2151 Mulvihill NT, Foley JB, Murphy RT, et al. Risk stratification in unstable angina and non-Q wave myocardial infarction using soluble cell adhesion molecules. Heart. Jun. 2001;85(6):623-7. X-7,X-8. [pmid: 11359739].
2152 Muneretto C, Bisleri G, Negri A, et al. Left internal thoracic artery-radial artery composite grafts as the technique of choice for myocardial revascularization in elderly patients: a prospective randomized evaluation. J Thorac Cardiovasc Surg. Jan. 2004;127(1):179-84. X-1,X-2,X-6,X-7,X-8. [pmid: 14752429].
2153 Munoz MA, Vila J, Cabanero M, et al. Efficacy of an intensive prevention program in coronary patients in primary care, a randomised clinical trial. Int J Cardiol. Jun. 12. 2007;118(3):312-20. X-1,X-8. [pmid: 17261336].
2154 Munoz R, Duran-Cantolla J, Martinez-Vila E, et al. Severe sleep apnea and risk of ischemic stroke in the elderly. Stroke. Sep. 2006;37(9):2317-21. X-1F,X-2. [pmid: 16888274].
2155 Muntner P, He J, Hamm L, et al. Renal insufficiency and subsequent death resulting from cardiovascular disease in the United States. J Am Soc Nephrol. Mar. 2002;13(3):745-53. X-1F,X-2,X-8. [pmid: 11856780].
2156 Murcia AM, Hennekens CH, Lamas GA, et al. Impact of diabetes on mortality in patients with myocardial infarction and left ventricular dysfunction. Arch Intern Med. Nov. 8. 2004;164(20):2273-9. X-1,X-2,X-8. [pmid: 15534166].
2157 Murphy BM, Elliott PC, Le Grande MR, et al. Living alone predicts 30-day hospital readmission after coronary artery bypass graft surgery. Eur J Cardiovasc Prev Rehabil. Apr. 2008;15(2):210-5. X-1,X-2,X-6,X-7,X-8. [pmid: 18391650].
2158 Murphy BP, Inder TE, Rooks V, et al. Posthaemorrhagic ventricular dilatation in the premature infant: natural history and predictors of outcome. Arch Dis Child Fetal Neonatal Ed. Jul. 2002;87(1):F37-41. X-1,X-2,X-6. [pmid: 12091289].
2159 Murtaugh MA, Jacobs DR Jr, Yu X, et al. Correlates of urinary albumin excretion in young adult blacks and whites: the Coronary Artery Risk Development in Young Adults Study. Am J Epidemiol. Oct. 1. 2003;158(7):676-86. X-1F,X-2,X-6. [pmid: 14507604].
2160 Muscari A, De Pascalis S, Cenni A, et al. Determinants of mean platelet volume (MPV) in an elderly population: relevance of body fat, blood glucose and ischaemic electrocardiographic changes. Thromb Haemost. Jun. 2008;99(6):1079-84. X-1,X-5,X-6. [pmid: 18521511].
2161 Musher DM, Rueda AM, Kaka AS, et al. The association between pneumococcal pneumonia and acute cardiac events. Clin Infect Dis. Jul. 15. 2007;45(2):158-65. X-1,X-5,X-6,X-7,X-8. [pmid: 17578773].
2162 Musicant SE, Taylor LM Jr, Peters D, et al. Prospective evaluation of the relationship between C-reactive protein, D-dimer and progression of peripheral arterial disease. J Vasc Surg. Apr. 2006;43(4):772-80. discussion 780. X-1. [pmid: 16616235].
2163 Musunuru K, Kral BG, Blumenthal RS, et al. The use of high-sensitivity assays for C-reactive protein in clinical practice. Nat Clin Pract Cardiovasc Med. Oct. 2008;5(10):621-35. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18711404].
2164 Myers J. Optimizing the clinical exercise test: a commentary on the exercise protocol. Heart Fail Monit. 2004;4(3):82-9. X-1,X-2,X-4,X-5,X-7,X-8. [pmid: 15772703].
2165 Myles RC, Jackson CE, Tsorlalis I, et al. Is microvolt T-wave alternans the answer to risk stratification in heart failure?. Circulation. Dec. 18. 2007;116(25):2984-91. X-1G,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 18086940].
2166 Mytton O, Gray A, Rayner M, et al. Could targeted food taxes improve health?. J Epidemiol Community Health. Aug. 2007;61(8):689-94. X-1,X-2,X-5,X-6. [pmid: 17630367].
2167 Nabar A, Rodriguez LM, Batra RK, et al. Echocardiographic predictors of survival in patients undergoing radiofrequency ablation of postinfarct clinical ventricular tachycardia. J Cardiovasc Electrophysiol. Jan. 2002;13(1 Suppl):S118-21. X-1,X-7,X-8. [pmid: 11852887].
2168 Nagahara D, Nakata T, Hashimoto A, et al. Early positive biomarker in relation to myocardial necrosis and impaired fatty acid metabolism in patients presenting with acute chest pain at an emergency room. Circ J. Apr. 2006;70(4):419-25. X-1,X-6,X-7,X-8. [pmid: 16565558].
2169 Nagai Y, Kitagawa K, Matsumoto M. Implication of earlier carotid atherosclerosis for stroke and its subtypes. Prev Cardiol. Spring. 2003;6(2):99-103. X-1,X-6. [pmid: 12732796].
2170 Nagai Y, Kitagawa K, Sakaguchi M, et al. Significance of earlier carotid atherosclerosis for stroke subtypes. Stroke. Aug. 2001;32(8):1780-5. X-1F,X-2,X-5,X-8. [pmid: 11486105].
2171 Nagai Y, Kitagawa K, Yamagami H, et al. Carotid artery intima-media thickness and plaque score for the risk assessment of stroke subtypes. Ultrasound Med Biol. Oct. 2002;28(10):1239-43. X-1,X-5,X-6. [pmid: 12467849].
2172 Nagamachi S, Fujita S, Nishii R, et al. Prognostic value of cardiac I-123 metaiodobenzylguanidine imaging in patients with non-insulin-dependent diabetes mellitus. J Nucl Cardiol. Jan-Feb. 2006;13(1):34-42. X-7. [pmid: 16464715].
2173 Naghavi M. Preventive Cardiology: the SHAPE of the future. A Synopsis from the Screening for Heart Attack Prevention and Education (SHAPE) Task Force report. Herz. Aug. 2007;32(5):356-61. X-2,X-3,X-4,X-5. [pmid: 17687524].
2174 Naidech A, Khasani S, Lafaye K, et al. Chart review and pilot study of blood pressure control in acute ischemic stroke. J La State Med Soc. Mar-Apr. 2003;155(2):99-102. X-1,X-5,X-6,X-7. [pmid: 12778994].
2175 Naidu SS, Vlachos H, Faxon D, et al. Usefulness of noncoronary vascular disease in predicting adverse events in the year following percutaneous coronary intervention. Am J Cardiol. Mar. 1. 2005;95(5):575-80. X-1,X-8. [pmid: 15721094].
2176 Nair GV, Chaput LA, Vittinghoff E, et al. Pulse pressure and cardiovascular events in postmenopausal women with coronary heart disease. Chest. May. 2005;127(5):1498-506. X-1,X-8. [pmid: 15888820].
2177 Nakagawa S, Pedersen L, Olsen ML, et al. Antipsychotics and risk of first-time hospitalization for myocardial infarction: a population-based case-control study. J Intern Med. Nov. 2006;260(5):451-8. X-1,X-5. [pmid: 17040251].
2178 Nakaguchi H, Teraoka A. Relationship between the occurrence of spontaneous intracerebral hemorrhage and holidays and traditionally unlucky days in Fukuyama City, Hiroshima Prefecture, Japan. J Stroke Cerebrovasc Dis. Sep-Oct. 2007;16(5):194-8. X-1,X-2,X-5,X-7,X-8. [pmid: 17845915].
2179 Nakamura K, Onitsuka T, Yano M, et al. Predictor of neurologic dysfunction after elective thoracic aorta repair using selective cerebral perfusion. Scand Cardiovasc J. Apr. 2005;39(1-2):96-101. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 16097422].
2180 Nakamura Y, Moss AJ, Brown MW, et al. Ethnicity and long-term outcome after an acute coronary event. Multicenter Myocardial Ischemia Research Group. Am Heart J. Sep. 1999;138(3 Pt 1):500-6. X-1,X-6,X-8. [pmid: 10467201].
2181 Nakamura Y, Moss AJ, Brown MW, et al. Long-term nitrate use may be deleterious in ischemic heart disease: A study using the databases from two large-scale postinfarction studies. Multicenter Myocardial Ischemia Research Group. Am Heart J. Sep. 1999;138(3 Pt 1):577-85. X-1,X-8. [pmid: 10467211].
2182 Nakatani D, Sakata Y, Sato H, et al. Clinical impact of metabolic syndrome and its additive effect with smoking on subsequent cardiac events after acute myocardial infarction. Am J Cardiol. Apr. 1. 2007;99(7):885-9. X-1F,X-2,X-8. [pmid: 17398177].
2183 Nakatani D, Sato H, Sakata Y, et al. Effect of intracoronary thrombectomy on 30-day mortality in patients with acute myocardial infarction. Am J Cardiol. Oct. 15. 2007;100(8):1212-7. X-1,X-6,X-8. [pmid: 17920359].
2184 Nakazawa G, Tanabe K, Aoki J, et al. Impact of renal insufficiency on clinical and angiographic outcomes following percutaneous coronary intervention with sirolimus-eluting stents. Catheter Cardiovasc Interv. May. 1. 2007;69(6):808-14. X-1,X-2,X-8. [pmid: 17191206].
2185 Nambi V, Hoogeveen RC, Chambless L, et al. Lipoprotein-associated phospholipase A2 and high-sensitivity C-reactive protein improve the stratification of ischemic stroke risk in the Atherosclerosis Risk in Communities (ARIC) study. Stroke. Feb. 2009;40(2):376-81. X-5. [pmid: 19095974].
2186 Nanasato M, Hirayama H, Ando A, et al. Incremental predictive value of myocardial scintigraphy with 123I-BMIPP in patients with acute myocardial infarction treated with primary percutaneous coronary intervention. Eur J Nucl Med Mol Imaging. Nov. 2004;31(11):1512-21. X-1,X-7,X-8. [pmid: 15232655].
2187 Nanchahal K, Ashton WD, Wood DA. Alcohol consumption, metabolic cardiovascular risk factors and hypertension in women. Int J Epidemiol. Feb. 2000;29(1):57-64. X-1,X-2,X-5,X-6. [pmid: 10750604].
2188 Nanchahal K, Duncan JR, Durrington PN, et al. Analysis of predicted coronary heart disease risk in England based on Framingham study risk appraisal models published in 1991 and 2000. BMJ. Jul. 27. 2002;325(7357):194-5. X-1,X-2,X-5,X-6. [pmid: 12142307].
2189 Naqvi TZ. Ultrasound vascular screening for cardiovascular risk assessment. Why, when and how?. Minerva Cardioangiol. Feb. 2006;54(1):53-67. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16467742].
2190 Narayan SM. T-wave alternans testing for ventricular arrhythmias. Prog Cardiovasc Dis. Sep-Oct. 2008;51(2):118-27. X-1,X-2,X-4,X-5,X-6. [pmid: 18774011].
2191 Nashef SA, Roques F, Hammill BG, et al. Validation of European System for Cardiac Operative Risk Evaluation (EuroSCORE) in North American cardiac surgery. Eur J Cardiothorac Surg. Jul. 2002;22(1):101-5. X-1,X-8. [pmid: 12103381].
2192 Nashef SA, Roques F, Michel P, et al. European system for cardiac operative risk evaluation (EuroSCORE). Eur J Cardiothorac Surg. Jul. 1999;16(1):9-13. X-1,X-8. [pmid: 10456395].
2193 Nasir K, Budoff MJ, Post WS, et al. Electron beam CT versus helical CT scans for assessing coronary calcification: current utility and future directions. Am Heart J. Dec. 2003;146(6):969-77. X-1,X-2,X-4,X-5,X-6. [pmid: 14660987].
2194 Nasir K, Raggi P, Rumberger JA, et al. Electron beam tomography in women. Is it a valuable test?. Cardiol Rev. Jul-Aug. 2005;13(4):174-83. X-1,X-2,X-4,X-5,X-7. [pmid: 15949051].
2195 Nasser SA, Lai Z, O'Connor S, et al. Does earlier attainment of blood pressure goal translate into fewer cardiovascular events?. Curr Hypertens Rep. Oct. 2008;10(5):398-404. X-1,X-2,X-4,X-5,X-6,X-7. [pmid: 18775119].
2196 Natarajan S, Lipsitz SR, Rimm E. A simple method of determining confidence intervals for population attributable risk from complex surveys. Stat Med. Jul. 30. 2007;26(17):3229-39. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 17309113].
2197 Nault P, Elkouri S, Daniel V, et al. Modification of outcomes by lowering ischemic events after reconstruction of extracranial vessels (MOLIERE): an internet-based prospective study to evaluate and improve the effectiveness of carotid endarterectomy. J Vasc Surg. Mar. 2008;47(3):530-6. X-1,X-2,X-5,X-8. [pmid: 18295104].
2198 Navare SM, Katten D, Johnson LL, et al. Risk stratification with electrocardiographic-gated dobutamine stress technetium-99m sestamibi single-photon emission tomographic imaging: value of heart rate response and assessment of left ventricular function. J Am Coll Cardiol. Feb. 21. 2006;47(4):781-8. X-1D,X-1F,X-2,X-8(95%). [pmid: 16487845].
2199 Ndrepepa G, Berger PB, Mehilli J, et al. Periprocedural bleeding and 1-year outcome after percutaneous coronary interventions: appropriateness of including bleeding as a component of a quadruple end point. J Am Coll Cardiol. Feb. 19. 2008;51(7):690-7. X-1,X-8. [pmid: 18279731].
2200 Ndrepepa G, Kastrati A, Braun S, et al. N-terminal probrain natriuretic peptide and C-reactive protein in stable coronary heart disease. Am J Med. Apr. 2006;119(4):355 e1-8. X-1,X-8.
2201 Negassa A, Monrad ES, Bang JY, et al. Tree-structured risk stratification of in-hospital mortality after percutaneous coronary intervention for acute myocardial infarction: a report from the New York State percutaneous coronary intervention database. Am Heart J. Aug. 2007;154(2):322-9. X-1,X-8. [pmid: 17643583].
2202 Nelson JC, Jiang XC, Tabas I, et al. Plasma sphingomyelin and subclinical atherosclerosis: findings from the multi-ethnic study of atherosclerosis. Am J Epidemiol. May. 15. 2006;163(10):903-12. X-1,X-5,X-6. [pmid: 16611667].
2203 Nelson MR, Liew D, Bertram M, et al. Epidemiological modelling of routine use of low dose aspirin for the primary prevention of coronary heart disease and stroke in those aged > or =70. BMJ. Jun. 4. 2005;330(7503):1306. X-1F,X-2,X-5. [pmid: 15908442].
2204 Nemes A, Forster T, Geleijnse ML, et al. Prognostic value of coronary flow reserve and aortic distensibility indices in patients with suspected coronary artery disease. Heart Vessels. May. 2008;23(3):167-73. X-1,X-2,X-5,X-7,X-8. [pmid: 18484159].
2205 Neragi-Miandoab S, Weiner S, Sugarbaker DJ. Incidence of atrial fibrillation after extrapleural pneumonectomy vs. pleurectomy in patients with malignant pleural mesothelioma. Interact Cardiovasc Thorac Surg. Dec. 2008;7(6):1039-42. X-1,X-2,X-6,X-7. [pmid: 18614551].
2206 Nettleton JA, Steffen LM, Ni H, et al. Dietary patterns and risk of incident type 2 diabetes in the Multi-Ethnic Study of Atherosclerosis (MESA). Diabetes Care. Sep. 2008;31(9):1777-82. X-1,X-2,X-6. [pmid: 18544792].
2207 Neuhauser HK, Ellert U, Kurth BM. A comparison of Framingham and SCORE-based cardiovascular risk estimates in participants of the German National Health Interview and Examination Survey 1998. Eur J Cardiovasc Prev Rehabil. Oct. 2005;12(5):442-50. X-5,X-6. [pmid: 16210930].
2208 Neumayer E. Recessions lower (some) mortality rates: evidence from Germany. Soc Sci Med. Mar. 2004;58(6):1037-47. X-1,X-2,X-5,X-6. [pmid: 14723900].
2209 Newby LK, Hasselblad V, Armstrong PW, et al. Time-based risk assessment after myocardial infarction. Implications for timing of discharge and applications to medical decision-making. Eur Heart J. Jan. 2003;24(2):182-9. X-1,X-6. [pmid: 12573275].
2210 Newsome BB, McClellan WM, Coffey CS, et al. Survival advantage of black patients with kidney disease after acute myocardial infarction. Clin J Am Soc Nephrol. Sep. 2006;1(5):993-9. X-1,X-8. [pmid: 17699318].
2211 Ngaage DL, Zehr KJ, Daly RC, et al. Off-pump strategy in high-risk coronary artery bypass reoperations. Mayo Clin Proc. May. 2007;82(5):567-71. X-1,X-6,X-7,X-8. [pmid: 17493423].
2212 Ngamtrairai P, Srimahachota S, Boonyaratavej S, et al. Initial and long-term results of coronary angioplasty: a report from King Chulalongkorn Memorial Hospital. J Med Assoc Thai. Jun. 1. 2002;85:S62-9. X-1,X-2,X-8. [pmid: 12188453].
2213 Nguyen S, McCulloch C, Brakeman P, et al. Being overweight modifies the association between cardiovascular risk factors and microalbuminuria in adolescents. Pediatrics. Jan. 2008;121(1):37-45. X-1,X-2,X-5,X-6,X-8. [pmid: 18166555].
2214 Niccoli G, Ferrante G, Mongiardo R, et al. Predictive value of preintervention C-reactive protein on clinical outcome after directional coronary atherectomy followed by stent implantation. Cardiovasc Revasc Med. Jul-Sep. 2007;8(3):156-60. X-1,X-2,X-6,X-7,X-8. [pmid: 17765643].
2215 Niccoli G, Giubilato S, Russo E, et al. Plasma levels of thromboxane A2 on admission are associated with no-reflow after primary percutaneous coronary intervention. Eur Heart J. Aug. 2008;29(15):1843-50. X-1,X-2,X-6,X-7,X-8. [pmid: 18617477].
2216 Nichols GA, Hillier TA, Brown JB. Normal fasting plasma glucose and risk of type 2 diabetes diagnosis. Am J Med. Jun. 2008;121(6):519-24. X-1,X-6,X-8. [pmid: 18501234].
2217 Nicklas BJ, Penninx BW, Cesari M, et al. Association of visceral adipose tissue with incident myocardial infarction in older men and women: the Health, Aging and Body Composition Study. Am J Epidemiol. Oct. 15. 2004;160(8):741-9. X-1,X-2. [pmid: 15466496].
2218 Nicol ED, Stirrup J, Reyes E, et al. Sixty-four-slice computed tomography coronary angiography compared with myocardial perfusion scintigraphy for the diagnosis of functionally significant coronary stenoses in patients with a low to intermediate likelihood of coronary artery disease. J Nucl Cardiol. May-Jun. 2008;15(3):311-8. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18513637].
2219 Nicolaides AN, Kakkos SK, Griffin M, et al. Severity of asymptomatic carotid stenosis and risk of ipsilateral hemispheric ischaemic events: results from the ACSRS study. Eur J Vasc Endovasc Surg. Sep. 2005;30(3):275-84. X-1D,X-1F,X-2,X-6,X-8. [pmid: 16130207].
2220 Niebauer J, Sixt S, Zhang F, et al. Contemporary outcome of cardiac catheterizations in 1085 consecutive octogenarians. Int J Cardiol. Feb. 2004;93(2-3):225-30. X-1,X-2,X-6,X-8. [pmid: 14975551].
2221 Nielson C, Fleming RM. Blood glucose and cerebrovascular disease in nondiabetic patients. Angiology. Oct-Nov. 2007;58(5):625-9. X-1E,X-1F,X-2,X-5. [pmid: 18024949].
2222 Nienhuis MB, Ottervanger JP, Bilo HJ, et al. Prognostic value of troponin after elective percutaneous coronary intervention: A meta-analysis. Catheter Cardiovasc Interv. Feb. 15. 2008;71(3):318-24. X-1,X-2,X-4,X-5,X-8. [pmid: 18288753].
2223 Niessner A, Hofmann R, Kypta A, et al. Low high-density lipoprotein cholesterol predicts cardiovascular events after carotid stenting: a long-term survey. J Thromb Haemost. May. 2007;5(5):950-4. X-1,X-8. [pmid: 17367491].
2224 Nieto FJ, Herrington DM, Redline S, et al. Sleep apnea and markers of vascular endothelial function in a large community sample of older adults. Am J Respir Crit Care Med. Feb. 1. 2004;169(3):354-60. X-1,X-6,X-8. [pmid: 14551166].
2225 Nigam A, Bourassa MG, Fortier A, et al. Fasting but not postprandial (postmeal) glycemia predicts the risk of death in subjects with coronary artery disease. Can J Cardiol. Sep. 2007;23(11):873-8. X-1E,X-1F,X-2,X-8. [pmid: 17876378].
2226 Nighoghossian N, Hermier M, Adeleine P, et al. Old microbleeds are a potential risk factor for cerebral bleeding after ischemic stroke: a gradient-echo T2*-weighted brain MRI study. Stroke. Mar. 2002;33(3):735-42. X-1,X-2,X-6,X-7,X-8. [pmid: 11872897].
2227 Nikolsky E, Holmes DR, Mehran R, et al. Impact of platelet glycoprotein IIb/IIIa receptor inhibitors on outcomes of diabetic patients undergoing percutaneous coronary interventions using sirolimus-eluting stents. Catheter Cardiovasc Interv. Jun. 1. 2008;71(7):896-906. X-1,X-4,X-5,X-8. [pmid: 18498145].
2228 Nilsson J, Algotsson L, Hoglund P, et al. Early mortality in coronary bypass surgery: the EuroSCORE versus The Society of Thoracic Surgeons risk algorithm. Ann Thorac Surg. Apr. 2004;77(4):1235-9. discussion 1239-40. X-1,X-6,X-8. [pmid: 15063242].
2229 Nilsson J, Algotsson L, Hoglund P, et al. Comparison of 19 pre-operative risk stratification models in open-heart surgery. Eur Heart J. Apr. 2006;27(7):867-74. X-1,X-6,X-8. [pmid: 16421172].
2230 Nilsson PM. Cardiovascular risk in the metabolic syndrome: fact or fiction?. Curr Cardiol Rep. Nov. 2007;9(6):479-85. X-1E,X-1F,X-2,X-4,X-5,X-6,X-8,X-9. [pmid: 17999873].
2231 Nishimura M, Tokoro T, Nishida M, et al. Myocardial fatty acid imaging identifies a group of hemodialysis patients at high risk for cardiac death after coronary revascularization. Kidney Int. Aug. 2008;74(4):513-20. X-1,X-2,X-7,X-8. [pmid: 18528325].
2232 Nishimura M, Tsukamoto K, Hasebe N, et al. Prediction of cardiac death in hemodialysis patients by myocardial fatty acid imaging. J Am Coll Cardiol. Jan. 15. 2008;51(2):139-45. X-1,X-2,X-8. [pmid: 18191738].
2233 Nishizawa Y, Shoji T, Kakiya R, et al. Non-high-density lipoprotein cholesterol (non-HDL-C) as a predictor of cardiovascular mortality in patients with end-stage renal disease. Kidney Int Suppl. May. 2003;(84):S117-20. X-1. [pmid: 12694324].
2234 Noda M, Takagi A, Kuwatsuru R, et al. Prognostic significance of multiple-detector computed tomography in conjunction with TIMI risk score for patients with non-ST elevation acute coronary syndrome. Heart Vessels. May. 2008;23(3):161-6. X-1,X-2,X-7,X-8. [pmid: 18484158].
2235 Noordzij PG, Boersma E, Bax JJ, et al. Prognostic value of routine preoperative electrocardiography in patients undergoing noncardiac surgery. Am J Cardiol. Apr. 1. 2006;97(7):1103-6. X-1,X-5. [pmid: 16563926].
2236 Norata GD, Ongari M, Garlaschelli K, et al. Effect of the -420C/G variant of the resistin gene promoter on metabolic syndrome, obesity, myocardial infarction and kidney dysfunction. J Intern Med. Jul. 2007;262(1):104-12. X-1,X-5,X-6. [pmid: 17598818].
2237 Nordenstrom E, Westerdahl J, Lindergard B, et al. Multifactorial risk profile for bone fractures in primary hyperparathyroidism. World J Surg. Dec. 2002;26(12):1463-7. X-1,X-5,X-6. [pmid: 12297914].
2238 Norkiene I, Ringaitiene D, Misiuriene I, et al. Incidence and precipitating factors of delirium after coronary artery bypass grafting. Scand Cardiovasc J. Jun. 2007;41(3):180-5. X-1,X-6,X-7,X-8. [pmid: 17487768].
2239 Norris CM, Saunders LD, Ghali WA, et al. Health-related quality of life outcomes of patients with coronary artery disease treated with cardiac surgery, percutaneous coronary intervention or medical management. Can J Cardiol. Oct. 2004;20(12):1259-66. X-1,X-2,X-8. [pmid: 15494780].
2240 Norris K, Bourgoigne J, Gassman J, et al. Cardiovascular outcomes in the African American Study of Kidney Disease and Hypertension (AASK) Trial. Am J Kidney Dis. Nov. 2006;48(5):739-51. X-1,X-2. [pmid: 17059993].
2241 Northrup KL, Cottrell LA, Wittberg RA. L.I.F.E.: a school-based heart-health screening and intervention program. J Sch Nurs. Feb. 2008;24(1):28-35. X-1,X-2,X-5,X-6. [pmid: 18220453].
2242 Novick RJ, Fox SA, Stitt LW, et al. Direct comparison of risk-adjusted and non-risk-adjusted CUSUM analyses of coronary artery bypass surgery outcomes. J Thorac Cardiovasc Surg. Aug. 2006;132(2):386-91. X-1,X-8. [pmid: 16872967].
2243 Novick RJ, Fox SA, Stitt LW, et al. Effect of off-pump coronary artery bypass grafting on risk-adjusted and cumulative sum failure outcomes after coronary artery surgery. J Card Surg. Nov-Dec. 2002;17(6):520-8. X-1,X-6,X-8. [pmid: 12643463].
2244 Nowicki ER, Birkmeyer NJ, Weintraub RW, et al. Multivariable prediction of in-hospital mortality associated with aortic and mitral valve surgery in Northern New England. Ann Thorac Surg. Jun. 2004;77(6):1966-77. X-1. [pmid: 15172248].
2245 Nunez-Gil IJ, Fernandez-Ortiz A, Perez-Isla L, et al. Clinical and prognostic comparison between left ventricular transient dyskinesia and a first non-ST-segment elevation acute coronary syndrome. Coron Artery Dis. Nov. 2008;19(7):449-53. X-1,X-2,X-7,X-8. [pmid: 18923239].
2246 Nybo M, Johnsen SP, Dethlefsen C, et al. Lack of observed association between high plasma osteoprotegerin concentrations and ischemic stroke risk in a healthy population. Clin Chem. Dec. 2008;54(12):1969-74. X-1,X-2,X-5,X-8. [pmid: 19042987].
2247 Nys GM, van Zandvoort MJ, de Kort PL, et al. Cognitive disorders in acute stroke: prevalence and clinical determinants. Cerebrovasc Dis. 2007;23(5-6):408-16. X-1,X-6,X-7. [pmid: 17406110].
2248 Obias-Manno D, Wijetunga M. Risk stratification and primary prevention of sudden cardiac death: sudden death prevention. AACN Clin Issues. Jul-Sep. 2004;15(3):404-18. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15475814].
2249 O'Brien MM, Shroyer AL, Moritz TE, et al. Relationship between processes of care and coronary bypass operative mortality and morbidity. Med Care. Jan. 2004;42(1):59-70. X-1,X-8. [pmid: 14713740].
2250 O'Connell DM, Watson ID. Definitive angiographic detection of subarachnoid haemorrhage compared with laboratory assessment of intracranial bleed in CT-negative patients. Ann Clin Biochem. May. 2003;40(Pt 3):269-73. X-1,X-4,X-5,X-6,X-7. [pmid: 12803841].
2251 O'Connor CM, Gattis WA, Hellkamp AS, et al. Comparison of two aspirin doses on ischemic stroke in post-myocardial infarction patients in the warfarin (Coumadin) Aspirin Reinfarction Study (CARS). Am J Cardiol. Sep. 1. 2001;88(5):541-6. X-1,X-8. [pmid: 11524065].
2252 Odegaard K, Borg S, Persson U, et al. The Swedish cost burden of overweight and obesity--evaluated with the PAR approach and a statistical modelling approach. Int J Pediatr Obes. 1. 2008;3:51-7. X-1,X-2,X-5,X-6. [pmid: 18278633].
2253 O'Donoghue M, de Lemos JA, Morrow DA, et al. Prognostic utility of heart-type fatty acid binding protein in patients with acute coronary syndromes. Circulation. Aug. 8. 2006;114(6):550-7. X-1,X-6,X-8. [pmid: 16880323].
2254 Ogasawara K, Mashiba S, Wada Y, et al. A serum amyloid A and LDL complex as a new prognostic marker in stable coronary artery disease. Atherosclerosis. Jun. 2004;174(2):349-56. X-1,X-2,X-7,X-8. [pmid: 15136066].
2255 Ogasawara K, Ogawa A, Yoshimoto T. Cerebrovascular reactivity to acetazolamide and outcome in patients with symptomatic internal carotid or middle cerebral artery occlusion: a xenon-133 single-photon emission computed tomography study. Stroke. Jul. 2002;33(7):1857-62. X-1,X-7,X-8. [pmid: 12105366].
2256 Ohayon J, Finet G, Gharib AM, et al. Necrotic core thickness and positive arterial remodeling index: emergent biomechanical factors for evaluating the risk of plaque rupture. Am J Physiol Heart Circ Physiol. Aug. 2008;295(2):H717-27. X-1,X-2,X-5,X-6. [pmid: 18586893].
2257 Ohira T, Iso H, Imano H, et al. Prospective study of major and minor ST-T abnormalities and risk of stroke among Japanese. Stroke. Dec. 2003;34(12):e250-3. X-6. [pmid: 14615610].
2258 Ohtani T, Ueda Y, Mizote I, et al. Number of yellow plaques detected in a coronary artery is associated with future risk of acute coronary syndrome: detection of vulnerable patients by angioscopy. J Am Coll Cardiol. Jun. 6. 2006;47(11):2194-200. X-1,X-8. [pmid: 16750684].
2259 Oikawa S, Kita T, Mabuchi H, et al. Risk of coronary events in Japanese patients with both hypercholesterolemia and type 2 diabetes mellitus on low-dose simvastatin therapy: implication from Japan Lipid Intervention Trial (J-LIT). Atherosclerosis. Apr. 2007;191(2):440-6. X-1F,X-2. [pmid: 16765358].
2260 Okajima K, Abe Y, Suzuki K, et al. Impact of valvular thickness on stroke recurrence in medically treated patients with stroke. Cerebrovasc Dis. 2007;24(4).
2261 Okamoto K, Horisawa R. The joint effect of oxidative stress and antioxidants on the risk of an aneurysmal rupture subarachnoid hemorrhage: a case-control study in Japan. Ann Epidemiol. May. 2007;17(5):359-63. X-1,X-5,X-8. [pmid: 17462545].
2262 Okamoto K, Horisawa R. Prediction of subarachnoid hemorrhage from a ruptured cerebral aneurysm by discriminant analysis in women. J Stroke Cerebrovasc Dis. Nov-Dec. 2007;16(6):245-50. X-1,X-6,X-7,X-8. [pmid: 18035241].
2263 Okazaki S, Moriwaki H, Minematsu K, et al. Extremely early computed tomography signs in hyperacute ischemic stroke as a predictor of parenchymal hematoma. Cerebrovasc Dis. 2008;25(3):241-6. X-1,X-5,X-6,X-8. [pmid: 18216466].
2264 Okin PM, Devereux RB, Fabsitz RR, et al. Principal component analysis of the T wave and prediction of cardiovascular mortality in American Indians: the Strong Heart Study. Circulation. Feb. 12. 2002;105(6):714-9. X-1F,X-2. [pmid: 11839627].
2265 Okin PM, Devereux RB, Jern S, et al. Regression of electrocardiographic left ventricular hypertrophy during antihypertensive treatment and the prediction of major cardiovascular events. JAMA. Nov. 17. 2004;292(19):2343-9. X-1E,X-1F,X-2,X-8. [pmid: 15547161].
2266 Okin PM, Devereux RB, Nieminen MS, et al. Electrocardiographic strain pattern and prediction of cardiovascular morbidity and mortality in hypertensive patients. Hypertension. Jul. 2004;44(1):48-54. X-1. [pmid: 15173125].
2267 Okosun IS, Choi S, Dent MM, et al. Abdominal obesity defined as a larger than expected waist girth is associated with racial/ethnic differences in risk of hypertension. J Hum Hypertens. May. 2001;15(5):307-12. X-1G,X-2,X-5,X-6. [pmid: 11378832].
2268 Oksala NK, Oksala A, Erkinjuntti T, et al. Long-term survival after ischemic stroke in postmenopausal women is affected by an interaction between smoking and genetic variation in nitric oxide synthases. Cerebrovasc Dis. 2008;26(3):250-8. X-1,X-2,X-8. [pmid: 18648197].
2269 Okuyama H, Hirono O, Tamura H, et al. Impact of aortic arch stiffness on recurrence of stroke in patients with acute ischemic stroke. Circ J. Aug. 2008;72(8):1296-302. X-1,X-2,X-8. [pmid: 18654017].
2270 O'Leary CM, Knuiman MW, Divitini ML. Homocysteine and cardiovascular disease: a 17-year follow-up study in Busselton. Eur J Cardiovasc Prev Rehabil. Aug. 2004;11(4):350-1. X-1. [pmid: 15292770].
2271 Olenchock BA, Wiviott SD, Murphy SA, et al. Lack of association between soluble CD40L and risk in a large cohort of patients with acute coronary syndrome in OPUS TIMI-16. J Thromb Thrombolysis. Oct. 2008;26(2):79-84. X-1,X-2,X-5,X-8. [pmid: 17917707].
2272 Oliveira A, Barros H, Maciel MJ, et al. Tobacco smoking and acute myocardial infarction in young adults: a population-based case-control study. Prev Med. Apr. 2007;44(4):311-6. X-1,X-2,X-5,X-6,X-8. [pmid: 17239433].
2273 Oliveira SF, Jatene AD, Solimene MC, et al. Coronary artery bypass graft surgery in patients with ischemic cardiomyopathy and severe left ventricular dysfunction: short and long-term results. Heart Surg Forum. 1999;2(1):47-53. X-1,X-2,X-6,X-7,X-8. [pmid: 11276460].
2274 Oliveira-Filho J, Silva SC, Trabuco CC, et al. Detrimental effect of blood pressure reduction in the first 24 hours of acute stroke onset. Neurology. Oct. 28. 2003;61(8):1047-51. X-1,X-5,X-6,X-7,X-8. [pmid: 14581662].
2275 Olsen MH, Hansen TW, Christensen MK, et al. N-terminal pro-brain natriuretic peptide, but not high sensitivity C-reactive protein, improves cardiovascular risk prediction in the general population. Eur Heart J. Jun. 2007;28(11):1374-81. X-1F,X-2,X-8(5.1%). [pmid: 17242007].
2276 Olsen MH, Hansen TW, Christensen MK, et al. Cardiovascular risk prediction by N-terminal pro brain natriuretic peptide and high sensitivity C-reactive protein is affected by age and sex. J Hypertens. Jan. 2008;26(1):26-34. X-1,X-2. [pmid: 18090537].
2277 Olsen MH, Wachtell K, Bella JN, et al. Albuminuria predicts cardiovascular events independently of left ventricular mass in hypertension: a LIFE substudy. J Hum Hypertens. Jun. 2004;18(6):453-9. X-1. [pmid: 15085167].
2278 Olsen MH, Wachtell K, Bella JN, et al. Aortic valve sclerosis and albuminuria predict cardiovascular events independently in hypertension: a losartan intervention for endpoint-reduction in hypertension (LIFE) substudy. Am J Hypertens. Nov. 2005;18(11):1430-6. X-1,X-8. [pmid: 16280277].
2279 Olsen MH, Wachtell K, Ibsen H, et al. Reductions in albuminuria and in electrocardiographic left ventricular hypertrophy independently improve prognosis in hypertension: the LIFE study. J Hypertens. Apr. 2006;24(4):775-81. X-1D,X-2,X-8(~76.6%). [pmid: 16531808].
2280 O'Malley PG, Taylor AJ, Jackson JL, et al. Prognostic value of coronary electron-beam computed tomography for coronary heart disease events in asymptomatic populations. Am J Cardiol. Apr. 15. 2000;85(8):945-8. X-2,X-4,X-5,X-8. [pmid: 10760331].
2281 Omland T, Persson A, Ng L, et al. N-terminal pro-B-type natriuretic peptide and long-term mortality in acute coronary syndromes. Circulation. Dec. 3. 2002;106(23):2913-8. X-1,X-6,X-8. [pmid: 12460871].
2282 Omland T, Sabatine MS, Jablonski KA, et al. Prognostic value of B-Type natriuretic peptides in patients with stable coronary artery disease: the PEACE Trial. J Am Coll Cardiol. Jul. 17. 2007;50(3):205-14. X-1,X-6. [pmid: 17631211].
2283 Onat A, Ceyhan K, Erer B, et al. Systolic, diastolic, and pulse pressures as coronary risk factors in a population with low cholesterol levels: a prospective 10-year evaluation. Clin Cardiol. Feb. 2003;26(2):91-7. X-1F,X-2, (Turkey). [pmid: 12625600].
2284 Onat A, Hergenc G, Turkmen S, et al. Discordance between insulin resistance and metabolic syndrome: features and associated cardiovascular risk in adults with normal glucose regulation. Metabolism. Apr. 2006;55(4):445-52. X-1F,X-2. [pmid: 16546474].
2285 Onat A, Sari I, Yazici M, et al. Plasma triglycerides, an independent predictor of cardiovascular disease in men: a prospective study based on a population with prevalent metabolic syndrome. Int J Cardiol. Mar. 22. 2006;108(1):89-95. X-1F,X-2. [pmid: 16085325].
2286 Onder G, Gambassi G, Landi F, et al. Trends in antihypertensive drugs in the elderly: the decline of thiazides. J Hum Hypertens. May. 2001;15(5):291-7. X-1,X-2,X-6,X-8. [pmid: 11378830].
2287 Onland-Moret NC, van der AD, van der Schouw YT, et al. Analysis of case-cohort data: a comparison of different methods. J Clin Epidemiol. Apr. 2007;60(4):350-5. X-5. [pmid: 17346608].
2288 Oomman A, Ramachandran P. Primary angioplasty: the past, the present and the future. J Assoc Physicians India. Sep. 2001;49:911-5. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 11837762].
2289 Oren A, Vos LE, Uiterwaal CS, et al. The Atherosclerosis Risk in Young Adults (ARYA) study: rationale and design. Eur J Epidemiol. 2003;18(7):715-27. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12952149].
2290 Orlowska-Baranowska E, Baranowski R, Michalek P, et al. Prediction of paroxysmal atrial fibrillation after aortic valve replacement in patients with aortic stenosis: identification of potential risk factors. J Heart Valve Dis. Mar. 2003;12(2):136-41. X-1,X-6. [pmid: 12701782].
2291 Ornato JP, Peberdy MA, Tadler SC, et al. Factors associated with the occurrence of cardiac arrest during hospitalization for acute myocardial infarction in the second national registry of myocardial infarction in the US. Resuscitation. Feb. 2001;48(2):117-23. X-1,X-2,X-5,X-6,X-8. [pmid: 11426473].
2292 Ortiz-Perez JT, Meyers SN, Lee DC, et al. Angiographic estimates of myocardium at risk during acute myocardial infarction: validation study using cardiac magnetic resonance imaging. Eur Heart J. Jul. 2007;28(14):1750-8. X-1,X-5,X-6,X-8. [pmid: 17586811].
2293 Osborn DP, Levy G, Nazareth I, et al. Relative risk of cardiovascular and cancer mortality in people with severe mental illness from the United Kingdom's General Practice Rsearch Database. Arch Gen Psychiatry. Feb. 2007;64(2):242-9. X-2. [pmid: 17283292].
2294 Osswald BR, Tochtermann U, Thomas G, et al. Influence of follow-up response on risk-factor analysis. Thorac Cardiovasc Surg. Feb. 1999;47(1):32-7. X-1,X-8. [pmid: 10218618].
2295 Ostman-Smith I, Wettrell G, Keeton B, et al. Echocardiographic and electrocardiographic identification of those children with hypertrophic cardiomyopathy who should be considered at high-risk of dying suddenly. Cardiol Young. Dec. 2005;15(6):632-42. X-1,X-7,X-8. [pmid: 16297259].
2296 Ostrom MP, Gopal A, Ahmadi N, et al. Mortality incidence and the severity of coronary atherosclerosis assessed by computed tomography angiography. J Am Coll Cardiol. Oct. 14. 2008;52(16):1335-43. X-1,X-2,X-8. [pmid: 18929245].
2297 Otani T, Iwasaki M, Yamamoto S, et al. Alcohol consumption, smoking, and subsequent risk of colorectal cancer in middle-aged and elderly Japanese men and women: Japan Public Health Center-based prospective study. Cancer Epidemiol Biomarkers Prev. Dec. 2003;12(12):1492-500. X-1,X-6. [pmid: 14693743].
2298 Oterdoom LH, van Ree RM, de Vries AP, et al. Urinary creatinine excretion reflecting muscle mass is a predictor of mortality and graft loss in renal transplant recipients. Transplantation. Aug. 15. 2008;86(3):391-8. X-1,X-2,X-6. [pmid: 18698241].
2299 Otsuka M, Hayashi Y, Ueda H, et al. Predictive value of preprocedural fibrinogen concerning coronary stenting. Atherosclerosis. Oct. 2002;164(2):371-8. X-1,X-2,X-8. [pmid: 12204810].
2300 Otsuka T, Kawada T, Katsumata M, et al. Utility of second derivative of the finger photoplethysmogram for the estimation of the risk of coronary heart disease in the general population. Circ J. Mar. 2006;70(3):304-10. X-1,X-5,X-6, (Japan). [pmid: 16501297].
2301 Otsuka T, Kawada T, Katsumata M, et al. High-sensitivity C-reactive protein is associated with the risk of coronary heart disease as estimated by the Framingham Risk Score in middle-aged Japanese men. Int J Cardiol. Sep. 26. 2008;129(2):245-50. X-1,X-2,X-5,X-6. [pmid: 17997174].
2302 Otsuka Y, Miyazaki S, Okumura H, et al. Abnormal glucose tolerance, not small vessel diameter, is a determinant of long-term prognosis in patients treated with balloon coronary angioplasty. Eur Heart J. Nov. 2000;21(21):1790-6. X-1,X-8. [pmid: 11052844].
2303 Ott RA, Gutfinger DE, Alimadadian H, et al. Simplified Parsonnet risk scale identifies limits to early patient discharge. J Card Surg. Sep-Oct. 2000;15(5):316-22. X-1,X-6,X-8. [pmid: 11599823].
2304 Ottesen MM, Dixen U, Torp-Pedersen C, et al. Prehospital behaviour of patients admitted with acute coronary syndrome or witnessed cardiac arrest. Scand Cardiovasc J. Jun. 2003;37(3):141-8. X-1,X-2,X-5,X-6,X-8. [pmid: 12881155].
2305 Otto SJ, Schroder FH, de Koning HJ. Risk of cardiovascular mortality in prostate cancer patients in the Rotterdam randomized screening trial. J Clin Oncol. Sep. 1. 2006;24(25):4184-9. X-1,X-2,X-5,X-8(~35%). [pmid: 16943535].
2306 Ouattara A, Niculescu M, Ghazouani S, et al. Predictive performance and variability of the cardiac anesthesia risk evaluation score. Anesthesiology. Jun. 2004;100(6):1405-10. X-1. [pmid: 15166559].
2307 Oudin A, Bjork J, Stromberg U. Efficiency of two-phase methods with focus on a planned population-based case-control study on air pollution and stroke. Environ Health. 2007;6(34). X-1,X-2,X-5.
2308 Ouzounian M, Lee DS, Gramolini AO, et al. Predict, prevent and personalize: Genomic and proteomic approaches to cardiovascular medicine. Can J Cardiol. Aug. A. 2007;23:28A-33A. X-4,X-5.
2309 Ovbiagele B, Lynn MJ, Saver JL, et al. Leukocyte count and vascular risk in symptomatic intracranial atherosclerosis. Cerebrovasc Dis. 2007;24(2-3):283-8. X-1,X-2. [pmid: 17646693].
2310 Overgaard CB, Ivanov J, Seidelin PH, et al. Thrombocytopenia at baseline is a predictor of inhospital mortality in patients undergoing percutaneous coronary intervention. Am Heart J. Jul. 2008;156(1):120-4. X-1,X-2,X-6,X-8. [pmid: 18585506].
2311 Ozer N, Kilic H, Arslan U, et al. Echocardiographic predictors of left atrial appendage spontaneous echocontrast in patients with stroke and atrial fibrillation. J Am Soc Echocardiogr. Dec. 2005;18(12):1362-5. X-1,X-5,X-6,X-7,X-8. [pmid: 16376767].
2312 Ozgun M, Rink M, Hoffmeier A, et al. Intraindividual comparison of 3D coronary MR angiography and coronary CT angiography. Acad Radiol. Aug. 2007;14(8):910-6. X-1,X-2,X-5,X-6,X-7. [pmid: 17659236].
2313 Pacanowski MA, Gong Y, Cooper-Dehoff RM, et al. beta-adrenergic receptor gene polymorphisms and beta-blocker treatment outcomes in hypertension. Clin Pharmacol Ther. Dec. 2008;84(6):715-21. X-1,X-2,X-6,X-8. [pmid: 18615004].
2314 Pacanowski MA, Zineh I, Li H, et al. Adrenergic gene polymorphisms and cardiovascular risk in the NHLBI-sponsored Women's Ischemia Syndrome Evaluation. J Transl Med. 2008;6:11. X-1,X-2. [pmid: 18331634].
2315 Pacileo M, Cirillo P, De Rosa S, et al. The role of neopterin in cardiovascular disease. Monaldi Arch Chest Dis. Jun. 2007;68(2):68-73. X-1,X-2,X-4,X-5. [pmid: 17886766].
2316 Pacini D, Ranocchi F, Angeli E, et al. Aortic root replacement with composite valve graft. Ann Thorac Surg. Jul. 2003;76(1):90-8. X-1,X-6,X-8. [pmid: 12842520].
2317 Packard CJ, Ford I, Robertson M, et al. Plasma lipoproteins and apolipoproteins as predictors of cardiovascular risk and treatment benefit in the PROspective Study of Pravastatin in the Elderly at Risk (PROSPER). Circulation. Nov. 15. 2005;112(20):3058-65. X-3,X-4,X-5. [pmid: 16275871].
2318 Painter PL, Hector L, Ray K, et al. Effects of exercise training on coronary heart disease risk factors in renal transplant recipients. Am J Kidney Dis. Aug. 2003;42(2):362-9. X-1,X-2,X-6,X-7. [pmid: 12900820].
2319 Palatini P. Exercise testing in asymptomatic subjects: from diagnostic test to prognostic tool?. Eur Heart J. Aug. 2008;29(15):1803-6. X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 18417460].
2320 Palazzuoli A, Deckers J, Calabro A, et al. Brain natriuretic peptide and other risk markers for outcome assessment in patients with non-ST-elevation coronary syndromes and preserved systolic function. Am J Cardiol. Nov. 15. 2006;98(10):1322-8. X-1,X-2,X-8. [pmid: 17134622].
2321 Palazzuoli A, Iovine F, Gallotta M, et al. Emerging cardiac markers in coronary disease: role of brain natriuretic peptide and other biomarkers. Minerva Cardioangiol. Aug. 2007;55(4):491-6. X-1,X-2,X-4,X-5,X-6. [pmid: 17653025].
2322 Palmas W, Pickering TG, Teresi J, et al. Ambulatory blood pressure monitoring and all-cause mortality in elderly people with diabetes mellitus. Hypertension. Feb. 2009;53(2):120-7. X-1,X-2. [pmid: 19124681].
2323 Palmerini T, Marzocchi A, Marrozzini C, et al. Preoperative C-reactive protein levels predict 9-month mortality after coronary artery bypass grafting surgery for the treatment of left main coronary artery stenosis. Eur J Cardiothorac Surg. Apr. 2007;31(4):685-90. X-1,X-7,X-8. [pmid: 17236785].
2324 Palombo D, Vola M, Lucertini G, et al. Cardiac risk assessment of asymptomatic patients by stress echocardiography before infrarenal aortic aneurysm surgery. J Cardiovasc Surg (Torino). Feb. 2005;46(1):31-6. X-1,X-5,X-7.
2325 Panagiotakos DB, Fitzgerald AP, Pitsavos C, et al. Statistical modelling of 10-year fatal cardiovascular disease risk in Greece: the HellenicSCORE (a calibration of the ESC SCORE project). Hellenic J Cardiol. Mar-Apr. 2007;48(2):55-63. X-2,X-5,X-6. [pmid: 17489342].
2326 Panagiotakos DB, Pitsavos C, Arvaniti F, et al. Adherence to the Mediterranean food pattern predicts the prevalence of hypertension, hypercholesterolemia, diabetes and obesity, among healthy adults; the accuracy of the MedDietScore. Prev Med. Apr. 2007;44(4):335-40. X-1,X-5,X-6. [pmid: 17350085].
2327 Panagiotakos DB, Stavrinos V. Methodological issues in cardiovascular epidemiology: the risk of determining absolute risk through statistical models. Vasc Health Risk Manag. 2006;2(3):309-15. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 17326336].
2328 Paniagua R, Amato D, Mujais S, et al. Predictive value of brain natriuretic peptides in patients on peritoneal dialysis: results from the ADEMEX trial. Clin J Am Soc Nephrol. Mar. 2008;3(2):407-15. X-1,X-2,X-6. [pmid: 18199844].
2329 Panico S, Palmieri L, Donfrancesco C, et al. Preventive potential of body mass reduction to lower cardiovascular risk: the Italian Progetto CUORE study. Prev Med. Jul. 2008;47(1):53-60. X-1,X-2. [pmid: 18329091].
2330 Paolucci S, Bragoni M, Coiro P, et al. Quantification of the probability of reaching mobility independence at discharge from a rehabilitation hospital in nonwalking early ischemic stroke patients: a multivariate study. Cerebrovasc Dis. 2008;26(1):16-22. X-1,X-6,X-8. [pmid: 18511867].
2331 Papa A, Emdin M, Passino C, et al. Predictive value of elevated neutrophil-lymphocyte ratio on cardiac mortality in patients with stable coronary artery disease. Clin Chim Acta. Sep. 2008;395(1-2):27-31. X-1,X-2,X-8. [pmid: 18498767].
2332 Papademetriou V, Piller LB, Ford CE, et al. Characteristics and lipid distribution of a large, high-risk, hypertensive population: the lipid-lowering component of the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). J Clin Hypertens (Greenwich). Nov-Dec. 2003;5(6):377-84. X-1,X-6,X-8. [pmid: 14688492].
2333 Papaioannou GI, Heller GV. Risk assessment by myocardial perfusion imaging for coronary revascularization, medical therapy, and noncardiac surgery. Cardiol Rev. Mar-Apr. 2003;11(2):60-72. X-1,X-4. [pmid: 12620131].
2334 Papaioannou GI, Seip RL, Grey NJ, et al. Brachial artery reactivity in asymptomatic patients with type 2 diabetes mellitus and microalbuminuria (from the Detection of Ischemia in Asymptomatic Diabetics-brachial artery reactivity study). Am J Cardiol. Aug. 1. 2004;94(3):294-9. X-1,X-5,X-6,X-7. [pmid: 15276091].
2335 Papathanasiou A, Milionis H, Toumpoulis I, et al. Smoking cessation is associated with reduced long-term mortality and the need for repeat interventions after coronary artery bypass grafting. Eur J Cardiovasc Prev Rehabil. Jun. 2007;14(3):448-50. X-1,X-6,X-8. [pmid: 17568247].
2336 Paramo JA, Beloqui O, Roncal C, et al. Validation of plasma fibrinogen as a marker of carotid atherosclerosis in subjects free of clinical cardiovascular disease. Haematologica. Oct. 2004;89(10):1226-31. X-1,X-2,X-5,X-6. [pmid: 15477208].
2337 Paraskevaidis IA, Tsiapras DP, Karavolias GK, et al. Doppler-derived left ventricular end-diastolic pressure prediction model using the combined analysis of mitral and pulmonary A waves in patients with coronary artery disease and preserved left ventricular systolic function. Am J Cardiol. Oct. 1. 2002;90(7):720-4. X-1,X-5,X-6,X-7. [pmid: 12356384].
2338 Paraskevas KI, Bessias N, Papas TT, et al. Is high-sensitivity C-reactive protein associated with subclinical peripheral atherosclerosis?. Angiology. Feb-Mar. 2009;60(1):8-11. X-1. [pmid: 19190029].
2339 Paraskevas S, Huizinga JD, Loos BG. A systematic review and meta-analyses on C-reactive protein in relation to periodontitis. J Clin Periodontol. Apr. 2008;35(4):277-90. X-1,X-2,X-4,X-5,X-6. [pmid: 18294231].
2340 Parikh NI, Hwang SJ, Larson MG, et al. Chronic kidney disease as a predictor of cardiovascular disease (from the Framingham Heart Study). Am J Cardiol. Jul. 1. 2008;102(1):47-53. X-1F,X-2,X-8. [pmid: 18572034].
2341 Park HK, Ahn HS, Yoon SJ, et al. Comparing risk-adjusted hospital mortality for CABG and AMI patients. J Int Med Res. Jul-Aug. 2005;33(4):425-33. X-1,X-8. [pmid: 16104446].
2342 Park HK, Yoon SJ, Ahn HS, et al. Comparison of risk-adjustment models using administrative or clinical data for outcome prediction in patients after myocardial infarction or coronary bypass surgery in Korea. Int J Clin Pract. Jul. 2007;61(7):1086-90. X-1,X-6,X-8. [pmid: 17537190].
2343 Park JW, Leithauser B, Hill P, et al. Resting magnetocardiography predicts 3-year mortality in patients presenting with acute chest pain without ST segment elevation. Ann Noninvasive Electrocardiol. Apr. 2008;13(2):171-9. X-1D,X-2,X-6,X-8, (Various Countries). [pmid: 18426443].
2344 Park KW. Tests of myocardial function: echocardiography and nuclear medicine studies. Int Anesthesiol Clin. Fall. 2001;39(4):11-9. X-1. [pmid: 11581534].
2345 Parodi G, Carrabba N, Santoro GM, et al. Heart failure and left ventricular remodeling after reperfused acute myocardial infarction in patients with hypertension. Hypertension. Apr. 2006;47(4):706-10. X-1,X-6,X-8. [pmid: 16520403].
2346 Parodi G, Memisha G, Carrabba N, et al. Prevalence, predictors, time course, and long-term clinical implications of left ventricular functional recovery after mechanical reperfusion for acute myocardial infarction. Am J Cardiol. Dec. 15. 2007;100(12):1718-22. X-1,X-6,X-8. [pmid: 18082514].
2347 Parra O, Arboix A, Montserrat JM, et al. Sleep-related breathing disorders: impact on mortality of cerebrovascular disease. Eur Respir J. Aug. 2004;24(2):267-72. X-1,X-2,X-7. [pmid: 15332396].
2348 Partan G, Mayrhofer R, Urban M, et al. Diagnostic performance of liquid crystal and cathode-ray-tube monitors in brain computed tomography. Eur Radiol. Oct. 2003;13(10):2397-401. X-1,X-6,X-8. [pmid: 14534808].
2349 Pasqualini L, Schillaci G, Pirro M, et al. Renal dysfunction predicts long-term mortality in patients with lower extremity arterial disease. J Intern Med. Dec. 2007;262(6):668-77. X-1E,X-1F,X-6. [pmid: 17908164].
2350 Patel DA, Srinivasan SR, Xu JH, et al. Adiponectin and its correlates of cardiovascular risk in young adults: the Bogalusa Heart Study. Metabolism. Nov. 2006;55(11):1551-7. X-1,X-2,X-5,X-6. [pmid: 17046560].
2351 Patel ND, Nwakanma LU, Weiss ES, et al. Impact of septal myocardial infarction on outcomes after surgical ventricular restoration. Ann Thorac Surg. Jan. 2008;85(1):135-45. discussion 145-6. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18154799].
2352 Paterson JM, Llewellyn-Thomas HA, Naylor CD. Using disease risk estimates to guide risk factor interventions: field test of a patient workbook for self-assessing coronary risk. Health Expect. Mar. 2002;5(1):3-15. X-2,X-6,X-7. [pmid: 11906538].
2353 Patrono C, Rocca B. Aspirin: promise and resistance in the new millennium. Arterioscler Thromb Vasc Biol. Mar. 2008;28(3):s25-32. X-1,X-2,X-4,X-5. [pmid: 18174450].
2354 Patterson RE, Frank LL, Kristal AR, et al. A comprehensive examination of health conditions associated with obesity in older adults. Am J Prev Med. Dec. 2004;27(5):385-90. X-1,X-2,X-5,X-8. [pmid: 15556738].
2355 Paul M, Raz A, Leibovici L, et al. Sternal wound infection after coronary artery bypass graft surgery: validation of existing risk scores. J Thorac Cardiovasc Surg. Feb. 2007;133(2):397-403. X-1,X-2,X-6,X-8. [pmid: 17258572].
2356 Pavlakis SG, Kingsley PB, Harper R, et al. Correlation of basal ganglia magnetic resonance spectroscopy with Apgar score in perinatal asphyxia. Arch Neurol. Dec. 1999;56(12):1476-81. X-1,X-6,X-7,X-8. [pmid: 10593302].
2357 Pavlovic M, Corovic N, Gomzi M, et al. Smoking habits, signs of chronic diseases and survival in inland and coastal regions of Croatia: a follow-up study. Coll Antropol. Dec. 2004;28(2):689-700. X-1. [pmid: 15666601].
2358 Payne JR, Dhamrait SS, Toor IS, et al. The -344T>C promoter variant of the gene for aldosterone synthase (CYP11B2) is not associated with cardiovascular risk in a prospective study of UK healthy men. Atherosclerosis. May. 2004;174(1):81-6. X-1,X-2. [pmid: 15135254].
2359 Peacock F, Morris DL, Anwaruddin S, et al. Meta-analysis of ischemia-modified albumin to rule out acute coronary syndromes in the emergency department. Am Heart J. Aug. 2006;152(2):253-62. X-1,X-4. [pmid: 16875905].
2360 Peacock WI, Emerman CL, McErlean ES, et al. Prediction of short- and long-term outcomes by troponin T levels in low-risk patients evaluated for acute coronary syndromes. Ann Emerg Med. Mar. 2000;35(3):213-20. X-1F,X-8. [pmid: 10692186].
2361 Pearce DC, Cadilhac DA, Pierce RJ, et al. Estimating the prevalence of sleep-disordered breathing in community-based, long-term stroke survivors using a validated predictive model. Cerebrovasc Dis. 2008;26(4):441-6. X-1,X-2,X-6,X-8. [pmid: 18799876].
2362 Pearce LA, Hart RG, Halperin JL. Assessment of three schemes for stratifying stroke risk in patients with nonvalvular atrial fibrillation. Am J Med. Jul. 2000;109(1):45-51. X-2. [pmid: 10936477].
2363 Pearson TA. New tools for coronary risk assessment: what are their advantages and limitations?. Circulation. Feb. 19. 2002;105(7):886-92. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 11854132].
2364 Pearson TA, Blair SN, Daniels SR, et al. AHA Guidelines for Primary Prevention of Cardiovascular Disease and Stroke: 2002. Update: Consensus Panel Guide to Comprehensive Risk Reduction for Adult Patients Without Coronary or Other Atherosclerotic Vascular Diseases. American Heart Association Science Advisory and Coordinating Committee. Circulation. Jul. 16. 2002;106(3):388-91. X-4. [pmid: 12119259].
2365 Pedersen PM, Vinter K, Olsen TS. Aphasia after stroke: type, severity and prognosis. The Copenhagen aphasia study. Cerebrovasc Dis. 2004;17(1):35-43. X-1,X-8.
2366 Pedersen SS, Denollet J. Validity of the Type D personality construct in Danish post-MI patients and healthy controls. J Psychosom Res. Sep. 2004;57(3):265-72. X-1,X-2,X-5,X-6,X-8. [pmid: 15507253].
2367 Pedersen SS, Denollet J, Ong AT, et al. Adverse clinical events in patients treated with sirolimus-eluting stents: the impact of Type D personality. Eur J Cardiovasc Prev Rehabil. Feb. 2007;14(1):135-40. X-1,X-8. [pmid: 17301639].
2368 Pedone C, Bax JJ, van Domburg RT, et al. Long-term prognostic value of ejection fraction changes during dobutamine-atropine stress echocardiography. Coron Artery Dis. Aug. 2005;16(5):309-13. X-1,X-7,X-8. [pmid: 16000889].
2369 Pedone C, Elhendy A, Biagini E, et al. Prognostic significance of myocardial ischemia by dobutamine stress echocardiography in patients without angina pectoris after coronary revascularization. Am J Cardiol. Nov. 1. 2008;102(9):1156-8. X-1,X-2,X-8. [pmid: 18940283].
2370 Pedone C, Schinkel AF, Elhendy A, et al. Incremental prognostic value of dobutamine-atropine stress 99mTc-tetrofosmin myocardial perfusion imaging for predicting outcome in diabetic patients with limited exercise capacity. Eur J Nucl Med Mol Imaging. Sep. 2005;32(9):1057-63. X-1,X-7. [pmid: 15864583].
2371 Pedreno J, Fernandez R, Ballester A, et al. Lack of association of serum lipoprotein (a) levels with type-2 diabetes mellitus in patients with angiographically defined coronary artery disease. Int J Cardiol. Jul. 31. 2000;74(2-3):159-67. X-5,X-6,X-8. [pmid: 10962116].
2372 Pelfrene E, Leynen F, Mak RP, et al. Relationship of perceived job stress to total coronary risk in a cohort of working men and women in Belgium. Eur J Cardiovasc Prev Rehabil. Oct. 2003;10(5):345-54. X-5. [pmid: 14663296].
2373 Pelter MM, Adams MG, Drew BJ. Transient myocardial ischemia is an independent predictor of adverse in-hospital outcomes in patients with acute coronary syndromes treated in the telemetry unit. Heart Lung. Mar-Apr. 2003;32(2):71-8. X-1,X-5,X-6,X-8. [pmid: 12734529].
2374 Pencina MJ, D'Agostino RB Sr, D'Agostino RB Jr, et al. Evaluating the added predictive ability of a new marker: from area under the ROC curve to reclassification and beyond. Stat Med. Jan. 30. 2008;27(2):157-72. discussion 207-12. X-1. [pmid: 17569110].
2375 Penckofer S, Filliung DR, Labropoulos N. Non-invasive cardiovascular risk assessment in women with type 2 diabetes. J Vasc Nurs. Mar. 2005;23(1):2-7. quiz 8-9. X-1,X-5,X-7. [pmid: 15741957].
2376 Pepine CJ. An ischemia-guided approach for risk stratification in patients with acute coronary syndromes. Am J Cardiol. Dec. 28. 2000;86(12B):27M-35M. X-8.
2377 Pepys MB, Hirschfield GM. C-reactive protein and atherothrombosis. Ital Heart J. Mar. 2001;2(3):196-9. X-1. [pmid: 11305531].
2378 Perers E, From Attebring M, Caidahl K, et al. Low risk is associated with poorer quality of life than high risk following acute coronary syndrome. Coron Artery Dis. Sep. 2006;17(6):501-10. X-1,X-6,X-8. [pmid: 16905961].
2379 Perez M, Casas JP, Cubillos-Garzon LA, et al. Using waist circumference as a screening tool to identify Colombian subjects at cardiovascular risk. Eur J Cardiovasc Prev Rehabil. Oct. 2003;10(5):328-35. X-1,X-5,X-7. [pmid: 14663294].
2380 Perez MV, Yaw TS, Myers J, et al. Prognostic value of the computerized ECG in Hispanics. Clin Cardiol. Apr. 2007;30(4):189-94. X-1,X-2. [pmid: 17443659].
2381 Perkiomaki JS, Jokinen V, Tapanainen J, et al. Autonomic markers as predictors of nonfatal acute coronary events after myocardial infarction. Ann Noninvasive Electrocardiol. Apr. 2008;13(2):120-9. X-1,X-8. [pmid: 18426437].
2382 Perry JJ, Stiell IG, Wells GA, et al. Attitudes and judgment of emergency physicians in the management of patients with acute headache. Acad Emerg Med. Jan. 2005;12(1):33-7. X-1,X-6. [pmid: 15635135].
2383 Persson GR, Persson RE, MacEntee CI, et al. Periodontitis and perceived risk for periodontitis in elders with evidence of depression. J Clin Periodontol. Aug. 2003;30(8):691-6. X-1,X-2,X-5,X-6. [pmid: 12887337].
2384 Persson M, Carlberg B, Weinehall L, et al. Risk stratification by guidelines compared with risk assessment by risk equations applied to a MONICA sample. J Hypertens. Jun. 2003;21(6):1089-95. X-2. [pmid: 12777945].
2385 Persson M, Hedblad B, Nelson JJ, et al. Elevated Lp-PLA2 levels add prognostic information to the metabolic syndrome on incidence of cardiovascular events among middle-aged nondiabetic subjects. Arterioscler Thromb Vasc Biol. Jun. 2007;27(6):1411-6. X-1E,X-1F,X-2. [pmid: 17431184].
2386 Perticone F, Ceravolo R, Pujia A, et al. Prognostic significance of endothelial dysfunction in hypertensive patients. Circulation. Jul. 10. 2001;104(2):191-6. X-1F,X-2. [pmid: 11447085].
2387 Peters A, Dockery DW, Muller JE, et al. Increased particulate air pollution and the triggering of myocardial infarction. Circulation. Jun. 12. 2001;103(23):2810-5. X-1,X-2,X-5,X-8. [pmid: 11401937].
2388 Peterson MD, Borger MA, Rao V, et al. Skeletonization of bilateral internal thoracic artery grafts lowers the risk of sternal infection in patients with diabetes. J Thorac Cardiovasc Surg. Nov. 2003;126(5):1314-9. X-1,X-6,X-7,X-8. [pmid: 14666001].
2389 Petix NR, Sestini S, Marcucci G, et al. Can the reversible regional wall motion abnormalities on stress gated Tc-99m sestamibi SPECT predict a future cardiac event?. J Nucl Cardiol. Jan-Feb. 2005;12(1):20-31. X-1,X-8. [pmid: 15682362].
2390 Pfeffer MA, Keech A, Sacks FM, et al. Safety and tolerability of pravastatin in long-term clinical trials: prospective Pravastatin Pooling (PPP) Project. Circulation. May. 21. 2002;105(20):2341-6. X-1,X-2,X-4,X-5,X-6. [pmid: 12021218].
2391 Pfisterer M, Brunner-La Rocca HP, Rickenbacher P, et al. Long-term benefit-risk balance of drug-eluting vs. bare-metal stents in daily practice: does stent diameter matter? Three-year follow-up of BASKET. Eur Heart J. Jan. 2009;30(1):16-24. X-1,X-2,X-8. [pmid: 19033260].
2392 Pfisterer M, Buser P, Osswald S, et al. Outcome of elderly patients with chronic symptomatic coronary artery disease with an invasive vs optimized medical treatment strategy: one-year results of the randomized TIME trial. JAMA. Mar. 5. 2003;289(9):1117-23. X-1,X-8. [pmid: 12622581].
2393 Pham PH, Rao DS, Vasunilashorn F, et al. Computed tomography calcium quantification as a measure of atherosclerotic plaque morphology and stability. Invest Radiol. Sep. 2006;41(9):674-80. X-1,X-5,X-6. [pmid: 16896302].
2394 Pham TM, Fujino Y, Tokui N, et al. Mortality and risk factors for stroke and its subtypes in a cohort study in Japan. Prev Med. Jun. 2007;44(6):526-30. X-1F,X-2,X-8. [pmid: 17376522].
2395 Phan TG, Donnan GA, Koga M, et al. Assessment of suitability of thrombolysis in middle cerebral artery infarction: a proof of concept study of a stereologically-based technique. Cerebrovasc Dis. 2007;24(4):321-7. X-1,X-2,X-5,X-7,X-8. [pmid: 17690543].
2396 Phornphutkul C, Introne WJ, Perry MB, et al. Natural history of alkaptonuria. N Engl J Med. Dec. 26. 2002;347(26):2111-21. X-1,X-2,X-5,X-6,X-7. [pmid: 12501223].
2397 Picca M, Agozzino F, Pelosi G. Influence of microalbuminuria on left ventricular geometry and function in hypertensive patients with type 2 diabetes mellitus. Ital Heart J. Jan. 2003;4(1):48-52. X-1,X-6,X-7. [pmid: 12690921].
2398 Piccini JP, Hranitzky PM, Kilaru R, et al. Relation of mortality to failure to prescribe beta blockers acutely in patients with sustained ventricular tachycardia and ventricular fibrillation following acute myocardial infarction (from the VALsartan In Acute myocardial iNfarcTion trial [VALIANT] Registry). Am J Cardiol. Dec. 1. 2008;102(11):1427-32. X-1,X-2,X-8. [pmid: 19026290].
2399 Pico F, Labreuche J, Gourfinkel-An I, et al. Basilar artery diameter and 5-year mortality in patients with stroke. Stroke. Sep. 2006;37(9):2342-7. X-1,X-6,X-8. [pmid: 16888278].
2400 Pierpont GL, Parenti CM. Physician risk assessment and APACHE scores in cardiac care units. Clin Cardiol. May. 1999;22(5):366-8. X-1,X-5,X-6,X-8. [pmid: 10326171].
2401 Pietrasik G, Goldenberg I, McNitt S, et al. Obesity as a risk factor for sustained ventricular tachyarrhythmias in MADIT II patients. J Cardiovasc Electrophysiol. Feb. 2007;18(2):181-4. X-1,X-8. [pmid: 17338766].
2402 Pinder MC, Duan Z, Goodwin JS, et al. Congestive heart failure in older women treated with adjuvant anthracycline chemotherapy for breast cancer. J Clin Oncol. Sep. 1. 2007;25(25):3808-15. X-1,X-2,X-6. [pmid: 17664460].
2403 Pindzola RR, Balzer JR, Nemoto EM, et al. Cerebrovascular reserve in patients with carotid occlusive disease assessed by stable xenon-enhanced ct cerebral blood flow and transcranial Doppler. Stroke. Aug. 2001;32(8):1811-7. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 11486110].
2404 Pine M, Jordan HS, Elixhauser A, et al. Enhancement of claims data to improve risk adjustment of hospital mortality. JAMA. Jan. 3. 2007;297(1):71-6. X-1. [pmid: 17200477].
2405 Pines JM, Szyld D. Risk tolerance for the exclusion of potentially life-threatening diseases in the ED. Am J Emerg Med. Jun. 2007;25(5):540-4. X-1,X-5,X-6,X-8. [pmid: 17543658].
2406 Pingitore A, Picano E, Varga A, et al. Prognostic value of pharmacological stress echocardiography in patients with known or suspected coronary artery disease: a prospective, large-scale, multicenter, head-to-head comparison between dipyridamole and dobutamine test. Echo-Persantine International Cooperative (EPIC) and Echo-Dobutamine International Cooperative (EDIC) Study Groups. J Am Coll Cardiol. Nov. 15. 1999;34(6):1769-77. X-1,X-6,X-7,X-8. [pmid: 10577568].
2407 Pinna Pintor P, Bobbio M, Colangelo S, et al. Can EuroSCORE predict direct costs of cardiac surgery?. Eur J Cardiothorac Surg. Apr. 2003;23(4):595-8. X-1,X-8. [pmid: 12694782].
2408 Pinna-Pintor P, Bobbio M, Colangelo S, et al. Inaccuracy of four coronary surgery risk-adjusted models to predict mortality in individual patients. Eur J Cardiothorac Surg. Feb. 2002;21(2):199-204. X-1,X-8. [pmid: 11825724].
2409 Pinto A, Tuttolomondo A, Di Raimondo D, et al. A case control study between diabetic and non-diabetic subjects with ischemic stroke. Int Angiol. Mar. 2007;26(1):26-32. X-1,X-5. [pmid: 17353885].
2410 Piper WD, Malenka DJ, Ryan TJ Jr, et al. Predicting vascular complications in percutaneous coronary interventions. Am Heart J. Jun. 2003;145(6):1022-9. X-1,X-6,X-8. [pmid: 12796758].
2411 Pipilis A, Kaliambakos S, Xenodochidis C, et al. Overestimation and underestimation of cardiovascular risk in clinical practice: usefulness of risk estimation charts. Hellenic J Cardiol. Nov-Dec. 2007;48(6):341-5. X-1,X-2,X-5,X-6,X-7. [pmid: 18196656].
2412 Pires LA, Lehmann MH, Buxton AE, et al. Differences in inducibility and prognosis of in-hospital versus out-of-hospital identified nonsustained ventricular tachycardia in patients with coronary artery disease: clinical and trial design implications. J Am Coll Cardiol. Oct. 2001;38(4):1156-62. X-1,X-2,X-8. [pmid: 11583897].
2413 Piros S, Karlehagen S, Lappas G, et al. Risk factors for myocardial infarction among Swedish railway engine drivers during 10 years follow-up. J Cardiovasc Risk. Oct. 2000;7(5):395-400. X-1F,X-2. [pmid: 11143770].
2414 Pirraglia PA, Peterson JC, Williams-Russo P, et al. Assessment of decline in health-related quality of life among angina-free patients undergoing coronary artery bypass graft surgery. Cardiology. 2003;99(3):115-20. X-1,X-6,X-8. [pmid: 12824718].
2415 Pischon T, Girman CJ, Sacks FM, et al. Non-high-density lipoprotein cholesterol and apolipoprotein B in the prediction of coronary heart disease in men. Circulation. Nov. 29. 2005;112(22):3375-83. X-1F,X-2,X-5. [pmid: 16316964].
2416 Pischon T, Mohlig M, Hoffmann K, et al. Comparison of relative and attributable risk of myocardial infarction and stroke according to C-reactive protein and low-density lipoprotein cholesterol levels. Eur J Epidemiol. 2007;22(7):429-38. X-2. [pmid: 17557140].
2417 Pitsavos C, Chrysohoou C, Panagiotakos DB, et al. Abdominal obesity and inflammation predicts hypertension among prehypertensive men and women: the ATTICA Study. Heart Vessels. Mar. 2008;23(2):96-103. X-1,X-2,X-6. [pmid: 18389333].
2418 Pitsavos C, Panagiotakos DB, Skoumas J, et al. Risk stratification of apolipoprotein B, apolipoprotein A1, and apolipoprotein B/AI ratio on the prevalence of the metabolic syndrome: the ATTICA study. Angiology. Jun-Jul. 2008;59(3):335-41. X-1,X-5,X-6. [pmid: 18388068].
2419 Pitsavos CH, Chrysohoou C, Panagiotakos DB, et al. Exercise capacity and heart rate recovery as predictors of coronary heart disease events, in patients with heterozygous Familial Hypercholesterolemia. Atherosclerosis. Apr. 2004;173(2):347-52. X-1. [pmid: 15064112].
2420 Pitt B, Ahmed A, Love TE, et al. History of hypertension and eplerenone in patients with acute myocardial infarction complicated by heart failure. Hypertension. Aug. 2008;52(2):271-8. X-1,X-8. [pmid: 18559720].
2421 Plein S, Greenwood JP, Ridgway JP, et al. Assessment of non-ST-segment elevation acute coronary syndromes with cardiac magnetic resonance imaging. J Am Coll Cardiol. Dec. 7. 2004;44(11):2173-81. X-1,X-5,X-6,X-7,X-8. [pmid: 15582315].
2422 Plein S, Radjenovic A, Ridgway JP, et al. Coronary artery disease: myocardial perfusion MR imaging with sensitivity encoding versus conventional angiography. Radiology. May. 2005;235(2):423-30. X-1,X-5,X-6,X-7,X-8. [pmid: 15858084].
2423 Pletcher MJ, Tice JA, Pignone M, et al. Using the coronary artery calcium score to predict coronary heart disease events: a systematic review and meta-analysis. Arch Intern Med. Jun. 28. 2004;164(12):1285-92. X-4,X-5. [pmid: 15226161].
2424 Plonska-Gosciniak E, Kleinrok A, Gackowski A, et al. Diagnostic and prognostic value of rapid pacing stress echocardiography for the detection of coronary artery disease: influence of pacing mode and concomitant antiischemic therapy (final results of multicenter study Pol-RAPSE). Echocardiography. Sep. 2008;25(8):827-34. X-1,X-2,X-7,X-8. [pmid: 18986411].
2425 Podgoreanu MV, White WD, Morris RW, et al. Inflammatory gene polymorphisms and risk of postoperative myocardial infarction after cardiac surgery. Circulation. Jul. 4. 2006;114(1 Suppl):I275-81. X-1B,X-1D,X-5,X-6,X-8. [pmid: 16820586].
2426 Pohle K, Maffert R, Ropers D, et al. Progression of aortic valve calcification: association with coronary atherosclerosis and cardiovascular risk factors. Circulation. Oct. 16. 2001;104(16):1927-32. X-1,X-2,X-6,X-7. [pmid: 11602496].
2427 Pohle K, Ropers D, Geitner P, et al. Analysis of coronary calcifications versus Framingham and PROCAM risk assessment in patients with a first myocardial infarction. Int J Cardiol. Jun. 16. 2006;110(2):231-6. X-1,X-5,X-6,X-7,X-8. [pmid: 16310268].
2428 Poludasu S, Cavusoglu E, Clark LT, et al. Impact of gender on in-hospital percutaneous coronary interventional outcomes in African-Americans. J Invasive Cardiol. Mar. 2007;19(3):123-8. X-1,X-8. [pmid: 17341779].
2429 Pons D, Monraats PS, de Maat MP, et al. The influence of established genetic variation in the haemostatic system on clinical restenosis after percutaneous coronary interventions. Thromb Haemost. Dec. 2007;98(6):1323-8. X-1,X-2,X-5,X-6,X-8. [pmid: 18064331].
2430 Poornima IG, Miller TD, Christian TF, et al. Utility of myocardial perfusion imaging in patients with low-risk treadmill scores. J Am Coll Cardiol. Jan. 21. 2004;43(2):194-9. X-8. [pmid: 14736437].
2431 Porchay-Balderelli I, Pean F, Bellili N, et al. The CETP TaqIB polymorphism is associated with the risk of sudden death in type 2 diabetic patients. Diabetes Care. Nov. 2007;30(11):2863-7. X-6. [pmid: 17666459].
2432 Poredos P, Jug B. The prevalence of peripheral arterial disease in high risk subjects and coronary or cerebrovascular patients. Angiology. Jun-Jul. 2007;58(3):309-15. X-1,X-5,X-6,X-7,X-8. [pmid: 17626985].
2433 Post PN, Stiggelbout AM, Wakker PP. The utility of health states after stroke: a systematic review of the literature. Stroke. Jun. 2001;32(6):1425-9. X-1,X-2,X-4,X-5. [pmid: 11387509].
2434 Postadzhiyan AS, Tzontcheva AV, Kehayov I, et al. Circulating soluble adhesion molecules ICAM-1 and VCAM-1 and their association with clinical outcome, troponin T and C-reactive protein in patients with acute coronary syndromes. Clin Biochem. Feb. 2008;41(3):126-33. X-1,X-5,X-7. [pmid: 18061588].
2435 Potluri SP, Mehra MR, Uber PA, et al. Relationship among epicardial coronary disease, tissue myocardial perfusion, and survival in heart transplantation. J Heart Lung Transplant. Aug. 2005;24(8):1019-25. X-1,X-2,X-7,X-8. [pmid: 16102436].
2436 Potter DD, Araoz PA, McGee KP, et al. Low-dose dobutamine cardiac magnetic resonance imaging with myocardial strain analysis predicts myocardial recoverability after coronary artery bypass grafting. J Thorac Cardiovasc Surg. Jun. 2008;135(6):1342-7. X-1,X-5,X-6,X-7,X-8. [pmid: 18544383].
2437 Potter DD, Sundt TM 3rd, Zehr KJ, et al. Operative risk of reoperative aortic valve replacement. J Thorac Cardiovasc Surg. Jan. 2005;129(1):94-103. X-1,X-2,X-8. [pmid: 15632830].
2438 Powars DR, Chan LS, Hiti A, et al. Outcome of sickle cell anemia: a 4-decade observational study of 1056 patients. Medicine (Baltimore). Nov. 2005;84(6):363-76. X-1,X-2. [pmid: 16267411].
2439 Powell JT, Turner RJ, Sian M, et al. Influence of fibrillin-1 genotype on the aortic stiffness in men. J Appl Physiol. Sep. 2005;99(3):1036-40. X-1,X-2,X-5,X-6,X-7. [pmid: 16103519].
2440 Prabhakaran D, Yusuf S, Mehta S, et al. Two-year outcomes in patients admitted with non-ST elevation acute coronary syndrome: results of the OASIS registry 1 and 2. Indian Heart J. May-Jun. 2005;57(3):217-25. X-1,X-8. [pmid: 16196178].
2441 Prabhakaran S, Rundek T, Ramas R, et al. Carotid plaque surface irregularity predicts ischemic stroke: the northern Manhattan study. Stroke. Nov. 2006;37(11):2696-701. X-1F,X-2. [pmid: 17008627].
2442 Pradeepa R, Deepa R, Mohan V. Epidemiology of diabetes in India--current perspective and future projections. J Indian Med Assoc. Mar. 2002;100(3):144-8. X-1,X-2,X-4,X-5,X-6. [pmid: 12408271].
2443 Pradhan AD, Rifai N, Buring JE, et al. Hemoglobin A1c predicts diabetes but not cardiovascular disease in nondiabetic women. Am J Med. Aug. 2007;120(8):720-7. X-2,X-6. [pmid: 17679132].
2444 Pradhan AD, Rifai N, Ridker PM. Soluble intercellular adhesion molecule-1, soluble vascular adhesion molecule-1, and the development of symptomatic peripheral arterial disease in men. Circulation. Aug. 13. 2002;106(7):820-5. X-1,X-5,X-6. [pmid: 12176954].
2445 Pradhan AD, Shrivastava S, Cook NR, et al. Symptomatic peripheral arterial disease in women: nontraditional biomarkers of elevated risk. Circulation. Feb. 12. 2008;117(6):823-31. X-6. [pmid: 18227386].
2446 Pradhan J, Vankayala H, Niraj A, et al. QT dispersion at rest and during adenosine stress myocardial perfusion imaging correlation with Myocardial Jeopardy Score. Clin Cardiol. May. 2008;31(5):205-10. X-1,X-2,X-6,X-7,X-8. [pmid: 18473373].
2447 Prasad A, Rihal CS, Lennon RJ, et al. Trends in outcomes after percutaneous coronary intervention for chronic total occlusions: a 25-year experience from the Mayo Clinic. J Am Coll Cardiol. Apr. 17. 2007;49(15):1611-8. X-1,X-2,X-8. [pmid: 17433951].
2448 Prati P, Tosetto A, Vanuzzo D, et al. Carotid intima media thickness and plaques can predict the occurrence of ischemic cerebrovascular events. Stroke. Sep. 2008;39(9):2470-6. X-1. [pmid: 18617662].
2449 Predescu D, Mitrut P, Giuca A. Microvolt T wave alternans (MTWA)--a new non-invasive predictor of sudden cardiac death. Rom J Intern Med. 2004;42(3):647-56. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16366137].
2450 Press MJ, Chassin MR, Wang J, et al. Predicting medical and surgical complications of carotid endarterectomy: comparing the risk indexes. Arch Intern Med. Apr. 24. 2006;166(8):914-20. X-1,X-8. [pmid: 16636219].
2451 Pretorius PH, King MA, Gifford HC, et al. Myocardial perfusion SPECT reconstruction: receiver operating characteristic comparison of CAD detection accuracy of filtered backprojection reconstruction with all of the clinical imaging information available to readers and solely stress slices iteratively reconstructed with combined compensation. J Nucl Cardiol. May-Jun. 2005;12(3):284-93. X-1,X-7,X-8. [pmid: 15944533].
2452 Previtali M, Scelsi L, Sebastiani R, et al. Feasibility, safety, and prognostic value of dobutamine stress echocardiography in patients > or = 70 years of age early after acute myocardial infarction. Am J Cardiol. Oct. 1. 2002;90(7):792-5. X-1. [pmid: 12356404].
2453 Price JF, Thomas AK, Grenier M, et al. B-type natriuretic peptide predicts adverse cardiovascular events in pediatric outpatients with chronic left ventricular systolic dysfunction. Circulation. Sep. 5. 2006;114(10):1063-9. X-1,X-5,X-6,X-7. [pmid: 16940194].
2454 Priebe HJ. The aged cardiovascular risk patient. Br J Anaesth. Nov. 2000;85(5):763-78. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 11094595].
2455 Prineas RJ, Rautaharju PM, Grandits G, et al. Independent risk for cardiovascular disease predicted by modified continuous score electrocardiographic criteria for 6-year incidence and regression of left ventricular hypertrophy among clinically disease free men: 16-year follow-up for the multiple risk factor intervention trial. J Electrocardiol. Apr. 2001;34(2):91-101. X-1F,X-2,X-8. [pmid: 11320456].
2456 Prior JO, Monbaron D, Koehli M, et al. Prevalence of symptomatic and silent stress-induced perfusion defects in diabetic patients with suspected coronary artery disease referred for myocardial perfusion scintigraphy. Eur J Nucl Med Mol Imaging. Jan. 2005;32(1):60-9. X-1,X-2,X-5,X-6,X-7. [pmid: 15309331].
2457 Priori SG, Napolitano C, Gasparini M, et al. Natural history of Brugada syndrome: insights for risk stratification and management. Circulation. Mar. 19. 2002;105(11):1342-7. X-1,X-8. [pmid: 11901046].
2458 Prosser J, MacGregor L, Lees KR, et al. Predictors of early cardiac morbidity and mortality after ischemic stroke. Stroke. Aug. 2007;38(8):2295-302. X-1,X-6,X-8. [pmid: 17569877].
2459 Protogerou AD, Blacher J, Mavrikakis M, et al. Increased pulse pressure amplification in treated hypertensive subjects with metabolic syndrome. Am J Hypertens. Feb. 2007;20(2):127-33. X-1,X-5,X-6. [pmid: 17261456].
2460 Przyluski J, Karcz M, Kalinczuk L, et al. Comparison of different methods of ST segment resolution analysis for prediction of 1-year mortality after primary angioplasty for acute myocardial infarction. Ann Noninvasive Electrocardiol. Jan. 2007;12(1):5-14. X-1,X-8. [pmid: 17286645].
2461 Ptaszynski P, Klingenheben T, Gerritse B, et al. Risk stratification after myocardial infarction: a new method of determining the neural component of the baroreflex is potentially more discriminative in distinguishing patients at high and low risk for arrhythmias. Europace. Feb. 2008;10(2):227-34. X-1,X-2,X-6,X-7,X-8. [pmid: 18256127].
2462 Puddu PE, Brancaccio G, Leacche M, et al. Prediction of early and delayed postoperative deaths after coronary artery bypass surgery alone in Italy. Multivariate predictions based on Cox and logistic models and a chart based on the accelerated failure time model. Ital Heart J. Mar. 2002;3(3):166-81. X-1,X-8. [pmid: 11974661].
2463 Pueyo E, Smetana P, Caminal P, et al. Characterization of QT interval adaptation to RR interval changes and its use as a risk-stratifier of arrhythmic mortality in amiodarone-treated survivors of acute myocardial infarction. IEEE Trans Biomed Eng. Sep. 2004;51(9):1511-20. X-1,X-2,X-4,X-5. [pmid: 15376499].
2464 Pugh KG, Kiely DK, Milberg WP, et al. Selective impairment of frontal-executive cognitive function in african americans with cardiovascular risk factors. J Am Geriatr Soc. Oct. 2003;51(10):1439-44. X-1,X-5,X-6,X-7,X-8. [pmid: 14511165].
2465 Pulkki-Raback L, Elovainio M, Kivimaki M, et al. Temperament in childhood predicts body mass in adulthood: the Cardiovascular Risk in Young Finns Study. Health Psychol. May. 2005;24(3):307-15. X-1,X-6. [pmid: 15898867].
2466 Pundik S, McWilliams-Dunnigan L, Blackham KL, et al. Older age does not increase risk of hemorrhagic complications after intravenous and/or intra-arterial thrombolysis for acute stroke. J Stroke Cerebrovasc Dis. Sep. 2008;17(5):266-72. X-1,X-2,X-6,X-8. [pmid: 18755405].
2467 Puri A, Narain VS, Mehrotra S, et al. N-terminal probrain natriuretic peptide as a predictor of short-term outcomes in acute myocardial infarction. Indian Heart J. Jul-Aug. 2005;57(4):304-10. X-1,X-7,X-8. [pmid: 16350675].
2468 Purroy F, Montaner J, Molina CA, et al. C-reactive protein predicts further ischemic events in transient ischemic attack patients. Acta Neurol Scand. Jan. 2007;115(1):60-6. X-1,X-2,X-7,X-8. [pmid: 17156267].
2469 Purroy F, Montaner J, Rovira A, et al. Higher risk of further vascular events among transient ischemic attack patients with diffusion-weighted imaging acute ischemic lesions. Stroke. Oct. 2004;35(10):2313-9. X-1,X-7. [pmid: 15322305].
2470 Purser JL, Kuchibhatla MN, Fillenbaum GG, et al. Identifying frailty in hospitalized older adults with significant coronary artery disease. J Am Geriatr Soc. Nov. 2006;54(11):1674-81. X-1,X-2,X-6,X-8. [pmid: 17087693].
2471 Puskas JD, Kilgo PD, Lattouf OM, et al. Off-pump coronary bypass provides reduced mortality and morbidity and equivalent 10-year survival. Ann Thorac Surg. Oct. 2008;86(4):1139-46. discussion 1146. X-1,X-2,X-8. [pmid: 18805149].
2472 Pussinen PJ, Tuomisto K, Jousilahti P, et al. Endotoxemia, immune response to periodontal pathogens, and systemic inflammation associate with incident cardiovascular disease events. Arterioscler Thromb Vasc Biol. Jun. 2007;27(6):1433-9. X-1,X-5,X-8. [pmid: 17363692].
2473 Puttonen S, Elovainio M, Kivimaki M, et al. Temperament, health-related behaviors, and autonomic cardiac regulation: the cardiovascular risk in young Finns study. Biol Psychol. May. 2008;78(2):204-10. X-1,X-2,X-5,X-6. [pmid: 18417269].
2474 Pyorala K, De Backer G, Graham I, et al. Prevention of coronary heart disease in clinical practice. Recommendations of the Task Force of the European Society of Cardiology, European Atherosclerosis Society and European Society of Hypertension. Eur Heart J. Oct. 1994;15(10):1300-31. X-4. [pmid: 7821306].
2475 Qiao Q, Jousilahti P, Eriksson J, et al. Predictive properties of impaired glucose tolerance for cardiovascular risk are not explained by the development of overt diabetes during follow-up. Diabetes Care. Oct. 2003;26(10):2910-4. X-1F,X-2. [pmid: 14514600].
2476 Qiao Q, Pyorala K, Pyorala M, et al. Two-hour glucose is a better risk predictor for incident coronary heart disease and cardiovascular mortality than fasting glucose. Eur Heart J. Aug. 2002;23(16):1267-75. X-4,X-5. [pmid: 12175663].
2477 Qu W, Le TT, Azen SP, et al. Value of coronary artery calcium scanning by computed tomography for predicting coronary heart disease in diabetic subjects. Diabetes Care. Mar. 2003;26(3):905-10. X-1F,X-2,X-8. [pmid: 12610057].
2478 Quaglini S, Cavallini A, Gerzeli S, et al. Economic benefit from clinical practice guideline compliance in stroke patient management. Health Policy. Sep. 2004;69(3):305-15. X-1,X-2,X-6. [pmid: 15276310].
2479 Quilliam BJ, Lapane KL. Clinical correlates and drug treatment of residents with stroke in long-term care. Stroke. Jun. 2001;32(6):1385-93. X-1,X-6,X-8. [pmid: 11387503].
2480 Quilliam BJ, Lapane KL, Eaton CB, et al. Effect of antiplatelet and anticoagulant agents on risk of hospitalization for bleeding among a population of elderly nursing home stroke survivors. Stroke. Oct. 2001;32(10):2299-304. X-1,X-2,X-5,X-6,X-8. [pmid: 11588317].
2481 Quinney K. Exercise tolerance testing after myocardial infarction. Nurs Times. Sep. 6-12. 2005;101(36):28-30. X-1,X-2,X-4,X-5,X-6,X-7,X-8.
2482 Qureshi AI, Suri MF, Mohammad Y, et al. Isolated and borderline isolated systolic hypertension relative to long-term risk and type of stroke: a 20-year follow-up of the national health and nutrition survey. Stroke. Dec. 2002;33(12):2781-8. X-1. [pmid: 12468770].
2483 Quyyumi AA. Prognostic value of endothelial function. Am J Cardiol. Jun. 19. 2003;91(12A):19H-24H. X-1,X-4,X-5,X-6.
2484 Raanani E, Keren A, Kogan A, et al. Trends in cardiac surgery in Israel, 1985-2002. Isr Med Assoc J. Mar. 2004;6(3):131-3. X-1,X-2,X-5,X-6. [pmid: 15055265].
2485 Rabadi MH, Rabadi FM, Peterson M. An analysis of falls occurring in patients with stroke on an acute rehabilitation unit. Rehabil Nurs. May-Jun. 2008;33(3):104-9. X-1,X-2,X-5,X-6. [pmid: 18517145].
2486 Rabbat CG, Treleaven DJ, Russell JD, et al. Prognostic value of myocardial perfusion studies in patients with end-stage renal disease assessed for kidney or kidney-pancreas transplantation: a meta-analysis. J Am Soc Nephrol. Feb. 2003;14(2):431-9. X-1,X-2,X-5. [pmid: 12538744].
2487 Rabindranath KS, Anderson NR, Gama R, et al. Comparative evaluation of the new Sheffield table and the modified joint British societies coronary risk prediction chart against a laboratory based risk score calculation. Postgrad Med J. May. 2002;78(919):269-72. X-1,X-5,X-6. [pmid: 12151567].
2488 Rachet B, Abrahamowicz M, Sasco AJ, et al. Estimating the distribution of lag in the effect of short-term exposures and interventions: adaptation of a non-parametric regression spline model. Stat Med. Jul. 30. 2003;22(14):2335-63. X-1,X-2. [pmid: 12854096].
2489 Rackley CE. New clinical markers predictive of cardiovascular disease: the role of inflammatory mediators. Cardiol Rev. May-Jun. 2004;12(3):151-7. X-1,X-2,X-4,X-5,X-6. [pmid: 15078584].
2490 Radder CM, Brand A, Kanhai HH. Will it ever be possible to balance the risk of intracranial haemorrhage in fetal or neonatal alloimmune thrombocytopenia against the risk of treatment strategies to prevent it?. Vox Sang. May. 2003;84(4):318-25. X-1,X-6,X-8. [pmid: 12757506].
2491 Rafter N, Connor J, Hall J, et al. Cardiovascular medications in primary care: treatment gaps and targeting by absolute risk. N Z Med J. Oct. 7. 2005;118(1223):U1676. X-1F,X-2,X-6,X-8. [pmid: 16224500].
2492 Rafter N, Wells S, Stewart A, et al. Gaps in primary care documentation of cardiovascular risk factors. N Z Med J. Feb. 15. 2008;121(1269):24-33. X-1,X-2,X-5,X-6.
2493 Raggi P, Callister TQ, Cooil B. Calcium scoring of the coronary artery by electron beam CT: how to apply an individual attenuation threshold. AJR Am J Roentgenol. Feb. 2002;178(2):497-502. X-1,X-5,X-6,X-7. [pmid: 11804925].
2494 Raggi P, Cooil B, Callister TQ. Use of electron beam tomography data to develop models for prediction of hard coronary events. Am Heart J. Mar. 2001;141(3):375-82. X-1. [pmid: 11231434].
2495 Raggi P, Gongora MC, Gopal A, et al. Coronary artery calcium to predict all-cause mortality in elderly men and women. J Am Coll Cardiol. Jul. 1. 2008;52(1):17-23. X-1,X-6. [pmid: 18582630].
2496 Raggi P, Khan A, Arepali C, et al. Coronary artery calcium scoring in the age of CT angiography: what is its role?. Curr Atheroscler Rep. Oct. 2008;10(5):438-43. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18706286].
2497 Raggi P, Shaw LJ, Berman DS, et al. Gender-based differences in the prognostic value of coronary calcification. J Womens Health (Larchmt). Apr. 2004;13(3):273-83. X-1,X-6. [pmid: 15130256].
2498 Rahmanian PB, Filsoufi F, Castillo JG, et al. Predicting postoperative renal failure requiring dialysis, and an analysis of long-term outcome in patients undergoing valve surgery. J Heart Valve Dis. Nov. 2008;17(6):657-65. X-1,X-2,X-6,X-8. [pmid: 19137798].
2499 Rajagopal V, Gurm HS, Brunken RC, et al. Prediction of death or myocardial infarction by exercise single photon emission computed tomography perfusion scintigraphy in patients who have had recent coronary artery stenting. Am Heart J. Mar. 2005;149(3):534-40. X-1,X-8. [pmid: 15864244].
2500 Rajakaruna C, Rogers CA, Suranimala C, et al. The effect of diabetes mellitus on patients undergoing coronary surgery: a risk-adjusted analysis. J Thorac Cardiovasc Surg. Oct. 2006;132(4):802-10. X-1,X-8. [pmid: 17000291].
2501 Rajappan K, Murphy E, Amber V, et al. Usage of troponin in the real world: a lesson for the introduction of biochemical assays. QJM. May. 2005;98(5):337-42. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15820972].
2502 Rajasekhar D, Srinivasa Rao PV, Latheef SA, et al. Association of serum antioxidants and risk of coronary heart disease in South Indian population. Indian J Med Sci. Nov. 2004;58(11):465-71. X-1,X-5,X-8. [pmid: 15567903].
2503 Rakhit DJ, Armstrong KA, Beller E, et al. Risk stratification of patients with chronic kidney disease: results of screening strategies incorporating clinical risk scoring and dobutamine stress echocardiography. Am Heart J. Aug. 2006;152(2):363-70. X-8(31%). [pmid: 16875924].
2504 Ramachandran S, French JM, Vanderpump MP, et al. Using the Framingham model to predict heart disease in the United Kingdom: retrospective study. BMJ. Mar. 11. 2000;320(7236):676-7. X-2. [pmid: 10710574].
2505 Ramachandran S, Labib MH. Hyperlipidaemia and primary prevention of coronary heart disease: are the right patients being treated?. J Cardiovasc Risk. Aug. 2000;7(4):245-9. X-1,X-6. [pmid: 11006894].
2506 Ramadan MM, Mahfouz EM, Gomaa GF, et al. Evaluation of coronary calcium score by multidetector computed tomography in relation to endothelial function and inflammatory markers in asymptomatic individuals. Circ J. May. 2008;72(5):778-85. X-1,X-2,X-5,X-6,X-7. [pmid: 18441459].
2507 Ramakrishna G, Miller TD, Breen JF, et al. Relationship and prognostic value of coronary artery calcification by electron beam computed tomography to stress-induced ischemia by single photon emission computed tomography. Am Heart J. May. 2007;153(5):807-14. X-1,X-8. [pmid: 17452158].
2508 Raman J, Ishikawa S, Storer MM, et al. Surgical radiofrequency ablation of both atria for atrial fibrillation: results of a multicenter trial. J Thorac Cardiovasc Surg. Nov. 2003;126(5):1357-66. X-1,X-6,X-7. [pmid: 14666007].
2509 Ramsay G, Podogrodzka M, McClure C, et al. Risk prediction in patients presenting with suspected cardiac pain: the GRACE and TIMI risk scores versus clinical evaluation. QJM. Jan. 2007;100(1):11-8. X-1C,X-1D,X-8,7-49%). [pmid: 17175559].
2510 Ramsey SD, Clarke LD, Roberts CS, et al. An economic evaluation of atorvastatin for primary prevention of cardiovascular events in type 2 diabetes. Pharmacoeconomics. 2008;26(4):329-39. X-1,X-2,X-4,X-5,X-6,X-7. [pmid: 18370567].
2511 Rankin JS, Hammill BG, Ferguson TB Jr, et al. Determinants of operative mortality in valvular heart surgery. J Thorac Cardiovasc Surg. Mar. 2006;131(3):547-57. X-1,X-2,X-5,X-6,X-8. [pmid: 16515904].
2512 Rantanen T, Volpato S, Ferrucci L, et al. Handgrip strength and cause-specific and total mortality in older disabled women: exploring the mechanism. J Am Geriatr Soc. May. 2003;51(5):636-41. X-1,X-5,X-6. [pmid: 12752838].
2513 Rao C, Stanbridge Rde L, Chikwe J, et al. Does previous percutaneous coronary stenting compromise the long-term efficacy of subsequent coronary artery bypass surgery? A microsimulation study. Ann Thorac Surg. Feb. 2008;85(2):501-7. X-1,X-2,X-4,X-5,X-6,X-7. [pmid: 18222252].
2514 Rao SV, Schulman KA, Curtis LH, et al. Socioeconomic status and outcome following acute myocardial infarction in elderly patients. Arch Intern Med. May. 24. 2004;164(10):1128-33. X-1,X-2,X-6,X-8. [pmid: 15159271].
2515 Rathore SS, Mehta RH, Wang Y, et al. Effects of age on the quality of care provided to older patients with acute myocardial infarction. Am J Med. Mar. 2003;114(4):307-15. X-1,X-6,X-8. [pmid: 12681459].
2516 Rathore SS, Weinfurt KP, Gross CP, et al. Validity of a simple ST-elevation acute myocardial infarction risk index: are randomized trial prognostic estimates generalizable to elderly patients?. Circulation. Feb. 18. 2003;107(6):811-6. X-1,X-6,X-8. [pmid: 12591749].
2517 Rautaharju PM, Kooperberg C, Larson JC, et al. Electrocardiographic abnormalities that predict coronary heart disease events and mortality in postmenopausal women: the Women's Health Initiative. Circulation. Jan. 31. 2006;113(4):473-80. X-1D,X-2,X-8(6.7%). [pmid: 16449726].
2518 Rautaharju PM, Prineas RJ, Wood J, et al. Electrocardiographic predictors of new-onset heart failure in men and in women free of coronary heart disease (from the Atherosclerosis in Communities [ARIC] Study). Am J Cardiol. Nov. 1. 2007;100(9):1437-41. X-1D,X-1F,X-2,X-6. [pmid: 17950804].
2519 Ravera M, Ratto E, Vettoretti S, et al. Microalbuminuria and subclinical cerebrovascular damage in essential hypertension. J Nephrol. Sep-Oct. 2002;15(5):519-24. X-1,X-5,X-6,X-7. [pmid: 12455718].
2520 Ray JA, Boye KS, Yurgin N, et al. Exenatide versus insulin glargine in patients with type 2 diabetes in the UK: a model of long-term clinical and cost outcomes. Curr Med Res Opin. Mar. 2007;23(3):609-22. X-1,X-5,X-6. [pmid: 17355742].
2521 Rea TD, Heckbert SR, Kaplan RC, et al. Body mass index and the risk of recurrent coronary events following acute myocardial infarction. Am J Cardiol. Sep. 1. 2001;88(5):467-72. X-1,X-8. [pmid: 11524051].
2522 Redberg RF, Shaw LJ. A review of electron beam computed tomography: implications for coronary artery disease screening. Prev Cardiol. Spring. 2002;5(2):71-8. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 11986551].
2523 Redgrave JN, Coutts SB, Schulz UG, et al. Systematic review of associations between the presence of acute ischemic lesions on diffusion-weighted imaging and clinical predictors of early stroke risk after transient ischemic attack. Stroke. May. 2007;38(5):1482-8. X-1,X-2,X-4,X-5. [pmid: 17379821].
2524 Redgrave JN, Schulz UG, Briley D, et al. Presence of acute ischaemic lesions on diffusion-weighted imaging is associated with clinical predictors of early risk of stroke after transient ischaemic attack. Cerebrovasc Dis. 2007;24(1):86-90. X-1,X-5,X-6. [pmid: 17519549].
2525 Reed JF 3rd, Olenchock SA Jr. Comparative analysis of risk-adjusted bypass surgery stratification models in a community hospital. Heart Lung. Nov-Dec. 2003;32(6):383-90. X-1,X-8. [pmid: 14652530].
2526 Reeves SW, Tielsch JM, Katz J, et al. A self-administered health questionnaire for the preoperative risk stratification of patients undergoing cataract surgery. Am J Ophthalmol. May. 2003;135(5):599-606. X-1,X-6. [pmid: 12719065].
2527 Reilly MP, Wolfe ML, Localio AR, et al. Coronary artery calcification and cardiovascular risk factors: impact of the analytic approach. Atherosclerosis. Mar. 2004;173(1):69-78. X-1,X-6. [pmid: 15177125].
2528 Reinecke H, Regetmeier A, Matzkies F, et al. Even moderate chronic renal failure is associated with impaired acute and long-term outcome after coronary angioplasty. Nephrology (Carlton). Jun. 2003;8(3):110-5. X-1,X-5,X-6,X-7,X-8. [pmid: 15012725].
2529 Reinhard W, Holmer SR, Fischer M, et al. Association of the metabolic syndrome with early coronary disease in families with frequent myocardial infarction. Am J Cardiol. Apr. 1. 2006;97(7):964-7. X-1F,X-2, (Germany). [pmid: 16563895].
2530 Reiter M, Effenberger I, Sabeti S, et al. Increasing carotid plaque echolucency is predictive of cardiovascular events in high-risk patients. Radiology. Sep. 2008;248(3):1050-5. X-6. [pmid: 18710994].
2531 Reiter M, Wirth S, Pourazim A, et al. Skin cholesterol: test performance, evaluation of potential determinants and correlation analysis with cardiovascular risk factors and circulating markers of inflammation. Vasa. Aug. 2006;35(3):167-73. X-1,X-5,X-6. [pmid: 16941405].
2532 Rejeski WJ, Foy CG, Brawley LR, et al. Older adults in cardiac rehabilitation: a new strategy for enhancing physical function. Med Sci Sports Exerc. Nov. 2002;34(11):1705-13. X-1,X-2,X-6,X-7. [pmid: 12439072].
2533 Reker DM, Rosen AK, Hoenig H, et al. The hazards of stroke case selection using administrative data. Med Care. Feb. 2002;40(2):96-104. X-1,X-5,X-8. [pmid: 11802082].
2534 Renew DC, Cook RF, Ball MC. A method for assessing occupational exposure to power-frequency magnetic fields for electricity generation and transmission workers. J Radiol Prot. Sep. 2003;23(3):279-303. X-1,X-5,X-6. [pmid: 14582720].
2535 Renvert S, Ohlsson O, Persson S, et al. Analysis of periodontal risk profiles in adults with or without a history of myocardial infarction. J Clin Periodontol. Jan. 2004;31(1):19-24. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15058370].
2536 Resnic FS, Ohno-Machado L, Selwyn A, et al. Simplified risk score models accurately predict the risk of major in-hospital complications following percutaneous coronary intervention. Am J Cardiol. Jul. 1. 2001;88(1):5-9. X-1,X-6,X-8. [pmid: 11423050].
2537 Resnic FS, Popma JJ, Ohno-Machado L. Development and evaluation of models to predict death and myocardial infarction following coronary angioplasty and stenting. Proc AMIA Symp. 2000:690-3. X-8.
2538 Reuter NP, Charette SD, Sticca RP. Cerebral protection during carotid endarterectomy. Am J Surg. Dec. 2004;188(6):772-7. X-1,X-2,X-8. [pmid: 15619498].
2539 Reuveni H, Greenberg-Dotan S, Simon-Tuval T, et al. Elevated healthcare utilisation in young adult males with obstructive sleep apnoea. Eur Respir J. Feb. 2008;31(2):273-9. X-1,X-2,X-5,X-6. [pmid: 17898013].
2540 Rexius H, Brandrup-Wognsen G, Oden A, et al. Gender and mortality risk on the waiting list for coronary artery bypass grafting. Eur J Cardiothorac Surg. Sep. 2004;26(3):521-7. X-1,X-6,X-8. [pmid: 15302046].
2541 Reynolds TM, Twomey P, Wierzbicki AS. Accuracy of cardiovascular risk estimation for primary prevention in patients without diabetes. J Cardiovasc Risk. Aug. 2002;9(4):183-90. X-1,X-5,X-6,X-7,X-8. [pmid: 12394326].
2542 Reynolds TM, Twomey PJ, Wierzbicki AS. Concordance evaluation of coronary risk scores: implications for cardiovascular risk screening. Curr Med Res Opin. Jun. 2004;20(6):811-8. X-5,X-6. [pmid: 15200737].
2543 Ribeiro JC, Guerra S, Oliveira J, et al. Body fatness and clustering of cardiovascular disease risk factors in Portuguese children and adolescents. Am J Hum Biol. Sep-Oct. 2004;16(5):556-62. X-1,X-5,X-6. [pmid: 15368603].
2544 Ribeiro JC, Guerra S, Oliveira J, et al. Physical activity and biological risk factors clustering in pediatric population. Prev Med. Sep. 2004;39(3):596-601. X-1,X-5,X-6. [pmid: 15313100].
2545 Ribera A, Ferreira-Gonzalez I, Cascant P, et al. The EuroSCORE and a local model consistently predicted coronary surgery mortality and showed complementary properties. J Clin Epidemiol. Jul. 2008;61(7):663-70. X-1,X-5,X-6,X-8. [pmid: 18538261].
2546 Ribera A, Permanyer-Miralda G, Alonso J, et al. Is psychometric scoring of the McNew Quality of Life after Myocardial Infarction questionnaire superior to the clinimetric scoring? A comparison of the two approaches. Qual Life Res. Apr. 2006;15(3):357-65. X-1,X-6,X-8. [pmid: 16547773].
2547 Richards AM, Nicholls MG, Espiner EA, et al. B-type natriuretic peptides and ejection fraction for prognosis after myocardial infarction. Circulation. Jun. 10. 2003;107(22):2786-92. X-1,X-6,X-8. [pmid: 12771003].
2548 Richardson CR, Kriska AM, Lantz PM, et al. Physical activity and mortality across cardiovascular disease risk groups. Med Sci Sports Exerc. Nov. 2004;36(11):1923-9. X-1,X-2. [pmid: 15514508].
2549 Richardson K, Engel G, Yamazaki T, et al. Electrocardiographic damage scores and cardiovascular mortality. Am Heart J. Mar. 2005;149(3):458-63. X-1,X-8. [pmid: 15864234].
2550 Rich-Edwards JW, Kleinman K, Michels KB, et al. Longitudinal study of birth weight and adult body mass index in predicting risk of coronary heart disease and stroke in women. BMJ. May. 14. 2005;330(7500):1115. X-1E,X-1F,X-2. [pmid: 15857857].
2551 Richie RC. Non-invasive assessment of the risk of coronary heart disease. J Insur Med. 2002;34(1):31-42. X-1,X-2,X-4,X-5. [pmid: 15303592].
2552 Riddell T, Lindsay G, Kenealy T, et al. The accuracy of ethnicity data in primary care and its impact on cardiovascular risk assessment and management--PREDICT CVD-8. N Z Med J. Sep. 5. 2008;121(1281):40-8. X-1,X-2,X-5,X-6. [pmid: 18797483].
2553 Ridker PM. High-sensitivity C-reactive protein: potential adjunct for global risk assessment in the primary prevention of cardiovascular disease. Circulation. Apr. 3. 2001;103(13):1813-8. X-4. [pmid: 11282915].
2554 Ridker PM. Cardiology Patient Page. C-reactive protein: a simple test to help predict risk of heart attack and stroke. Circulation. Sep. 23. 2003;108(12):e81-5. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 14504253].
2555 Ridker PM, Cook N. Clinical usefulness of very high and very low levels of C-reactive protein across the full range of Framingham Risk Scores. Circulation. Apr. 27. 2004;109(16):1955-9. X-1F,X-2. [pmid: 15051634].
2556 Ridker PM, Rifai N, Rose L, et al. Comparison of C-reactive protein and low-density lipoprotein cholesterol levels in the prediction of first cardiovascular events. N Engl J Med. Nov. 14. 2002;347(20):1557-65. X-1F,X-2. [pmid: 12432042].
2557 Ridker PM, Wilson PW, Grundy SM. Should C-reactive protein be added to metabolic syndrome and to assessment of global cardiovascular risk?. Circulation. Jun. 15. 2004;109(23):2818-25. X-2,X-4,X-5,X-6. [pmid: 15197153].
2558 Ridley S. Cardiac scoring systems--what is their value?. Anaesthesia. Oct. 2003;58(10):985-91. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12969039].
2559 Riebel T, Kebelmann-Betzing C, Gotze R, et al. Transcranial Doppler ultrasonography in neurologically asymptomatic children and young adults with sickle cell disease. Eur Radiol. Mar. 2003;13(3):563-70. X-1,X-6,X-7,X-8. [pmid: 12594560].
2560 Rieber J, Jung P, Koenig A, et al. Five-year follow-up in patients after therapy stratification based on intracoronary pressure measurement. Am Heart J. Mar. 2007;153(3):403-9. X-1,X-7,X-8. [pmid: 17307420].
2561 Rieck M, Moreland J. The Orpington Prognostic Scale for patients with stroke: reliability and pilot predictive data for discharge destination and therapeutic services. Disabil Rehabil. Dec. 15. 2005;27(23):1425-33. X-1,X-6,X-7,X-8. [pmid: 16418057].
2562 Riedel BJ, Grattan A, Martin CB, et al. Long-term outcome of patients with perioperative myocardial infarction as diagnosed by troponin I after routine surgical coronary artery revascularization. J Cardiothorac Vasc Anesth. Dec. 2006;20(6):781-7. X-1,X-2,X-7,X-8. [pmid: 17138080].
2563 Rietbrock S, Heeley E, Plumb J, et al. Chronic atrial fibrillation: Incidence, prevalence, and prediction of stroke using the Congestive heart failure, Hypertension, Age >75, Diabetes mellitus, and prior Stroke or transient ischemic attack (CHADS2) risk stratification scheme. Am Heart J. Jul. 2008;156(1):57-64. X-1. [pmid: 18585497].
2564 Riezebos RK, Ronner E, de Boer BA, et al. Dynamics in N-terminal pro-brain natriuretic peptide concentration in patients with non-ST-elevation acute coronary syndrome. Am Heart J. Dec. 2005;150(6):1255-9. X-1,X-2,X-6,X-7,X-8. [pmid: 16338268].
2565 Rifai N. C-reactive protein and coronary heart disease: diagnostic and therapeutic implications for primary prevention. Cardiovasc Toxicol. 2001;1(2):153-7. X-2,X-4,X-5,X-6. [pmid: 12213988].
2566 Rifai N, Ridker PM. High-sensitivity C-reactive protein: a novel and promising marker of coronary heart disease. Clin Chem. Mar. 2001;47(3):403-11. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 11238289].
2567 Rigatelli G. Assessing the appropriateness and increasing the yield of renal angiography in patients undergoing coronary angiography: a scoring system. Int J Cardiovasc Imaging. Apr. 2006;22(2):135-9. X-1,X-5,X-6,X-8. [pmid: 16021331].
2568 Rigatelli G, Cardaioli P, Dell'Avvocata F, et al. Peculiar angiographic predictors of impending left ventricular rupture after primary coronary angioplasty. Cardiovasc Revasc Med. Oct-Dec. 2008;9(4):235-7. X-1X-2,,X-8. [pmid: 18928948].
2569 Rihal CS, Grill DE, Bell MR, et al. Prediction of death after percutaneous coronary interventional procedures. Am Heart J. Jun. 2000;139(6):1032-8. X-1,X-5,X-8. [pmid: 10827384].
2570 Riley WA. Cardiovascular risk assessment in individual patients from carotid intimal-medial thickness measurements. Curr Atheroscler Rep. May. 2004;6(3):225-31. X-1,X-2,X-4,X-5,X-6. [pmid: 15068748].
2571 Riordan CJ, Engoren M, Zacharias A, et al. Resource utilization in coronary artery bypass operation: does surgical risk predict cost?. Ann Thorac Surg. Apr. 2000;69(4):1092-7. X-1,X-6,X-8. [pmid: 10800799].
2572 Ristow B, Ahmed S, Wang L, et al. Pulmonary regurgitation end-diastolic gradient is a Doppler marker of cardiac status: data from the Heart and Soul Study. J Am Soc Echocardiogr. Sep. 2005;18(9):885-91. X-1,X-5,X-6,X-7,X-8. [pmid: 16153508].
2573 Roberts EB, Ramnath R, Fallows S, et al. “First-hit” heart attack risk calculators on the world wide web: implications for laypersons and healthcare practitioners. Int J Med Inform. Jun. 2008;77(6):405-12. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 17904896].
2574 Roberts MA, MacMillan N, Hare DL, et al. Cardiac troponin levels in asymptomatic patients on the renal transplant waiting list. Nephrology (Carlton). Oct. 2006;11(5):471-6. X-1,X-2,X-5,X-6. [pmid: 17014564].
2575 Robinson JG, Wallace R, Limacher M, et al. Elderly women diagnosed with nonspecific chest pain may be at increased cardiovascular risk. J Womens Health (Larchmt). Dec. 2006;15(10):1151-60. X-1,X-2,X-8. [pmid: 17199456].
2576 Rockx MA, Fox SA, Stitt LW, et al. Is obesity a predictor of mortality, morbidity and readmission after cardiac surgery?. Can J Surg. Feb. 2004;47(1):34-8. X-1,X-6,X-8. [pmid: 14997923].
2577 Rodriguez BL, Lau N, Burchfiel CM, et al. Glucose intolerance and 23-year risk of coronary heart disease and total mortality: the Honolulu Heart Program. Diabetes Care. Aug. 1999;22(8):1262-5. X-1F,X-2. [pmid: 10480768].
2578 Rogowski O, Shapira I, Toker S, et al. Obesity-related correlation between C-reactive protein and the calculated 10-y Framingham Coronary Heart Disease Risk Score. Int J Obes (Lond). Jul. 2005;29(7):772-7. X-1,X-5. [pmid: 15795749].
2579 Rohde LE, Polanczyk CA, Goldman L, et al. Usefulness of transthoracic echocardiography as a tool for risk stratification of patients undergoing major noncardiac surgery. Am J Cardiol. Mar. 1. 2001;87(5):505-9. X-1. [pmid: 11230829].
2580 Rohrig R, Hartmann B, Junger A, et al. Corrected incidences of co-morbidities - a statistical approach for risk-assessment in anesthesia using an AIMS. J Clin Monit Comput. Jun. 2007;21(3):159-66. X-1,X-6. [pmid: 17410476].
2581 Rohrig R, Junger A, Hartmann B, et al. The incidence and prediction of automatically detected intraoperative cardiovascular events in noncardiac surgery. Anesth Analg. Mar. 2004;98(3):569-77. table of contents. X-1. [pmid: 14980900].
2582 Romagnoli E, Burzotta F, Trani C, et al. EuroSCORE as predictor of in-hospital mortality after percutaneous coronary intervention. Heart. Jan. 2009;95(1):43-8. X-1,X-8. [pmid: 18208829].
2583 Romano PS, Chan BK. Risk-adjusting acute myocardial infarction mortality: are APR-DRGs the right tool?. Health Serv Res. Mar. 2000;34(7):1469-89. X-1,X-5,X-6,X-8. [pmid: 10737448].
2584 Roquer J, Ois A, Rodriguez Campello A, et al. Clustering of vascular risk factors and in-hospital death after acute ischemic stroke. J Neurol. Dec. 2007;254(12):1636-41. X-1,X-6,X-8. [pmid: 18004645].
2585 Roquer J, Rodriguez Campello A, Gomis M, et al. Previous antiplatelet therapy is an independent predictor of 30-day mortality after spontaneous supratentorial intracerebral hemorrhage. J Neurol. Apr. 2005;252(4):412-6. X-1,X-7. [pmid: 15739042].
2586 Roques F, Nashef SA, Michel P, et al. Does EuroSCORE work in individual European countries?. Eur J Cardiothorac Surg. Jul. 2000;18(1):27-30. X-1,X-6,X-8. [pmid: 10869937].
2587 Rosamond W, Flegal K, Furie K, et al. Heart disease and stroke statistics--2008 update: a report from the American Heart Association Statistics Committee and Stroke Statistics Subcommittee. Circulation. Jan. 29. 2008;117(4):e25-146. X-1. [pmid: 18086926].
2588 Rosato R, Ciccone G, Bo S, et al. Evaluating cardiovascular mortality in type 2 diabetes patients: an analysis based on competing risks Markov chains and additive regression models. J Eval Clin Pract. Jun. 2007;13(3):422-8. X-1F,X-2,X-8. [pmid: 17518809].
2589 Rosmarakis ES, Prapas SN, Rellos K, et al. Nosocomial infections after off-pump coronary artery bypass surgery: frequency, characteristics, and risk factors. Interact Cardiovasc Thorac Surg. Dec. 2007;6(6):759-67. X-1,X-2,X-6,X-8. [pmid: 17905781].
2590 Ross MJ, Herrmann HC, Moliterno DJ, et al. Angiographic variables predict increased risk for adverse ischemic events after coronary stenting with glycoprotein IIb/IIIa inhibition: results from the TARGET trial. J Am Coll Cardiol. Sep. 17. 2003;42(6):981-8. X-1,X-8. [pmid: 13678916].
2591 Rossi E, Biasucci LM, Citterio F, et al. Risk of myocardial infarction and angina in patients with severe peripheral vascular disease: predictive role of C-reactive protein. Circulation. Feb. 19. 2002;105(7):800-3. X-1,X-7,X-8. [pmid: 11854118].
2592 Rosvall M, Chaix B, Lynch J, et al. Similar support for three different life course socioeconomic models on predicting premature cardiovascular mortality and all-cause mortality. BMC Public Health. 2006;6:203. X-1,X-6. [pmid: 16889658].
2593 Roth EJ, Lovell L, Harvey RL, et al. Incidence of and risk factors for medical complications during stroke rehabilitation. Stroke. Feb. 2001;32(2):523-9. X-1,X-6,X-8. [pmid: 11157192].
2594 Rothenbacher D, Koenig W, Brenner H. Comparison of N-terminal pro-B-natriuretic peptide, C-reactive protein, and creatinine clearance for prognosis in patients with known coronary heart disease. Arch Intern Med. Dec. 11-25. 2006;166(22):2455-60. X-1D,X-1F,X-2,X-6,X-8(CABG)(100%). [pmid: 17159010].
2595 Rothwell PM, Buchan A, Johnston SC. Recent advances in management of transient ischaemic attacks and minor ischaemic strokes. Lancet Neurol. Apr. 2006;5(4):323-31. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16545749].
2596 Rothwell PM, Howard SC, Spence JD. Relationship between blood pressure and stroke risk in patients with symptomatic carotid occlusive disease. Stroke. Nov. 2003;34(11):2583-90. X-1,X-6,X-8. [pmid: 14593126].
2597 Rotstein Z, Mandelzweig L, Lavi B, et al. Does the coronary care unit improve prognosis of patients with acute myocardial infarction? A thrombolytic era study. Eur Heart J. Jun. 1999;20(11):813-8. X-1,X-6,X-8. [pmid: 10329079].
2598 Roumeguere T, Wespes E, Carpentier Y, et al. Erectile dysfunction is associated with a high prevalence of hyperlipidemia and coronary heart disease risk. Eur Urol. Sep. 2003;44(3):355-9. X-1,X-5,X-8. [pmid: 12932936].
2599 Roy P, Raya V, Okabe T, et al. Incidence, predictors, and outcomes of post-percutaneous coronary intervention nephropathy in patients with diabetes mellitus and normal baseline serum creatinine levels. Am J Cardiol. Jun. 1. 2008;101(11):1544-9. X-1,X-8. [pmid: 18489931].
2600 Roy P, Torguson R, Okabe T, et al. Comparison between sirolimus- and paclitaxel-eluting stents in complex patient and lesions subsets. Catheter Cardiovasc Interv. Aug. 1. 2007;70(2):167-72. X-1,X-5,X-6,X-8. [pmid: 17503503].
2601 Royston P, Ambler G, Sauerbrei W. The use of fractional polynomials to model continuous risk variables in epidemiology. Int J Epidemiol. Oct. 1999;28(5):964-74. X-1,X-6. [pmid: 10597998].
2602 Roze S, Liens D, Palmer A, et al. A health economic model to determine the long-term costs and clinical outcomes of raising low HDL-cholesterol in the prevention of coronary heart disease. Curr Med Res Opin. Dec. 2006;22(12):2549-56. X-1,X-5,X-6. [pmid: 17166337].
2603 Rubin C, Nolin TD, Himmelfarb J. Are biomarkers useful for assessing cardiovascular risk in patients with chronic kidney disease?. Curr Opin Nephrol Hypertens. Nov. 2007;16(6):506-11. X-1,X-2,X-4,X-5. [pmid: 18089962].
2604 Rubinshtein R, Halon DA, Gaspar T, et al. Usefulness of 64-slice cardiac computed tomographic angiography for diagnosing acute coronary syndromes and predicting clinical outcome in emergency department patients with chest pain of uncertain origin. Circulation. Apr. 3. 2007;115(13):1762-8. X-7. [pmid: 17372178].
2605 Ruel M, Rubens FD, Masters RG, et al. Late incidence and predictors of persistent or recurrent heart failure in patients with aortic prosthetic valves. J Thorac Cardiovasc Surg. Jan. 2004;127(1):149-59. X-1,X-8. [pmid: 14752425].
2606 Ruiz-Sandoval JL, Chiquete E, Romero-Vargas S, et al. Grading scale for prediction of outcome in primary intracerebral hemorrhages. Stroke. May. 2007;38(5):1641-4. X-1,X-6. [pmid: 17379820].
2607 Rumberger JA. Cost effectiveness of coronary calcification scanning using electron beam tomography in intermediate and high risk asymptomatic individuals. J Cardiovasc Risk. Apr. 2000;7(2):113-9. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 10879414].
2608 Rumley A, Emberson JR, Wannamethee SG, et al. Effects of older age on fibrin D-dimer, C-reactive protein, and other hemostatic and inflammatory variables in men aged 60-79 years. J Thromb Haemost. May. 2006;4(5):982-7. X-1,X-2,X-6. [pmid: 16689748].
2609 Rumsfeld JS, MaWhinney S, McCarthy M Jr, et al. Health-related quality of life as a predictor of mortality following coronary artery bypass graft surgery. Participants of the Department of Veterans Affairs Cooperative Study Group on Processes, Structures, and Outcomes of Care in Cardiac Surgery. JAMA. Apr. 14. 1999;281(14):1298-303. X-1,X-6,X-8. [pmid: 10208145].
2610 Rundek T, Arif H, Boden-Albala B, et al. Carotid plaque, a subclinical precursor of vascular events: the Northern Manhattan Study. Neurology. Apr. 1. 2008;70(14):1200-7. X-2,X-8(21.8%). [pmid: 18354078].
2611 Ruppert K, Roberts MS, Orchard TJ, et al. Cardiovascular disease risk prediction in type 1 diabetes: accounting for the differences. Diabetes Res Clin Pract. Nov. 2007;78(2):234-7. X-1. [pmid: 17467846].
2612 Russo A, Grigioni F, Avierinos JF, et al. Thromboembolic complications after surgical correction of mitral regurgitation incidence, predictors, and clinical implications. J Am Coll Cardiol. Mar. 25. 2008;51(12):1203-11. X-1,X-2,X-6,X-8. [pmid: 18355659].
2613 Russo AM, Hafley GE, Lee KL, et al. Racial differences in outcome in the Multicenter UnSustained Tachycardia Trial (MUSTT): a comparison of whites versus blacks. Circulation. Jul. 8. 2003;108(1):67-72. X-1,X-6. [pmid: 12821551].
2614 Russo AM, Stamato NJ, Lehmann MH, et al. Influence of gender on arrhythmia characteristics and outcome in the Multicenter UnSustained Tachycardia Trial. J Cardiovasc Electrophysiol. Sep. 2004;15(9):993-8. X-1,X-6. [pmid: 15363069].
2615 Rutledge T, Reis SE, Olson M, et al. Socioeconomic status variables predict cardiovascular disease risk factors and prospective mortality risk among women with chest pain. The WISE Study Behav Modif. Jan. 2003;27(1):54-67. X-1,X-8.
2616 Rutter MK, Wahid ST, McComb JM, et al. Significance of silent ischemia and microalbuminuria in predicting coronary events in asymptomatic patients with type 2 diabetes. J Am Coll Cardiol. Jul. 3. 2002;40(1):56-61. X-7. [pmid: 12103256].
2617 Rutter MK, Wilson PW, Sullivan LM, et al. Use of alternative thresholds defining insulin resistance to predict incident type 2 diabetes mellitus and cardiovascular disease. Circulation. Feb. 26. 2008;117(8):1003-9. X-1F. [pmid: 18250267].
2618 Ryan CJ, DeVon HA, Horne R, et al. Symptom clusters in acute myocardial infarction: a secondary data analysis. Nurs Res. Mar-Apr. 2007;56(2):72-81. X-1,X-2,X-5,X-8. [pmid: 17356437].
2619 Ryan G, Knuiman MW, Divitini ML, et al. Decline in lung function and mortality: the Busselton Health Study. J Epidemiol Community Health. Apr. 1999;53(4):230-4. X-1,X-6. [pmid: 10396549].
2620 Saaristo T, Peltonen M, Lindstrom J, et al. Cross-sectional evaluation of the Finnish Diabetes Risk Score: a tool to identify undetected type 2 diabetes, abnormal glucose tolerance and metabolic syndrome. Diab Vasc Dis Res. May. 2005;2(2):67-72. X-1,X-5,X-6. [pmid: 16305061].
2621 Sabatine MS, Antman EM. The thrombolysis in myocardial infarction risk score in unstable angina/non-ST-segment elevation myocardial infarction. J Am Coll Cardiol. Feb. 19. 2003;41(4 Suppl S):89S-95S. X-1,X-6,X-8. [pmid: 12644346].
2622 Sabatine MS, Januzzi JL, Snapinn S, et al. A risk score system for predicting adverse outcomes and magnitude of benefit with glycoprotein IIb/IIIa inhibitor therapy in patients with unstable angina pectoris. Am J Cardiol. Sep. 1. 2001;88(5):488-92. X-1,X-8. [pmid: 11524055].
2623 Sabatine MS, Ploughman L, Simonsen KL, et al. Association between ADAMTS1 matrix metalloproteinase gene variation, coronary heart disease, and benefit of statin therapy. Arterioscler Thromb Vasc Biol. Mar. 2008;28(3):562-7. X-1,X-2. [pmid: 18174457].
2624 Sabik JF 3rd, Lytle BW, Blackstone EH, et al. Does competitive flow reduce internal thoracic artery graft patency?. Ann Thorac Surg. Nov. 2003;76(5):1490-6. discussion 1497. X-1,X-6,X-8. [pmid: 14602274].
2625 Sabri N, Azouz S, Lale E, et al. Initial results, predictors of success, and long-term outcome of primary coronary angioplasty for acute myocardial infarction in a community hospital. Am J Cardiol. May. 1. 2001;87(9):1103-5. A9. X-1,X-6,X-8. [pmid: 11348611].
2626 Sacks FM. The apolipoprotein story. Atheroscler Suppl. Aug. 2006;7(4):23-7. X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9,. [pmid: 16822722].
2627 Sacks FM, Alaupovic P, Moye LA, et al. VLDL, apolipoproteins B, CIII, and E, and risk of recurrent coronary events in the Cholesterol and Recurrent Events (CARE) trial. Circulation. Oct. 17. 2000;102(16):1886-92. X-1,X-8. [pmid: 11034934].
2628 Saczynski JS, White L, Peila RL, et al. The relation between apolipoprotein A-I and dementia: the Honolulu-Asia aging study. Am J Epidemiol. May. 1. 2007;165(9):985-92. X-1,X-6. [pmid: 17298957].
2629 Sadanandan S, Cannon CP, Gibson CM, et al. A risk score to estimate the likelihood of coronary artery bypass surgery during the index hospitalization among patients with unstable angina and non-ST-segment elevation myocardial infarction. J Am Coll Cardiol. Aug. 18. 2004;44(4):799-803. X-1,X-6,X-8. [pmid: 15312862].
2630 Sadeghi HM, Stone GW, Grines CL, et al. Impact of renal insufficiency in patients undergoing primary angioplasty for acute myocardial infarction. Circulation. Dec. 2. 2003;108(22):2769-75. X-1,X-8. [pmid: 14638545].
2631 Sadrzadeh Rafie AH, Sungar GW, Dewey FE, et al. Prognostic value of double product reserve. Eur J Cardiovasc Prev Rehabil. Oct. 2008;15(5):541-7. X-1,X-2. [pmid: 18665099].
2632 Saevarsdottir S, Oskarsson OO, Aspelund T, et al. Mannan binding lectin as an adjunct to risk assessment for myocardial infarction in individuals with enhanced risk. J Exp Med. Jan. 3. 2005;201(1):117-25. X-5. [pmid: 15623574].
2633 Safar ME, Henry O, Meaume S. Aortic pulse wave velocity: an independent marker of cardiovascular risk. Am J Geriatr Cardiol. Sep-Oct. 2002;11(5):295-8. X-2,X-4,X-5,X-6. [pmid: 12214167].
2634 Saini SD, Schoenfeld P, Fendrick AM, et al. Cost-effectiveness of proton pump inhibitor cotherapy in patients taking long-term, low-dose aspirin for secondary cardiovascular prevention. Arch Intern Med. Aug. 11. 2008;168(15):1684-90. discussion 1691. X-1,X-2,X-5,X-6,X-8. [pmid: 18695083].
2635 Saito S, Tanaka S, Hiroe Y, et al. Angioplasty for chronic total occlusion by using tapered-tip guidewires. Catheter Cardiovasc Interv. Jul. 2003;59(3):305-11. X-1,X-6,X-8. [pmid: 12822146].
2636 Saitz R, Gaeta J, Cheng DM, et al. Risk of mortality during four years after substance detoxification in urban adults. J Urban Health. Mar. 2007;84(2):272-82. X-1,X-2. [pmid: 17221296].
2637 Sajadieh A, Nielsen OW, Rasmussen V, et al. Ventricular arrhythmias and risk of death and acute myocardial infarction in apparently healthy subjects of age >or=55 years. Am J Cardiol. May. 1. 2006;97(9):1351-7. X-1F,X-2, (Denmark). [pmid: 16635610].
2638 Sajadieh A, Nielsen OW, Rasmussen V, et al. Increased ventricular ectopic activity in relation to C-reactive protein, and NT-pro-brain natriuretic peptide in subjects with no apparent heart disease. Pacing Clin Electrophysiol. Nov. 2006;29(11):1188-94. X-1,X-2,X-6,X-8. [pmid: 17100670].
2639 Sajadieh A, Rasmussen V, Hein HO, et al. Familial predisposition to premature heart attack and reduced heart rate variability. Am J Cardiol. Jul. 15. 2003;92(2):234-6. X-1,X-2,X-6. [pmid: 12860234].
2640 Sakaguchi M, Kitagawa K, Nagai Y, et al. Equivalence of plaque score and intima-media thickness of carotid ultrasonography for predicting severe coronary artery lesion. Ultrasound Med Biol. Mar. 2003;29(3):367-71. X-1,X-6,X-8. [pmid: 12706187].
2641 Salinas G, Daher IN, Okorodudu AO, et al. B-type natriuretic peptide is not a marker of ischemia during dobutamine stress echocardiography. J Am Soc Echocardiogr. Jan. 2007;20(1):23-6. X-1X-6,,X-7. [pmid: 17218198].
2642 Salisbury AC, Reid KJ, Spertus JA. Impact of chronic obstructive pulmonary disease on post-myocardial infarction outcomes. Am J Cardiol. Mar. 1. 2007;99(5):636-41. X-1,X-8. [pmid: 17317363].
2643 Salles G, Xavier S, Sousa A, et al. Prognostic value of QT interval parameters for mortality risk stratification in Chagas' disease: results of a long-term follow-up study. Circulation. Jul. 22. 2003;108(3):305-12. X-1,X-6,X-8. [pmid: 12835217].
2644 Salles GF, Xavier SS, Sousa AS, et al. T-wave axis deviation as an independent predictor of mortality in chronic Chagas' disease. Am J Cardiol. May. 1. 2004;93(9):1136-40. X-1,X-2. [pmid: 15110206].
2645 Saloheimo P, Juvela S, Hillbom M. Use of aspirin, epistaxis, and untreated hypertension as risk factors for primary intracerebral hemorrhage in middle-aged and elderly people. Stroke. Feb. 2001;32(2):399-404. X-5,X-8. [pmid: 11157173].
2646 Samaha FF, Kimmel SE, Kizer JR, et al. Usefulness of the TIMI risk score in predicting both short- and long-term outcomes in the Veterans Affairs Non-Q-Wave Myocardial Infarction Strategies In-Hospital (VANQWISH) Trial. Am J Cardiol. Nov. 1. 2002;90(9):922-6. X-1,X-8. [pmid: 12398955].
2647 San Roman JA, Sanz-Ruiz R, Ortega JR, et al. Safety and predictors of complications with a new accelerated dobutamine stress echocardiography protocol. J Am Soc Echocardiogr. Jan. 2008;21(1):53-7. X-1,X-5,X-6. [pmid: 17628422].
2648 Sanches FM, Avesani CM, Kamimura MA, et al. Waist circumference and visceral fat in CKD: a cross-sectional study. Am J Kidney Dis. Jul. 2008;52(1):66-73. X-1,X-2,X-5,X-6,X-7. [pmid: 18440683].
2649 Sanchis J, Bodi V, Llacer A, et al. Usefulness of C-reactive protein and left ventricular function for risk assessment in survivors of acute myocardial infarction. Am J Cardiol. Sep. 15. 2004;94(6):766-9. X-1,X-8. [pmid: 15374783].
2650 Sanchis J, Bodi V, Nunez J, et al. New risk score for patients with acute chest pain, non-ST-segment deviation, and normal troponin concentrations: a comparison with the TIMI risk score. J Am Coll Cardiol. Aug. 2. 2005;46(3):443-9. X-1,X-8. [pmid: 16053956].
2651 Sanchis J, Bodi V, Nunez J, et al. Limitations of clinical history for evaluation of patients with acute chest pain, non-diagnostic electrocardiogram, and normal troponin. Am J Cardiol. Mar. 1. 2008;101(5):613-7. X-1D,X-8(24.40%). [pmid: 18308008].
2652 Sanchis J, Bosch X, Bodi V, et al. Combination of clinical risk profile, early exercise testing and circulating biomarkers for evaluation of patients with acute chest pain without ST-segment deviation or troponin elevation. Heart. Mar. 2008;94(3):311-5. X-1. [pmid: 17639094].
2653 Sanders GD, Al-Khatib SM, Berliner E, et al. Preventing tomorrow's sudden cardiac death today: part II: Translating sudden cardiac death risk assessment strategies into practice and policy. Am Heart J. Jun. 2007;153(6):951-9. X-1,X-2,X-3,X-4,X-5,X-6,X-7,X-8. [pmid: 17540195].
2654 Sanderson SC, Wardle J, Jarvis MJ, et al. Public interest in genetic testing for susceptibility to heart disease and cancer: a population-based survey in the UK. Prev Med. Sep. 2004;39(3):458-64. X-1,X-2,X-5,X-6. [pmid: 15313084].
2655 Sangiorgi GM, Clementi F, Cola C, et al. Plaque vulnerability and related coronary event prediction by intravascular ultrasound with virtual histology: “it's a long way to tipperary”?. Catheter Cardiovasc Interv. Aug. 1. 2007;70(2):203-10. X-1. [pmid: 17630663].
2656 Santamaria A, Oliver A, Borrell M, et al. Risk of ischemic stroke associated with functional thrombin-activatable fibrinolysis inhibitor plasma levels. Stroke. Oct. 2003;34(10):2387-91. X-1,X-5. [pmid: 12947154].
2657 Santana CA, Garcia EV, Vansant JP, et al. Three-dimensional color-modulated display of myocardial SPECT perfusion distributions accurately assesses coronary artery disease. J Nucl Med. Dec. 2000;41(12):1941-6. X-1,X-6,X-7,X-8. [pmid: 11138676].
2658 Santana CA, Shaw LJ, Garcia EV, et al. Incremental prognostic value of left ventricular function by myocardial ECG-gated FDG PET imaging in patients with ischemic cardiomyopathy. J Nucl Cardiol. Sep-Oct. 2004;11(5):542-50. X-1,X-7,X-8. [pmid: 15472639].
2659 Santopinto J, Gurfinkel EP, Torres V, et al. Prior aspirin users with acute non-ST-elevation coronary syndromes are at increased risk of cardiac events and benefit from enoxaparin. Am Heart J. Apr. 2001;141(4):566-72. X-1. [pmid: 11275921].
2660 Saribulbul O, Alat I, Coskun S, et al. The role of brain natriuretic peptide in the prediction of cardiac performance in coronary artery bypass grafting. Tex Heart Inst J. 2003;30(4):298-304. X-1,X-2,X-8. [pmid: 14677740].
2661 Sarker SJ, Heuschmann PU, Burger I, et al. Predictors of survival after haemorrhagic stroke in a multi-ethnic population: the South London Stroke Register (SLSR). J Neurol Neurosurg Psychiatry. Mar. 2008;79(3):260-5. X-1,X-6,X-8. [pmid: 18032456].
2662 Sarnak MJ, Katz R, Stehman-Breen CO, et al. Cystatin C concentration as a risk factor for heart failure in older adults. Ann Intern Med. Apr. 5. 2005;142(7):497-505. X-1,X-6. [pmid: 15809461].
2663 Sarrafzadegan N, Rabiei K, Shirani S, et al. Drop-out predictors in cardiac rehabilitation programmes and the impact of sex differences among coronary heart disease patients in an Iranian sample: a cohort study. Clin Rehabil. Apr. 2007;21(4):362-72. X-1,X-5,X-6,X-7,X-8. [pmid: 17613578].
2664 Sarullo FM, Di Pasquale P, Orlando G, et al. Utility and safety of immediate exercise testing of low-risk patients admitted to the hospital with acute chest pain. Int J Cardiol. Sep. 15. 2000;75(2-3):239-43. X-1,X-7,X-8. [pmid: 11077140].
2665 Sarveswaran J, Ikponmwosa A, Asthana S, et al. Should cardiac troponins be used as a risk stratification tool for patients with chronic critical limb ischaemia?. Eur J Vasc Endovasc Surg. Jun. 2007;33(6):703-7. X-1,X-2,X-6,X-7. [pmid: 17275360].
2666 Sarzynska-Dlugosz I, Nowaczenko M, Blazejewska-Hyzorek B, et al. Echolucent internal carotid artery plaques are a risk factor for stroke. Neurol Neurochir Pol. Mar-Apr. 2008;42(2):91-8. X-1,X-2,X-5,X-6,X-8. [pmid: 18512164].
2667 Sasaki S, Niwano S, Fukaya H, et al. Clinical usefulness of electrophysiologic study (EPS)-guided risk stratification for life-threatening arrhythmia in patients with heart failure. Int Heart J. Mar. 2007;48(2):155-63. X-1,X-6. [pmid: 17409581].
2668 Sassi F, McDaid D, Ricciardi W. Conjoint analysis of p s for cardiac risk assessment in primary care. Int J Technol Assess Health Care. Spring. 2005;21(2):211-8. X-1,X-5,X-6. [pmid: 15921061].
2669 Sato A, Asayama K, Ohkubo T, et al. Optimal cutoff point of waist circumference and use of home blood pressure as a definition of metabolic syndrome: the Ohasama study. Am J Hypertens. May. 2008;21(5):514-20. X-1,X-6. [pmid: 18437142].
2670 Satoh H, Nishino T, Tomita K, et al. Risk factors and the incidence of coronary artery disease in young middle-aged Japanese men: results from a 10-year cohort study. Intern Med. 2006;45(5):235-9. X-1F,X-2. [pmid: 16595986].
2671 Satre H, Holmvang L, Wagner GS, et al. Reduction of myocardial damage by prolonged treatment with subcutaneous low molecular weight heparin in unstable coronary artery disease. FRISC study group. Fragmin during Instability in Coronary Artery Disease. Eur Heart J. May. 1999;20(9):645-52. X-1,X-5,X-6. [pmid: 10208784].
2672 Sattar N. Why metabolic syndrome criteria have not made prime time: a view from the clinic. Int J Obes (Lond). May. 2. 2008;32:S30-4. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18469837].
2673 Sattar N, Gaw A, Scherbakova O, et al. Metabolic syndrome with and without C-reactive protein as a predictor of coronary heart disease and diabetes in the West of Scotland Coronary Prevention Study. Circulation. Jul. 29. 2003;108(4):414-9. X-2. [pmid: 12860911].
2674 Sattar N, Lowe GD. High sensitivity C-reactive protein and cardiovascular disease: an association built on unstable foundations?. Ann Clin Biochem. Jul. 2006;43(Pt 4):252-6. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9,. [pmid: 16824274].
2675 Sattar N, McConnachie A, Shaper AG, et al. Can metabolic syndrome usefully predict cardiovascular disease and diabetes? Outcome data from two prospective studies. Lancet. Jun. 7. 2008;371(9628):1927-35. X-1F,X-1D,X-2,X-8. [pmid: 18501419].
2676 Sattar N, Murray HM, McConnachie A, et al. C-reactive protein and prediction of coronary heart disease and global vascular events in the Prospective Study of Pravastatin in the Elderly at Risk (PROSPER). Circulation. Feb. 27. 2007;115(8):981-9. X-1D,X-1F,X-2,X-8(~40%). [pmid: 17283264].
2677 Sauer WH, Berlin JA, Strom BL, et al. Cigarette yield and the risk of myocardial infarction in smokers. Arch Intern Med. Feb. 11. 2002;162(3):300-6. X-2,X-5,X-8. [pmid: 11822922].
2678 Saumarez RC, Pytkowski M, Sterlinski M, et al. Paced ventricular electrogram fractionation predicts sudden cardiac death in hypertrophic cardiomyopathy. Eur Heart J. Jul. 2008;29(13):1653-61. X-1,X-2,X-7,X-8. [pmid: 18385118].
2679 Sauvaget C, Ramadas K, Thomas G, et al. Body mass index, weight change and mortality risk in a prospective study in India. Int J Epidemiol. Oct. 2008;37(5):990-1004. X-1,X-2. [pmid: 18388152].
2680 Sayeed S, Stanziale SF, Wholey MH, et al. Angiographic lesion characteristics can predict adverse outcomes after carotid artery stenting. J Vasc Surg. Jan. 2008;47(1):81-7. X-1,X-2,X-5,X-6,X-8. [pmid: 18178457].
2681 Schachinger V, Zeiher AM. Stem cells and cardiovascular and renal disease: today and tomorrow. J Am Soc Nephrol. Mar. 1. 2005;16:S2-6. X-1,X-2,X-5,X-6,X-7. [pmid: 15938024].
2682 Schaeffner ES, Kurth T, Bowman TS, et al. Blood pressure measures and risk of chronic kidney disease in men. Nephrol Dial Transplant. Apr. 2008;23(4):1246-51. X-1,X-6. [pmid: 17984108].
2683 Schaer BA, Zellweger MJ, Cron TA, et al. Value of routine holter monitoring for the detection of paroxysmal atrial fibrillation in patients with cerebral ischemic events. Stroke. Mar. 2004;35(3):e68-70. X-1,X-2,X-5,X-6,X-8. [pmid: 14963276].
2684 Schelleman H, Klungel OH, Witteman JC, et al. Diuretic-gene interaction and the risk of myocardial infarction and stroke. Pharmacogenomics J. Oct. 2007;7(5):346-52. X-1,X-2. [pmid: 17189961].
2685 Schett G, Kiechl S, Weger S, et al. High-sensitivity C-reactive protein and risk of nontraumatic fractures in the Bruneck study. Arch Intern Med. Dec. 11-25. 2006;166(22):2495-501. X-1,X-2,X-6. [pmid: 17159016].
2686 Schiano V, Brevetti G, Sirico G, et al. Functional status measured by walking impairment questionnaire and cardiovascular risk prediction in peripheral arterial disease: results of the Peripheral Arteriopathy and Cardiovascular Events (PACE) study. Vasc Med. Nov. 2006;11(3):147-54. X-1. [pmid: 17288120].
2687 Schiele F, Descotes-Genon V, Seronde MF, et al. Predictive value of admission hyperglycaemia on mortality in patients with acute myocardial infarction. Diabet Med. Dec. 2006;23(12):1370-6. X-1,X-2,X-8. [pmid: 17116190].
2688 Schiele F, Legalery P, Didier K, et al. Impact of renal dysfunction on 1-year mortality after acute myocardial infarction. Am Heart J. Mar. 2006;151(3):661-7. X-1,X-8. [pmid: 16504628].
2689 Schiele F, Seronde MF, Descotes-Genon V, et al. Impact of renal dysfunction and glucometabolic status on one month mortality after acute myocardial infarction. Acute Card Care. 2007;9(1):34-42. X-1,X-6,X-8. [pmid: 17453537].
2690 Schillaci G, Reboldi G, Verdecchia P. High-normal serum creatinine concentration is a predictor of cardiovascular risk in essential hypertension. Arch Intern Med. Mar. 26. 2001;161(6):886-91. X-1F,X-2. [pmid: 11268234].
2691 Schillinger M, Exner M, Mlekusch W, et al. Serum albumin predicts cardiac adverse events in patients with advanced atherosclerosis - interrelation with traditional cardiovascular risk factors. Thromb Haemost. Mar. 2004;91(3):610-8. X-1F,X-2,X-8. [pmid: 14983239].
2692 Schillinger M, Sodeck G, Meron G, et al. Acute chest pain--identification of patients at low risk for coronary events. The impact of symptoms, medical history and risk factors. Wien Klin Wochenschr. Feb. 16. 2004;116(3):83-9. X-1,X-2,X-8. [pmid: 15008316].
2693 Schindhelm RK, Dekker JM, Nijpels G, et al. Alanine aminotransferase predicts coronary heart disease events: a 10-year follow-up of the Hoorn Study. Atherosclerosis. Apr. 2007;191(2):391-6. X-1F,X-2. [pmid: 16682043].
2694 Schinkel AF, Elhendy A, Biagini E, et al. Prognostic stratification using dobutamine stress 99mTc-tetrofosmin myocardial perfusion SPECT in elderly patients unable to perform exercise testing. J Nucl Med. Jan. 2005;46(1):12-8. X-1,X-2,X-6. [pmid: 15632027].
2695 Schloss TW, Gage BF, Rich MW. An invasive strategy is associated with decreased mortality in patients 80 years and older with acute myocardial infarction. Am J Geriatr Cardiol. Mar-Apr. 2007;16(2):84-91. X-1,X-5,X-6,X-7,X-8. [pmid: 17380617].
2696 Schlosser FJ, Mojibian HR, Dardik A, et al. Simultaneous sizing and preoperative risk stratification for thoracic endovascular aneurysm repair: role of gated computed tomography. J Vasc Surg. Sep. 2008;48(3):561-70. X-1,X-6,X-7. [pmid: 18586438].
2697 Schluter M, Reimers B, Castriota F, et al. Impact of diabetes, patient age, and gender on the 30-day incidence of stroke and death in patients undergoing carotid artery stenting with embolus protection: a post-hoc subanalysis of a prospective multicenter registry. J Endovasc Ther. Jun. 2007;14(3):271-8. X-1,X-2,X-8. [pmid: 17723014].
2698 Schmermund A, Bailey KR, Rumberger JA, et al. An algorithm for noninvasive identification of angiographic three-vessel and/or left main coronary artery disease in symptomatic patients on the basis of cardiac risk and electron-beam computed tomographic calcium scores. J Am Coll Cardiol. Feb. 1999;33(2):444-52. X-1,X-5,X-6. [pmid: 9973025].
2699 Schmermund A, Denktas AE, Rumberger JA, et al. Independent and incremental value of coronary artery calcium for predicting the extent of angiographic coronary artery disease: comparison with cardiac risk factors and radionuclide perfusion imaging. J Am Coll Cardiol. Sep. 1999;34(3):777-86. X-1,X-6,X-8. [pmid: 10483960].
2700 Schmermund A, Lehmann N, Bielak LF, et al. Comparison of subclinical coronary atherosclerosis and risk factors in unselected populations in Germany and US-America. Atherosclerosis. Nov. 2007;195(1):e207-16. X-1F,X-1G,X-2,X-4,X-5,X-6. [pmid: 17532322].
2701 Schmermund A, Stang A, Mohlenkamp S, et al. Prognostic value of electron-beam computed tomography-derived coronary calcium scores compared with clinical parameters in patients evaluated for coronary artery disease. Prognostic value of EBCT in symptomatic patients. Z Kardiol. Sep. 2004;93(9):696-705. X-1,X-2,X-8. [pmid: 15365737].
2702 Schmidt C, Fagerberg B, Hulthe J. Non-stenotic echolucent ultrasound-assessed femoral artery plaques are predictive for future cardiovascular events in middle-aged men. Atherosclerosis. Jul. 2005;181(1):125-30. X-1E,X-1F,X-2. [pmid: 15939063].
2703 Schmidt H, Fazekas F, Kostner GM, et al. Angiotensinogen gene promoter haplotype and microangiopathy-related cerebral damage: results of the Austrian Stroke Prevention Study. Stroke. Feb. 2001;32(2):405-12. X-1,X-2,X-6. [pmid: 11157174].
2704 Schmitt C, Barthel P, Ndrepepa G, et al. Value of programmed ventricular stimulation for prophylactic internal cardioverter-defibrillator implantation in postinfarction patients preselected by noninvasive risk stratifiers. J Am Coll Cardiol. Jun. 1. 2001;37(7):1901-7. X-1,X-6,X-8. [pmid: 11401129].
2705 Schnabel R, Blankenberg S, Lubos E, et al. Asymmetric dimethylarginine and the risk of cardiovascular events and death in patients with coronary artery disease: results from the AtheroGene Study. Circ Res. Sep. 2. 2005;97(5):e53-9. X-1,X-8. [pmid: 16100045].
2706 Schnabel R, Lackner KJ, Rupprecht HJ, et al. Glutathione peroxidase-1 and homocysteine for cardiovascular risk prediction: results from the AtheroGene study. J Am Coll Cardiol. May. 17. 2005;45(10):1631-7. X-1,X-8. [pmid: 15893179].
2707 Schnabel R, Rupprecht HJ, Lackner KJ, et al. Analysis of N-terminal-pro-brain natriuretic peptide and C-reactive protein for risk stratification in stable and unstable coronary artery disease: results from the AtheroGene study. Eur Heart J. Feb. 2005;26(3):241-9. X-1,X-8. [pmid: 15618051].
2708 Schneweis S, Grond M, Staub F, et al. Predictive value of neurochemical monitoring in large middle cerebral artery infarction. Stroke. Aug. 2001;32(8):1863-7. X-1,X-2,X-6,X-7,X-8. [pmid: 11486118].
2709 Schoenenberger AW, Erne P, Ammann S, et al. Prediction of arrhythmic events after myocardial infarction based on signal-averaged electrocardiogram and ejection fraction. Pacing Clin Electrophysiol. Feb. 2008;31(2):221-8. X-1,X-6,X-7,X-8. [pmid: 18233976].
2710 Schouten BW, Bohnen AM, Bosch JL, et al. Erectile dysfunction prospectively associated with cardiovascular disease in the Dutch general population: results from the Krimpen Study. Int J Impot Res. Jan-Feb. 2008;20(1):92-9. X-1D,X-1E,X-1F,X-2. [pmid: 17728804].
2711 Schouten O, Poldermans D, Visser L, et al. Fluvastatin and bisoprolol for the reduction of perioperative cardiac mortality and morbidity in high-risk patients undergoing non-cardiac surgery: rationale and design of the DECREASE-IV study. Am Heart J. Dec. 2004;148(6):1047-52. X-1. [pmid: 15632892].
2712 Schramm P, Schellinger PD, Fiebach JB, et al. Comparison of CT and CT angiography source images with diffusion-weighted imaging in patients with acute stroke within 6 hours after onset. Stroke. Oct. 2002;33(10):2426-32. X-1,X-5,X-6X-7. [pmid: 12364733].
2713 Schreier L, Gonzalez AI, Elbert A, et al. Utility of non-high-density lipoprotein cholesterol in hemodialyzed patients. Metabolism. Aug. 2004;53(8):1013-5. X-1,X-5,X-6,X-7. [pmid: 15281010].
2714 Schroder R, Zeymer U, Wegscheider K, et al. Comparison of the predictive value of ST segment elevation resolution at 90 and 180 min after start of streptokinase in acute myocardial infarction. A substudy of the hirudin for improvement of thrombolysis (HIT)-4 study. Eur Heart J. Nov. 1999;20(21):1563-71. X-1,X-6,X-8. [pmid: 10529324].
2715 Schuchlenz HW, Weihs W, Berghold A, et al. Secondary prevention after cryptogenic cerebrovascular events in patients with patent foramen ovale. Int J Cardiol. May. 11. 2005;101(1):77-82. X-1,X-6. [pmid: 15860387].
2716 Schulmeyer MC, Santelices E, Vega R, et al. Impact of intraoperative transesophageal echocardiography during noncardiac surgery. J Cardiothorac Vasc Anesth. Dec. 2006;20(6):768-71. X-1,X-2,X-5,X-7. [pmid: 17138077].
2717 Schulz AJ, Kannan S, Dvonch JT, et al. Social and physical environments and disparities in risk for cardiovascular disease: the healthy environments partnership conceptual model. Environ Health Perspect. Dec. 2005;113(12):1817-25. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16330371].
2718 Schunkert H, Moebus S, Hanisch J, et al. The correlation between waist circumference and ESC cardiovascular risk score: data from the German metabolic and cardiovascular risk project (GEMCAS). Clin Res Cardiol. Nov. 2008;97(11):827-35. X-1,X-2,X-5,X-6. [pmid: 18648725].
2719 Schwab JO, Eichner G, Balta O, et al. Determinants of heart rate turbulence after ventricular premature beats in healthy volunteers. Hellenic J Cardiol. Jan-Feb. 2005;46(1):31-4. X-1,X-2,X-5,X-6,X-7. [pmid: 15807392].
2720 Schwamm LH, Rosenthal ES, Swap CJ, et al. Hypoattenuation on CT angiographic source images predicts risk of intracerebral hemorrhage and outcome after intra-arterial reperfusion therapy. AJNR Am J Neuroradiol. Aug. 2005;26(7):1798-803. X-1,X-5,X-6,X-7. [pmid: 16091532].
2721 Schwitter J, Oelhafen M, Wyss BM, et al. 2D-spatially-selective real-time magnetic resonance imaging for the assessment of microvascular function and its relation to the cardiovascular risk profile. J Cardiovasc Magn Reson. 2006;8(5):759-69. X-5,X-7. [pmid: 16891237].
2722 Sciagra R, Imperiale A, Antoniucci D, et al. Relationship of infarct size and severity versus left ventricular ejection fraction and volumes obtained from 99mTc-sestamibi gated single-photon emission computed tomography in patients treated with primary percutaneous coronary intervention. Eur J Nucl Med Mol Imaging. Jul. 2004;31(7):969-74. X-1,X-2,X-6,X-8. [pmid: 15004727].
2723 Sciangula A, Puddu PE, Schiariti M, et al. Comparative application of multivariate models developed in Italy and Europe to predict early (28 days) and late (1 year) postoperative death after on- or off-pump coronary artery bypass grafting. Heart Surg Forum. 2007;10(4):E258-66. X-1,X-8. [pmid: 17599870].
2724 Scirica BM, Morrow DA. Troponins in acute coronary syndromes. Semin Vasc Med. Nov. 2003;3(4):363-74. X-1,X-2,X-4,X-5,X-6. [pmid: 15199443].
2725 Scirica BM, Morrow DA, Cannon CP, et al. Intensive statin therapy and the risk of hospitalization for heart failure after an acute coronary syndrome in the PROVE IT-TIMI 22 study. J Am Coll Cardiol. Jun. 6. 2006;47(11):2326-31. X-1,X-2,X-8. [pmid: 16750703].
2726 Scott B, Deman A, Peeters P, et al. Cardiac troponin T and malondialdehyde modified plasma lipids in haemodialysis patients. Nephrol Dial Transplant. Apr. 2003;18(4):737-42. X-1,X-6,X-7. [pmid: 12637643].
2727 Scott IA. Evaluating cardiovascular risk assessment for asymptomatic people. BMJ. 2009;338:a2844. X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 19124547].
2728 Scott IA, Thomson PL, Narasimhan S. Comparing risk-prediction methods using administrative or clinical data in assessing excess in-hospital mortality in patients with acute myocardial infarction. Med J Aust. Mar. 17. 2008;188(6):332-6. X-1,X-4,X-5,X-8. [pmid: 18341455].
2729 Sedrakyan A, Zhang H, Treasure T, et al. Recursive partitioning-based preoperative risk stratification for atrial fibrillation after coronary artery bypass surgery. Am Heart J. Mar. 2006;151(3):720-4. X-1,X-6,X-8. [pmid: 16504639].
2730 See R, de Lemos JA. Current status of risk stratification methods in acute coronary syndromes. Curr Cardiol Rep. Jul. 2006;8(4):282-8. X-1,X-8. [pmid: 16822363].
2731 Seitz RJ, Meisel S, Moll M, et al. Partial rescue of the perfusion deficit area by thrombolysis. J Magn Reson Imaging. Aug. 2005;22(2):199-205. X-1,X-2,X-5,X-6,X-7. [pmid: 16028252].
2732 Seliger SL, Longstreth WT Jr, Katz R, et al. Cystatin C and subclinical brain infarction. J Am Soc Nephrol. Dec. 2005;16(12):3721-7. X-1,X-2,X-5,X-8. [pmid: 16236809].
2733 Selim M, Fink JN, Kumar S, et al. Predictors of hemorrhagic transformation after intravenous recombinant tissue plasminogen activator: prognostic value of the initial apparent diffusion coefficient and diffusion-weighted lesion volume. Stroke. Aug. 2002;33(8):2047-52. X-1,X-2,X-7,X-8. [pmid: 12154261].
2734 Sellmayer A, Limmert T, Hoffmann U. High sensitivity C-reactive protein in cardiovascular risk assessment. CRP mania or useful screening?. Int Angiol. Mar. 2003;22(1):15-23. X-1,X-4. [pmid: 12771851].
2735 Selvaraj CL, Van De Graaff EJ, Campbell CL, et al. Point-of-care determination of baseline platelet function as a predictor of clinical outcomes in patients who present to the emergency department with chest pain. J Thromb Thrombolysis. Oct. 2004;18(2):109-15. X-1,X-7,X-8. [pmid: 15789177].
2736 Senn M, Favrat B, Vaucher P, et al. Physicians' estimates of the 10 year cardiovascular risk in hypertensive patients: an evaluation in primary care physicians in training. Swiss Med Wkly. Sep. 16. 2006;136(37-38):603-8. X-1,X-5,X-6. [pmid: 17043954].
2737 Sensoz Y, Ates M, Sahin S, et al. Does atherosclerotic aortic plaque detected by telecardiography indicate an increased risk of coronary artery disease?. Heart Surg Forum. 2007;10(2):E120-4. X-1,X-5. [pmid: 17597034].
2738 Senti M, Tomas M, Vila J, et al. Relationship of age-related myocardial infarction risk and Gln/Arg 192 variants of the human paraoxonase1 gene: the REGICOR study. Atherosclerosis. Jun. 2001;156(2):443-9. X-1,X-2,X-5,X-8. [pmid: 11395042].
2739 Sequist TD, Bates DW, Cook EF, et al. Prediction of missed myocardial infarction among symptomatic outpatients without coronary heart disease. Am Heart J. Jan. 2005;149(1):74-81. X-1,X-5,X-7,X-8. [pmid: 15660037].
2740 Sequist TD, Marshall R, Lampert S, et al. Missed opportunities in the primary care management of early acute ischemic heart disease. Arch Intern Med. Nov. 13. 2006;166(20):2237-43. X-5,X-8. [pmid: 17101942].
2741 Sergeant P, de Worm E, Meyns B. Single centre, single domain validation of the EuroSCORE on a consecutive sample of primary and repeat CABG. Eur J Cardiothorac Surg. Dec. 2001;20(6):1176-82. X-1,X-8. [pmid: 11717024].
2742 Sergeant P, Meyns B, Wouters P, et al. Long-term outcome after coronary artery bypass grafting in cardiogenic shock or cardiopulmonary resuscitation. J Thorac Cardiovasc Surg. Nov. 2003;126(5):1279-86. X-1,X-2,X-6,X-7,X-8. [pmid: 14665997].
2743 Serra V, de Isla LP, Ferro MP, et al. Identification of stunned myocardium with parametric imaging-based, quantitative myocardial contrast echocardiography after acute myocardial infarction. Am J Cardiol. Jul. 15. 2005;96(2):167-72. X-1,X-6,X-7,X-8. [pmid: 16018835].
2744 Serrano N, Garcia C, Villegas J, et al. Prolonged intubation rates after coronary artery bypass surgery and ICU risk stratification score. Chest. Aug. 2005;128(2):595-601. X-1,X-6,X-8. [pmid: 16100143].
2745 Seshadri N, Whitlow PL, Acharya N, et al. Emergency coronary artery bypass surgery in the contemporary percutaneous coronary intervention era. Circulation. Oct. 29. 2002;106(18):2346-50. X-1,X-8. [pmid: 12403665].
2746 Seshadri S, Wolf PA, Beiser A, et al. Elevated midlife blood pressure increases stroke risk in elderly persons: the Framingham Study. Arch Intern Med. Oct. 22. 2001;161(19):2343-50. X-1F,X-2. [pmid: 11606150].
2747 Setakis E, Leufkens HG, van Staa TP. Changes in the characteristics of patients prescribed selective cyclooxygenase 2 inhibitors after the 2004 withdrawal of rofecoxib. Arthritis Rheum. Aug. 15. 2008;59(8):1105-11. X-1,X-2,X-6,X-8. [pmid: 18668614].
2748 Seth R, Moss AJ, McNitt S, et al. Long QT syndrome and pregnancy. J Am Coll Cardiol. Mar. 13. 2007;49(10):1092-8. X-1,X-8. [pmid: 17349890].
2749 Sevrukov A, Pratap A, Doss C, et al. Electron beam tomography imaging of coronary calcium: the effect of body mass index on radiologic noise. J Comput Assist Tomogr. Jul-Aug. 2002;26(4):592-7. X-1,X-2,X-5,X-6. [pmid: 12218826].
2750 Shabsigh R, Shah M, Sand M. Erectile dysfunction and men's health: developing a comorbidity risk calculator. J Sex Med. May. 2008;5(5):1237-43. X-1F,X-2,X-6,X-8. [pmid: 18439154].
2751 Shadman R, Criqui MH, Bundens WP, et al. Subclavian artery stenosis: prevalence, risk factors, and association with cardiovascular diseases. J Am Coll Cardiol. Aug. 4. 2004;44(3):618-23. X-1,X-5,X-6. [pmid: 15358030].
2752 Shah BR, Velazquez E, Shaw LK, et al. Revascularization improves survival in ischemic cardiomyopathy regardless of electrocardiographic criteria for prior small-to-medium myocardial infarcts. Am Heart J. Jan. 2002;143(1):111-7. X-1,X-2,X-6,X-7,X-8. [pmid: 11773920].
2753 Shah PJ, Bui K, Blackmore S, et al. Has the in situ right internal thoracic artery been overlooked? An angiographic study of the radial artery, internal thoracic arteries and saphenous vein graft patencies in symptomatic patients. Eur J Cardiothorac Surg. May. 2005;27(5):870-5. X-1,X-5,X-8. [pmid: 15848328].
2754 Shah PJ, Hare DL, Raman JS, et al. Survival after myocardial revascularization for ischemic cardiomyopathy: a prospective ten-year follow-up study. J Thorac Cardiovasc Surg. Nov. 2003;126(5):1320-7. X-1,X-6,X-7,X-8. [pmid: 14666002].
2755 Shahraki T, Shahraki M, Roudbari M, et al. Determination of the leading central obesity index among cardiovascular risk factors in Iranian women. Food Nutr Bull. Mar. 2008;29(1):43-8. X-1,X-2,X-5,X-6. [pmid: 18510204].
2756 Shaikh F, Maddikunta R, Djelmami-Hani M, et al. Stent fracture, an incidental finding or a significant marker of clinical in-stent restenosis?. Catheter Cardiovasc Interv. Apr. 1. 2008;71(5):614-8. X-1,X-2,X-6,X-8. [pmid: 18360853].
2757 Shakouri P, Nezami N, Tarzamni MK, et al. The elusive link between high sensitivity C-reactive protein and carotid subclinical atherosclerosis in coronary artery bypass grafting candidates: a cross-sectional study. Cardiovasc Ultrasound. 2008;6:23. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18513415].
2758 Shapiro S. Recent epidemiological evidence relevant to the clinical management of the menopause. Climacteric. Oct. 2. 2007;10:2-15. X-1,X-4. [pmid: 17882666].
2759 Sharir T, Germano G, Kang X, et al. Prediction of myocardial infarction versus cardiac death by gated myocardial perfusion SPECT: risk stratification by the amount of stress-induced ischemia and the poststress ejection fraction. J Nucl Med. Jun. 2001;42(6):831-7. X-1F,X-2,X-8. [pmid: 11390544].
2760 Sharma AK, Ajani AE, Garg N, et al. Usefulness of gamma intracoronary radiation for totally occluded in-stent restenotic coronary narrowing. Am J Cardiol. Mar. 1. 2003;91(5):595-7. X-1,X-6,X-8. [pmid: 12615269].
2761 Sharma R, Chemla E, Tome M, et al. Echocardiography-based score to predict outcome after renal transplantation. Heart. Apr. 2007;93(4):464-9. X-1D,X-2,X-6,X-8(~50%). [pmid: 16980518].
2762 Sharrett AR, Ballantyne CM, Coady SA, et al. Coronary heart disease prediction from lipoprotein cholesterol levels, triglycerides, lipoprotein(a), apolipoproteins A-I and B, and HDL density subfractions: The Atherosclerosis Risk in Communities (ARIC) Study. Circulation. Sep. 4. 2001;104(10):1108-13. X-1F,X-2,X-8. [pmid: 11535564].
2763 Shaw JA, Andrianopoulos N, Duffy S, et al. Renal impairment is an independent predictor of adverse events post coronary intervention in patients with and without drug-eluting stents. Cardiovasc Revasc Med. Oct-Dec. 2008;9(4):218-23. X-1,X-2,X-8. [pmid: 18928945].
2764 Shaw LJ, Berman DS, Hendel RC, et al. Cardiovascular disease risk stratification with stress single-photon emission computed tomography technetium-99m tetrofosmin imaging in patients with the metabolic syndrome and diabetes mellitus. Am J Cardiol. May. 15. 2006;97(10):1538-44. X-1F,X-2,X-8(>61%). [pmid: 16679101].
2765 Shaw LJ, Hachamovitch R, Heller GV, et al. Noninvasive strategies for the estimation of cardiac risk in stable chest pain patients. The Economics of Noninvasive Diagnosis (END) Study Group. Am J Cardiol. Jul. 1. 2000;86(1):1-7. X-1E,X-1F,X-1G,X-2,X-8. [pmid: 10867083].
2766 Shaw LJ, Raggi P, Berman DS, et al. Coronary artery calcium as a measure of biologic age. Atherosclerosis. Sep. 2006;188(1):112-9. X-1. [pmid: 16289071].
2767 Shaw LJ, Taylor A, Raggi P, et al. Role of noninvasive imaging in asymptomatic high-risk patients. J Nucl Cardiol. Mar-Apr. 2006;13(2):156-62. X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 16580949].
2768 Shaw RE, Anderson HV, Brindis RG, et al. Development of a risk adjustment mortality model using the American College of Cardiology-National Cardiovascular Data Registry (ACC-NCDR) experience: 1998-2000. J Am Coll Cardiol. Apr. 3. 2002;39(7):1104-12. X-1,X-8. [pmid: 11923032].
2769 Sheehan P, Blennerhassett J, Vasikaran SD. Decision limit for troponin I and assay performance. Ann Clin Biochem. May. 2002;39(Pt 3):231-6. X-1. [pmid: 12038597].
2770 Sheiban I, Moretti C, Kumar P, et al. Immediate and medium-term outcomes following the treatment of very long (> or =50 mm) chronic total coronary artery occlusions. J Invasive Cardiol. Jan. 2004;16(1):5-9. X-1,X-6,X-8. [pmid: 14699214].
2771 Shelton FD, Volpe BT, Reding M. Motor impairment as a predictor of functional recovery and guide to rehabilitation treatment after stroke. Neurorehabil Neural Repair. 2001;15(3):229-37. X-1,X-6,X-7,X-8. [pmid: 11944745].
2772 Shen BJ, Avivi YE, Todaro JF, et al. Anxiety characteristics independently and prospectively predict myocardial infarction in men the unique contribution of anxiety among psychologic factors. J Am Coll Cardiol. Jan. 15. 2008;51(2):113-9. X-1E,X-2. [pmid: 18191733].
2773 Shepherd J, Cobbe SM, Ford I, et al. Prevention of coronary heart disease with pravastatin in men with hypercholesterolemia. 1995. Atheroscler Suppl. Oct. 2004;5(3):91-7. X-1. [pmid: 15531281].
2774 Sheridan S, Pignone M, Mulrow C. Framingham-based tools to calculate the global risk of coronary heart disease: a systematic review of tools for clinicians. J Gen Intern Med. Dec. 2003;18(12):1039-52. X-2,X-4,X-5,X-6. [pmid: 14687264].
2775 Sherlaw-Johnson C, Lovegrove J, Treasure T, et al. Likely variations in perioperative mortality associated with cardiac surgery: when does high mortality reflect bad practice?. Heart. Jul. 2000;84(1):79-82. X-1,X-6,X-8. [pmid: 10862596].
2776 Sheth T, Amlani S, Ellins ML, et al. Computed tomographic coronary angiographic assessment of high-risk coronary anatomy in patients with suspected coronary artery disease and intermediate pretest probability. Am Heart J. May. 2008;155(5):918-23. X-1,X-6,X-7,X-8. [pmid: 18440342].
2777 Shiffman D, Ellis SG, Rowland CM, et al. Identification of four gene variants associated with myocardial infarction. Am J Hum Genet. Oct. 2005;77(4):596-605. X-1,X-2,X-5,X-8. [pmid: 16175505].
2778 Shin SJ, Kim HW, Chung S, et al. Late referral to a nephrologist increases the risk of uremia-related cardiac hypertrophy in patients on hemodialysis. Nephron Clin Pract. 2007;107(4):c139-46. X-7. [pmid: 17957125].
2779 Shinde AA, Juneman EB, Mitchell B, et al. Shocks from pacemaker cardioverter defibrillators increase with amiodarone in patients at high risk for sudden cardiac death. Cardiology. 2003;100(3):143-8. X-1,X-5,X-6,X-7. [pmid: 14631135].
2780 Shinokawa N, Hirai T, Takashima S, et al. A transesophageal echocardiographic study on risk factors for stroke in elderly patients with atrial fibrillation: a comparison with younger patients. Chest. Sep. 2001;120(3):840-6. X-1,X-2,X-5,X-6. [pmid: 11555518].
2781 Shishehbor MH, Oliveira LP, Lauer MS, et al. Emerging cardiovascular risk factors that account for a significant portion of attributable mortality risk in chronic kidney disease. Am J Cardiol. Jun. 15. 2008;101(12):1741-6. X-1F,X-2,X-6,X-8. [pmid: 18549850].
2782 Shlipak MG, Angeja BG, Go AS, et al. Hormone therapy and in-hospital survival after myocardial infarction in postmenopausal women. Circulation. Nov. 6. 2001;104(19):2300-4. X-1,X-2,X-6,X-8. [pmid: 11696469].
2783 Shlipak MG, Chaput LA, Vittinghoff E, et al. Lipid changes on hormone therapy and coronary heart disease events in the Heart and Estrogen/progestin Replacement Study (HERS). Am Heart J. Nov. 2003;146(5):870-5. X-1,X-6,X-8. [pmid: 14597937].
2784 Shoukat S, Gowani SA, Khimani F, et al. Predictive model of blood transfusion during CABG surgery in Pakistan. J Pak Med Assoc. Aug. 2008;58(8):421-6. X-1,X-2,X-6,X-8. [pmid: 18822637].
2785 Shuhaiber JH, Goldsmith K, Nashef SA. Impact of cardiothoracic resident turnover on mortality after cardiac surgery: a dynamic human factor. Ann Thorac Surg. Jul. 2008;86(1):123-30. discussion 130-1. X-1,X-4,X-6. [pmid: 18573410].
2786 Shuhaiber JH, Goldsmith K, Nashef SA. The influence of seasonal variation on cardiac surgery: a time-related clinical outcome predictor. J Thorac Cardiovasc Surg. Oct. 2008;136(4):894-9. X-1,X-2,X-6,X-8. [pmid: 18954627].
2787 Sicari R, Ripoli A, Picano E, et al. Perioperative prognostic value of dipyridamole echocardiography in vascular surgery: A large-scale multicenter study in 509 patients. EPIC (Echo Persantine International Cooperative) Study Group. Circulation. Nov. 9. 1999;100(19 Suppl):II269-74. X-1,X-6,X-7. [pmid: 10567315].
2788 Sicari R, Ripoli A, Picano E, et al. Long-term prognostic value of dipyridamole echocardiography in vascular surgery: a large-scale multicenter study. Coron Artery Dis. Feb. 2002;13(1):49-55. X-1,X-8. [pmid: 11917199].
2789 Sidawy AN, Zwolak RM, White RA, et al. Risk-adjusted 30-day outcomes of carotid stenting and endarterectomy: results from the SVS Vascular Registry. J Vasc Surg. Jan. 2009;49(1):71-9. X-1,X-2,X-8. [pmid: 19028045].
2790 Siddiqui TS, Stoddard MF. Safety of dobutamine stress transesophageal echocardiography in obese patients for evaluation of potential ischemic heart disease. Echocardiography. Oct. 2004;21(7):603-8. X-1,X-2,X-5,X-6,X-7. [pmid: 15488087].
2791 Sierra-Johnson J, Wright SR, Lopez-Jimenez F, et al. Relation of body mass index to fatal and nonfatal cardiovascular events after cardiac rehabilitation. Am J Cardiol. Jul. 15. 2005;96(2):211-4. X-1,X-8. [pmid: 16018844].
2792 Sihvonen S, Korpela M, Mustonen J, et al. Mortality in patients with rheumatoid arthritis treated with low-dose oral glucocorticoids. A population-based cohort study. J Rheumatol. Sep. 2006;33(9):1740-6. X-1,X-6. [pmid: 16881099].
2793 Silber S, Albertsson P, Aviles FF, et al. Guidelines for percutaneous coronary interventions. The Task Force for Percutaneous Coronary Interventions of the European Society of Cardiology. Eur Heart J. Apr. 2005;26(8):804-47. X-1,X-2,X-3,X-4,X-5,X-6,X-7,X-8. [pmid: 15769784].
2794 Silke B, Campbell C, King DJ. The potential cardiotoxicity of antipsychotic drugs as assessed by heart rate variability. J Psychopharmacol. Dec. 2002;16(4):355-60. X-1,X-2,X-5,X-6,X-7. [pmid: 12503835].
2795 Siller-Matula JM, Lang I, Christ G, et al. Calcium-channel blockers reduce the antiplatelet effect of clopidogrel. J Am Coll Cardiol. Nov. 4. 2008;52(19):1557-63. X-1,X-2,X-6,X-8. [pmid: 19007592].
2796 Silva AA, Maeno Y, Hashmi A, et al. Cardiovascular risk factors after Kawasaki disease: a case-control study. J Pediatr. Mar. 2001;138(3):400-5. X-1,X-2,X-6,X-7. [pmid: 11241050].
2797 Silvestrelli G, Parnetti L, Paciaroni M, et al. Early admission to stroke unit influences clinical outcome. Eur J Neurol. Mar. 2006;13(3):250-5. X-1,X-2,X-8. [pmid: 16618341].
2798 Simchen E, Galai N, Zitser-Gurevich Y, et al. Sequential logistic models for 30 days mortality after CABG: pre-operative, intra-operative and post-operative experience--The Israeli CABG study (ISCAB). Three models for early mortality after CABG. Eur J Epidemiol. Jun. 2000;16(6):543-55. X-1,X-8. [pmid: 11049098].
2799 Simes RJ, Marschner IC, Hunt D, et al. Relationship between lipid levels and clinical outcomes in the Long-term Intervention with Pravastatin in Ischemic Disease (LIPID) Trial: to what extent is the reduction in coronary events with pravastatin explained by on-study lipid levels?. Circulation. Mar. 12. 2002;105(10):1162-9. X-1,X-8. [pmid: 11889008].
2800 Simon A, Chironi G, Gariepy J, et al. Differences between markers of atherogenic lipoproteins in predicting high cardiovascular risk and subclinical atherosclerosis in asymptomatic men. Atherosclerosis. Apr. 2005;179(2):339-44. X-1,X-5. [pmid: 15777551].
2801 Simon A, Chironi G, Levenson J. Comparative performance of subclinical atherosclerosis tests in predicting coronary heart disease in asymptomatic individuals. Eur Heart J. Dec. 2007;28(24):2967-71. X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9,. [pmid: 17967818].
2802 Simon C, Capuano F, Roscitano A, et al. Cardiac troponin I vs EuroSCORE: myocardial infarction and hospital mortality. Asian Cardiovasc Thorac Ann. Apr. 2008;16(2):97-102. X-1,X-7,X-8. [pmid: 18381864].
2803 Simons PC, Algra A, Bots ML, et al. Common carotid intima-media thickness and arterial stiffness: indicators of cardiovascular risk in high-risk patients. The SMART Study (Second Manifestations of ARTerial disease). Circulation. Aug. 31. 1999;100(9):951-7. X-1,X-5,X-6. [pmid: 10468526].
2804 Simpson CF, Punjabi NM, Wolfenden L, et al. Relationship between lung function and physical performance in disabled older women. J Gerontol A Biol Sci Med Sci. Mar. 2005;60(3):350-4. X-1,X-5,X-6. [pmid: 15860473].
2805 Simpson KN, Jones WJ, Rajagopalan R, et al. Cost effectiveness of lopinavir/ritonavir compared with atazanavir plus ritonavir in antiretroviral-experienced patients in the US. Clin Drug Investig. 2007;27(7):443-52. X-1,X-2,X-6,X-8.
2806 Simpson KN, Luo MP, Chumney EC, et al. Cost effectiveness of lopinavir/ritonavir compared with atazanavir in antiretroviral-naive patients: modelling the combined effects of HIV and heart disease. Clin Drug Investig. 2007;27(1):67-74. X-1,X-2,X-5,X-6.
2807 Sin DD, Man SF. Systemic inflammation and mortality in chronic obstructive pulmonary disease. Can J Physiol Pharmacol. Jan. 2007;85(1):141-7. X-1,X-6. [pmid: 17487253].
2808 Sin DD, Wu L, Man SF. The relationship between reduced lung function and cardiovascular mortality: a population-based study and a systematic review of the literature. Chest. Jun. 2005;127(6):1952-9. X-1F,X-2. [pmid: 15947307].
2809 Singer OC, Humpich MC, Fiehler J, et al. Risk for symptomatic intracerebral hemorrhage after thrombolysis assessed by diffusion-weighted magnetic resonance imaging. Ann Neurol. Jan. 2008;63(1):52-60. X-1,X-6,X-8. [pmid: 17880020].
2810 Singh M, Gersh BJ, Li S, et al. Mayo Clinic Risk Score for percutaneous coronary intervention predicts in-hospital mortality in patients undergoing coronary artery bypass graft surgery. Circulation. Jan. 22. 2008;117(3):356-62. X-1,X-6,X-8. [pmid: 18172033].
2811 Singh M, Gersh BJ, McClelland RL, et al. Clinical and angiographic predictors of restenosis after percutaneous coronary intervention: insights from the Prevention of Restenosis With Tranilast and Its Outcomes (PRESTO) trial. Circulation. Jun. 8. 2004;109(22):2727-31. X-1,X-6,X-8. [pmid: 15173022].
2812 Singh M, Lennon RJ, Holmes DR Jr, et al. Correlates of procedural complications and a simple integer risk score for percutaneous coronary intervention. J Am Coll Cardiol. Aug. 7. 2002;40(3):387-93. X-1,X-8. [pmid: 12142101].
2813 Singh M, Reeder GS, Jacobsen SJ, et al. Scores for post-myocardial infarction risk stratification in the community. Circulation. Oct. 29. 2002;106(18):2309-14. X-1,X-8. [pmid: 12403659].
2814 Singh M, Reeder GS, Ohman EM, et al. Does the presence of thrombus seen on a coronary angiogram affect the outcome after percutaneous coronary angioplasty? An Angiographic Trials Pool data experience. J Am Coll Cardiol. Sep. 2001;38(3):624-30. X-1,X-8. [pmid: 11527607].
2815 Singh M, Rihal CS, Lennon RJ, et al. Comparison of Mayo Clinic risk score and American College of Cardiology/American Heart Association lesion classification in the prediction of adverse cardiovascular outcome following percutaneous coronary interventions. J Am Coll Cardiol. Jul. 21. 2004;44(2):357-61. X-1,X-8. [pmid: 15261931].
2816 Singh M, Rihal CS, Lennon RJ, et al. A critical appraisal of current models of risk stratification for percutaneous coronary interventions. Am Heart J. May. 2005;149(5):753-60. X-1,X-8. [pmid: 15894953].
2817 Singh M, Rihal CS, Lennon RJ, et al. Prediction of complications following nonemergency percutaneous coronary interventions. Am J Cardiol. Oct. 1. 2005;96(7):907-12. X-1,X-8. [pmid: 16188514].
2818 Singh M, Rihal CS, Lennon RJ, et al. Bedside estimation of risk from percutaneous coronary intervention: the new Mayo Clinic risk scores. Mayo Clin Proc. Jun. 2007;82(6):701-8. X-1,X-8. [pmid: 17550750].
2819 Singh M, Rihal CS, Roger VL, et al. Comorbid conditions and outcomes after percutaneous coronary intervention. Heart. Nov. 2008;94(11):1424-8. X-1,X-8. [pmid: 17923464].
2820 Singh M, Rihal CS, Selzer F, et al. Validation of Mayo Clinic risk adjustment model for in-hospital complications after percutaneous coronary interventions, using the National Heart, Lung, and Blood Institute dynamic registry. J Am Coll Cardiol. Nov. 19. 2003;42(10):1722-8. X-1,X-8. [pmid: 14642678].
2821 Singh T, Mullick SS, Calton R, et al. Quantification of coronary risk score. Indian J Pediatr. Jan. 2002;69(1):27-9. X-1,X-2,X-5,X-6. [pmid: 11876116].
2822 Sinha S, Luben RN, Welch A, et al. Fibrinogen and cigarette smoking in men and women in the European Prospective Investigation into Cancer in Norfolk (EPIC-Norfolk) population. Eur J Cardiovasc Prev Rehabil. Apr. 2005;12(2):144-50. X-1,X-2,X-5,X-6. [pmid: 15785300].
2823 Sinkovic A, Pogacar V. Risk stratification in patients with unstable angina and/or non-ST-elevation myocardial infarction by Troponin T and plasminogen-activator-inhibitor-1 (PAI-1). Thromb Res. 2004;114(4):251-7. X-1,X-7,X-8. [pmid: 15381388].
2824 Sir JJ, Chung WY, Hwang SJ, et al. N-terminal pro-B-type natriuretic peptide as a predictor of repeat coronary revascularization. Int J Cardiol. Jun. 6. 2008;126(3):322-32. X-1,X-2,X-5,X-8. [pmid: 17544525].
2825 Sirtori CR, Calabresi L, Marchioli R, et al. Cardiovascular risk changes after lipid lowering medications: are they predictable?. Atherosclerosis. Sep. 2000;152(1):1-8. X-1. [pmid: 10996333].
2826 Sjauw KD, van der Horst IC, Nijsten MW, et al. Value of routine admission laboratory tests to predict thirty-day mortality in patients with acute myocardial infarction. Am J Cardiol. May. 15. 2006;97(10):1435-40. X-1,X-8. [pmid: 16679079].
2827 Skelding KA, Best PJ, Bartholomew BA, et al. Validation of a predictive risk score for radiocontrast-induced nephropathy following percutaneous coronary intervention. J Invasive Cardiol. May. 2007;19(5):229-33. X-1,X-8. [pmid: 17476039].
2828 Skilton MR. Intrauterine risk factors for precocious atherosclerosis. Pediatrics. Mar. 2008;121(3):570-4. X-1,X-2,X-4,X-5,X-6,X-7. [pmid: 18310207].
2829 Skodova Z, Nagyova I, Rosenberger J, et al. Vital exhaustion in coronary heart disease: the impact of socioeconomic status. Eur J Cardiovasc Prev Rehabil. Oct. 2008;15(5):572-6. X-1,X-2,X-5,X-6,X-8. [pmid: 18753955].
2830 Skouby SO, Jespersen J, Kluft C, et al. On the route to combined evidence from OC and HRT/ERT. Eur J Contracept Reprod Health Care. Dec. 2002;7(4):185-98. X-1F,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 12656302].
2831 Slart RH, Bax JJ, van Veldhuisen DJ, et al. Prediction of functional recovery after revascularization in patients with coronary artery disease and left ventricular dysfunction by gated FDG-PET. J Nucl Cardiol. Mar-Apr. 2006;13(2):210-9. X-1,X-6,X-7,X-8. [pmid: 16580957].
2832 Slomka PJ, Fieno D, Thomson L, et al. Automatic detection and size quantification of infarcts by myocardial perfusion SPECT: clinical validation by delayed-enhancement MRI. J Nucl Med. May. 2005;46(5):728-35. X-1,X-5,X-6,X-7. [pmid: 15872343].
2833 Slooter AJ, Cruts M, Hofman A, et al. The impact of APOE on myocardial infarction, stroke, and dementia: the Rotterdam Study. Neurology. Apr. 13. 2004;62(7):1196-8. X-1. [pmid: 15079025].
2834 Smart S, Sagar K, Tresch D. Age-related determinants of outcome after acute myocardial infarction: a dobutamine-atropine stress echocardiographic study. J Am Geriatr Soc. Jul. 2002;50(7):1176-85. X-1,X-7,X-8. [pmid: 12133010].
2835 Smebye ML, Iversen EK, Hoieggen A, et al. Effect of hemoglobin levels on cardiovascular outcomes in patients with isolated systolic hypertension and left ventricular hypertrophy (from the LIFE study). Am J Cardiol. Sep. 1. 2007;100(5):855-9. X-1F,X-2,X-8. [pmid: 17719333].
2836 Smieja M, Gnarpe J, Lonn E, et al. Multiple infections and subsequent cardiovascular events in the Heart Outcomes Prevention Evaluation (HOPE) Study. Circulation. Jan. 21. 2003;107(2):251-7. X-1,X-2. [pmid: 12538424].
2837 Smilde TJ, van Wissen S, Wollersheim H, et al. Genetic and metabolic factors predicting risk of cardiovascular disease in familial hypercholesterolemia. Neth J Med. Oct. 2001;59(4):184-95. X-1G,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 11578794].
2838 Smith CL. C-reactive protein and asymmetric dimethylarginine: markers or mediators in cardiovascular disorders?. Curr Pharm Des. 2007;13(16):1619-29. X-1. [pmid: 17584093].
2839 Smith GL, Smith BD, Buchholz TA, et al. Cerebrovascular disease risk in older head and neck cancer patients after radiotherapy. J Clin Oncol. Nov. 1. 2008;26(31):5119-25. X-1,X-2. [pmid: 18725647].
2840 Smith J, Forster A, Young J. Use of the ‘STRATIFY’ falls risk assessment in patients recovering from acute stroke. Age Ageing. Mar. 2006;35(2):138-43. X-1,X-6,X-8. [pmid: 16368736].
2841 Smith NL, Barzilay JI, Shaffer D, et al. Fasting and 2-hour postchallenge serum glucose measures and risk of incident cardiovascular events in the elderly: the Cardiovascular Health Study. Arch Intern Med. Jan. 28. 2002;162(2):209-16. X-1F,X-2. [pmid: 11802755].
2842 Smith PM, Ottenbacher KJ, Cranley M, et al. Predicting follow-up living setting in patients with stroke. Arch Phys Med Rehabil. Jun. 2002;83(6):764-70. X-1,X-6,X-8. [pmid: 12048653].
2843 Smith SC Jr, Anderson JL, Cannon RO 3rd, et al. CDC/AHA Workshop on Markers of Inflammation and Cardiovascular Disease: Application to Clinical and Public Health Practice: report from the clinical practice discussion group. Circulation. Dec. 21. 2004;110(25):e550-3. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 15611380].
2844 Smith SC Jr, Blair SN, Bonow RO, et al. AHA/ACC Guidelines for Preventing Heart Attack and Death in Patients With Atherosclerotic Cardiovascular Disease: 2001 update A statement for healthcare professionals from the American Heart Association and the American College of Cardiology. J Am Coll Cardiol. Nov. 1. 2001;38(5):1581-3. X-4. [pmid: 11691544].
2845 Smock AL, Larson B, Brown C, et al. Early prediction of 30-day mortality after Q-wave myocardial infarction by echocardiographic assessment of left ventricular function--a pilot investigation. Clin Cardiol. Mar. 2001;24(3):191-5. X-1,X-8. [pmid: 11288963].
2846 Snapir A, Heinonen P, Tuomainen TP, et al. An insertion/deletion polymorphism in the alpha2B-adrenergic receptor gene is a novel genetic risk factor for acute coronary events. J Am Coll Cardiol. May. 2001;37(6):1516-22. X-1F,X-1G,X-2. [pmid: 11345359].
2847 So L, Evans D, Quan H. ICD-10 coding algorithms for defining comorbidities of acute myocardial infarction. BMC Health Serv Res. 2006;6:161. X-1,X-5,X-6,X-7. [pmid: 17173686].
2848 Sobesky J, Frackowiak M, Zaro Weber O, et al. The Cologne stroke experience: safety and outcome in 450 patients treated with intravenous thrombolysis. Cerebrovasc Dis. 2007;24(1):56-65. X-1,X-5,X-8. [pmid: 17519545].
2849 Sobolev BG, Levy AR, Kuramoto L, et al. The risk of death associated with delayed coronary artery bypass surgery. BMC Health Serv Res. 2006;6:85. X-1,X-8. [pmid: 16822309].
2850 Sodeck G, Domanovits H, Schillinger M, et al. Pre-operative N-terminal pro-brain natriuretic peptide predicts outcome in type A aortic dissection. J Am Coll Cardiol. Mar. 18. 2008;51(11):1092-7. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18342228].
2851 Sodhi HS, Shrestha SK, Rauniyar R, et al. Prevalence of peripheral arterial disease by ankle-brachial index and its correlation with carotid intimal thickness and coronary risk factors in Nepalese population over the age of forty years. Kathmandu Univ Med J (KUMJ). Jan-Mar. 2007;5(1):12-5. X-1,X-2,X-5,X-6,X-7. [pmid: 18603979].
2852 Soedamah-Muthu SS, Fuller JH, Mulnier HE, et al. High risk of cardiovascular disease in patients with type 1 diabetes in the U.K.: a cohort study using the general practice research database. Diabetes Care. Apr. 2006;29(4):798-804. X-1F,X-2. [pmid: 16567818].
2853 Sohaib SM, Papacosta O, Morris RW, et al. Length of the QT interval: determinants and prognostic implications in a population-based prospective study of older men. J Electrocardiol. Nov-Dec. 2008;41(6):704-10. X-1,X-2,X-6,X-8. [pmid: 18367203].
2854 Sokejima S, Nakatani Y, Kario K, et al. Seismic intensity and risk of cerebrovascular stroke: 1995 Hanshin-Awaji earthquake. Prehosp Disaster Med. Oct-Dec. 2004;19(4):297-306. X-1. [pmid: 15645625].
2855 Solberg OG, Dahl M, Mowinckel P, et al. Derivation and validation of a simple risk score for predicting 1-year mortality in stroke. J Neurol. Oct. 2007;254(10):1376-83. X-1,X-8. [pmid: 17934885].
2856 Soliman Hamad MA, Tan ME, van Straten AH, et al. Long-term results of coronary artery bypass grafting in patients with left ventricular dysfunction. Ann Thorac Surg. Feb. 2008;85(2):488-93. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18222250].
2857 Solomon DH, Ganz DA, Avorn J, et al. Which patients with unstable angina or non-Q-wave myocardial infarction should have immediate cardiac catheterization? A clinical decision rule for predicting who will fail medical therapy. J Clin Epidemiol. Feb. 2002;55(2):121-8. X-1,X-6,X-8. [pmid: 11809349].
2858 Solomon DH, Stone PH, Glynn RJ, et al. Use of risk stratification to identify patients with unstable angina likeliest to benefit from an invasive versus conservative management strategy. J Am Coll Cardiol. Oct. 2001;38(4):969-76. X-1,X-8. [pmid: 11583866].
2859 Solomon SD, Wittes J, Finn PV, et al. Cardiovascular risk of celecoxib in 6 randomized placebo-controlled trials: the cross trial safety analysis. Circulation. Apr. 22. 2008;117(16):2104-13. X-1,X-2,X-4,X-5. [pmid: 18378608].
2860 Soman P, Dave DM, Udelson JE, et al. Vascular endothelial dysfunction is associated with reversible myocardial perfusion defects in the absence of obstructive coronary artery disease. J Nucl Cardiol. Nov. 2006;13(6):756-60. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 17174806].
2861 Song YM, Byeon JJ. Excess mortality from avoidable and non-avoidable causes in men of low socioeconomic status: a prospective study in Korea. J Epidemiol Community Health. Mar. 2000;54(3):166-72. X-1,X-2,X-6. [pmid: 10746109].
2862 Song YM, Kwon SU, Sung J, et al. Different risk factor profiles between subtypes of ischemic stroke. A case-control study in Korean men. Eur J Epidemiol. 2005;20(7):605-12. X-1,X-2,X-5,X-8. [pmid: 16119434].
2863 Soo L, Huff N, Gray D, et al. Geographical distribution of cardiac arrest in Nottinghamshire. Resuscitation. Feb. 2001;48(2):137-47. X-1,X-2,X-5. [pmid: 11426475].
2864 Soon KH, Kelly AM, Cox N, et al. Practicality, safety and accuracy of computed tomography coronary angiography in the evaluation of low TIMI-risk score chest pain patients: a pilot study. Emerg Med Australas. Apr. 2007;19(2):129-35. X-1,X-2,X-6,X-7,X-8. [pmid: 17448098].
2865 Sorensen HT, Thulstrup AM, Norgdard B, et al. Fetal growth and blood pressure in a Danish population aged 31-51 years. Scand Cardiovasc J. Aug. 2000;34(4):390-5. X-1,X-6. [pmid: 10983673].
2866 Sosnowski M, MacFarlane PW, Czyz Z, et al. Age-adjustment of HRV measures and its prognostic value for risk assessment in patients late after myocardial infarction. Int J Cardiol. Dec. 2002;86(2-3):249-58. X-1,X-8. [pmid: 12419563].
2867 Southern DA, Quan H, Ghali WA. Comparison of the Elixhauser and Charlson/Deyo methods of comorbidity measurement in administrative data. Med Care. Apr. 2004;42(4):355-60. X-1,X-2,X-6,X-8. [pmid: 15076812].
2868 Sozzi FB, Elhendy A, Rizzello V, et al. Prognostic significance of myocardial ischemia during dobutamine stress echocardiography in asymptomatic patients with diabetes mellitus and no prior history of coronary events. Am J Cardiol. May. 1. 2007;99(9):1193-5. X-1,X-7. [pmid: 17478139].
2869 Sozzi FB, Elhendy A, Rizzello V, et al. Prognostic significance of akinesis becoming dyskinesis during dobutamine stress echocardiography. J Am Soc Echocardiogr. Mar. 2007;20(3):257-61. X-1D,X-2,X-8(99%). [pmid: 17336751].
2870 Sozzi FB, Elhendy A, Rizzello V, et al. Prognostic value of dobutamine stress echocardiography in patients with systemic hypertension and known or suspected coronary artery disease. Am J Cardiol. Sep. 15. 2004;94(6):733-9. X-1. [pmid: 15374776].
2871 Speel TG, van Langen H, Meuleman EJ. The risk of coronary heart disease in men with erectile dysfunction. Eur Urol. Sep. 2003;44(3):366-70. discussion 370-1. X-1,X-7. [pmid: 12932938].
2872 Spence JD, Eliasziw M, DiCicco M, et al. Carotid plaque area: a tool for targeting and evaluating vascular preventive therapy. Stroke. Dec. 2002;33(12):2916-22. X-1F,X-2,X-8. [pmid: 12468791].
2873 Spencer CA, Jamrozik K, Norman PE, et al. A simple lifestyle score predicts survival in healthy elderly men. Prev Med. Jun. 2005;40(6):712-7. X-1G,X-2,X-6. [pmid: 15850869].
2874 Spencer FA, Moscucci M, Granger CB, et al. Does comorbidity account for the excess mortality in patients with major bleeding in acute myocardial infarction?. Circulation. Dec. 11. 2007;116(24):2793-801. X-1,X-5,X-6,X-8. [pmid: 18025530].
2875 Spiegelhalter DJ. Handling over-dispersion of performance indicators. Qual Saf Health Care. Oct. 2005;14(5):347-51. X-1,X-6,X-8. [pmid: 16195568].
2876 Spinelli L, Petretta M, Acampa W, et al. Prognostic value of combined assessment of regional left ventricular function and myocardial perfusion by dobutamine and rest gated SPECT in patients with uncomplicated acute myocardial infarction. J Nucl Med. Jul. 2003;44(7):1023-9. X-1,X-2,X-6,X-8. [pmid: 12843215].
2877 Spodick DH, Ariyarajah V, Apiyasawat S. Higher prevalence of cardiovascular events among patients with abnormal atrial depolarization and coronary artery disease at 18 months' post-exercise tolerance testing. Am Heart Hosp J. Fall. 2007;5(4):236-40. X-7. [pmid: 17982305].
2878 Sprecher DL, Goodman SG, Kannampuzha P, et al. Skin tissue cholesterol (SkinTc) is related to angiographically-defined cardiovascular disease. Atherosclerosis. Dec. 2003;171(2):255-8. X-1,X-5,X-6. [pmid: 14644394].
2879 Sprecher DL, Pearce GL. Skin cholesterol adds to Framingham risk assessment. Am Heart J. Oct. 2006;152(4):694-6. X-2,X-5,X-6,X-8(90%). [pmid: 16996840].
2880 Sramek A, Reiber JH, Gerrits WB, et al. Decreased coagulability has no clinically relevant effect on atherogenesis: observations in individuals with a hereditary bleeding tendency. Circulation. Aug. 14. 2001;104(7):762-7. X-1,X-2,X-5,X-6. [pmid: 11502699].
2881 Srinivas VS, Cannon CP, Gibson CM, et al. Myoglobin levels at 12 hours identify patients at low risk for 30-day mortality after thrombolysis in acute myocardial infarction: a Thrombolysis in Myocardial Infarction 10B substudy. Am Heart J. Jul. 2001;142(1):29-36. X-1,X-8. [pmid: 11431653].
2882 Srinivas VS, Garg S, Negassa A, et al. Persistent sex difference in hospital outcome following percutaneous coronary intervention: results from the New York State reporting system. J Invasive Cardiol. Jun. 2007;19(6):265-8. X-1,X-6,X-8. [pmid: 17541128].
2883 Srinivas VS, Skeif B, Negassa A, et al. Effectiveness of glycoprotein IIb/IIIa inhibitor use during primary coronary angioplasty: results of propensity analysis using the New York State Percutaneous Coronary Intervention Reporting System. Am J Cardiol. Feb. 15. 2007;99(4):482-5. X-1,X-8. [pmid: 17293189].
2884 Srinivas VS, Vakili BA, Brown DL. Comparison of in-hospital outcomes following early or delayed angioplasty for acute myocardial infarction. J Invasive Cardiol. Dec. 2002;14(12):746-50. X-1,X-8. [pmid: 12454338].
2885 Srinivasan SR, Segrest JP, Elkasabany AM, et al. Distribution and correlates of lipoproteins and their subclasses in black and white young adults. The Bogalusa Heart Study Atherosclerosis. Dec. 2001;159(2):391-7. X-1,X-2,X-5,X-6.
2886 Sritara P, Patoomanunt P, Woodward M, et al. Associations between serum lipids and causes of mortality in a cohort of 3,499 urban Thais: The Electricity Generating Authority of Thailand (EGAT) study. Angiology. 2007 Dec-2008 Jan. 58(6):757-63. X-1E,X-2. [pmid: 18216384].
2887 Staat P, Cucherat M, George M, et al. Severe morbidity after coronary artery surgery: development and validation of a simple predictive clinical score. Eur Heart J. Jul. 1999;20(13):960-6. X-1,X-6,X-8. [pmid: 10361048].
2888 Staessen JA, Wang J. Do ancillary properties of antihypertensive drugs explain the outcome results of recent trials?. J Nephrol. Jul-Aug. 2002;15(4):422-7. X-1,X-2,X-4,X-5. [pmid: 12243374].
2889 Stagmo M, Juul-Moller S, Israelsson B. Fifteen-year risk of major coronary events predicted by Holter ST-monitoring in asymptomatic middle-aged men. Eur J Cardiovasc Prev Rehabil. Oct. 2005;12(5):478-83. X-7. [pmid: 16210935].
2890 Stamou SC, Jablonski KA, Hill PC, et al. Coronary revascularization without cardiopulmonary bypass versus the conventional approach in high-risk patients. Ann Thorac Surg. Feb. 2005;79(2):552-7. X-1,X-8. [pmid: 15680833].
2891 Stanek EJ, Sarawate C, Willey VJ, et al. Risk of cardiovascular events in patients at optimal values for combined lipid parameters. Curr Med Res Opin. Mar. 2007;23(3):553-63. X-1F,X-8(35%). [pmid: 17357251].
2892 Stanescu C. Exercise echocardiography in coronary artery disease. Rom J Intern Med. 2004;42(3):473-89. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16366125].
2893 Stapf C, Mohr JP, Sciacca RR, et al. Incident hemorrhage risk of brain arteriovenous malformations located in the arterial borderzones. Stroke. Oct. 2000;31(10):2365-8. X-1. [pmid: 11022065].
2894 Stavenow L, Kjellstrom T. Influence of serum triglyceride levels on the risk for myocardial infarction in 12,510 middle aged males: interaction with serum cholesterol. Atherosclerosis. Dec. 1999;147(2):243-7. X-1. [pmid: 10559509].
2895 Stefanadis C, Dernellis J, Tsiamis E, et al. Aortic stiffness as a risk factor for recurrent acute coronary events in patients with ischaemic heart disease. Eur Heart J. Mar. 2000;21(5):390-6. X-1,X-7,X-8. [pmid: 10666353].
2896 Stefani MA, Porter PJ, terBrugge KG, et al. Large and deep brain arteriovenous malformations are associated with risk of future hemorrhage. Stroke. May. 2002;33(5):1220-4. X-1,X-2. [pmid: 11988594].
2897 Stefanick ML, Anderson GL, Margolis KL, et al. Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA. Apr. 12. 2006;295(14):1647-57. X-1,X-2,X-6. [pmid: 16609086].
2898 Steg PG, Cambou JP, Goldstein P, et al. Bypassing the emergency room reduces delays and mortality in ST elevation myocardial infarction: the USIC 2000 registry. Heart. Oct. 2006;92(10):1378-83. X-1,X-6,X-8. [pmid: 16914481].
2899 Steg PG, Lopez-Sendon J, Lopez de Sa E, et al. External validity of clinical trials in acute myocardial infarction. Arch Intern Med. Jan. 8. 2007;167(1):68-73. X-1,X-6,X-8. [pmid: 17210880].
2900 Stein JH, Fraizer MC, Aeschlimann SE, et al. Vascular age: integrating carotid intima-media thickness measurements with global coronary risk assessment. Clin Cardiol. Jul. 2004;27(7):388-92. X-5,X-6,X-7. [pmid: 15298037].
2901 Stein JH, Korcarz CE, Hurst RT, et al. Use of carotid ultrasound to identify subclinical vascular disease and evaluate cardiovascular disease risk: a consensus statement from the American Society of Echocardiography Carotid Intima-Media Thickness Task Force. Endorsed by the Society for Vascular Medicine. J Am Soc Echocardiogr. Feb. 2008;21(2):93-111. quiz 189-90. X-1,X-2,X-4. [pmid: 18261694].
2902 Stein KM. Noninvasive risk stratification for sudden death: signal-averaged electrocardiography, nonsustained ventricular tachycardia, heart rate variability, baroreflex sensitivity, and QRS duration. Prog Cardiovasc Dis. Sep-Oct. 2008;51(2):106-17. X-1D,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 18774010].
2903 Stein RA, Chaitman BR, Balady GJ, et al. Safety and utility of exercise testing in emergency room chest pain centers: An advisory from the Committee on Exercise, Rehabilitation, and Prevention, Council on Clinical Cardiology, American Heart Association. Circulation. Sep. 19. 2000;102(12):1463-7. X-1. [pmid: 10993869].
2904 Steinberg BA, Moghbeli N, Buros J, et al. Global outcomes of ST-elevation myocardial infarction: comparisons of the Enoxaparin and Thrombolysis Reperfusion for Acute Myocardial Infarction Treatment-Thrombolysis In Myocardial Infarction study 25 (ExTRACT-TIMI 25) registry and trial. Am Heart J. Jul. 2007;154(1):54-61. X-1,X-8. [pmid: 17584551].
2905 Stengard JH, Kardia SL, Tervahauta M, et al. Utility of the predictors of coronary heart disease mortality in a longitudinal study of elderly Finnish men aged 65 to 84 years is dependent on context defined by Apo E genotype and area of residence. Clin Genet. Nov. 1999;56(5):367-77. X-1F,X-2,X-5. [pmid: 10668927].
2906 Stenvinkel P, Alvestrand A. Inflammation in end-stage renal disease: sources, consequences, and therapy. Semin Dial. Sep-Oct. 2002;15(5):329-37. X-1,X-4,X-5,X-6. [pmid: 12358637].
2907 Stenvinkel P, Heimburger O, Wang T, et al. High serum hyaluronan indicates poor survival in renal replacement therapy. Am J Kidney Dis. Dec. 1999;34(6):1083-8. X-1,X-6,X-7. [pmid: 10585318].
2908 Steptoe A, Shamaei-Tousi A, Gylfe A, et al. Socioeconomic status, pathogen burden and cardiovascular disease risk. Heart. Dec. 2007;93(12):1567-70. X-5. [pmid: 17488763].
2909 Stern AH. A review of the studies of the cardiovascular health effects of methylmercury with consideration of their suitability for risk assessment. Environ Res. May. 2005;98(1):133-42. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15721894].
2910 Stern RH. Evaluating new cardiovascular risk factors for risk stratification. J Clin Hypertens (Greenwich). Jun. 2008;10(6):485-8. X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 18550940].
2911 Stevens LM, Carrier M, Perrault LP, et al. Single versus bilateral internal thoracic artery grafts with concomitant saphenous vein grafts for multivessel coronary artery bypass grafting: effects on mortality and event-free survival. J Thorac Cardiovasc Surg. May. 2004;127(5):1408-15. X-1,X-6,X-8. [pmid: 15116000].
2912 Stevens LM, Carrier M, Perrault LP, et al. Influence of diabetes and bilateral internal thoracic artery grafts on long-term outcome for multivessel coronary artery bypass grafting. Eur J Cardiothorac Surg. Feb. 2005;27(2):281-8. X-1,X-8. [pmid: 15691683].
2913 Stevens RJ, Kothari V, Adler AI, et al. The UKPDS risk engine: a model for the risk of coronary heart disease in Type II diabetes (UKPDS 56). Clin Sci (Lond). Dec. 2001;101(6):671-9. X-2. [pmid: 11724655].
2914 Stevens RJ, Kothari V, Adler AI, et al. The UKPDS risk engine: a model for the risk of coronary heart disease in Type II diabetes (UKPDS 56). Clin Sci (Lond). Dec. 2001;101(6):671-9. X-2. [pmid: 11724655].
2915 Stewart JE, Allred EN, Collins M, et al. Risk of cranial ultrasound abnormalities in very-low-birth-weight infants conceived with assisted reproductive techniques. J Perinatol. Jan. 2002;22(1):37-45. X-1,X-2,X-6. [pmid: 11840241].
2916 Steyerberg EW, Eijkemans MJ, Boersma E, et al. Applicability of clinical prediction models in acute myocardial infarction: a comparison of traditional and empirical Bayes adjustment methods. Am Heart J. Nov. 2005;150(5):920. X-1,X-8.
2917 Steyerberg EW, Eijkemans MJ, Boersma E, et al. Equally valid models gave divergent predictions for mortality in acute myocardial infarction patients in a comparison of logistic [corrected] regression models. J Clin Epidemiol. Apr. 2005;58(4):383-90. X-1,X-8. [pmid: 15862724].
2918 Steyerberg EW, Eijkemans MJ, Harrell FE Jr, et al. Prognostic modeling with logistic regression analysis: in search of a sensible strategy in small data sets. Med Decis Making. Jan-Feb. 2001;21(1):45-56. X-1,X-8. [pmid: 11206946].
2919 Steyn K, Levitt NS, Hoffman M, et al. The global cardiovascular diseases risk pattern in a peri-urban working-class community in South Africa. The Mamre study. Ethn Dis. Spring. 2004;14(2):233-42. X-1,X-2,X-5,X-6. [pmid: 15132209].
2920 Stolz E, Valdueza JM, Grebe M, et al. Anemia as a risk factor for cerebral venous thrombosis? An old hypothesis revisited. Results of a prospective study. J Neurol. Jun. 2007;254(6):729-34. X-1,X-2,X-5,X-6. [pmid: 17450317].
2921 Stone GW, Peterson MA, Lansky AJ, et al. Impact of normalized myocardial perfusion after successful angioplasty in acute myocardial infarction. J Am Coll Cardiol. Feb. 20. 2002;39(4):591-7. X-1,X-2,X-6,X-7,X-8. [pmid: 11849856].
2922 Stork S, Feelders RA, van den Beld AW, et al. Prediction of mortality risk in the elderly. Am J Med. Jun. 2006;119(6):519-25. X-2. [pmid: 16750966].
2923 Stork S, van den Beld AW, von Schacky C, et al. Carotid artery plaque burden, stiffness, and mortality risk in elderly men: a prospective, population-based cohort study. Circulation. Jul. 20. 2004;110(3):344-8. X-1. [pmid: 15238459].
2924 Strand BH, Kunst A. Childhood socioeconomic position and cause-specific mortality in early adulthood. Am J Epidemiol. Jan. 1. 2007;165(1):85-93. X-1F,X-2. [pmid: 17041134].
2925 Strand M, Soderstrom I, Wiklund PG, et al. Polymorphisms at the osteoprotegerin and interleukin-6 genes in relation to first-ever stroke. Cerebrovasc Dis. 2007;24(5):418-25. X-1,X-2,X-5,X-8. [pmid: 17878722].
2926 Strandberg TE, Strandberg AY, Pitkala KH, et al. Cardiovascular risk in midlife and psychological well-being among older men. Arch Intern Med. Nov. 13. 2006;166(20):2266-71. X-1,X-2,X-6,X-8. [pmid: 17101946].
2927 Strasak AM, Kelleher CC, Klenk J, et al. Longitudinal change in serum gamma-glutamyltransferase and cardiovascular disease mortality: a prospective population-based study in 76,113 Austrian adults. Arterioscler Thromb Vasc Biol. Oct. 2008;28(10):1857-65. X-1,X-2. [pmid: 18617645].
2928 Straus SM, Kors JA, De Bruin ML, et al. Prolonged QTc interval and risk of sudden cardiac death in a population of older adults. J Am Coll Cardiol. Jan. 17. 2006;47(2):362-7. X-2,X-8(MI, 6.3%). [pmid: 16412861].
2929 Struthers A, Lang C. The potential to improve primary prevention in the future by using BNP/N-BNP as an indicator of silent ‘pancardiac’ target organ damage: BNP/N-BNP could become for the heart what microalbuminuria is for the kidney. Eur Heart J. Jul. 2007;28(14):1678-82. X-1,X-6. [pmid: 17569679].
2930 Struthers R, Baker M, Savik K. Cardiovascular risk factors among Native American women Inter-Tribal Heart Project participants. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2006;35(4):482-90. X-5.
2931 Stukel TA, Fisher ES, Wennberg DE, et al. Analysis of observational studies in the presence of treatment selection bias: effects of invasive cardiac management on AMI survival using propensity score and instrumental variable methods. JAMA. Jan. 17. 2007;297(3):278-85. X-1,X-8. [pmid: 17227979].
2932 Stukenborg GJ, Wagner DP, Harrell FE Jr, et al. Present-at-admission diagnoses improved mortality risk adjustment among acute myocardial infarction patients. J Clin Epidemiol. Feb. 2007;60(2):142-54. X-1,X-8. [pmid: 17208120].
2933 Stukenborg GJ, Wagner DP, Harrell FE Jr, et al. Which hospitals have significantly better or worse than expected mortality rates for acute myocardial infarction patients? Improved risk adjustment with present-at-admission diagnoses. Circulation. Dec. 18. 2007;116(25):2960-8. X-1,X-2,X-5,X-6,X-8. [pmid: 18071076].
2934 Sturmer T, Buring JE, Lee IM, et al. Colorectal cancer after start of nonsteroidal anti-inflammatory drug use. Am J Med. Jun. 2006;119(6):494-502. X-1,X-2,X-6. [pmid: 16750963].
2935 Sudhir K. Lipoprotein-associated phospholipase A2, vascular inflammation and cardiovascular risk prediction. Vasc Health Risk Manag. 2006;2(2):153-6. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 17319459].
2936 Sukiennik A, Ostrowska-Nowak J, Wisniewska-Szmyt J, et al. Predicted and observed in-hospital mortality after left main coronary artery stenting in 204 patients. Cardiol J. 2008;15(3):268-76. X-1,X-7,X-8. [pmid: 18651420].
2937 Suleiman M, Gruberg L, Hammerman H, et al. Comparison of two platelet glycoprotein IIb/IIIa inhibitors, eptifibatide and abciximab: outcomes, complications and thrombocytopenia during percutaneous coronary intervention. J Invasive Cardiol. Jun. 2003;15(6):319-23. X-1,X-5,X-8. [pmid: 12777670].
2938 Sullivan LM, Massaro JM, D'Agostino RB Sr. Presentation of multivariate data for clinical use: The Framingham Study risk score functions. Stat Med. May. 30. 2004;23(10):1631-60. X-4,X-5,X-6. [pmid: 15122742].
2939 Sun L, Li Z, Zhang H, et al. Pentanucleotide TTTTA repeat polymorphism of apolipoprotein(a) gene and plasma lipoprotein(a) are associated with ischemic and hemorrhagic stroke in Chinese: a multicenter case-control study in China. Stroke. Jul. 2003;34(7):1617-22. X-1,X-6. [pmid: 12791946].
2940 Sun L, Sun Y, Zhao X, et al. Predictive role of BNP and NT-proBNP in hemodialysis patients. Nephron Clin Pract. 2008;110(3):c178-84. X-1,X-2. [pmid: 18957868].
2941 Sun X, Hill PC, Bafi AS, et al. Is cardiac surgery safe in extremely obese patients (body mass index 50 or greater)?. Ann Thorac Surg. Feb. 2009;87(2):540-6. X-1,X-2,X-7,X-8. [pmid: 19161775].
2942 Sunaga K, Miura K, Naruse Y, et al. Glycated hemoglobin and risk of stroke, ischemic and hemorrhagic, in Japanese men and women. Cerebrovasc Dis. 2008;26(3):310-6. X-1,X-2. [pmid: 18667812].
2943 Sundberg G, Bagust A, Terent A. A model for costs of stroke services. Health Policy. Jan. 2003;63(1):81-94. X-1,X-2,X-5,X-6. [pmid: 12468120].
2944 Sundquist J, Johansson SE, Yang M, et al. Low linking social capital as a predictor of coronary heart disease in Sweden: a cohort study of 2.8 million people. Soc Sci Med. Feb. 2006;62(4):954-63. X-1,X-5. [pmid: 16081195].
2945 Sundquist K, Qvist J, Johansson SE, et al. The long-term effect of physical activity on incidence of coronary heart disease: a 12-year follow-up study. Prev Med. Jul. 2005;41(1):219-25. X-1E,X-1F,X-2. [pmid: 15917014].
2946 Sung J, Lim SJ, Choe Y, et al. Comparison of the coronary calcium score with the estimated coronary risk. Coron Artery Dis. Nov. 2008;19(7):475-9. X-1,X-2,X-5,X-6. [pmid: 18923243].
2947 Suominen V, Rantanen T, Venermo M, et al. Prevalence and risk factors of PAD among patients with elevated ABI. Eur J Vasc Endovasc Surg. Jun. 2008;35(6):709-14. X-1,X-2,X-5,X-6. [pmid: 18313338].
2948 Surgenor SD, O'Connor GT, Lahey SJ, et al. Predicting the risk of death from heart failure after coronary artery bypass graft surgery. Anesth Analg. Mar. 2001;92(3):596-601. X-1,X-8. [pmid: 11226084].
2949 Suri MF, Ezzeddine MA, Lakshminarayan K, et al. Validation of two different grading schemes to identify patients with asymptomatic carotid artery stenosis in general population. J Neuroimaging. Apr. 2008;18(2):142-7. X-1,X-5,X-6. [pmid: 18380694].
2950 Susen S, Sautiere K, Mouquet F, et al. Serum hepatocyte growth factor levels predict long-term clinical outcome after percutaneous coronary revascularization. Eur Heart J. Nov. 2005;26(22):2387-95. X-1X-8. [pmid: 16105849].
2951 Sutton-Tyrrell K, Venkitachalam L, Kanaya AM, et al. Relationship of ankle blood pressures to cardiovascular events in older adults. Stroke. Mar. 2008;39(3):863-9. X-1E,X-2,X-8(23.6%). [pmid: 18258843].
2952 Suzuki T, Hirata K, Elkind MS, et al. Metabolic syndrome, endothelial dysfunction, and risk of cardiovascular events: the Northern Manhattan Study (NOMAS). Am Heart J. Aug. 2008;156(2):405-10. X-1,X-2. [pmid: 18657678].
2953 Svensson AM, Abrahamsson P, McGuire DK, et al. Influence of diabetes on long-term outcome among unselected patients with acute coronary events. Scand Cardiovasc J. Aug. 2004;38(4):229-34. X-1,X-8. [pmid: 15553934].
2954 Swinburn BA, Carey D, Hills AP, et al. Effect of orlistat on cardiovascular disease risk in obese adults. Diabetes Obes Metab. May. 2005;7(3):254-62. X-1,X-6,X-7. [pmid: 15811142].
2955 Swinburn JM, Senior R. Myocardial viability assessed by dobutamine stress echocardiography predicts reduced mortality early after acute myocardial infarction: determining the risk of events after myocardial infarction (DREAM) study. Heart. Jan. 2006;92(1):44-8. X-1,X-8. [pmid: 15831597].
2956 Synnergren MJ, Ekroth R, Oden A, et al. Incomplete revascularization reduces survival benefit of coronary artery bypass grafting: role of off-pump surgery. J Thorac Cardiovasc Surg. Jul. 2008;136(1):29-36. X-1,X-2,X-6. [pmid: 18603050].
2957 Szczech LA, Best PJ, Crowley E, et al. Outcomes of patients with chronic renal insufficiency in the bypass angioplasty revascularization investigation. Circulation. May. 14. 2002;105(19):2253-8. X-1,X-2,X-8. [pmid: 12010906].
2958 Sze KH, Wong E, Leung HY, et al. Falls among Chinese stroke patients during rehabilitation. Arch Phys Med Rehabil. Sep. 2001;82(9):1219-25. X-1,X-2,X-6,X-8. [pmid: 11552194].
2959 Szymanski P, Rezler J, Stec S, et al. Long-term prognostic value of an index of myocardial performance in patients with myocardial infarction. Clin Cardiol. Aug. 2002;25(8):378-83. X-1,X-7,X-8. [pmid: 12173905].
2960 Taal MW, Sigrist MK, Fakis A, et al. Markers of arterial stiffness are risk factors for progression to end-stage renal disease among patients with chronic kidney disease stages 4 and 5. Nephron Clin Pract. 2007;107(4):c177-81. X-7. [pmid: 17975325].
2961 Tadros GM, McConnell TR, Wood GC, et al. Clinical predictors of 30-day cardiac events in patients with acute coronary syndrome at a community hospital. South Med J. Nov. 2003;96(11):1113-20. X-1,X-7,X-8. [pmid: 14632360].
2962 Takahara Y, Mogi K, Sakurai M, et al. Total aortic arch grafting via median sternotomy using integrated antegrade cerebral perfusion. Ann Thorac Surg. Nov. 2003;76(5):1485-9. discussion 1489. X-1,X-5,X-6,X-8. [pmid: 14602272].
2963 Takahashi O, Cook EF, Nakamura T, et al. Risk stratification for in-hospital mortality in spontaneous intracerebral haemorrhage: a Classification and Regression Tree analysis. QJM. Nov. 2006;99(11):743-50. X-1,X-2,X-6,X-8. [pmid: 17030527].
2964 Takeshita H, Shimada Y, Kobayashi Y, et al. Impact of body mass index and Framingham risk score on coronary artery plaque. Osaka City Med J. Jun. 2008;54(1):31-9. X-1,X-2,X-6,X-8. [pmid: 18819263].
2965 Talbott EO, Zborowski J, Rager J, et al. Is there an independent effect of polycystic ovary syndrome (PCOS) and menopause on the prevalence of subclinical atherosclerosis in middle aged women?. Vasc Health Risk Manag. 2008;4(2):453-62. X-6,X-8. [pmid: 18561521].
2966 Talmud PJ, Cooper JA, Palmen J, et al. Chromosome 9p21.3 coronary heart disease locus genotype and prospective risk of CHD in healthy middle-aged men. Clin Chem. Mar. 2008;54(3):467-74. X-1F,X-1G. [pmid: 18250146].
2967 Talmud PJ, Hawe E, Miller GJ, et al. Nonfasting apolipoprotein B and triglyceride levels as a useful predictor of coronary heart disease risk in middle-aged UK men. Arterioscler Thromb Vasc Biol. Nov. 1. 2002;22(11):1918-23. X-1F,X-2. [pmid: 12426225].
2968 Talmud PJ, Hawe E, Miller GJ, et al. Nonfasting apolipoprotein B and triglyceride levels as a useful predictor of coronary heart disease risk in middle-aged UK men. Arterioscler Thromb Vasc Biol. Nov. 1. 2002;22(11):1918-23. X-1. [pmid: 12426225].
2969 Tam LS, Tomlinson B, Chu TT, et al. Cardiovascular risk profile of patients with psoriatic arthritis compared to controls--the role of inflammation. Rheumatology (Oxford). May. 2008;47(5):718-23. X-1,X-2,X-5,X-6,X-7. [pmid: 18400833].
2970 Tamaki N, Morita K. SPET in cardiology. Diagnosis, prognosis, and management of patients with coronary artery disease. Q J Nucl Med Mol Imaging. Jun. 2005;49(2):193-203. X-1,X-8. [pmid: 16010254].
2971 Tamburino C, Angiolillo DJ, Capranzano P, et al. Complete versus incomplete revascularization in patients with multivessel disease undergoing percutaneous coronary intervention with drug-eluting stents. Catheter Cardiovasc Interv. Oct. 1. 2008;72(4):448-56. X-1,X-2,X-8. [pmid: 18814218].
2972 Tamis-Holland JE, Homel P, Durani M, et al. Atrial fibrillation after minimally invasive direct coronary artery bypass surgery. J Am Coll Cardiol. Nov. 15. 2000;36(6):1884-8. X-1,X-6,X-8. [pmid: 11092660].
2973 Tan ZS, Seshadri S, Beiser A, et al. Plasma total cholesterol level as a risk factor for Alzheimer disease: the Framingham Study. Arch Intern Med. May. 12. 2003;163(9):1053-7. X-1,X-6. [pmid: 12742802].
2974 Tanasescu M, Leitzmann MF, Rimm EB, et al. Physical activity in relation to cardiovascular disease and total mortality among men with type 2 diabetes. Circulation. May. 20. 2003;107(19):2435-9. X-1F,X-2. [pmid: 12719277].
2975 Tanemoto K. Surgical treatment of ischemic mitral valve regurgitation. Ann Thorac Cardiovasc Surg. Aug. 2005;11(4):228-31. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16148868].
2976 Tang EW, Wong CK, Herbison P. Global Registry of Acute Coronary Events (GRACE) hospital discharge risk score accurately predicts long-term mortality post acute coronary syndrome. Am Heart J. Jan. 2007;153(1):29-35. X-1,X-8. [pmid: 17174633].
2977 Tang EW, Wong CK, Restieaux NJ, et al. Clinical outcome of older patients with acute coronary syndrome over the last three decades. Age Ageing. May. 2006;35(3):280-5. X-1,X-8. [pmid: 16638768].
2978 Tang J, Zhao J, Zhao Y, et al. Apolipoprotein E epsilon4 and the risk of unfavorable outcome after aneurysmal subarachnoid hemorrhage. Surg Neurol. Nov. 2003;60(5):391-6. discussion 396-7. X-1,X-5,X-6,X-8. [pmid: 14572957].
2979 Tang WH, Steinhubl SR, Van Lente F, et al. Risk stratification for patients undergoing nonurgent percutaneous coronary intervention using N-terminal pro-B-type natriuretic peptide: a Clopidogrel for the Reduction of Events During Observation (CREDO) substudy. Am Heart J. Jan. 2007;153(1):36-41. X-1,X-2,X-8. [pmid: 17174634].
2980 Tanko LB, Christiansen C, Cox DA, et al. Relationship between osteoporosis and cardiovascular disease in postmenopausal women. J Bone Miner Res. Nov. 2005;20(11):1912-20. X-1F,X-2,X-8. [pmid: 16234963].
2981 Tanne D, Benderly M, Goldbourt U, et al. C-reactive protein as a predictor of incident ischemic stroke among patients with preexisting cardiovascular disease. Stroke. Jul. 2006;37(7):1720-4. X-1,X-8. [pmid: 16741173].
2982 Tanne D, Haim M, Boyko V, et al. Soluble intercellular adhesion molecule-1 and risk of future ischemic stroke: a nested case-control study from the Bezafibrate Infarction Prevention (BIP) study cohort. Stroke. Sep. 2002;33(9):2182-6. X-1,X-5,X-6,X-8. [pmid: 12215584].
2983 Tanne D, Haim M, Goldbourt U, et al. Prospective study of serum homocysteine and risk of ischemic stroke among patients with preexisting coronary heart disease. Stroke. Mar. 2003;34(3):632-6. X-1,X-8. [pmid: 12624283].
2984 Tanne D, Kasner SE, Demchuk AM, et al. Markers of increased risk of intracerebral hemorrhage after intravenous recombinant tissue plasminogen activator therapy for acute ischemic stroke in clinical practice: the Multicenter rt-PA Stroke Survey. Circulation. Apr. 9. 2002;105(14):1679-85. X-1,X-2,X-8. [pmid: 11940547].
2985 Targonski PV, Bonetti PO, Pumper GM, et al. Coronary endothelial dysfunction is associated with an increased risk of cerebrovascular events. Circulation. Jun. 10. 2003;107(22):2805-9. X-1,X-5,X-6. [pmid: 12771004].
2986 Tartan Z, Uyarel H, Kasikcioglu H, et al. Metabolic syndrome as a predictor of non-dipping hypertension. Tohoku J Exp Med. Sep. 2006;210(1):57-66. X-1,X-6,X-7. [pmid: 16960346].
2987 Tartiere JM, Henry OF, Safar H, et al. Carotid intima-media thickness and carotid and/or iliofemoral plaques: comparison of two markers of cardiovascular risk in hypertensive patients. J Hypertens. Apr. 2003;21(4):739-46. X-1,X-5. [pmid: 12658020].
2988 Tay SY, Ampil ER, Chen CP, et al. The relationship between homocysteine, cognition and stroke subtypes in acute stroke. J Neurol Sci. Dec. 1. 2006;250(1-2):58-61. X-1,X-5,X-6,X-7,X-8. [pmid: 16935307].
2989 Taylor AJ. Atherosclerosis imaging to detect and monitor cardiovascular risk. Am J Cardiol. Nov. 21. 2002;90(10C):8L-11L. X-1,X-2,X-4,X-5,X-6.
2990 Taylor AJ, Arora NS, Bindeman J, et al. Conventional, emerging, heredity, lifestyle, and psychosocial coronary risk factors: relationships to subclinical atherosclerosis. Prev Cardiol. Winter. 2006;9(1):25-32. X-1,X-2,X-5,X-6. [pmid: 16407700].
2991 Taylor AJ, Bindeman J, Feuerstein I, et al. Coronary calcium independently predicts incident premature coronary heart disease over measured cardiovascular risk factors: mean three-year outcomes in the Prospective Army Coronary Calcium (PACC) project. J Am Coll Cardiol. Sep. 6. 2005;46(5):807-14. X-1. [pmid: 16139129].
2992 Taylor AJ, Bindeman J, Le TP, et al. Progression of calcified coronary atherosclerosis: relationship to coronary risk factors and carotid intima-media thickness. Atherosclerosis. Mar. 2008;197(1):339-45. X-6,X-7. [pmid: 17727858].
2993 Taylor AJ, Feuerstein I, Wong H, et al. Do conventional risk factors predict subclinical coronary artery disease? Results from the Prospective Army Coronary Calcium Project. Am Heart J. Mar. 2001;141(3):463-8. X-6. [pmid: 11231446].
2994 Tello-Montoliu A, Molto JM, Lopez-Hernandez N, et al. Common carotid artery intima-media thickness and intracranial pulsatility index in non-ST-elevation acute coronary syndromes. Cerebrovasc Dis. 2007;24(4):338-42. X-1,X-5,X-6,X-8. [pmid: 17690545].
2995 ten Broecke PW, De Hert SG, Mertens E, et al. Effect of preoperative beta-blockade on perioperative mortality in coronary surgery. Br J Anaesth. Jan. 2003;90(1):27-31. X-1,X-6,X-8. [pmid: 12488374].
2996 Tentori F, Blayney MJ, Albert JM, et al. Mortality risk for dialysis patients with different levels of serum calcium, phosphorus, and PTH: the Dialysis Outcomes and Practice Patterns Study (DOPPS). Am J Kidney Dis. Sep. 2008;52(3):519-30. X-1D,X-1F,X-2,X-8. [pmid: 18514987].
2997 ter Avest E, Holewijn S, Bredie SJ, et al. Pulse wave velocity in familial combined hyperlipidemia. Am J Hypertens. Mar. 2007;20(3):263-9. X-1,X-5,X-6,X-8. [pmid: 17324737].
2998 Terracciano A, Lockenhoff CE, Zonderman AB, et al. Personality predictors of longevity: activity, emotional stability, and conscientiousness. Psychosom Med. Jul. 2008;70(6):621-7. X-1,X-2,X-6. [pmid: 18596250].
2999 Thatipelli MR, Pellikka PA, McBane RD, et al. Prognostic value of ankle-brachial index and dobutamine stress echocardiography for cardiovascular morbidity and all-cause mortality in patients with peripheral arterial disease. J Vasc Surg. Jul. 2007;46(1):62-70. discussion 70. X-1F,X-2,X-5,X-8. [pmid: 17583463].
3000 Thielmann M, Jakob H. Surgical revascularization and perioperative management in patients with non-ST-elevation acute coronary syndromes. Rocz Akad Med Bialymst. 2005;50:37-44. X-1,X-8. [pmid: 16358937].
3001 Thielmann M, Massoudy P, Neuhauser M, et al. Risk stratification with cardiac troponin I in patients undergoing elective coronary artery bypass surgery. Eur J Cardiothorac Surg. May. 2005;27(5):861-9. X-1,X-8. [pmid: 15848327].
3002 Thielmann M, Massoudy P, Neuhauser M, et al. Prognostic value of preoperative cardiac troponin I in patients with non-ST-segment elevation acute coronary syndromes undergoing coronary artery bypass surgery. Chest. Nov. 2005;128(5):3526-36. X-1,X-8. [pmid: 16304309].
3003 Thijs VN, Albers GW. Symptomatic intracranial atherosclerosis: outcome of patients who fail antithrombotic therapy. Neurology. Aug. 22. 2000;55(4):490-7. X-7,X-8. [pmid: 10953179].
3004 Thomas AJ, Eberly LE, Davey Smith G, et al. Race/ethnicity, income, major risk factors, and cardiovascular disease mortality. Am J Public Health. Aug. 2005;95(8):1417-23. X-1F,X-2,X-8(~1.5%). [pmid: 16006418].
3005 Thomas GN, Chen XY, Lin JW, et al. Middle cerebral artery stenosis increased the risk of vascular disease mortality among type 2 diabetic patients. Cerebrovasc Dis. 2008;25(3):261-7. X-1,X-2. [pmid: 18270486].
3006 Thomas KE, Josephson ME. The role of electrophysiology study in risk stratification of sudden cardiac death. Prog Cardiovasc Dis. Sep-Oct. 2008;51(2):97-105. X-1D,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 18774009].
3007 Thomas KL, Al-Khatib SM, Lokhnygina Y, et al. Amiodarone use after acute myocardial infarction complicated by heart failure and/or left ventricular dysfunction may be associated with excess mortality. Am Heart J. Jan. 2008;155(1):87-93. X-1,X-2,X-8. [pmid: 18082495].
3008 Thomas LC, Rivett DA, Bolton PS. Pre-manipulative testing and the use of the velocimeter. Man Ther. Feb. 2008;13(1):29-36. X-1,X-5. [pmid: 17532252].
3009 Thompson BH, Stanford W. Update on using coronary calcium screening by computed tomography to measure risk for coronary heart disease. Int J Cardiovasc Imaging. Feb. 2005;21(1):39-53. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15915939].
3010 Thompson CR, Humphries KH, Gao M, et al. Revascularization use and survival outcomes after cardiac catheterization in British Columbia and Alberta. Can J Cardiol. Dec. 2004;20(14):1417-23. X-1,X-6,X-8. [pmid: 15614334].
3011 Thomsen TF, Davidsen M, Ibsen H, et al. A new method for CHD prediction and prevention based on regional risk scores and randomized clinical trials; PRECARD and the Copenhagen Risk Score. J Cardiovasc Risk. Oct. 2001;8(5):291-7. X-2. [pmid: 11702035].
3012 Thomsen TF, McGee D, Davidsen M, et al. A cross-validation of risk-scores for coronary heart disease mortality based on data from the Glostrup Population Studies and Framingham Heart Study. Int J Epidemiol. Aug. 2002;31(4):817-22. X-4,X-5. [pmid: 12177028].
3013 Thorand B, Lowel H, Schneider A, et al. C-reactive protein as a predictor for incident diabetes mellitus among middle-aged men: results from the MONICA Augsburg cohort study, 1984-1998. Arch Intern Med. Jan. 13. 2003;163(1):93-9. X-1,X-2,X-6. [pmid: 12523922].
3014 Thrainsdottir IS, Aspelund T, Hardarson T, et al. Glucose abnormalities and heart failure predict poor prognosis in the population-based Reykjavik Study. Eur J Cardiovasc Prev Rehabil. Oct. 2005;12(5):465-71. X-1,X-8. [pmid: 16210933].
3015 Thurston RC, Kubzansky LD, Kawachi I, et al. Is the association between socioeconomic position and coronary heart disease stronger in women than in men?. Am J Epidemiol. Jul. 1. 2005;162(1):57-65. X-1F,X-2. [pmid: 15961587].
3016 Tillin T, Chambers J, Malik I, et al. Measurement of pulse wave velocity: site matters. J Hypertens. Feb. 2007;25(2):383-9. X-1,X-5,X-6,X-7. [pmid: 17211245].
3017 Tillin T, Forouhi N, McKeigue P, et al. Microalbuminuria and coronary heart disease risk in an ethnically diverse UK population: a prospective cohort study. J Am Soc Nephrol. Dec. 2005;16(12):3702-10. X-1F,X-2,X-6,X-8(2-11%), (England). [pmid: 16207830].
3018 Tilling K, Sterne JA, Rudd AG, et al. A new method for predicting recovery after stroke. Stroke. Dec. 1. 2001;32(12):2867-73. X-1,X-6,X-8. [pmid: 11739989].
3019 Timaran CH, Rosero EB, Smith ST, et al. Trends and outcomes of concurrent carotid revascularization and coronary bypass. J Vasc Surg. Aug. 2008;48(2):355-360. discussion 360-1. X-1,X-6,X-8. [pmid: 18572353].
3020 Tirkes AT, Gottlieb RH, Voci SL, et al. Risk of significant coronary artery disease as determined by CT measurement of the distribution of abdominal adipose tissue. J Comput Assist Tomogr. Mar-Apr. 2002;26(2):210-5. X-1,X-2,X-5,X-7,X-8. [pmid: 11884776].
3021 Tiroch KA, Arora N, Matheny ME, et al. Risk predictors of retroperitoneal hemorrhage following percutaneous coronary intervention. Am J Cardiol. Dec. 1. 2008;102(11):1473-6. X-1,X-2,X-6,X-8. [pmid: 19026298].
3022 Tjandrawidjaja MC, Fu Y, Al-Khalidi H, et al. Failure of investigator adherence to electrocardiographic entry criteria is frequent and influences clinical outcomes: lessons from APEX-AMI. Eur Heart J. Dec. 2007;28(23):2850-7. X-1,X-2,X-8. [pmid: 17967823].
3023 Todaro JF, Con A, Niaura R, et al. Combined effect of the metabolic syndrome and hostility on the incidence of myocardial infarction (the Normative Aging Study). Am J Cardiol. Jul. 15. 2005;96(2):221-6. X-1F,X-2,X-6. [pmid: 16018847].
3024 Toft U, Kristoffersen LH, Lau C, et al. The Dietary Quality Score: validation and association with cardiovascular risk factors: the Inter99 study. Eur J Clin Nutr. Feb. 2007;61(2):270-8. X-1,X-5,X-6. [pmid: 16929244].
3025 Togni M, Eber S, Widmer J, et al. Impact of vessel size on outcome after implantation of sirolimus-eluting and paclitaxel-eluting stents: a subgroup analysis of the SIRTAX trial. J Am Coll Cardiol. Sep. 18. 2007;50(12):1123-31. X-1,X-8. [pmid: 17868802].
3026 Tolbert PE, Klein M, Peel JL, et al. Multipollutant modeling issues in a study of ambient air quality and emergency department visits in Atlanta. J Expo Sci Environ Epidemiol. Dec. 2. 2007;17:S29-35. X-1,X-2,X-5. [pmid: 18079762].
3027 Tomiyama H, Arai T, Koji Y, et al. The relationship between high-sensitive C-reactive protein and pulse wave velocity in healthy Japanese men. Atherosclerosis. Jun. 2004;174(2):373-7. X-1,X-2,X-5,X-6. [pmid: 15136069].
3028 Tonelli M, Wiebe N, Culleton B, et al. Chronic kidney disease and mortality risk: a systematic review. J Am Soc Nephrol. Jul. 2006;17(7):2034-47. X-1,X-2,X-4,X-5,X-6. [pmid: 16738019].
3029 Tong DC, Adami A, Moseley ME, et al. Relationship between apparent diffusion coefficient and subsequent hemorrhagic transformation following acute ischemic stroke. Stroke. Oct. 2000;31(10):2378-84. X-1,X-6,X-7,X-8. [pmid: 11022067].
3030 Tonstad S, Graff-Iversen S. Action levels for obesity treatment in 40 to 42-y-old men and women compared with action levels for prevention of coronary heart disease. Int J Obes Relat Metab Disord. Nov. 2001;25(11):1698-704. X-1G,X-2,X-5,X-6. [pmid: 11753593].
3031 Topkara VK, Dang NC, John R, et al. A decade experience of cardiac retransplantation in adult recipients. J Heart Lung Transplant. Nov. 2005;24(11):1745-50. X-1,X-8. [pmid: 16297775].
3032 Topol EJ, Easton D, Harrington RA, et al. Randomized, double-blind, placebo-controlled, international trial of the oral IIb/IIIa antagonist lotrafiban in coronary and cerebrovascular disease. Circulation. Jul. 29. 2003;108(4):399-406. X-1,X-2. [pmid: 12874182].
3033 Torquati A, Wright K, Melvin W, et al. Effect of gastric bypass operation on Framingham and actual risk of cardiovascular events in class II to III obesity. J Am Coll Surg. May. 2007;204(5):776-82. discussion 782-3. X-1. [pmid: 17481482].
3034 Torres JL, Ridker PM. Clinical use of high sensitivity C-reactive protein for the prediction of adverse cardiovascular events. Curr Opin Cardiol. Nov. 2003;18(6):471-8. X-1,X-3,X-4,X-5,X-6. [pmid: 14597888].
3035 Touboul PJ, Hernandez-Hernandez R, Kucukoglu S, et al. Carotid artery intima media thickness, plaque and Framingham cardiovascular score in Asia, Africa/Middle East and Latin America: the PARC-AALA study. Int J Cardiovasc Imaging. Oct. 2007;23(5):557-67. X-1. [pmid: 17186134].
3036 Touboul PJ, Labreuche J, Vicaut E, et al. Carotid intima-media thickness, plaques, and Framingham risk score as independent determinants of stroke risk. Stroke. Aug. 2005;36(8):1741-5. X-1,X-5. [pmid: 16020769].
3037 Toumpoulis IK, Anagnostopoulos CE, DeRose JJ, et al. Early and midterm outcome after off-pump coronary artery bypass grafting in patients with left ventricular dysfunction. Heart Surg Forum. 2004;7(6):E539-45. discussion E539-45. X-1,X-8. [pmid: 15769682].
3038 Toumpoulis IK, Anagnostopoulos CE, DeRose JJ, et al. European system for cardiac operative risk evaluation predicts long-term survival in patients with coronary artery bypass grafting. Eur J Cardiothorac Surg. Jan. 2004;25(1):51-8. X-1,X-8. [pmid: 14690732].
3039 Toumpoulis IK, Anagnostopoulos CE, DeRose JJ, et al. Does EuroSCORE predict length of stay and specific postoperative complications after coronary artery bypass grafting?. Int J Cardiol. Oct. 20. 2005;105(1):19-25. X-1,X-8. [pmid: 15908026].
3040 Toumpoulis IK, Anagnostopoulos CE, Swistel DG, et al. Does EuroSCORE predict length of stay and specific postoperative complications after cardiac surgery?. Eur J Cardiothorac Surg. Jan. 2005;27(1):128-33. X-1,X-8. [pmid: 15621484].
3041 Touze E, Varenne O, Chatellier G, et al. Risk of myocardial infarction and vascular death after transient ischemic attack and ischemic stroke: a systematic review and meta-analysis. Stroke. Dec. 2005;36(12):2748-55. X-1,X-4,X-5,X-8. [pmid: 16254218].
3042 Toyama T, Hoshizaki H, Seki R, et al. Evaluation of myocardial viability following acute myocardial infarction using 201Tl SPECT after thallium-glucose-insulin infusion--comparison with 18F-FDG positron emission tomography. Ann Nucl Med. Sep. 2004;18(6):463-8. X-1,X-2,X-6,X-7,X-8. [pmid: 15515744].
3043 Toyoda K, Okada Y, Ibayashi S, et al. Antithrombotic therapy and predilection for cerebellar hemorrhage. Cerebrovasc Dis. 2007;23(2-3):109-16. X-1,X-2,X-8. [pmid: 17124390].
3044 Trehan N, Khanna SN, Mishra Y, et al. Predictors of early outcome after coronary artery surgery in patients with severe left ventricular dysfunction. J Card Surg. Mar-Apr. 2003;18(2):101-6. X-1,X-6,X-8. [pmid: 12757335].
3045 Tretter MJ Jr, Hertzer NR, Mascha EJ, et al. Perioperative risk and late outcome of nonelective carotid endarterectomy. J Vasc Surg. Oct. 1999;30(4):618-31. X-1,X-6,X-8. [pmid: 10514201].
3046 Tricoci P, Peterson ED, Mulgund J, et al. Temporal trends in the use of early cardiac catheterization in patients with non-ST-segment elevation acute coronary syndromes (results from CRUSADE). Am J Cardiol. Nov. 1. 2006;98(9):1172-6. X-1,X-2,X-5,X-6,X-8. [pmid: 17056321].
3047 Tripathi M, Pandey M. Intrathoracic pulmonary artery catheter allocation in the of left atrial dilatation. J Cardiovasc Surg (Torino). Dec. 2003;44(6):719-24. X-1,X-2,X-6,X-7,X-8.
3048 Tsai HK, D'Amico AV, Sadetsky N, et al. Androgen deprivation therapy for localized prostate cancer and the risk of cardiovascular mortality. J Natl Cancer Inst. Oct. 17. 2007;99(20):1516-24. X-1. [pmid: 17925537].
3049 Tsang TS, Barnes ME, Gersh BJ, et al. Prediction of risk for first age-related cardiovascular events in an elderly population: the incremental value of echocardiography. J Am Coll Cardiol. Oct. 1. 2003;42(7):1199-205. X-2. [pmid: 14522480].
3050 Tschanz JT, Corcoran C, Skoog I, et al. Dementia: the leading predictor of death in a defined elderly population: the Cache County Study. Neurology. Apr. 13. 2004;62(7):1156-62. X-1,X-2,X-6. [pmid: 15079016].
3051 Tsukamoto T, Morita K, Naya M, et al. Myocardial flow reserve is influenced by both coronary artery stenosis severity and coronary risk factors in patients with suspected coronary artery disease. Eur J Nucl Med Mol Imaging. Oct. 2006;33(10):1150-6. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 16733686].
3052 Tsuru R, Kondo H, Hojo Y, et al. Increased granzyme B production from peripheral blood mononuclear cells in patients with acute coronary syndrome. Heart. Mar. 2008;94(3):305-10. X-1,X-5,X-6,X-7,X-8. [pmid: 17591646].
3053 Tsuruda T, Kato J, Sumi T, et al. Combined use of brain natriuretic peptide and C-reactive protein for predicting cardiovascular risk in outpatients with type 2 diabetes mellitus. Vasc Health Risk Manag. 2007;3(4):417-23. X-7. [pmid: 17969372].
3054 Tsushima Y, Aoki J, Endo K. Brain microhemorrhages detected on T2*-weighted gradient-echo MR images. AJNR Am J Neuroradiol. Jan. 2003;24(1):88-96. X-1,X-2. [pmid: 12533332].
3055 Tsutsumi A, Kayaba K, Kario K, et al. Prospective study on occupational stress and risk of stroke. Arch Intern Med. Jan. 12. 2009;169(1):56-61. X-1,X-2. [pmid: 19139324].
3056 Tu JV, Wang H, Bowyer B, et al. Risk factors for death or stroke after carotid endarterectomy: observations from the Ontario Carotid Endarterectomy Registry. Stroke. Nov. 2003;34(11):2568-73. X-1G,X-2,X-8. [pmid: 14526040].
3057 Tugtekin S, Kappert U, Alexiou K, et al. Coronary artery bypass grafting in octogenarians-outcome with and without extracorporeal circulation. Thorac Cardiovasc Surg. Oct. 2007;55(7):407-11. X-1,X-6,X-8. [pmid: 17902060].
3058 Tully MA, Cupples ME, Chan WS, et al. Brisk walking, fitness, and cardiovascular risk: a randomized controlled trial in primary care. Prev Med. Aug. 2005;41(2):622-8. X-1X-7. [pmid: 15917061].
3059 Tunstall-Pedoe H. The Dundee coronary risk-disk for management of change in risk factors. BMJ. Sep. 28. 1991;303(6805):744-7. X-2. [pmid: 1932933].
3060 Tuomainen AM, Nyyssonen K, Laukkanen JA, et al. Serum matrix metalloproteinase-8 concentrations are associated with cardiovascular outcome in men. Arterioscler Thromb Vasc Biol. Dec. 2007;27(12):2722-8. X-1E,X-1F,X-2. [pmid: 17932311].
3061 Turhan H, Erbay AR, Yasar AS, et al. Plasma soluble adhesion molecules; intercellular adhesion molecule-1, vascular cell adhesion molecule-1 and E-selectin levels in patients with isolated coronary artery ectasia. Coron Artery Dis. Feb. 2005;16(1):45-50. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15654200].
3062 Turin TC, Kita Y, Murakami Y, et al. Increase of stroke incidence after weekend regardless of traditional risk factors: Takashima Stroke Registry, Japan; 1988-2003. Cerebrovasc Dis. 2007;24(4):328-37. X-2. [pmid: 17690544].
3063 Tuttolomondo A, Pinto A, Salemi G, et al. Diabetic and non-diabetic subjects with ischemic stroke: differences, subtype distribution and outcome. Nutr Metab Cardiovasc Dis. Feb. 2008;18(2):152-7. X-5. [pmid: 17702553].
3064 Tverdal A. Calculation of risk for the development of acute myocardial infarction in the normal population based on long-term follow-up studies: smokers compared with non-smokers. J Cardiovasc Risk. Oct. 1999;6(5):287-91. X-1E,X-1F,X-2. [pmid: 10534129].
3065 Twisk JW, Kemper HC, van Mechelen W. Prediction of cardiovascular disease risk factors later in life by physical activity and physical fitness in youth: introduction. Int J Sports Med. May. 1. 2002;23:S5-7. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12012255].
3066 Tziakas DN, Chalikias GK, Kaski JC, et al. Inflammatory and anti-inflammatory variable clusters and risk prediction in acute coronary syndrome patients: a factor analysis approach. Atherosclerosis. Jul. 2007;193(1):196-203. X-1,X-8. [pmid: 16857204].
3067 Ueda K, Tsukuma H, Tanaka H, et al. Estimation of individualized probabilities of developing breast cancer for Japanese women. Breast Cancer. 2003;10(1):54-62. X-1,X-2,X-6. [pmid: 12525764].
3068 Ueda R, Yokouchi M, Suzuki T, et al. Prognostic value of high plasma brain natriuretic peptide concentrations in very elderly persons. Am J Med. Mar. 2003;114(4):266-70. X-1,X-6,X-7. [pmid: 12681452].
3069 Uehara R, Yashiro M, Hayasaka S, et al. Serum alanine aminotransferase concentrations in patients with Kawasaki disease. Pediatr Infect Dis J. Sep. 2003;22(9):839-42. X-1,X-6. [pmid: 14515833].
3070 Ueno H, Nakayama M, Kojima S, et al. The synergistic combined effect of anemia with high plasma levels of B-type natriuretic peptide significantly predicts an enhanced risk for major adverse cardiac events. Heart Vessels. Jul. 2008;23(4):243-8. X-1,X-2,X-7. [pmid: 18649054].
3071 Ugarte MD, Ibanez B, Militino AF. Modelling risks in disease mapping. Stat Methods Med Res. Feb. 2006;15(1):21-35. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16477946].
3072 Ugolini C, Nobilio L. Risk adjustment for coronary artery bypass graft surgery: an administrative approach versus EuroSCORE. Int J Qual Health Care. Apr. 2004;16(2):157-64. X-1,X-2,X-5,X-6. [pmid: 15051710].
3073 Uitterlinden AG, Fang Y, Van Meurs JB, et al. Genetics and biology of vitamin D receptor polymorphisms. Gene. Sep. 1. 2004;338(2):143-56. X-1,X-2,X-4,X-5,X-6. [pmid: 15315818].
3074 Uitterlinden AG, Fang Y, van Meurs JB, et al. Vitamin D receptor gene polymorphisms in relation to Vitamin D related disease states. J Steroid Biochem Mol Biol. May. 2004;89-90(1-5):187-93. X-1,X-2,X-4,X-5,X-6. [pmid: 15225770].
3075 Ulgen MS, Bilici A, Acar M, et al. The relationship of coronary artery disease and carotid Doppler flow velocity and resistance index in patients with no significant carotid stenosis. Angiology. Jun. 2001;52(6):433-4. X-1. [pmid: 11437036].
3076 Ulus T, Yildirir A, Sade LE, et al. Serum gamma-glutamyl transferase activity: new high-risk criteria in acute coronary syndrome patients?. Coron Artery Dis. Nov. 2008;19(7):489-95. X-1,X-2,X-7,X-8. [pmid: 18923245].
3077 Umana JP, Miller DC, Mitchell RS. What is the best treatment for patients with acute type B aortic dissections--medical, surgical, or endovascular stent-grafting?. Ann Thorac Surg. Nov. 2002;74(5):S1840-3. discussion S1857-63. X-1,X-2,X-6,X-7. [pmid: 12440677].
3078 Unwin N, Shaw J, Zimmet P, et al. Impaired glucose tolerance and impaired fasting glycaemia: the current status on definition and intervention. Diabet Med. Sep. 2002;19(9):708-23. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 12207806].
3079 Urbonaviciene G, Urbonavicius S, Vorum H, et al. Evaluation of prognostic clinical and ECG parameters in patients after myocardial infarction by applying logistic regression method. Pacing Clin Electrophysiol. Nov. 2008;31(11):1391-8. X-1,X-2,X-7,X-8. [pmid: 18950295].
3080 Usmani A, Sharma P, Aneja A. Can brain natriuretic peptide identify noncardiac surgery patients at high risk for cardiac events?. Cleve Clin J Med. Sep. 1. 2007;74:S12-3. X-1.
3081 Uthoff H, Staub D, Meyerhans A, et al. Intima-media thickness and carotid resistive index: progression over 6 years and predictive value for cardiovascular events. Ultraschall Med. Dec. 2008;29(6):604-10. X-1,X-2,X-7,X-8. [pmid: 18528807].
3082 Uyttenboogaart M, Koch MW, Koopman K, et al. Safety of antiplatelet therapy prior to intravenous thrombolysis in acute ischemic stroke. Arch Neurol. May. 2008;65(5):607-11. X-1,X-2,X-5,X-6,X-8. [pmid: 18332238].
3083 Uyttenboogaart M, Vroomen PC, Stewart RE, et al. Safety of routine IV thrombolysis between 3 and 4.5 h after ischemic stroke. J Neurol Sci. Mar. 15. 2007;254(1-2):28-32. X-1,X-7,X-8. [pmid: 17257623].
3084 Uzunca I, Asil T, Balci K, et al. Evaluation of vasomotor reactivity by transcranial Doppler sonography in patients with acute stroke who have symptomatic intracranial and extracranial stenosis. J Ultrasound Med. Feb. 2007;26(2):179-85. X-1,X-7,X-8. [pmid: 17255179].
3085 Vaananen A, Koskinen A, Joensuu M, et al. Lack of predictability at work and risk of acute myocardial infarction: an 18-year prospective study of industrial employees. Am J Public Health. Dec. 2008;98(12):2264-71. X-1,X-2. [pmid: 18923130].
3086 Vaccarino V, Abramson JL, Veledar E, et al. Sex differences in hospital mortality after coronary artery bypass surgery: evidence for a higher mortality in younger women. Circulation. Mar. 12. 2002;105(10):1176-81. X-1,X-5,X-8. [pmid: 11889010].
3087 Vaidya D, Kelemen MD, Bittner V, et al. Fasting plasma glucose predicts survival and angiographic progression in high-risk postmenopausal women with coronary artery disease. J Womens Health (Larchmt). Mar. 2007;16(2):228-34. X-1F,X-2,X-8. [pmid: 17388739].
3088 Valdes-Canedo F, Pita-Fernandez S, Seijo-Bestilleiro R, et al. Incidence of cardiovascular events in renal transplant recipients and clinical relevance of modifiable variables. Transplant Proc. Sep. 2007;39(7):2239-41. X-1F,X-2,X-8. [pmid: 17889150].
3089 Valencia JF, Vallverdu M, Cygankiewicz I, et al. Multiscale regularity analysis of the Heart Rate Variability: stratification of cardiac death risk. Conf Proc IEEE Eng Med Biol Soc. 2007. 2007:5947-50. X-1,X-8.
3090 Valenzuela LF, Vazquez R, Fournier JA, et al. Prediction of infarction-related artery occlusion and multivessel disease in postinfarction angina. Int J Cardiol. Feb. 14. 2007;115(3):381-5. X-1,X-7,X-8. [pmid: 16814417].
3091 Valeti US, Miller TD, Hodge DO, et al. Exercise single-photon emission computed tomography provides effective risk stratification of elderly men and elderly women. Circulation. Apr. 12. 2005;111(14):1771-6. X-1D,X-1F,X-1G,X-8(MI, 13%W, 20%M). [pmid: 15809375].
3092 Valgimigli M, Serruys PW, Tsuchida K, et al. Cyphering the complexity of coronary artery disease using the syntax score to predict clinical outcome in patients with three-vessel lumen obstruction undergoing percutaneous coronary intervention. Am J Cardiol. Apr. 15. 2007;99(8):1072-81. X-1,X-8. [pmid: 17437730].
3093 Vallejo E, Morales M, Sanchez I, et al. Myocardial perfusion SPECT imaging in patients with myocardial bridging. J Nucl Cardiol. May-Jun. 2005;12(3):318-23. X-1,X-6,X-7,X-8. [pmid: 15944537].
3094 van Bemmel T, Vinkers DJ, Macfarlane PW, et al. Markers of autonomic tone on a standard ECG are predictive of mortality in old age. Int J Cardiol. Feb. 8. 2006;107(1):36-41. X-1F,X-2,X-6,X-8. [pmid: 16337495].
3095 van den Belt-Dusebout AW, Nuver J, de Wit R, et al. Long-term risk of cardiovascular disease in 5-year survivors of testicular cancer. J Clin Oncol. Jan. 20. 2006;24(3):467-75. X-1,X-2. [pmid: 16421423].
3096 van der Harst P, Voors AA, Volbeda M, et al. Usefulness of preoperative C-reactive protein and soluble intercellular adhesion molecule-1 level for predicting future cardiovascular events after coronary artery bypass grafting. Am J Cardiol. Jun. 15. 2006;97(12):1697-701. X-1,X-7,X-8. [pmid: 16765116].
3097 van der Meer IM, de Maat MP, Kiliaan AJ, et al. The value of C-reactive protein in cardiovascular risk prediction: the Rotterdam Study. Arch Intern Med. Jun. 9. 2003;163(11):1323-8. X-1,X-5. [pmid: 12796068].
3098 van der Net JB, Janssens AC, Defesche JC, et al. Usefulness of genetic polymorphisms and conventional risk factors to predict coronary heart disease in patients with familial hypercholesterolemia. Am J Cardiol. Feb. 1. 2009;103(3):375-80. X-1. [pmid: 19166692].
3099 van der Steeg WA, Boekholdt SM, Stein EA, et al. Role of the apolipoprotein B-apolipoprotein A-I ratio in cardiovascular risk assessment: a case-control analysis in EPIC-Norfolk. Ann Intern Med. May. 1. 2007;146(9):640-8. X-1. [pmid: 17470832].
3100 van der Weijden T, van Steenkiste B, Stoffers HE, et al. Primary prevention of cardiovascular diseases in general practice: mismatch between cardiovascular risk and patients' risk perceptions. Med Decis Making. Nov-Dec. 2007;27(6):754-61. X-1,X-2,X-5,X-6. [pmid: 17873263].
3101 van Domburg RT, Scmidt Pedersen S, van den Brand MJ, et al. Feelings of being disabled as a predictor of mortality in men 10 years after percutaneous coronary transluminal angioplasty. J Psychosom Res. Sep. 2001;51(3):469-77. X-1,X-2,X-6,X-8. [pmid: 11602216].
3102 van Domburg RT, Takkenberg JJ, van Herwerden LA, et al. Short-term and 5-year outcome after primary isolated coronary artery bypass graft surgery: results of risk stratification in a bilocation center. Eur J Cardiothorac Surg. Apr. 2002;21(4):733-40. X-1,X-8. [pmid: 11932176].
3103 van Exel E, Gussekloo J, de Craen AJ, et al. Inflammation and stroke: the Leiden 85-Plus Study. Stroke. Apr. 2002;33(4):1135-8. X-1,X-2,X-8. [pmid: 11935072].
3104 van Gameren M, Kappetein AP, Steyerberg EW, et al. Do we need separate risk stratification models for hospital mortality after heart valve surgery?. Ann Thorac Surg. Mar. 2008;85(3):921-30. X-1,X-8. [pmid: 18291172].
3105 van Gorp MJ, Steyerberg EW, Kallewaard M, et al. Clinical prediction rule for 30-day mortality in Bjork-Shiley convexo-concave valve replacement. J Clin Epidemiol. Oct. 2003;56(10):1006-12. X-1. [pmid: 14568633].
3106 van Melle JP, de Jonge P, Kuyper AM, et al. Prediction of depressive disorder following myocardial infarction data from the Myocardial INfarction and Depression-Intervention Trial (MIND-IT). Int J Cardiol. Apr. 28. 2006;109(1):88-94. X-1,X-6,X-8. [pmid: 16002163].
3107 Van Puymbroeck M, Rittman MR. Quality-of-life predictors for caregivers at 1 and 6 months poststroke: Results of path analyses. J Rehabil Res Dev. Nov-Dec. 2005;42(6):747-60. X-1,X-2,X-6,X-8. [pmid: 16680612].
3108 van Steenkiste B, van der Weijden TM, Stoffers JH, et al. Patients' responsiveness to a decision support tool for primary prevention of cardiovascular diseases in primary care. Patient Educ Couns. Jul. 2008;72(1):63-70. X-1,X-2,X-6. [pmid: 18395393].
3109 Van Voorhees BW, Paunesku D, Gollan J, et al. Predicting future risk of depressive episode in adolescents: the Chicago Adolescent Depression Risk Assessment (CADRA). Ann Fam Med. Nov-Dec. 2008;6(6):503-11. X-1,X-6. [pmid: 19001302].
3110 van Walraven C, Hart RG, Wells GA, et al. A clinical prediction rule to identify patients with atrial fibrillation and a low risk for stroke while taking aspirin. Arch Intern Med. Apr. 28. 2003;163(8):936-43. X-1,X-6. [pmid: 12719203].
3111 Van Werkhoven JM, Schuijf JD, Jukema JW, et al. Multi-slice computed tomography coronary angiography: anatomic vs functional assessment in clinical practice. Minerva Cardioangiol. Apr. 2008;56(2):215-26. X-1C,X-1F,X-1G,X-2,X-4,X-5,X-6,,X-7,X-8,X-9. [pmid: 18319700].
3112 Vanagas G, Kinduris S, Buivydaite K. Assessment of validity for EuroSCORE risk stratification system. Scand Cardiovasc J. Apr. 2005;39(1-2):67-70. X-1B,X-2,X8(CABG 100%). [pmid: 16097417].
3113 Vanninen E, Kuikka JT, Aikia M, et al. Heterogeneity of cerebral blood flow in symptomatic patients undergoing carotid endarterectomy. Nucl Med Commun. Aug. 2003;24(8):893-900. X-1,X-2,X-8. [pmid: 12869822].
3114 Varas-Lorenzo C, Maguire A, Castellsague J, et al. Quantitative assessment of the gastrointestinal and cardiovascular risk-benefit of celecoxib compared to individual NSAIDs at the population level. Pharmacoepidemiol Drug Saf. Apr. 2007;16(4):366-76. X-1,X-6. [pmid: 16897817].
3115 Varela G, Cordovilla R, Jimenez MF, et al. Utility of standardized exercise oximetry to predict cardiopulmonary morbidity after lung resection. Eur J Cardiothorac Surg. Mar. 2001;19(3):351-4. X-1,X-7. [pmid: 11251278].
3116 Varga A, Gruber N, Forster T, et al. Atherosclerosis of the descending aorta predicts cardiovascular events: a transesophageal echocardiography study. Cardiovasc Ultrasound. 2004;2:21. X-1D,X-1F,X-2,X-6,X-8(~15%). [pmid: 15500685].
3117 Vargas RB, Mangione CM, Asch S, et al. Can a chronic care model collaborative reduce heart disease risk in patients with diabetes?. J Gen Intern Med. Feb. 2007;22(2):215-22. X-1,X-6,X-8. [pmid: 17356989].
3118 Varosy PD, Shlipak MG, Vittinghoff E, et al. Fracture and the risk of coronary events in women with heart disease. Am J Med. Aug. 15. 2003;115(3):196-202. X-1,X-8. [pmid: 12935826].
3119 Vartdal T, Brunvand H, Pettersen E, et al. Early prediction of infarct size by strain Doppler echocardiography after coronary reperfusion. J Am Coll Cardiol. Apr. 24. 2007;49(16):1715-21. X-1,X-2,X-6,X-7,X-8. [pmid: 17448374].
3120 Vasan RS, Massaro JM, Wilson PW, et al. Antecedent blood pressure and risk of cardiovascular disease: the Framingham Heart Study. Circulation. Jan. 1. 2002;105(1):48-53. X-1F,X-2. [pmid: 11772875].
3121 Vasan RS, Sullivan LM, Wilson PW, et al. Relative importance of borderline and elevated levels of coronary heart disease risk factors. Ann Intern Med. Mar. 15. 2005;142(6):393-402. X-1F,X-2. [pmid: 15767617].
3122 Vasu S, Gruberg L, Brown DL. The impact of advanced chronic kidney disease on in-hospital mortality following percutaneous coronary intervention for acute myocardial infarction. Catheter Cardiovasc Interv. Nov. 1. 2007;70(5):701-5. X-1,X-6,X-8. [pmid: 17932900].
3123 Veeger NJ, Panday GF, Voors AA, et al. Excellent long-term clinical outcome after coronary artery bypass surgery using three pedicled arterial grafts in patients with three-vessel disease. Ann Thorac Surg. Feb. 2008;85(2):508-12. X-1,X-5,X-8. [pmid: 18222253].
3124 Veenhuyzen GD, Singh SN, McAreavey D, et al. Prior coronary artery bypass surgery and risk of death among patients with ischemic left ventricular dysfunction. Circulation. Sep. 25. 2001;104(13):1489-93. X-1,X-2,X-8. [pmid: 11571241].
3125 Vendrell J, Fernandez-Real JM, Gutierrez C, et al. A polymorphism in the promoter of the tumor necrosis factor-alpha gene (-308) is associated with coronary heart disease in type 2 diabetic patients. Atherosclerosis. Apr. 2003;167(2):257-64. X-1,X-5,X-6. [pmid: 12818408].
3126 Venkatachalm L, Georgievski AB, Al Yazeedi W, et al. Length of stay in in-patient rehabilitation after stroke in Qatar. ScientificWorldJournal. 2008;8:547-55. X-1,X-5,X-6,X-7,X-8. [pmid: 18516476].
3127 Venkataraman R, Hage FG, Dorfman T, et al. Role of myocardial perfusion imaging in patients with end-stage renal disease undergoing coronary angiography. Am J Cardiol. Dec. 1. 2008;102(11):1451-6. X-1,X-2,X-6,X-7. [pmid: 19026294].
3128 Verdecchia P, Angeli F, Reboldi G, et al. Improved cardiovascular risk stratification by a simple ECG index in hypertension. Am J Hypertens. Aug. 2003;16(8):646-52. X-1,X-2. [pmid: 12878370].
3129 Verdecchia P, Porcellati C, Reboldi G, et al. Left ventricular hypertrophy as an independent predictor of acute cerebrovascular events in essential hypertension. Circulation. Oct. 23. 2001;104(17):2039-44. X-1F,X-2. [pmid: 11673343].
3130 Verdecchia P, Reboldi G, Porcellati C, et al. Risk of cardiovascular disease in relation to achieved office and ambulatory blood pressure control in treated hypertensive subjects. J Am Coll Cardiol. Mar. 6. 2002;39(5):878-85. X-1,X-2,X-8. [pmid: 11869856].
3131 Vergopoulos A, Knoblauch H, Schuster H. DNA testing for familial hypercholesterolemia: improving disease recognition and patient care. Am J Pharmacogenomics. 2002;2(4):253-62. X-1,X-2,X-4,X-5,X-6. [pmid: 12421096].
3132 Verma S. C-reactive protein incites atherosclerosis. Can J Cardiol. Aug. B. 2004;20:29B-31B. X-1,X-2,X-4,X-5,X-6.
3133 Verma S, Szmitko PE, Ridker PM. C-reactive protein comes of age. Nat Clin Pract Cardiovasc Med. Jan. 2005;2(1):29-36. quiz 58. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16265340].
3134 Verma S, Wang CH, Li SH, et al. The relationship between soluble CD40 ligand levels and Framingham coronary heart disease risk score in healthy volunteers. Atherosclerosis. Oct. 2005;182(2):361-5. X-1E,X-1F,X-2,X-5,X-6,X-8. [pmid: 16159609].
3135 Verma S, Wang CH, Lonn E, et al. Cross-sectional evaluation of brachial artery flow-mediated vasodilation and C-reactive protein in healthy individuals. Eur Heart J. Oct. 2004;25(19):1754-60. X-1F,X-2,X-6. [pmid: 15451155].
3136 Vermeer SE, Algra A, Franke CL, et al. Long-term prognosis after recovery from primary intracerebral hemorrhage. Neurology. Jul. 23. 2002;59(2):205-9. X-1,X-8. [pmid: 12136058].
3137 Vermeulen EG, Rauwerda JA, Erix P, et al. Normohomocysteinaemia and vitamin-treated hyperhomocysteinaemia are associated with similar risks of cardiovascular events in patients with premature atherothrombotic cerebrovascular disease. A prospective cohort study. Neth J Med. Apr. 2000;56(4):138-46. X-1,X-8. [pmid: 10727759].
3138 Vermeulen MJ, Tu JV, Schull MJ. ICD-10 adaptations of the Ontario acute myocardial infarction mortality prediction rules performed as well as the original versions. J Clin Epidemiol. Sep. 2007;60(9):971-4. X-2,X-6,X-8. [pmid: 17689814].
3139 Vernick W, Fleisher LA. Risk stratification. Best Pract Res Clin Anaesthesiol. Mar. 2008;22(1):1-21. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18494386].
3140 Verrier RL, Nearing BD, La Rovere MT, et al. Ambulatory electrocardiogram-based tracking of T wave alternans in postmyocardial infarction patients to assess risk of cardiac arrest or arrhythmic death. J Cardiovasc Electrophysiol. Jul. 2003;14(7):705-11. X-1,X-5,X-7,X-8. [pmid: 12930249].
3141 Viazzi F, Leoncini G, Parodi D, et al. Impact of target organ damage assessment in the evaluation of global risk in patients with essential hypertension. J Am Soc Nephrol. Mar. 1. 2005;16:S89-91. X-1C,X-2,X-5,X-6. [pmid: 15938043].
3142 Vikse BE, Irgens LM, Bostad L, et al. Adverse perinatal outcome and later kidney biopsy in the mother. J Am Soc Nephrol. Mar. 2006;17(3):837-45. X-1,X-2,X-6. [pmid: 16421228].
3143 Vila N, Millan M, Ferrer X, et al. Levels of alpha1-antitrypsin in plasma and risk of spontaneous cervical artery dissections: a case-control study. Stroke. Sep. 2003;34(9):E168-9. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 12893950].
3144 Villella M, Villella A, Santoro L, et al. Ergometric score systems after myocardial infarction: prognostic performance of the Duke Treadmill Score, Veterans Administration Medical Center Score, and of a novel score system, GISSI-2 Index, in a cohort of survivors of acute myocardial infarction. Am Heart J. Mar. 2003;145(3):475-83. X-1,X-6,X-8. [pmid: 12660671].
3145 Villeneuve PJ, Burnett RT, Shi Y, et al. A time-series study of air pollution, socioeconomic status, and mortality in Vancouver, Canada. J Expo Anal Environ Epidemiol. Nov. 2003;13(6):427-35. X-1,X-5,X-6. [pmid: 14603343].
3146 Villuendas R, Kadish AH. Cardiac magnetic resonance for risk stratification: the sudden death risk portrayed. Prog Cardiovasc Dis. Sep-Oct. 2008;51(2):128-34. X-2,X-6. [pmid: 18774012].
3147 Vinereanu D. Risk factors for atherosclerotic disease: present and future. Herz. Dec. 3. 2006;31:5-24. X-1,X-2,X-4,X-5,X-6.
3148 Virani SS, Polsani VR, Nambi V. Novel markers of inflammation in atherosclerosis. Curr Atheroscler Rep. Apr. 2008;10(2):164-70. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18417072].
3149 Virdis A, Schiffrin EL. Vascular inflammation: a role in vascular disease in hypertension?. Curr Opin Nephrol Hypertens. Mar. 2003;12(2):181-7. X-1,X-4. [pmid: 12589179].
3150 Viskin S, Ish-Shalom M, Koifman E, et al. Ventricular flutter induced during electrophysiologic studies in patients with old myocardial infarction: clinical and electrophysiologic predictors, and prognostic significance. J Cardiovasc Electrophysiol. Sep. 2003;14(9):913-9. X-1,X-6,X-8. [pmid: 12950532].
3151 Viswanathan A, Rakich SM, Engel C, et al. Antiplatelet use after intracerebral hemorrhage. Neurology. Jan. 24. 2006;66(2):206-9. X-1,X-8. [pmid: 16434655].
3152 Vivekananthan DP, Bhatt DL, Chew DP, et al. Effect of clopidogrel pretreatment on periprocedural rise in C-reactive protein after percutaneous coronary intervention. Am J Cardiol. Aug. 1. 2004;94(3):358-60. X-1. [pmid: 15276105].
3153 Vlaar PJ, Rihal CS, Singh M, et al. Safety and efficacy of drug-eluting stent for ST-segment elevation myocardial infarction in an unselected consecutive cohort. Catheter Cardiovasc Interv. May. 1. 2008;71(6):764-9. X-1,X-2,X-8. [pmid: 18412074].
3154 Voetsch B, Benke KS, Damasceno BP, et al. Paraoxonase 192 Gln-->Arg polymorphism: an independent risk factor for nonfatal arterial ischemic stroke among young adults. Stroke. Jun. 2002;33(6):1459-64. X-1,X-2,X-5,X-8. [pmid: 12052975].
3155 Vogel RA. The changing view of hormone replacement therapy. Rev Cardiovasc Med. Spring. 2003;4(2):68-71. X-1,X-4. [pmid: 12776015].
3156 Vogel RA, Benitez RM. Noninvasive assessment of cardiovascular risk: from Framingham to the future. Rev Cardiovasc Med. Summer. 2000;1(1):34-42. X-2,X-4,X-5,X-6. [pmid: 12457150].
3157 Vojdani A. Antibodies as predictors of complex autoimmune diseases. Int J Immunopathol Pharmacol. Apr-Jun. 2008;21(2):267-78. X-1,X-2. [pmid: 18547471].
3158 Voko Z, Hollander M, Koudstaal PJ, et al. How do American stroke risk functions perform in a Western European population?. Neuroepidemiology. Sep-Oct. 2004;23(5):247-53. X-2. [pmid: 15316252].
3159 Volcik KA, Ballantyne CM, Braun MC, et al. Association of the complement factor H Y402H polymorphism with cardiovascular disease is dependent upon hypertension status: The ARIC study. Am J Hypertens. May. 2008;21(5):533-8. X-1. [pmid: 18292760].
3160 Volpato S, Guralnik JM, Ferrucci L, et al. Cardiovascular disease, interleukin-6, and risk of mortality in older women: the women's health and aging study. Circulation. Feb. 20. 2001;103(7):947-53. X-1,X-6. [pmid: 11181468].
3161 von Beckerath N, Koch W, Mehilli J, et al. Glycoprotein Ia C807T polymorphism and risk of restenosis following coronary stenting. Atherosclerosis. Jun. 2001;156(2):463-8. X-1,X-2,X-8. [pmid: 11395045].
3162 von Beckerath N, Schusterschitz Y, Koch W, et al. G protein beta 3 subunit 825T allele carriage and risk of coronary artery disease. Atherosclerosis. Mar. 2003;167(1):135-9. X-1,X-5,X-6. [pmid: 12618278].
3163 von Kummer R. Early major ischemic changes on computed tomography should preclude use of tissue plasminogen activator. Stroke. Mar. 2003;34(3):820-1. X-1. [pmid: 12624316].
3164 Vos LE, Oren A, Bots ML, et al. Does a routinely measured blood pressure in young adolescence accurately predict hypertension and total cardiovascular risk in young adulthood?. J Hypertens. Nov. 2003;21(11):2027-34. X-1,X-6. [pmid: 14597845].
3165 Vos LE, Oren A, Bots ML, et al. Birth size and coronary heart disease risk score in young adulthood. The Atherosclerosis Risk in Young Adults (ARYA) study. Eur J Epidemiol. 2006;21(1):33-8. X-1,X-2,X-6,X-9. [pmid: 16450204].
3166 Voss R, Cullen P, Schulte H, et al. Prediction of risk of coronary events in middle-aged men in the Prospective Cardiovascular Munster Study (PROCAM) using neural networks. Int J Epidemiol. Dec. 2002;31(6):1253-62. discussion 1262-64. X-1. [pmid: 12540731].
3167 Vrentzos GE, Papadakis JA, Ganotakis ES, et al. Predicting coronary heart disease risk using the Framingham and PROCAM equations in dyslipidaemic patients without overt vascular disease. Int J Clin Pract. Oct. 2007;61(10):1643-53. X-1G,X-2,X-5,X-6. [pmid: 17877651].
3168 Vukovich TC, Mustafa S, Rumpold H, et al. Evaluation of a turbidimetric Denka Seiken C-reactive protein assay for cardiovascular risk estimation and conventional inflammation diagnosis. Clin Chem. Mar. 2003;49(3):511-2. X-1F,X-2,X-5,X-6,X-7,X-8,X-9. [pmid: 12600971].
3169 Wachtell K, Okin PM, Olsen MH, et al. Regression of electrocardiographic left ventricular hypertrophy during antihypertensive therapy and reduction in sudden cardiac death: the LIFE Study. Circulation. Aug. 14. 2007;116(7):700-5. X-1,X-2,X-6. [pmid: 17664372].
3170 Wackers FJ. Diabetes and coronary artery disease: the role of stress myocardial perfusion imaging. Cleve Clin J Med. Jan. 2005;72(1):21-5. 29. 33. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 15691055].
3171 Waggoner JR 3rd, Wass CT, Polis TZ, et al. The effect of changing transfusion practice on rates of perioperative stroke and myocardial infarction in patients undergoing carotid endarterectomy: a retrospective analysis of 1114 Mayo Clinic patients. Mayo Perioperative Outcomes Group. Mayo Clin Proc. Apr. 2001;76(4):376-83. X-1,X-6,X-8. [pmid: 11322353].
3172 Wagner J, Lacey K, Chyun D, et al. Development of a questionnaire to measure heart disease risk knowledge in people with diabetes: the Heart Disease Fact Questionnaire. Patient Educ Couns. Jul. 2005;58(1):82-7. X-1,X-5,X-6. [pmid: 15950840].
3173 Wahl A, Paetsch I, Roethemeyer S, et al. High-dose dobutamine-atropine stress cardiovascular MR imaging after coronary revascularization in patients with wall motion abnormalities at rest. Radiology. Oct. 2004;233(1):210-6. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 15304662].
3174 Waisbren EC, Stevens LM, Avery EG, et al. Changes in mitral regurgitation after replacement of the stenotic aortic valve. Ann Thorac Surg. Jul. 2008;86(1):56-62. X-1,X-2,X-5,X-6,X-8. [pmid: 18573398].
3175 Walldius G, Aastveit AH, Jungner I. Stroke mortality and the apoB/apoA-I ratio: results of the AMORIS prospective study. J Intern Med. Mar. 2006;259(3):259-66. X-2. [pmid: 16476103].
3176 Wallis EJ, Ramsay LE, Haq IU, et al. Is coronary risk an accurate surrogate for cardiovascular risk for treatment decisions in mild hypertension? A population validation. J Hypertens. Apr. 2001;19(4):691-6. X-1F,X-2,X-5,X-6. [pmid: 11330871].
3177 Wallis EJ, Ramsay LE, Ul Haq I, et al. Coronary and cardiovascular risk estimation for primary prevention: validation of a new Sheffield table in the 1995 Scottish health survey population. BMJ. Mar. 11. 2000;320(7236):671-6. X-1,X-2,X-5,X-6. [pmid: 10710573].
3178 Wallner S, Watzinger N, Lindschinger M, et al. Effects of intensified lifestyle modification on the need for further revascularization after coronary angioplasty. Eur J Clin Invest. May. 1999;29(5):372-9. X-1,X-6,X-8. [pmid: 10354193].
3179 Walsh JP, Bremner AP, Bulsara MK, et al. Subclinical thyroid dysfunction as a risk factor for cardiovascular disease. Arch Intern Med. Nov. 28. 2005;165(21):2467-72. X-5,X-8. [pmid: 16314542].
3180 Wan Q, Harris MF, Jayasinghe UW, et al. Quality of diabetes care and coronary heart disease absolute risk in patients with type 2 diabetes mellitus in Australian general practice. Qual Saf Health Care. Apr. 2006;15(2):131-5. X-1,X-2,X-6. [pmid: 16585115].
3181 Wanby P, Palmquist P, Brudin L, et al. Genetic variation of the intestinal fatty acid-binding protein 2 gene in carotid atherosclerosis. Vasc Med. May. 2005;10(2):103-8. X-1,X-6,X-7,X-8. [pmid: 16013194].
3182 Wang AY, Lam CW, Wang M, et al. Prognostic value of cardiac troponin T is independent of inflammation, residual renal function, and cardiac hypertrophy and dysfunction in peritoneal dialysis patients. Clin Chem. May. 2007;53(5):882-9. X-1. [pmid: 17395709].
3183 Wang FW, Uretsky BF, Freeman JL, et al. Survival advantage in Medicare patients receiving drug-eluting stents compared with bare metal stents: real or artefactual?. Catheter Cardiovasc Interv. Apr. 1. 2008;71(5):636-43. X-1,X-2,X-6,X-8. [pmid: 18360856].
3184 Wang H, Sekine M, Yokokawa H, et al. The relationship between new stroke onset and serum thiocyanate as an indicator to cigarette smoking. J Epidemiol. Sep. 2001;11(5):233-7. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 11579932].
3185 Wang J, Zhang S, Jin Y, et al. Elevated levels of platelet-monocyte aggregates and related circulating biomarkers in patients with acute coronary syndrome. Int J Cardiol. Feb. 14. 2007;115(3):361-5. X-1,X-5,X-6,X-7. [pmid: 16887214].
3186 Wang JJ, Liew G, Wong TY, et al. Retinal vascular calibre and the risk of coronary heart disease-related death. Heart. Nov. 2006;92(11):1583-7. X-1F,X-2,X-8. [pmid: 16840510].
3187 Wang TD, Lee CM, Wu CC, et al. The effects of dyslipidemia on left ventricular systolic function in patients with stable angina pectoris. Atherosclerosis. Sep. 1999;146(1):117-24. X-1,X-6,X-7,X-8. [pmid: 10487494].
3188 Wang TJ, Evans JC, Benjamin EJ, et al. Natural history of asymptomatic left ventricular systolic dysfunction in the community. Circulation. Aug. 26. 2003;108(8):977-82. X-1,X-6,X-8. [pmid: 12912813].
3189 Wang TJ, Gona P, Larson MG, et al. Multiple biomarkers for the prediction of first major cardiovascular events and death. N Engl J Med. Dec. 21. 2006;355(25):2631-9. X-1F,X-8(3-9%). [pmid: 17182988].
3190 Wang TJ, Massaro JM, Levy D, et al. A risk score for predicting stroke or death in individuals with new-onset atrial fibrillation in the community: the Framingham Heart Study. JAMA. Aug. 27. 2003;290(8):1049-56. X-2. [pmid: 12941677].
3191 Wang Y, Lim LL, Heller RF, et al. A prediction model of 1-year mortality for acute ischemic stroke patients. Arch Phys Med Rehabil. Jul. 2003;84(7):1006-11. X-1,X-6,X-8. [pmid: 12881825].
3192 Wang Z, Rowley K, Piers L, et al. Anthropometric indices and their relationship with diabetes, hypertension and dyslipidemia in Australian Aboriginal people and Torres Strait Islanders. Eur J Cardiovasc Prev Rehabil. Apr. 2007;14(2):172-8. X-1E,X-1F,X-1G,X-2,X-5,X-6. [pmid: 17446794].
3193 Wannamethee SG, Shaper AG. Taking up regular drinking in middle age: effect on major coronary heart disease events and mortality. Heart. Jan. 2002;87(1):32-6. X-2,X-8. [pmid: 11751661].
3194 Wannamethee SG, Shaper AG, Lennon L, et al. Height loss in older men: associations with total mortality and incidence of cardiovascular disease. Arch Intern Med. Dec. 11-25. 2006;166(22):2546-52. X-1,X-2. [pmid: 17159023].
3195 Warensjo E, Sundstrom J, Vessby B, et al. Markers of dietary fat quality and fatty acid desaturation as predictors of total and cardiovascular mortality: a population-based prospective study. Am J Clin Nutr. Jul. 2008;88(1):203-9. X-1,X-2. [pmid: 18614742].
3196 Warner MM, Guo J, Zhao Y. The relationship between plasma apolipoprotein A-IV levels and coronary heart disease. Chin Med J (Engl). Mar. 2001;114(3):275-9. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 11780313].
3197 Warren MP. A comparative review of the risks and benefits of hormone replacement therapy regimens. Am J Obstet Gynecol. Apr. 2004;190(4):1141-67. X-1,X-2,X-4,X-5,X-6. [pmid: 15118656].
3198 Watanabe H, Tanabe N, Makiyama Y, et al. ST-segment abnormalities and premature complexes are predictors of new-onset atrial fibrillation: the Niigata preventive medicine study. Am Heart J. Oct. 2006;152(4):731-5. X-1,X-6. [pmid: 16996849].
3199 Watanabe K, Ohsumi Y, Abe H, et al. Benefits of quantitative gated SPECT in evaluation of perioperative cardiac risk in noncardiac surgery. Ann Nucl Med. Dec. 2007;21(10):563-8. X-1,X-2,X-7. [pmid: 18092132].
3200 Watanabe Y, Ozasa K, Ito Y, et al. Medical history of circulatory diseases and colorectal cancer death in the JACC Study. J Epidemiol. Jun. 2. 2005;15:S168-72. X-1,X-6,X-8. [pmid: 16127229].
3201 Waterhouse DF, Cahill RA, Sheehan F, et al. Prediction of calculated future cardiovascular disease by monocyte count in an asymptomatic population. Vasc Health Risk Manag. 2008;4(1):177-87. X-1F,X-1G,X-2,X-5,X-6. [pmid: 18629357].
3202 Waterhouse DF, Cahill RA, Sheehan F, et al. Concomitant detection of systemic atherosclerotic disease while screening for abdominal aortic aneurysm. World J Surg. Jul. 2006;30(7):1350-9. X-2,X-5,X-6. [pmid: 16773254].
3203 Waters DD, Schwartz GG, Olsson AG, et al. Effects of atorvastatin on stroke in patients with unstable angina or non-Q-wave myocardial infarction: a Myocardial Ischemia Reduction with Aggressive Cholesterol Lowering (MIRACL) substudy. Circulation. Sep. 24. 2002;106(13):1690-5. X-1,X-8. [pmid: 12270864].
3204 Wattanasuwan N, Khan IA, Gowda RM, et al. Effect of acute myocardial infarction on cholesterol ratios. Chest. Oct. 2001;120(4):1196-9. X-1,X-2,X-6,X-7,X-8. [pmid: 11591560].
3205 Waugh N, Black C, Walker S, et al. The effectiveness and cost-effectiveness of computed tomography screening for coronary artery disease: systematic review. Health Technol Assess. Oct. 2006;10(39):iii-iv. ix. x. 1. 41. X-1,X-2,X-4,X-5.
3206 Weatherley BD, Nelson JJ, Heiss G, et al. The association of the ankle-brachial index with incident coronary heart disease: the Atherosclerosis Risk In Communities (ARIC) study, 1987-2001. BMC Cardiovasc Disord. 2007;7:3. X-1F,X-2. [pmid: 17227586].
3207 Weber T, Auer J, Lamm G, et al. Arterial stiffness, central blood pressures, and wave reflections in cardiomyopathy-implications for risk stratification. J Card Fail. Jun. 2007;13(5):353-9. X-1,X-5,X-6,X-7. [pmid: 17602981].
3208 Wechsler LR, Roberts R, Furlan AJ, et al. Factors influencing outcome and treatment effect in PROACT II. Stroke. May. 2003;34(5):1224-9. X-1,X-6. [pmid: 12677011].
3209 Weeks WB, Bazos DA, Bott DM, et al. New York's statistical model accurately predicts mortality risk for veterans who obtain private sector CABG. Health Serv Res. Aug. 2005;40(4):1186-96. X-1,X-8. [pmid: 16033499].
3210 Wei L, MacDonald TM, Watson AD, et al. Effectiveness of two statin prescribing strategies with respect to adherence and cardiovascular outcomes: observational study. Pharmacoepidemiol Drug Saf. Apr. 2007;16(4):385-92. X-1. [pmid: 16998946].
3211 Weimar C, Diener HC, Alberts MJ, et al. The Essen stroke risk score predicts recurrent cardiovascular events: a validation within the REduction of Atherothrombosis for Continued Health (REACH) registry. Stroke. Feb. 2009;40(2):350-4. X-1,X-8. [pmid: 19023098].
3212 Weimar C, Goertler M, Rother J, et al. Predictive value of the Essen Stroke Risk Score and Ankle Brachial Index in acute ischaemic stroke patients from 85 German stroke units. J Neurol Neurosurg Psychiatry. Dec. 2008;79(12):1339-43. X-1,X-2,X-8. [pmid: 18586863].
3213 Weimar C, Goertler M, Rother J, et al. Systemic risk score evaluation in ischemic stroke patients (SCALA): a prospective cross sectional study in 85 German stroke units. J Neurol. Nov. 2007;254(11):1562-8. X-5,X-6,X-8. [pmid: 17668260].
3214 Weintraub WS. Is an invasive interventional strategy of value in non-ST-elevation acute coronary syndromes?. Nat Clin Pract Cardiovasc Med. Dec. 2008;5(12):754-5. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18838964].
3215 Weintraub WS, Mahoney EM, Ghazzal ZM, et al. Trends in outcome and costs of coronary intervention in the 1990s. Am J Cardiol. Sep. 1. 2001;88(5):497-503. X-1,X-2,X-6,X-8. [pmid: 11524057].
3216 Weir CJ, Muir SW, Walters MR, et al. Serum urate as an independent predictor of poor outcome and future vascular events after acute stroke. Stroke. Aug. 2003;34(8):1951-6. X-1,X-2,X-6,X-8. [pmid: 12843346].
3217 Weir N, Dennis MS. Towards a national system for monitoring the quality of hospital-based stroke services. Stroke. Jun. 2001;32(6):1415-21. X-1,X-2,X-6,X-8. [pmid: 11387507].
3218 Weisfeldt ML, Zieman SJ. Advances in the prevention and treatment of cardiovascular disease. Health Aff (Millwood). Jan-Feb. 2007;26(1):25-37. X-1,X-2,X-4,X-5,X-6,X-7,X-8,X-9. [pmid: 17211011].
3219 Weiss ES, Chang DD, Joyce DL, et al. Optimal timing of coronary artery bypass after acute myocardial infarction: a review of California discharge data. J Thorac Cardiovasc Surg. Mar. 2008;135(3):503-11. 511 e1. 3. X-1,X-2,X-6,X-8. [pmid: 18329460].
3220 Welborn TA, Knuiman MW, Vu HT. Body mass index and alternative indices of obesity in relation to height, triceps skinfold and subsequent mortality: the Busselton health study. Int J Obes Relat Metab Disord. Jan. 2000;24(1):108-15. X-1,X-5,X-6. [pmid: 10702759].
3221 Wells RG, Vetter C, Laud P. Intracranial hemorrhage in children younger than 3 years: prediction of intent. Arch Pediatr Adolesc Med. Mar. 2002;156(3):252-7. X-1. [pmid: 11876669].
3222 Welty FK, Lewis SM, Kowalker W, et al. Reasons for higher in-hospital mortality >24 hours after percutaneous transluminal coronary angioplasty in women compared with men. Am J Cardiol. Sep. 1. 2001;88(5):473-7. X-1,X-8. [pmid: 11524052].
3223 Wen CP, Tsai SP, Chen CJ, et al. The mortality risks of smokers in Taiwan: Part I: cause-specific mortality. Prev Med. Sep. 2004;39(3):528-35. X-1. [pmid: 15313092].
3224 Wennberg DE, Makenka DJ, Sengupta A, et al. Percutaneous transluminal coronary angioplasty in the elderly: epidemiology, clinical risk factors, and in-hospital outcomes. The Northern New England Cardiovascular Disease Study Group. Am Heart J. Apr. 1999;137(4 Pt 1):639-45. X-1,X-6,X-8. [pmid: 10223895].
3225 Werner GS. Simultaneous Doppler and pressure recordings to assess microvascular dysfunction in chronic total coronary occlusions--potential for recovery during follow-up. Z Kardiol. 3. 2002;91:120-5. X-1,X-6. [pmid: 12641026].
3226 Werner N, Wassmann S, Ahlers P, et al. Endothelial progenitor cells correlate with endothelial function in patients with coronary artery disease. Basic Res Cardiol. Nov. 2007;102(6):565-71. X-1,X-2,X-6,X-7,X-8. [pmid: 17932708].
3227 Wesorick DH, Eagle KA. The preoperative cardiovascular evaluation of the intermediate-risk patient: new data, changing strategies. Am J Med. Dec. 2005;118(12):1413. X-1,X-2,X-4,X-5,X-6,X-7,X-8.
3228 West JC, Napoliello DA, Costello JM, et al. Preoperative dobutamine stress echocardiography versus cardiac arteriography for risk assessment prior to renal transplantation. Transpl Int. 1. 2000;13:S27-30. X-2,X-7. [pmid: 11111956].
3229 Westerhout CM, Fu Y, Lauer MS, et al. Short- and long-term risk stratification in acute coronary syndromes: the added value of quantitative ST-segment depression and multiple biomarkers. J Am Coll Cardiol. Sep. 5. 2006;48(5):939-47. X-1D,X-8(100%). [pmid: 16949483].
3230 Westin L, Nilstun T, Carlsson R, et al. Patients with ischemic heart disease: quality of life predicts long-term mortality. Scand Cardiovasc J. Apr. 2005;39(1-2):50-4. X-1,X-8. [pmid: 16097414].
3231 Wexberg P, Pacher R, Rodler S, et al. Intimal hyperplasia and coronary flow reserve after heart transplantation: association with big endothelin-1. J Heart Lung Transplant. Dec. 2002;21(12):1257-63. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 12490270].
3232 Weyman AE. The year in echocardiography. J Am Coll Cardiol. Mar. 20. 2007;49(11):1212-9. X-1. [pmid: 17367666].
3233 White CM, Sander S, Coleman CI, et al. Impact of epicardial anterior fat pad retention on postcardiothoracic surgery atrial fibrillation incidence: the AFIST-III Study. J Am Coll Cardiol. Jan. 23. 2007;49(3):298-303. X-1,X-2,X-6,X-7,X-8. [pmid: 17239710].
3234 White HD, Palmeri ST, Sleeper LA, et al. Electrocardiographic findings in cardiogenic shock, risk prediction, and the effects of emergency revascularization: results from the SHOCK trial. Am Heart J. Nov. 2004;148(5):810-7. X-1,X-7,X-8. [pmid: 15523311].
3235 Whitfield MD, Gillett M, Holmes M, et al. Predicting the impact of population level risk reduction in cardio-vascular disease and stroke on acute hospital admission rates over a 5 year period--a pilot study. Public Health. Dec. 2006;120(12):1140-8. X-1,X-2,X-5,X-6. [pmid: 17084425].
3236 Whitmer RA, Sidney S, Selby J, et al. Midlife cardiovascular risk factors and risk of dementia in late life. Neurology. Jan. 25. 2005;64(2):277-81. X-1,X-6. [pmid: 15668425].
3237 Whooley MA, Kiefe CI, Chesney MA, et al. Depressive symptoms, unemployment, and loss of income: The CARDIA Study. Arch Intern Med. Dec. 9-23. 2002;162(22):2614-20. X-1,X-6. [pmid: 12456234].
3238 Wichterle D, Camm AJ, Malik M. Turbulence slope after atrial premature complexes is an independent predictor of mortality in survivors of acute myocardial infarction. J Cardiovasc Electrophysiol. Dec. 2004;15(12):1350-6. X-1,X-8. [pmid: 15610277].
3239 Wichterle D, Simek J, Camm J, et al. Predictive characteristics of holter-based postinfarction risk stratifiers appear superior to electrophysiological testing. Pacing Clin Electrophysiol. Jan. 1. 2005;28:S182-6. X-1,X-8. [pmid: 15683492].
3240 Wichterle D, Simek J, La Rovere MT, et al. Prevalent low-frequency oscillation of heart rate: novel predictor of mortality after myocardial infarction. Circulation. Sep. 7. 2004;110(10):1183-90. X-1,X-6,X-8. [pmid: 15313954].
3241 Wijeysundera DN, Karkouti K, Dupuis JY, et al. Derivation and validation of a simplified predictive index for renal replacement therapy after cardiac surgery. JAMA. Apr. 25. 2007;297(16):1801-9. X-1,X-6. [pmid: 17456822].
3242 Wijnhoud AD, Franckena M, van der Lugt A, et al. Inadequate acoustical temporal bone window in patients with a transient ischemic attack or minor stroke: role of skull thickness and bone density. Ultrasound Med Biol. Jun. 2008;34(6):923-9. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18243493].
3243 Wilhelmsen L, Pyorala K, Wedel H, et al. Risk factors for a major coronary event after myocardial infarction in the Scandinavian Simvastatin Survival Study (4S). Impact of predicted risk on the benefit of cholesterol-lowering treatment. Eur Heart J. Jul. 2001;22(13):1119-27. X-1,X-2,X-8. [pmid: 11428852].
3244 Will BP, Nobrega KM, Berthelot JM, et al. First do no harm: extending the debate on the provision of preventive tamoxifen. Br J Cancer. Nov. 2. 2001;85(9):1280-8. X-1,X-4,X-5,X-6. [pmid: 11720461].
3245 Williams DO, Abbott JD, Kip KE. Outcomes of 6906 patients undergoing percutaneous coronary intervention in the era of drug-eluting stents: report of the DEScover Registry. Circulation. Nov. 14. 2006;114(20):2154-62. X-1,X-2,X-6,X-8. [pmid: 17060386].
3246 Williams GR, Jiang JG. Development of an ischemic stroke survival score. Stroke. Oct. 2000;31(10):2414-20. X-1,X-8. [pmid: 11022073].
3247 Williams JE, Nieto FJ, Sanford CP, et al. Effects of an angry temperament on coronary heart disease risk : The Atherosclerosis Risk in Communities Study. Am J Epidemiol. Aug. 1. 2001;154(3):230-5. X-1F,X-2. [pmid: 11479187].
3248 Williams ML, Morris MT 2nd, Ahmad U, et al. Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center. Ethn Dis. Winter. 2002;12(1):S1-58-62. X-1,X-2,X-6,X-8.
3249 Williams PT. The illusion of improved physical fitness and reduced mortality. Med Sci Sports Exerc. May. 2003;35(5):736-40. X-1,X-5,X-6. [pmid: 12750581].
3250 Wilsgaard T, Jacobsen BK, Schirmer H, et al. Tracking of cardiovascular risk factors: the Tromso study, 1979-1995. Am J Epidemiol. Sep. 1. 2001;154(5):418-26. X-6. [pmid: 11532783].
3251 Wilson AM, Kimura E, Harada RK, et al. Beta2-microglobulin as a biomarker in peripheral arterial disease: proteomic profiling and clinical studies. Circulation. Sep. 18. 2007;116(12):1396-403. X-1,X-5,X-6,X-7. [pmid: 17724262].
3252 Wilson AM, Ryan MC, Boyle AJ. The novel role of C-reactive protein in cardiovascular disease: risk marker or pathogen. Int J Cardiol. Jan. 26. 2006;106(3):291-7. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 16337036].
3253 Wilson PW, D'Agostino RB, Parise H, et al. Metabolic syndrome as a precursor of cardiovascular disease and type 2 diabetes mellitus. Circulation. Nov. 15. 2005;112(20):3066-72. X-1F,X-2. [pmid: 16275870].
3254 Wilson PW, Nam BH, Pencina M, et al. C-reactive protein and risk of cardiovascular disease in men and women from the Framingham Heart Study. Arch Intern Med. Nov. 28. 2005;165(21):2473-8. X-1F. [pmid: 16314543].
3255 Wilson PW, Narayan KM. Low-cost strategies to predict cardiovascular disease. Nat Clin Pract Cardiovasc Med. Sep. 2008;5(9):518-9. X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 18628774].
3256 Wilson S, Johnston A, Robson J, et al. Predicting coronary risk in the general population--is it necessary to measure high-density lipoprotein cholesterol?. J Cardiovasc Risk. Apr. 2003;10(2):137-41. X-1F,X-2,X-5,X-6,X-8. [pmid: 12668911].
3257 Windhagen-Mahnert B, Kadish AH. Application of noninvasive and invasive tests for risk assessment in patients with ventricular arrhythmias. Cardiol Clin. May. 2000;18(2):243-63. vii. X-5. [pmid: 10849872].
3258 Windhausen F, Hirsch A, Sanders GT, et al. N-terminal pro-brain natriuretic peptide for additional risk stratification in patients with non-ST-elevation acute coronary syndrome and an elevated troponin T: an Invasive versus Conservative Treatment in Unstable coronary Syndromes (ICTUS) substudy. Am Heart J. Apr. 2007;153(4):485-92. X-1,X-8. [pmid: 17383283].
3259 Windhausen F, Hirsch A, Tijssen JG, et al. ST-segment deviation on the admission electrocardiogram, treatment strategy, and outcome in non-ST-elevation acute coronary syndromes A substudy of the Invasive versus Conservative Treatment in Unstable coronary Syndromes (ICTUS) Trial. J Electrocardiol. Sep-Oct. 2007;40(5):408-15. X-1,X-8. [pmid: 17604045].
3260 Winkelmayer WC, Glynn RJ, Levin R, et al. Determinants of delayed nephrologist referral in patients with chronic kidney disease. Am J Kidney Dis. Dec. 2001;38(6):1178-84. X-1,X-2,X-5,X-6. [pmid: 11728948].
3261 Wintermark M, Dillon WP, Smith WS, et al. Visual grading system for vasospasm based on perfusion CT imaging: comparisons with conventional angiography and quantitative perfusion CT. Cerebrovasc Dis. 2008;26(2):163-70. X-1,X-2,X-7,X-8. [pmid: 18560220].
3262 Wison S, Foo K, Cunningham J, et al. Renal function and risk stratification in acute coronary syndromes. Am J Cardiol. May. 1. 2003;91(9):1051-4. X-1,X-6. [pmid: 12714145].
3263 Witczak B, Hartmann A, Svennevig JL. Multiple risk assessment of cardiovascular surgery in chronic renal failure patients. Ann Thorac Surg. Apr. 2005;79(4):1297-302. X-1,X-2,X-5,X-7,X-8. [pmid: 15797066].
3264 Witt N, Wong TY, Hughes AD, et al. Abnormalities of retinal microvascular structure and risk of mortality from ischemic heart disease and stroke. Hypertension. May. 2006;47(5):975-81. X-1,X-2,X-5,X-8. [pmid: 16585415].
3265 Wittkowski KM, Haider A, Sehayek E, et al. Bioinformatics tools enabling u-statistics for microarrays. Conf Proc IEEE Eng Med Biol Soc. 2006;1:3464-9. X-1,X-2,X-4,X-5,X-6,X-7,X-8. [pmid: 17947031].
3266 Wittlinger T, Martinovic I, Moosdorf R, et al. Imaging of calcified coronary arteries with multislice computed tomography. Asian Cardiovasc Thorac Ann. Aug. 2006;14(4):321-7. X-1,X-6,X-7. [pmid: 16868107].
3267 Wiviott SD, Morrow DA, Frederick PD, et al. Application of the Thrombolysis in Myocardial Infarction risk index in non-ST-segment elevation myocardial infarction: evaluation of patients in the National Registry of Myocardial Infarction. J Am Coll Cardiol. Apr. 18. 2006;47(8):1553-8. X-1,X-8. [pmid: 16630990].
3268 Wiviott SD, Morrow DA, Frederick PD, et al. Performance of the thrombolysis in myocardial infarction risk index in the National Registry of Myocardial Infarction-3 and -4: a simple index that predicts mortality in ST-segment elevation myocardial infarction. J Am Coll Cardiol. Aug. 18. 2004;44(4):783-9. X-1,X-8. [pmid: 15312859].
3269 Woertgen C, Ullrich OW, Rothoerl RD, et al. Comparison of the Claassen and Fisher CT classification scale to predict ischemia after aneurysmatic SAH?. Zentralbl Neurochir. 2003;64(3):104-8. X-1,X-6. [pmid: 12975744].
3270 Wojner AW, Alexandrov AV. Predictors of tube feeding in acute stroke patients with dysphagia. AACN Clin Issues. Nov. 2000;11(4):531-40. X-1,X-6,X-8. [pmid: 11288417].
3271 Wolak A, Ayzenberg Y, Cafri C, et al. Can enoxaparin safely replace unfractionated heparin during coronary intervention in acute coronary syndromes?. Int J Cardiol. Aug. 2004;96(2):151-5. X-1,X-2,X-6,X-7,X-8. [pmid: 15262028].
3272 Wolak A, Yaroslavtsev S, Amit G, et al. Grade 3 ischemia on the admission electrocardiogram predicts failure of ST resolution and of adequate flow restoration after primary percutaneous coronary intervention for acute myocardial infarction. Am Heart J. Mar. 2007;153(3):410-7. X-1,X-6,X-7,X-8. [pmid: 17307421].
3273 Wolber T, Maeder M, Weilenmann D, et al. Integration of B-type natriuretic peptide levels with clinical data and exercise testing for predicting coronary artery disease. Am J Cardiol. Sep. 15. 2006;98(6):764-7. X-1,X-5,X-7,X-8. [pmid: 16950181].
3274 Wolf R, Habel F, Heiermann M, et al. Cardiac risk of coronary patients after reintegration into occupations with heavy physical exertion. Z Kardiol. Apr. 2005;94(4):265-73. X-1,X-7,X-8. [pmid: 15803263].
3275 Wolf SL, Catlin PA, Ellis M, et al. Assessing Wolf motor function test as outcome measure for research in patients after stroke. Stroke. Jul. 2001;32(7):1635-9. X-1,X-2,X-6,X-7,X-8. [pmid: 11441212].
3276 Wolk R, Berger P, Lennon RJ, et al. Body mass index: a risk factor for unstable angina and myocardial infarction in patients with angiographically confirmed coronary artery disease. Circulation. Nov. 4. 2003;108(18):2206-11. X-1,X-6,X-8. [pmid: 14557360].
3277 Wong CF, Little MA, Vinjamuri S, et al. Technetium myocardial perfusion scanning in prerenal transplant evaluation in the United kingdom. Transplant Proc. Jun. 2008;40(5):1324-8. X-1,X-2,X-5,X-6,X-7. [pmid: 18589097].
3278 Wong CW, Christen T, Pfenniger A, et al. Do allelic variants of the connexin37 1019 gene polymorphism differentially predict for coronary artery disease and myocardial infarction?. Atherosclerosis. Apr. 2007;191(2):355-61. X-1,X-5,X-8. [pmid: 16677656].
3279 Wong DT, Cheng DC, Kustra R, et al. Risk factors of delayed extubation, prolonged length of stay in the intensive care unit, and mortality in patients undergoing coronary artery bypass graft with fast-track cardiac anesthesia: a new cardiac risk score. Anesthesiology. Oct. 1999;91(4):936-44. X-1,X-6,X-8. [pmid: 10519495].
3280 Wong E, Freiberg M, Tracy R, et al. Epidemiology of cytokines: the Women On the Move through Activity and Nutrition (WOMAN) Study. Am J Epidemiol. Aug. 15. 2008;168(4):443-53. X-1,X-6. [pmid: 18579536].
3281 Wong KS, Li H. Long-term mortality and recurrent stroke risk among Chinese stroke patients with predominant intracranial atherosclerosis. Stroke. Oct. 2003;34(10):2361-6. X-1F,X-2,X-8. [pmid: 12947158].
3282 Wong KY, McSwiggan S, Kennedy NS, et al. B-type natriuretic peptide identifies silent myocardial ischaemia in stroke survivors. Heart. Apr. 2006;92(4):487-9. X-1,X-5,X-6,X-7,X-8. [pmid: 16216865].
3283 Wong ND, Gransar H, Shaw LJ, et al. Comparison of atherosclerotic calcification burden in persons with the cardiometabolic syndrome and diabetes. J Cardiometab Syndr. Spring. 2006;1(2):90-4. X-1,X-2,X-6. [pmid: 17679823].
3284 Wong ND, Sciammarella M, Arad Y, et al. Relation of thoracic aortic and aortic valve calcium to coronary artery calcium and risk assessment. Am J Cardiol. Oct. 15. 2003;92(8):951-5. X-1,X-5,X-6. [pmid: 14556872].
3285 Wong TY. Is retinal photography useful in the measurement of stroke risk?. Lancet Neurol. Mar. 2004;3(3):179-83. X-1,X-2,X-4,X-5,X-6. [pmid: 15029894].
3286 Wong YK, Dawkins S, Grimes R, et al. Improving the positive predictive value of exercise testing in women. Heart. Dec. 2003;89(12):1416-21. X-1,X-5,X-8. [pmid: 14617551].
3287 Woo D, Sauerbeck LR, Kissela BM, et al. Genetic and environmental risk factors for intracerebral hemorrhage: preliminary results of a population-based study. Stroke. May. 2002;33(5):1190-5. X-1,X-2,X-5,X-8. [pmid: 11988589].
3288 Woo YM, McLean D, Kavanagh D, et al. The influence of pre-operative electrocardiographic abnormalities and cardiovascular risk factors on patient and graft survival following renal transplantation. J Nephrol. Jul-Aug. 2002;15(4):380-6. X-1,X-2,X-6,X-8. [pmid: 12243367].
3289 Wood GN, Keevil B, Gupta J, et al. Serum troponin T measurement in patients with chronic renal impairment predicts survival and vascular disease: a 2 year prospective study. Nephrol Dial Transplant. Aug. 2003;18(8):1610-5. X-1,X-2,X-7. [pmid: 12897102].
3290 Woods SE, Noble G, Smith JM, et al. The influence of gender in patients undergoing coronary artery bypass graft surgery: an eight-year prospective hospitalized cohort study. J Am Coll Surg. Mar. 2003;196(3):428-34. X-1,X-6,X-8. [pmid: 12648695].
3291 Worthley MI, Unger SA, Mathew TH, et al. Usefulness of tachycardic-stress perfusion imaging to predict coronary artery disease in high-risk patients with chronic renal failure. Am J Cardiol. Dec. 1. 2003;92(11):1318-20. X-5,X-6. [pmid: 14636911].
3292 Wouters SC, Noyez L, Verheugt FW, et al. Preoperative prediction of early mortality and morbidity in coronary bypass surgery. Cardiovasc Surg. Oct. 2002;10(5):500-5. X-1,X-8. [pmid: 12379410].
3293 Wu AH, Aaronson KD, Bolling SF, et al. Impact of mitral valve annuloplasty on mortality risk in patients with mitral regurgitation and left ventricular systolic dysfunction. J Am Coll Cardiol. Feb. 1. 2005;45(3):381-7. X-1,X-8. [pmid: 15680716].
3294 Wu C, Hannan EL, Walford G, et al. A risk score to predict in-hospital mortality for percutaneous coronary interventions. J Am Coll Cardiol. Feb. 7. 2006;47(3):654-60. X-1,X-8. [pmid: 16458151].
3295 Wu C, Hannan EL, Walford G, et al. Utilization and outcomes of unprotected left main coronary artery stenting and coronary artery bypass graft surgery. Ann Thorac Surg. Oct. 2008;86(4):1153-9. X-1,X-2,X-5,X-8. [pmid: 18805151].
3296 Wu EB, Hodson F, Chambers JB. A simple score for predicting coronary artery disease in patients with chest pain. QJM. Nov. 2005;98(11):803-11. X-1C,X-5,X-6,X-8(CAD). [pmid: 16234250].
3297 Wu HY, Chen LL, Zheng J, et al. Simple anthropometric indices in relation to cardiovascular risk factors in Chinese type 2 diabetic patients. Chin J Physiol. Jun. 30. 2007;50(3):135-42. X-6. [pmid: 17867434].
3298 Wu MT, Yang P, Huang YL, et al. Coronary arterial calcification on low-dose ungated MDCT for lung cancer screening: concordance study with dedicated cardiac CT. AJR Am J Roentgenol. Apr. 2008;190(4):923-8. X-1,X-2,X-6. [pmid: 18356438].
3299 Wu O, Koroshetz WJ, Ostergaard L, et al. Predicting tissue outcome in acute human cerebral ischemia using combined diffusion- and perfusion-weighted MR imaging. Stroke. Apr. 2001;32(4):933-42. X-1,X-8. [pmid: 11283394].
3300 Wu Y, Furnary AP, Grunkemeier GL. Using the National Death Index to validate the noninformative censoring assumption of survival estimation. Ann Thorac Surg. Apr. 2008;85(4):1256-60. X-1,X-2,X-5,X-6,X-8. [pmid: 18355506].
3301 Wu Y, Grunkemeier GL, Handy JR Jr. Coronary artery bypass grafting: are risk models developed from on-pump surgery valid for off-pump surgery?. J Thorac Cardiovasc Surg. Jan. 2004;127(1):174-8. X-1,X-6,X-8. [pmid: 14752428].
3302 Wu YW, Tadamura E, Kanao S, et al. Left ventricular functional analysis using 64-slice multidetector row computed tomography: comparison with left ventriculography and cardiovascular magnetic resonance. Cardiology. 2008;109(2):135-42. X-1,X-2,X-6,X-7,X-8. [pmid: 17713329].
3303 Wu ZK, Iivainen T, Pehkonen E, et al. Fibrillation in patients subjected to coronary artery bypass grafting. J Thorac Cardiovasc Surg. Nov. 2003;126(5):1477-82. X-1,X-5,X-6,X-7,X-8. [pmid: 14666022].
3304 Wylie JV, Murphy SA, Morrow DA, et al. Validated risk score predicts the development of congestive heart failure after presentation with unstable angina or non-ST-elevation myocardial infarction: results from OPUS-TIMI 16 and TACTICS-TIMI 18. Am Heart J. Jul. 2004;148(1):173-80. X-1,X-8. [pmid: 15215808].
3305 Wynne R. Variable definitions: implications for the prediction of pulmonary complications after adult cardiac surgery. Eur J Cardiovasc Nurs. Apr. 2004;3(1):43-52. X-1,X-5,X-6. [pmid: 15053887].
3306 Wynne-Jones K, Jackson M, Grotte G, et al. Limitations of the Parsonnet score for measuring risk stratified mortality in the north west of England. The North West Regional Cardiac Surgery Audit Steering Group. Heart. Jul. 2000;84(1):71-8. X-1,X-6,X-8. [pmid: 10862595].
3307 Xu G, Liu X, Wu W, et al. Recurrence after ischemic stroke in Chinese patients: impact of uncontrolled modifiable risk factors. Cerebrovasc Dis. 2007;23(2-3):117-20. X-1,X-2,X-8. [pmid: 17124391].
3308 Xu J, Eilat-Adar S, Loria C, et al. Dietary fat intake and risk of coronary heart disease: the Strong Heart Study. Am J Clin Nutr. Oct. 2006;84(4):894-902. X-1F,X-2. [pmid: 17023718].
3309 Yaman O, Gulpinar O, Hasan T, et al. Erectile dysfunction may predict coronary artery disease: relationship between coronary artery calcium scoring and erectile dysfunction severity. Int Urol Nephrol. 2008;40(1):117-23. X-1,X-2,X-5,X-6,X-7. [pmid: 17975736].
3310 Yamani MH, Tuzcu EM, Starling RC, et al. Computerized scoring of histopathology for predicting coronary vasculopathy, validated by intravascular ultrasound. J Heart Lung Transplant. Aug. 2002;21(8):850-9. X-1,X-7,X-8. [pmid: 12163084].
3311 Yamashina A, Tomiyama H, Arai T, et al. Brachial-ankle pulse wave velocity as a marker of atherosclerotic vascular damage and cardiovascular risk. Hypertens Res. Aug. 2003;26(8):615-22. X-5. [pmid: 14567500].
3312 Yan AT, Jong P, Yan RT, et al. Clinical trial--derived risk model may not generalize to real-world patients with acute coronary syndrome. Am Heart J. Dec. 2004;148(6):1020-7. X-1,X-8. [pmid: 15632888].
3313 Yan AT, Shayne AJ, Brown KA, et al. Characterization of the peri-infarct zone by contrast-enhanced cardiac magnetic resonance imaging is a powerful predictor of post-myocardial infarction mortality. Circulation. Jul. 4. 2006;114(1):32-9. X-1,X-7,X-8. [pmid: 16801462].
3314 Yan AT, Yan RT, Kennelly BM, et al. Relationship of ST elevation in lead aVR with angiographic findings and outcome in non-ST elevation acute coronary syndromes. Am Heart J. Jul. 2007;154(1):71-8. X-1,X-5,X-6. [pmid: 17584554].
3315 Yan AT, Yan RT, Tan M, et al. Risk scores for risk stratification in acute coronary syndromes: useful but simpler is not necessarily better. Eur Heart J. May. 2007;28(9):1072-8. X-1,X-8. [pmid: 17437970].
3316 Yan AT, Yan RT, Tan M, et al. ST-segment depression in non-ST elevation acute coronary syndromes: quantitative analysis may not provide incremental prognostic value beyond comprehensive risk stratification. Am Heart J. Aug. 2006;152(2):270-6. X-1,X-8. [pmid: 16875907].
3317 Yan AT, Yan RT, Tan M, et al. Long-term prognostic value and therapeutic implications of continuous ST-segment monitoring in acute coronary syndrome. Am Heart J. Apr. 2007;153(4):500-6. X-1,X-6,X-8. [pmid: 17383285].
3318 Yanase T, Nasu S, Mukuta Y, et al. Evaluation of a new carotid intima-media thickness measurement by B-mode ultrasonography using an innovative measurement software, intimascope. Am J Hypertens. Dec. 2006;19(12):1206-12. X-5,X-6. [pmid: 17161764].
3319 Yang JH, Gwon HC, Cho SJ, et al. Comparison of coronary artery bypass grafting with drug-eluting stent implantation for the treatment of multivessel coronary artery disease. Ann Thorac Surg. Jan. 2008;85(1):65-70. X-1,X-2,X-8. [pmid: 18154782].
3320 Yang X, Ma RC, So WY, et al. Development and validation of a risk score for hospitalization for heart failure in patients with Type 2 diabetes mellitus. Cardiovasc Diabetol. 2008;7:9. X-1,X-8. [pmid: 18430204].
3321 Yang X, Sun K, Zhang W, et al. Prevalence of and risk factors for peripheral arterial disease in the patients with hypertension among Han Chinese. J Vasc Surg. Aug. 2007;46(2):296-302. X-1,X-5. [pmid: 17600667].
3322 Yap AG, Baladi N, Allman G, et al. Coronary artery bypass surgery on small patients. J Invasive Cardiol. May. 2000;12(5):242-6. discussion 247. X-1,X-2,X-6,X-8. [pmid: 10825765].
3323 Yap CH, Mohajeri M, Ihle BU, et al. Validation of Euroscore model in an Australian patient population. ANZ J Surg. Jul. 2005;75(7):508-12. X-1,X-8. [pmid: 15972032].
3324 Yap CH, Reid C, Yii M, et al. Validation of the EuroSCORE model in Australia. Eur J Cardiothorac Surg. Apr. 2006;29(4):441-6. discussion 446. X-1,X-8. [pmid: 16473519].
3325 Yap S, Boers GH, Wilcken B, et al. Vascular outcome in patients with homocystinuria due to cystathionine beta-synthase deficiency treated chronically: a multicenter observational study. Arterioscler Thromb Vasc Biol. Dec. 2001;21(12):2080-5. X-1,X-2,X-5. [pmid: 11742888].
3326 Yarali H, Yildirir A, Aybar F, et al. Diastolic dysfunction and increased serum homocysteine concentrations may contribute to increased cardiovascular risk in patients with polycystic ovary syndrome. Fertil Steril. Sep. 2001;76(3):511-6. X-1,X-2,X-5,X-6,X-7. [pmid: 11532474].
3327 Yarnell J, Yu S, Patterson C, et al. Family history, longevity, and risk of coronary heart disease: the PRIME Study. Int J Epidemiol. Feb. 2003;32(1):71-7. X-1F,X-2. [pmid: 12690013].
3328 Yarnell JW, Patterson CC, Sweetnam PM, et al. Haemostatic/inflammatory markers predict 10-year risk of IHD at least as well as lipids: the Caerphilly collaborative studies. Eur Heart J. Jun. 2004;25(12):1049-56. X-1. [pmid: 15191776].
3329 Yatskar L, Selzer F, Feit F, et al. Access site hematoma requiring blood transfusion predicts mortality in patients undergoing percutaneous coronary intervention: data from the National Heart, Lung, and Blood Institute Dynamic Registry. Catheter Cardiovasc Interv. Jun. 1. 2007;69(7):961-6. X-1,X-2,X-6,X-8. [pmid: 17421023].
3330 Yau TM, Fedak PW, Weisel RD, et al. Predictors of operative risk for coronary bypass operations in patients with left ventricular dysfunction. J Thorac Cardiovasc Surg. Dec. 1999;118(6):1006-13. X-1,X-8. [pmid: 10595971].
3331 Yeboah J, Crouse JR, Hsu FC, et al. Brachial flow-mediated dilation predicts incident cardiovascular events in older adults: the Cardiovascular Health Study. Circulation. May. 8. 2007;115(18):2390-7. X-1D,X-1F,X-2,X-8(20%). [pmid: 17452608].
3332 Yeh ET. C-reactive protein is an essential aspect of cardiovascular risk factor stratification. Can J Cardiol. Aug. B. 2004;20:93B-96B. X-1,X-2,X-4,X-5,X-6,X-7,X-8.
3333 Yende S, Wunderink R. Validity of scoring systems to predict risk of prolonged mechanical ventilation after coronary artery bypass graft surgery. Chest. Jul. 2002;122(1):239-44. X-1,X-6,X-8. [pmid: 12114365].
3334 Yeo WW, Yeo KR. Predicting CHD risk in patients with diabetes mellitus. Diabet Med. May. 2001;18(5):341-4. X-4. [pmid: 11472442].
3335 Yi G, Poloniecki J, Dickie S, et al. Can the assessment of dynamic QT dispersion on exercise electrocardiogram predict sudden cardiac death in hypertrophic cardiomyopathy?. Pacing Clin Electrophysiol. Nov. 2000;23(11 Pt 2):1953-6. X-5,X-6,X-7,X-8. [pmid: 11139965].
3336 Yikona JI, Wallis EJ, Ramsay LE, et al. Coronary and cardiovascular risk estimation in uncomplicated mild hypertension. A comparison of risk assessment methods. J Hypertens. Nov. 2002;20(11):2173-82. X-1F,X-2,X-5,X-6,X-9. [pmid: 12409955].
3337 Yildirim A, Soylu O, Dagdeviren B, et al. Sympathetic overactivity in patients with left ventricular aneurysm in early period after anterior myocardial infarction: does sympathetic activity predict aneurysm formation?. Angiology. Jun-Jul. 2007;58(3):275-82. X-1,X-2,X-5,X-6,X-7. [pmid: 17626980].
3338 Yilmaz MB, Cihan G, Guray Y, et al. Role of mean platelet volume in triagging acute coronary syndromes. J Thromb Thrombolysis. Aug. 2008;26(1):49-54. X-1,X-2,X-5,X-6,X-8. [pmid: 17705053].
3339 Yip HK, Liou CW, Chang HW, et al. Link between platelet activity and outcomes after an ischemic stroke. Cerebrovasc Dis. 2005;20(2):120-8. X-1,X-7,X-8. [pmid: 16006760].
3340 Yip HK, Wu CJ, Chang HW, et al. Prognostic value of circulating levels of endothelin-1 in patients after acute myocardial infarction undergoing primary coronary angioplasty. Chest. May. 2005;127(5):1491-7. X-1,X-7,X-8. [pmid: 15888819].
3341 Yip YB, Wong TK, Chung JW, et al. Cardiovascular disease: application of a composite risk index from the Telehealth System in a district community. Public Health Nurs. Nov-Dec. 2004;21(6):524-32. X-1G,X-2,X-5,X-8. [pmid: 15566557].
3342 Yokokawa H, Goto A, Watanabe K, et al. Evaluation of atherosclerosis-associated factors and pulse wave velocity for predicting cerebral infarction: a hospital-based, case-control study in Japan. Intern Med J. Mar. 2007;37(3):161-7. X-1,X-5,X-7,X-8. [pmid: 17316334].
3343 Yologlu S, Sezgin AT, Sezgin N, et al. Comparison of different regression analyses for identifying risk factors in obese and nonobese patients with coronary artery disease. Angiology. Oct-Nov. 2007;58(5):543-9. X-1E,X-1F,X-2,X-5,X-6,X-8. [pmid: 18024936].
3344 Yoneyama K, Tsuboya A, Kogo M, et al. Predictors of restenosis after coronary artery stenting. Minerva Cardioangiol. Jun. 2008;56(3):295-305. X-1,X-6,X-7,X-8. [pmid: 18509290].
3345 Yong M, Diener HC, Kaste M, et al. Long-term outcome as function of blood pressure in acute ischemic stroke and effects of thrombolysis. Cerebrovasc Dis. 2007;24(4):349-54. X-1,X-6,X-8. [pmid: 17690547].
3346 Yoon BW, Bae HJ, Kang DW, et al. Intracranial cerebral artery disease as a risk factor for central nervous system complications of coronary artery bypass graft surgery. Stroke. Jan. 2001;32(1):94-9. X-1,X-6,X-8. [pmid: 11136921].
3347 Yoshinaga K, Chow BJ, Williams K, et al. What is the prognostic value of myocardial perfusion imaging using rubidium-82 positron emission tomography?. J Am Coll Cardiol. Sep. 5. 2006;48(5):1029-39. X-1D,X-2,X-8(>54%). [pmid: 16949498].
3348 Youn YN, Kwak YL, Yoo KJ. Can the EuroSCORE predict the early and mid-term mortality after off-pump coronary artery bypass grafting?. Ann Thorac Surg. Jun. 2007;83(6):2111-7. X-1,X-8. [pmid: 17532408].
3349 Young QR, Ignaszewski A, Fofonoff D, et al. Brief screen to identify 5 of the most common forms of psychosocial distress in cardiac patients: validation of the screening tool for psychological distress. J Cardiovasc Nurs. Nov-Dec. 2007;22(6):525-34. X-1,X-2,X-5,X-6,X-7,X-8. [pmid: 18090195].
3350 Yu CM, Sanderson JE. Plasma brain natriuretic peptide--an independent predictor of cardiovascular mortality in acute heart failure. Eur J Heart Fail. Mar. 1999;1(1):59-65. X-1,X-7,X-8. [pmid: 10937981].
3351 Yu L, Ioannou GN. Survival of liver transplant recipients with hemochromatosis in the United States. Gastroenterology. Aug. 2007;133(2):489-95. X-1,X-6. [pmid: 17681170].
3352 Yu S, Yarnell JW, Sweetnam P, et al. High density lipoprotein subfractions and the risk of coronary heart disease: 9-years follow-up in the Caerphilly Study. Atherosclerosis. Feb. 2003;166(2):331-8. X-1,X-2,X-5. [pmid: 12535746].
3353 Yung KC, Piccirillo JF. The incidence and impact of comorbidity diagnosed after the onset of head and neck cancer. Arch Otolaryngol Head Neck Surg. Oct. 2008;134(10):1045-9. X-1,X-2,X-7. [pmid: 18936348].
3354 Yuo TH, Goodney PP, Powell RJ, et al. “Medical high risk” designation is not associated with survival after carotid artery stenting. J Vasc Surg. Feb. 2008;47(2):356-62. X-1,X-2,X-5,X-6,X-8. [pmid: 18155875].
3355 Yusuf S, Mehta SR, Chrolavicius S, et al. Effects of fondaparinux on mortality and reinfarction in patients with acute ST-segment elevation myocardial infarction: the OASIS-6 randomized trial. JAMA. Apr. 5. 2006;295(13):1519-30. X-1,X-2,X-8. [pmid: 16537725].
3356 Yuyun MF, Adler AI, Wareham NJ. What is the evidence that microalbuminuria is a predictor of cardiovascular disease events?. Curr Opin Nephrol Hypertens. May. 2005;14(3):271-6. X-1,X-2,X-4,X-5,X-7,X-8. [pmid: 15821422].
3357 Yuyun MF, Khaw KT, Luben R, et al. Microalbuminuria and stroke in a British population: the European Prospective Investigation into Cancer in Norfolk (EPIC-Norfolk) population study. J Intern Med. Feb. 2004;255(2):247-56. X-1E,X-1F,X-2. [pmid: 14746562].
3358 Zabel M, Malik M. Predictive value of T-wave morphology variables and QT dispersion for postmyocardial infarction risk assessment. J Electrocardiol. 2001;34(Suppl):27-35. X-1,X-8. [pmid: 11781933].
3359 Zabel M, Malik M, Hnatkova K, et al. Analysis of T-wave morphology from the 12-lead electrocardiogram for prediction of long-term prognosis in male US veterans. Circulation. Mar. 5. 2002;105(9):1066-70. X-1. [pmid: 11877356].
3360 Zacharias A, Schwann TA, Riordan CJ, et al. Is hospital procedure volume a reliable marker of quality for coronary artery bypass surgery? A comparison of risk and propensity adjusted operative and midterm outcomes. Ann Thorac Surg. Jun. 2005;79(6):1961-9. X-1,X-5,X-8. [pmid: 15919292].
3361 Zacharias A, Schwann TA, Riordan CJ, et al. Late results of conventional versus all-arterial revascularization based on internal thoracic and radial artery grafting. Ann Thorac Surg. Jan. 2009;87(1):19-26. e2. X-1,X-2,X-8. [pmid: 19101262].
3362 Zafarmand MH, van der Schouw YT, Grobbee DE, et al. Peroxisome proliferator-activated receptor gamma-2 P12A polymorphism and risk of acute myocardial infarction, coronary heart disease and ischemic stroke: a case-cohort study and meta-analyses. Vasc Health Risk Manag. 2008;4(2):427-36. X-1E,X-1F,X-2,X-5. [pmid: 18561518].
3363 Zafrir N, Mats I, Solodky A, et al. Characteristics and outcome of octogenarian population referred for myocardial perfusion imaging: comparison with non-octogenarian population with to gender. Clin Cardiol. Mar. 2006;29(3):117-20. X-1F,X-2,X-6,X-8. [pmid: 16596834].
3364 Zairis MN, Adamopoulou EN, Manousakis SJ, et al. The impact of hs C-reactive protein and other inflammatory biomarkers on long-term cardiovascular mortality in patients with acute coronary syndromes. Atherosclerosis. Oct. 2007;194(2):397-402. X-1,X-8. [pmid: 16962598].
3365 Zairis MN, Ambrose JA, Manousakis SJ, et al. The impact of plasma levels of C-reactive protein, lipoprotein (a) and homocysteine on the long-term prognosis after successful coronary stenting: The Global Evaluation of New Events and Restenosis After Stent Implantation Study. J Am Coll Cardiol. Oct. 16. 2002;40(8):1375-82. X-1,X-8. [pmid: 12392824].
3366 Zairis MN, Papadaki OA, Manousakis SJ, et al. C-reactive protein and multiple complex coronary artery plaques in patients with primary unstable angina. Atherosclerosis. Oct. 2002;164(2):355-9. X-1,X-2,X-5,X-6,X-8. [pmid: 12204808].
3367 Zalenski RJ, Grzybowski M, Ross MA, et al. ECG scores for a triage of patients with acute myocardial infarction transported by the emergency medical system. J Electrocardiol. 2000;33(Suppl):245-9. X-1,X-5,X-8. [pmid: 11265729].
3368 Zalewski J, Undas A, Godlewski J, et al. No-reflow phenomenon after acute myocardial infarction is associated with reduced clot permeability and susceptibility to lysis. Arterioscler Thromb Vasc Biol. Oct. 2007;27(10):2258-65. X-1,X-2,X-5,X-8. [pmid: 17673704].
3369 Zaliunas R, Babarskiene MR, Luksiene D, et al. The risk of cardiovascular death following the first acute ischaemic syndrome: experience in Kaunas between 1997 and 2001. Acta Cardiol. Aug. 2007;62(4):329-37. X-1,X-2,X-8. [pmid: 17824292].
3370 Zaliunas R, Babarskiene MR, Slapikas R, et al. Informative value of clinical markers for the risk of cardiovascular death in postinfarction chronic heart failure. Acta Cardiol. Aug. 2005;60(4):395-401. X-1,X-8. [pmid: 16128372].
3371 Zaman MJ, Sanders J, Crook AM, et al. Cardiothoracic ratio within the “normal” range independently predicts mortality in patients undergoing coronary angiography. Heart. Apr. 2007;93(4):491-4. X-1,X-5. [pmid: 17164481].
3372 Zareba W, Moss AJ, Jackson Hall W, et al. Clinical course and implantable cardioverter defibrillator therapy in postinfarction women with severe left ventricular dysfunction. J Cardiovasc Electrophysiol. Dec. 2005;16(12):1265-70. X-1,X-6,X-8. [pmid: 16403053].
3373 Zaroff JG, diTommaso DG, Barron HV. A risk model derived from the National Registry of Myocardial Infarction 2 database for predicting mortality after coronary artery bypass grafting during acute myocardial infarction. Am J Cardiol. Jul. 1. 2002;90(1):1-4. X-1,X-8. [pmid: 12088769].
3374 Zaroff JG, Pawlikowska L, Miss JC, et al. Adrenoceptor polymorphisms and the risk of cardiac injury and dysfunction after subarachnoid hemorrhage. Stroke. Jul. 2006;37(7):1680-5. X-1,X-7,X-8. [pmid: 16728691].
3375 Zebis LR, Christensen TD, Thomsen HF, et al. Practical regimen for amiodarone use in preventing postoperative atrial fibrillation. Ann Thorac Surg. Apr. 2007;83(4):1326-31. X-1,X-6,X-8. [pmid: 17383335].
3376 Zebrack JS, Muhlestein JB, Horne BD, et al. C-reactive protein and angiographic coronary artery disease: independent and additive predictors of risk in subjects with angina. J Am Coll Cardiol. Feb. 20. 2002;39(4):632-7. X-1,X-8. [pmid: 11849862].
3377 Zee RY, Brophy VH, Cheng S, et al. Polymorphisms of the phosphodiesterase 4D, cAMP-specific (PDE4D) gene and risk of ischemic stroke: a prospective, nested case-control evaluation. Stroke. Aug. 2006;37(8):2012-7. X-1,X-5,X-8. [pmid: 16825591].
3378 Zee RY, Cheng S, Erlich HA, et al. Intercellular adhesion molecule 1 (ICAM1) Lys56Met and Gly241Arg gene variants, plasma-soluble ICAM1 concentrations, and risk of incident cardiovascular events in 23,014 initially healthy white women. Stroke. Dec. 2007;38(12):3152-7. X-1E,X-1F,X-2. [pmid: 17962597].
3379 Zee RY, Cook NR, Cheng S, et al. Multi-locus candidate gene polymorphisms and risk of myocardial infarction: a population-based, prospective genetic analysis. J Thromb Haemost. Feb. 2006;4(2):341-8. X-1G. [pmid: 16420563].
3380 Zee RY, Hoh J, Cheng S, et al. Multi-locus interactions predict risk for post-PTCA restenosis: an approach to the genetic analysis of common complex disease. Pharmacogenomics J. 2002;2(3):197-201. X-1,X-6,X-8. [pmid: 12082592].
3381 Zeljkovic A, Spasojevic-Kalimanovska V, Vekic J, et al. Does simultaneous determination of LDL and HDL particle size improve prediction of coronary artery disease risk?. Clin Exp Med. Jun. 2008;8(2):109-16. X-2,X-5,X-7,X-8. [pmid: 18618221].
3382 Zellweger MJ, Weinbacher M, Zutter AW, et al. Long-term outcome of patients with silent versus symptomatic ischemia six months after percutaneous coronary intervention and stenting. J Am Coll Cardiol. Jul. 2. 2003;42(1):33-40. X-1,X-2,X-8. [pmid: 12849656].
3383 Zethelius B, Berglund L, Sundstrom J, et al. Use of multiple biomarkers to improve the prediction of death from cardiovascular causes. N Engl J Med. May. 15. 2008;358(20):2107-16. X-1. [pmid: 18480203].
3384 Zeymer U, Schroder K, Wegscheider K, et al. ST resolution in a single electrocardiographic lead: a simple and accurate predictor of cardiac mortality in patients with fibrinolytic therapy for acute ST-elevation myocardial infarction. Am Heart J. Jan. 2005;149(1):91-7. X-1,X-8. [pmid: 15660039].
3385 Zhan RY, Tong Y, Shen JF, et al. Study of clinical features of amyloid angiopathy hemorrhage and hypertensive intracerebral hemorrhage. J Zhejiang Univ Sci. Oct. 2004;5(10):1262-9. X-1,X-5,X-7. [pmid: 15362199].
3386 Zhang M, Li J, Cai YM, et al. A risk-predictive score for cardiogenic shock after acute myocardial infarction in Chinese patients. Clin Cardiol. Apr. 2007;30(4):171-6. X-1,X-6,X-8. [pmid: 17443658].
3387 Zhang R, Brennan ML, Fu X, et al. Association between myeloperoxidase levels and risk of coronary artery disease. JAMA. Nov. 7. 2001;286(17):2136-42. X-1,X-2,X-5,X-6,X-8. [pmid: 11694155].
3388 Zhang R, Kofidis T, Kamiya H, et al. Creatine kinase isoenzyme MB relative index as predictor of mortality on extracorporeal membrane oxygenation support for postcardiotomy cardiogenic shock in adult patients. Eur J Cardiothorac Surg. Oct. 2006;30(4):617-20. X-1,X-6. [pmid: 16934992].
3389 Zhang SM, Manson JE, Rexrode KM, et al. Use of oral conjugated estrogen alone and risk of breast cancer. Am J Epidemiol. Mar. 1. 2007;165(5):524-9. X-1,X-2,X-6. [pmid: 17132697].
3390 Zhang X, Liu X, He ZX, et al. Long-term prognostic value of exercise 99mTc-MIBI SPET myocardial perfusion imaging in patients after percutaneous coronary intervention. Eur J Nucl Med Mol Imaging. May. 2004;31(5):655-62. X-1,X-8. [pmid: 14740177].
3391 Zhang X, Shu XO, Signorello LB, et al. Correlates of high serum C-reactive protein levels in a socioeconomically disadvantaged population. Dis Markers. 2008;24(6):351-9. X-1,X-2,X-5,X-6. [pmid: 18688084].
3392 Zhang ZM, Prineas RJ, Case D, et al. Comparison of the prognostic significance of the electrocardiographic QRS/T angles in predicting incident coronary heart disease and total mortality (from the atherosclerosis risk in communities study). Am J Cardiol. Sep. 1. 2007;100(5):844-9. X-1E,X-1F,X-2. [pmid: 17719331].
3393 Zhou Z, Hu D. An epidemiological study on the prevalence of atrial fibrillation in the Chinese population of mainland China. J Epidemiol. 2008;18(5):209-16. X-1,X-2,X-5. [pmid: 18776706].
3394 Zhu H, Hill MD. Stroke: the Elixhauser Index for comorbidity adjustment of in-hospital case fatality. Neurology. Jul. 22. 2008;71(4):283-7. X-1,X-2,X-6,X-8. [pmid: 18645167].
3395 Zhu H, Yan W, Ge D, et al. Relationships of cardiovascular phenotypes with healthy weight, at risk of overweight, and overweight in US youths. Pediatrics. Jan. 2008;121(1):115-22. X-1,X-2,X-5,X-6. [pmid: 18166564].
3396 Zhu S, St-Onge MP, Heshka S, et al. Lifestyle behaviors associated with lower risk of having the metabolic syndrome. Metabolism. Nov. 2004;53(11):1503-11. X-1,X-2,X-5,X-6. [pmid: 15536610].
3397 Zimmerli LU, Schiffer E, Zurbig P, et al. Urinary proteomic biomarkers in coronary artery disease. Mol Cell Proteomics. Feb. 2008;7(2):290-8. X-1,X-5,X-6,X-8. [pmid: 17951555].
3398 Zingone B, Gatti G, Rauber E, et al. Early and late outcomes of cardiac surgery in octogenarians. Ann Thorac Surg. Jan. 2009;87(1):71-8. X-1,X-2,X-8. [pmid: 19101271].
3399 Ziskind AA, Lauer MA, Bishop G, et al. Assessing the appropriateness of coronary revascularization: the University of Maryland Revascularization Appropriateness Score (RAS) and its comparison to RAND expert panel ratings and American College of Cardiology/American Heart Association guidelines with regard to assigned appropriateness rating and ability to predict outcome. Clin Cardiol. Feb. 1999;22(2):67-76. X-1,X-6,X-8. [pmid: 10068842].
3400 Zitser-Gurevich Y, Simchen E, Galai N, et al. Effect of perioperative complications on excess mortality among women after coronary artery bypass: the Israeli Coronary Artery Bypass Graft Study (ISCAB). J Thorac Cardiovasc Surg. Mar. 2002;123(3):517-24. X-1,X-8. [pmid: 11882825].
3401 Zodpey SP, Tiwari RR. A risk scoring system for prediction of haemorrhagic stroke. Indian J Public Health. Oct-Dec. 2005;49(4):218-22. X-5,X-7. [pmid: 16479901].
3402 Zoppini G, Verlato G, Zamboni C, et al. Pulse pressure and mortality from cerebrovascular diseases in type 2 diabetic patients: the Verona Diabetes Study. Cerebrovasc Dis. 2007;23(1):20-6. X-1F,X-2,X-8. [pmid: 16968982].
3403 Zubkov AY, Mandrekar JN, Claassen DO, et al. Predictors of outcome in warfarin-related intracerebral hemorrhage. Arch Neurol. Oct. 2008;65(10):1320-5. X-1,X-2,X-7,X-8. [pmid: 18852345].
3404 Zulli R, Donati P, Nicosia F, et al. Increased QT dispersion: a negative prognostic finding in chronic obstructive pulmonary disease. Intern Emerg Med. 2006;1(4):279-86. X-1,X-2. [pmid: 17217149].