# Summary Table 10

Table 10a Quality Grading – Study Breakdown

Year | Author | Does the article state both the inclusion/exclusion criteria and any additional exclusions that were made after cohort inception? | Was the study population well described? | Was the loss to followup over the course of the study less than 20%? | If more than 20% were lost, did the authors acknowledge the potential effects on the model? | Did missing data cause more than 20% of the population to be excluded from the model? | If more than 20% of the data was excluded due to missing data, was a missing data technique applied? | For validation studies, did the authors report both discrimination and calibration? | For model development, did the authors assess internal validation?
Americas
1999 | Detrano RC18 | + | ++ | - | NA | - | NA | ++ | +
1999a | Liao Y3 | + | ++ | - | NA | - | NA | ++ | --
1999b | Liao Y1 | ++ | ++ | + | NA | -- | NA | NA | --
2000 | Grover SA68 | + | ++ | - | NA | - | NA | + | NA
2001 | D'Agostino RB4 | + | ++ | - | NA | - | NA | ++ | --
2002 | Kothari V54 | ++ | + | ++ | NA | -- | NA | NA | -
2002 | Orford JL67 | + | + | -- | NA | NA | NA | + | NA
2003 | Folsom A13 | ++ | + | - | - | + | NA | ++ | --
2004 | Chambless LE12 | ++ | ++ | -- | NA | -- | NA | + | +
2004 | Greenland P17 | + | + | + | NA | -- | NA | + | --
2004 | Stern MP66 | ++ | - | - | NA | -- | NA | + | NA
2005 | Arad Y91 | ++ | + | + | NA | - | - | + | --
2005 | McNeill AM15 | ++ | ++ | + | NA | -- | NA | + | NA
2006 | Cook NR19 | + | ++ | - | - | - | - | ++ | +
2006 | Lee ET16 | + | ++ | + | NA | - | - | NA | +
2007 | Berry JD5 | ++ | + | + | NA | -- | NA | - | NA
2007 | Denes P63 | + | ++ | - | NA | -- | NA | + | --
2007 | Mainous AG14 | - | ++ | - | - | - | - | + | +
2007 | Miyasaka Y9 | ++ | ++ | - | - | + | NA | -- | --
2007 | Ridker PM20 | ++ | ++ | - | - | - | NA | ++ | +
2007 | Vaidya D10 | + | ++ | - | NA | - | NA | - | NA
2007 | Weiner DE64 | ++ | ++ | + | NA | -- | NA | ++ | NA
2008 | D'Agostino RB6 | + | ++ | - | NA | - | NA | ++ | +
2008 | Gaizano TA8 | ++ | ++ | - | + | -- | NA | ++ | +
2008 | Mainous AG11 | - | + | - | - | - | - | + | --
2008 | Wilson P7 | ++ | ++ | + | NA | -- | NA | + | --
2009 | Paynter N55 | ++ | ++ | - | - | -- | NA | ++ | --
Asia
2001 | Suka M89 | ++ | ++ | + | NA | + | NA | ++ | NA
2002 | Suka M90 | + | - | - | -- | - | -- | + | NA
2004 | Liu J47 | + | + | + | NA | + | - | ++ | --
2007 | Barzi F45 | + | + | - | NA | - | NA | ++ | --
2007 | Yang X50 | ++ | ++ | - | NA | - | NA | ++ | +
2008 | Jee SH46 | ++ | ++ | + | NA | -- | NA | ++ | +
2008 | Yang X49 | + | ++ | - | NA | - | NA | ++ | +
Europe
2002 | Assmann G27 | + | + | + | NA | - | - | ++ | --
2002 | Bastuji-Garin S37 | + | + | - | - | - | - | + | NA
2003 | Brindle PM73 | + | + | + | NA | -- | NA | ++ | NA
2003 | Empana JP80 | - | + | - | - | - | - | ++ | NA
2003 | Hense HW61 | + | + | - | - | - | - | + | NA
2003 | Milne R81 | + | - | - | - | -- | NA | + | NA
2003 | Simons LA56 | - | + | -- | -- | - | - | -- | NA
2004 | Ducloux D69 | + | ++ | + | NA | -- | NA | -- | --
2004 | Dunder K22 | ++ | ++ | + | NA | + | -- | ++ | +
2004 | Erikssen G24 | + | + | + | NA | - | - | NA | +
2004 | Koenig W75 | ++ | ++ | + | NA | -- | NA | + | --
2004 | McEwan P85 | + | + | -- | -- | - | + | + | NA
2004 | Stephens JW33 | ++ | ++ | -- | + | -- | NA | ++ | NA
2005 | Bernard S21 | + | ++ | - | - | - | - | + | --
2005 | Bhopal R83 | - | + | - | - | NA | NA | -- | --
2005 | Brindle PM70 | + | ++ | - | - | -- | NA | + | NA
2005 | Cooper JA31 | + | ++ | - | - | - | - | ++ | NA
2005 | Ferrario M29 | + | - | - | - | - | - | ++ | +
2005 | Guzder RN86 | ++ | ++ | + | NA | -- | NA | ++ | NA
2005 | Silventoinen K78 | - | ++ | - | - | - | - | + | NA
2005 | Ulmer HB76 | + | + | - | - | - | - | + | NA
2005 | Vliegenthart R79 | ++ | ++ | + | NA | -- | NA | + | --
2005 | Wang Z82 | ++ | ++ | + | NA | + | -- | - | NA
2005 | Wannamethee SG72 | ++ | ++ | + | NA | -- | NA | + | --
2006 | Donnan PT39 | + | ++ | - | - | + | -- | NA | +
2006 | May MD44 | + | + | - | - | - | + | ++ | --
2007 | Assmann G26 | + | ++ | - | NA | - | NA | + | +
2007 | Buyken AE74 | + | - | - | NA | - | NA | -- | NA
2007 | Hippisley-Cox JC40 | + | ++ | -- | -- | - | - | ++ | +
2007 | Koller MT84 | + | + | + | NA | -- | NA | ++ | NA
2007 | Lindman AS71 | ++ | + | - | - | -- | NA | + | NA
2007 | Macfarlane PW32 | + | ++ | - | - | - | - | NA | --
2007 | Marrugat J38 | ++ | + | + | NA | -- | NA | ++ | NA
2007 | Reissigova J25 | ++ | + | + | NA | - | NA | ++ | NA
2007 | Strom Moller C23 | ++ | ++ | -- | -- | - | - | + | --
2007 | Woodward M30 | - | ++ | -- | NA | -- | + | + | --
2008 | Assmann G28 | + | ++ | - | - | -- | NA | + | NA
2008 | Becker A41 | ++ | ++ | + | NA | -- | NA | + | --
2008 | Becker A87 | + | ++ | + | NA | - | - | + | NA
2008 | Cederholm J43 | - | + | - | - | -- | NA | NA | --
2008 | de Ruijter W42 | ++ | ++ | - | NA | -- | NA | + | +
2008 | Elkeles R88 | + | ++ | -- | NA | - | - | + | NA
2008 | Hippisley-Cox JC62 | ++ | ++ | + | NA | - | + | ++ | --
2008 | Hippisley-Cox JC34 | ++ | ++ | - | - | - | + | ++ | NA
2008 | Scheltens T77 | + | ++ | - | - | -- | NA | ++ | NA
2008 | Simmons RK35 | ++ | ++ | - | NA | -- | NA | + | --
2008 | Vergnaud A36 | ++ | ++ | + | NA | - | - | ++ | NA