# Summary Table 9

Table 9a Outcome Incidence Rates – All

Study 1^st^ Author | Study Yr Pub | Country | Cohort | Cohort Abbrev | Group Name | Female % | Diabetes % | Outcome Name | Enrollment | Outcomes | Event %
Wilson PWF7 | 2008 | US | Framingham Offspring Study | FRS-O | All | 51.6 | 2.8 | Stroke 2 | 4780 | 111 | 2.3
Wilson PWF7 | 2008 | US | Framingham Offspring Study | FRS-O | All | 51.6 | 2.8 | Total CHD 1 | 4780 | 492 | 10.3
Wilson PWF7 | 2008 | US | Framingham Offspring Study | FRS-O | All | 51.6 | 2.8 | CVD 12 | 4780 | 684 | 14.3
Hippisley-Cox J34 | 2008 | UK | Members of QRESEARCH database | QRESEARCH | All | 75.4 | 2.9 | CVD 1 | 2285815 | 96709 | 4.2
Simmons RK35 | 2008 | UK | European Prospective Investigation of Cancer [EPIC]–Norfolk | EPIC-Norfolk | All | 56.2 | 2.8 | Total CHD 1 | 10295 | 680 | 6.6
Gaizano TA8 | 2008 | US | National Health and Nutrition Examination Survey I Epidemiologic Follow-Up Study | NHANES-I EFS | All | 54.1 | 3.8 | CVD 7 | 6186 | 578 | 9.3
Yang X49 | 2008 | China | Hong Kong Diabetes Registry | HKD Registry | All | 54.6 | 100 | Hard CHD 1 | 7067 | 157 | 2.2
Yang X49 | 2008 | China | Hong Kong Diabetes Registry | HKD Registry | All | 54.6 | 100 | Total CHD 1 | 7067 | 351 | 5
D'Agostino RB92 | 2008 | US | Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87) | FRS, FRS-O | All | 53.3 | 5 | CVD 2 | 8491 | 1174 | 13.8
Becker A41 | 2008 | Germany | Consecutive patients referred by primary care provider for preventive cardiological exam | | All | 41 | 17 | Hard CHD 2 | 1726 | 380 | 22
Becker A41 | 2008 | Germany | Consecutive patients referred by primary care provider for preventive cardiological exam | | All | 41 | 17 | Hard CHD 1 | 1726 | 180 | 10.4
Assmann G26 | 2007 | Germany | PROCAM cohort; employees of 52 companies and local government authorities in Germany, aged 20-78 yrs | PROCAM | All | 29.4 | 6.2 | Hard CHD 1 (10 Year) | 7295 | 345 | 4.7
Vaidya D10 | 2007 | US | John Hopkins Sibling Study | JHSS | All | 48.5 | 6.3 | Total CHD 1 | 784 | 108 | 13.8
Hippisley-Cox JC62 | 2008 | UK | THIN cohort; data from 288 UK practices using INPS Vision system (~20%); including 24 practices (54709 patients) from Scotland and 14 practices (36904) from Northern Ireland | THIN | All | 50.6 | 0 | CVD 10 (10 yr) | 1072800 | 87858 | 8.2
Hippisley-Cox JC62 | 2008 | UK | QRESEARCH | QRESEARCH | All | 50.4 | 0 | CVD 10 (10 yr) | 607733 | 47557 | 7.8
Hippisley-Cox JC62 | 2008 | UK | QRESEARCH | QRESEARCH | All | 50.4 | 0 | CVD 10 | 607733 | 30087 | 5
Hippisley-Cox JC62 | 2008 | UK | THIN cohort; data from 288 UK practices using INPS Vision system (~20%); including 24 practices (54709 patients) from Scotland and 14 practices (36904) from Northern Ireland | THIN | All | 50.6 | 0 | CVD 10 | 1072800 | 44152 | 4.1
Lindman AS71 | 2007 | Norway | Cardiovascular Program in Norway (ages 60-69) | CP-Norway | All | 53.7 | 0 | CVD Mortality | 8085 | 427 | 5.3
Lindman AS71 | 2007 | Norway | Norwegian Counties Study (ages 40-59) | NCS | All | 50.9 | 0 | CVD Mortality | 49144 | 517 | 1.1
Weiner DE64 | 2007 | US | Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD | ARIC, CHS | All | 61.8 | 14 | Hard CHD 1 (10yr) | 934 | 130 | 13.9
Weiner DE64 | 2007 | US | Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD | ARIC, CHS | All | 61.8 | 14 | Hard CHD 1 (5yr) | 934 | 65 | 7
Hippisley-Cox JC40 | 2007 | UK | QRESEARCH database, constructed from 160 UK general practices; validation cohort | QRESEARCH (Validation) | All | 50.3 | 0 | CVD 4 (10 yr) | 614553 | 48738 | 7.9
Jee SH46 | 2008 | Korea | Koreans insured by National Health Insurance Corporation (NHIC) | | All | 36.5 | 4.5 | Stroke 6 (10 yr) | 1205268 | 42995 | 3.6
Koller MT84 | 2007 | Netherlands | Rotterdam Study | | All | 63.9 | | Hard CHD 1 | 6795 | 799 | 11.8
Berry JD5 | 2007 | US | Chicago young adults | CHA | All | 0 | 0 | Hard CHD 1 (10 yr) | 10375 | 24 | 0.2
Berry JD5 | 2007 | US | Chicago young adults | CHA | All | 0 | 0 | Hard CHD 1 (30 yr) | 10375 | 271 | 2.6
Strom Moller C23 | 2007 | Sweden | Uppsala Longitudinal Study of Adult Men (baseline age 70 cohort) | ULSAM | All | 0 | | CVD Mortality | 1221 | 139 | 11.4
Mainous AG14 | 2007 | US | Atherosclerosis Risk In Communities Study | ARIC | All | 56.5 | 6.9 | Hard CHD 2 | 14343 | 1108 | 7.7
Buyken AE74 | 2007 | Germany | Men at work in public authorities and large companies in the region of Munster, Germany | | All | 0 | | Hard CHD 1 | 4818 | 325 | 6.7
Miyasaka Y9 | 2007 | US | Adult residents of Olmsted County, MN | | All | 52.4 | 12.8 | Total CHD 1 | 2768 | 463 | 16.7
Denes P63 | 2007 | US | Women's Health Initiative study | WHI | All | 100 | 3.9 | Hard CHD 1 | 14749 | 246 | 1.7
Denes P63 | 2007 | US | Women's Health Initiative study | WHI | All | 100 | 3.9 | CVD 15 | 14749 | 595 | 4
Ridker PM20 | 2007 | US | Women's Health Study (validation cohort) | WHS | All | 100 | 2.9 | CVD 3 | 8158 | 262 | 3.2
Barzi F45 | 2007 | China | Asia Pacific Cohort Studies Collaboration - Total Chinese Cohort | APCSC China | All | 41.4 | | CVD 8 | 25682 | 542 | 2.1
Reissigova J25 | 2007 | Czech Republic | Study of Atherosclerotic Risk Factors | STULONG | All | 0 | 0 | Total CHD 1 | 646 | 106 | 16.4
Yang X50 | 2007 | China | Hong Kong Diabetes Registry | HKD Registry | All | 54.5 | 100 | Stroke 3 | 3541 | 150 | 4.2
Yang X50 | 2007 | China | Hong Kong Diabetes Registry | HKD Registry | All | 54.5 | 100 | Stroke 5 | 3541 | 32 | 0.9
Yang X50 | 2007 | China | Hong Kong Diabetes Registry | HKD Registry | All | 54.5 | 100 | Stroke 1 | 3541 | 182 | 5.1
Marrugat J38 | 2007 | Spain | Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidencts Cohort | VERIFICA | All | 57.3 | 16.4 | Total CHD 1 | 5732 | 180 | 3.1
Woodward M30 | 2007 | Scotland | Scottish Hearth Health Extended Cohort | SHHEC | All | 50.8 | 1.4 | CVD 11 (10 yr) | 13297 | 1165 | 8.8
Macfarlane PW32 | 2007 | Scotland | West of Scotland Coronary Prevention Study | WOSCOPS | All | 0 | 1.2 | | 6595
Cook NR19 | 2006 | US | Women's Health Study | WHS | All | 100 | 0 | CVD 3 | 15048 | 498 | 3.3
Lee ET16 | 2006 | US | Strong Heart Study | SHS | All | 60.6 | 44 | Hard CHD 1 | 4372 | 724 | 16.6
Donnan PT39 | 2006 | UK | Patients with diabetes receiving care in Salford, UK | DARTS | All | 47.4 | 100 | | 3472
Donnan PT39 | 2006 | UK | Subjects with type 2 diabetes registered with a Tayside GP | DARTS | All | 47.4 | 100 | Hard CHD 1 | 4569 | 243 | 5.3
May MD44 | 2006 | UK | British Women's Heart and Health Cohort | BWHH | All | 100 | 4.4 | CVD 11 | 3582 | 240 | 6.7
May MD44 | 2006 | UK | British Women's Heart and Health Cohort | BWHH | All | 100 | 4.4 | Total CHD 3 | 3582 | 198 | 5.5
Wannamethee SG72 | 2005 | UK | British Regional Heart Study; men aged 40-59 yrs | BRHS | All | 0 | 0 | Hard CHD 1 (20 yrs) | 5077 | 763 | 15
Wannamethee SG72 | 2005 | UK | British Regional Heart Study; men aged 40-59 yrs | BRHS | All | 0 | 0 | Diabetes, Type 2 (20 yrs) | 5077 | 299 | 5.9
Wannamethee SG72 | 2005 | UK | British Regional Heart Study; men aged 40-59 yrs | BRHS | All | 0 | 0 | Stroke 1 (20 yrs) | 5077 | 291 | 5.7
Brindle PM70 | 2005 | Scotland | Renfrew and Paisley Study | | All | 54.3 | 1.2 | CVD Mortality | 12304 | 696 | 5.7
Silventoinen K78 | 2005 | Finland | Individuals aged 25-65 yrs identified from Finnish population register and participating in 3 cross-sectional risk factor surveys in Finland in 1987, 1992, & 1997 | | All | 53.4 | 1.5 | Stroke 1 | 17725 | 324 | 1.8
Silventoinen K78 | 2005 | Finland | Individuals aged 25-65 yrs identified from Finnish population register and participating in 3 cross-sectional risk factor surveys in Finland in 1987, 1992, & 1997 | | All | 53.4 | 1.5 | All-Cause Mortality | 17725 | 765 | 4.3
Silventoinen K78 | 2005 | Finland | Individuals aged 25-65 yrs identified from Finnish population register and participating in 3 cross-sectional risk factor surveys in Finland in 1987, 1992, & 1997 | | All | 53.4 | 1.5 | Total CHD 1 | 17725 | 699 | 3.9
Ulmer HB76 | 2005 | Austria | Vorarlberg Health Monitoring and Promotion Program (VHM&PP); cohort of individuals undergoing general health examinations in Vorarlberg province | VHM&PP | All | 54.8 | | CHD Mortality | 44649 | 300 | 0.7
Ulmer HB76 | 2005 | Austria | Vorarlberg Health Monitoring and Promotion Program (VHM&PP); cohort of individuals undergoing general health examinations in Vorarlberg province | VHM&PP | All | 54.8 | | CVD Mortality | 44649 | 487 | 1.1
Vliegenthart R79 | 2005 | Netherlands | Rotterdam Coronary Calcification Study | RCC | All | 57.5 | 12.3 | CVD 3 | 1795 | 88 | 4.9
Arad Y91 | 2005 | US | St Francis Heart Study | SFHS | All | 35 | 6 | CVD 16 | 4613 | 119 | 2.6
Cooper JA31 | 2005 | UK | Second Northwick Park Heart Study | NPHS-II | All | 0 | 2.1 | Hard CHD 2 | 2732 | 219 | 8
Bernard S21 | 2005 | France | Lyon, France | | All | 35.4 | 100 | CVD 6 | 229 | 34 | 14.8
Guzder RN86 | 2005 | UK | Poole Diabetes Study | PDS | All | 43.7 | 100 | Total CHD 3 | 428 | 60 | 14
Guzder RN86 | 2005 | UK | Poole Diabetes Study | PDS | All | 43.7 | 100 | CVD 13 | 428 | 98 | 22.9
Guzder RN86 | 2005 | UK | Poole Diabetes Study | PDS | All | 43.7 | 100 | Total CHD 3 | 428 | 60 | 14
Guzder RN86 | 2005 | UK | Poole Diabetes Study | PDS | All | 43.7 | 100 | CVD 13 | 428 | 98 | 22.9
Bhopal R83 | 2005 | India | Newcastle Heart Project - Indian | NHP - India | All | 63 | 16 | | 230
Bhopal R83 | 2005 | UK | Newcastle Heart Project - Europeans | NHP Europe | All | 50 | 4 | Stroke Mortality | 725 | 9 | 1.2
Bhopal R83 | 2005 | South Asia | Newcastle Heart Project - South Asians | NHP-South Asia | All | 54.5 | 20.5 | Stroke Mortality | 576 | 3 | 0.5
Bhopal R83 | 2005 | South Asia | Newcastle Heart Project - South Asians | NHP-South Asia | All | 54.5 | 20.5 | CHD mortality | 576 | 19 | 3.3
Bhopal R83 | 2005 | Pakistan | Newcastle Heart Project - Pakistani | NHP-Pakistan | All | 51.1 | 27 | | 264
Bhopal R83 | 2005 | UK | Newcastle Heart Project - Europeans | NHP Europe | All | 50 | 4 | CHD Mortality | 725 | 22 | 3
McNeill AM15 | 2005 | US | Atherosclerosis Risk in Communities Study | ARIC | All | 100 | 0 | Hard CHD 2 | 12089 | 879 | 7.3
McNeill AM15 | 2005 | US | Atherosclerosis Risk in Communities Study | ARIC | All | 100 | 0 | Stroke 3 | 12089 | 216 | 1.8
Ferrario M29 | 2005 | Italy | CUORE | CUORE | All | 0 | 5 | Hard CHD 2 | 6865 | 312 | 4.5
Wang Z82 | 2005 | Australia | Aboriginal community | | All | 48.2 | 12.5 | Total CHD 1 | 687 | 68 | 9.9
Stephens JW33 | 2004 | UK | Diabetes clinic at University College London Hospitals NHS Trust | | All | 36 | 100 | Total CHD 2 | 798 | 269 | 33.7
Stephens JW33 | 2004 | UK | Diabetes clinic at University College London Hospitals NHS Trust | | All | 36 | 100 | CVD 18 | 798 | 358 | 44.9
Stern Michael P66 | 2004 | US | San Antonio Heart Study | SAHS | All | 58 | 12.6 | CVD 15 | 2570 | 156 | 6.1
Dunder K22 | 2004 | Sweden | Uppsala Longitudinal Study of Adult Men | ULSAM | All | 0 | 1.5 | MI | 1108 | 251 | 22.7
Dunder K22 | 2004 | Sweden | Uppsala Longitudinal Study of Adult Men | ULSAM | All | 0 | 1.5 | Hard CHD 1 (10 yrs) | 1108 | 33 | 3
Chambless LE12 | 2004 | US | Atherosclerosis Risk in Communities Study | ARIC | All | 55.3 | | Stroke 3 | 13161 | 376 | 2.9
Ducloux D69 | 2004 | France | Consecutive renal transplant patients | | All | 36.9 | 10.8 | Total CHD 1 | 344 | 27 | 7.8
Liu J47 | 2004 | China | Chinese Multi-Provincial Cohort Study; individuals aged 35-64 yrs from 16 centers in 11 provinces (1992-1993) and Beijing (1996-1999) | MUCA | All | 46.7 | 5.5 | Hard CHD 1 | 30121 | 191 | 0.6
Erikssen G24 | 2004 | Norway | Apparently healthy Norwegian men aged 40-60 yrs recruited from 5 govt agencies | | All | 0 | 0 | CHD Mortality | 2014 | 300 | 14.9
McEwan P85 | 2004 | UK | Cardiff Diabetes Database (type 1 and type 2) | | All | 42.2 | 100 | CVD 2 | 938 | 172 | 18.3
Koenig W75 | 2004 | Germany | Men randomly selected from general population in 1984-5, 1989-90 and 1994-5 | | All | 0 | 5.8 | Hard CHD 1 | 3435 | 191 | 5.6
Greenland P17 | 2004 | US | South Bay Heart Watch cohort | SBHW | All | 10.2 | 0 | Hard CHD 1 | 1029 | 84 | 8.2
Brindle P73 | 2003 | UK | British Regional Heart Study; men aged 40-59 yrs randomly selected from registers of one general practice in each town | BRHS | All | 0 | 1.1 | Total CHD 1 | 6643 | 677 | 10.2
Brindle P73 | 2003 | UK | British Regional Heart Study; men aged 40-59 yrs randomly selected from registers of one general practice in each town | BRHS | All | 0 | 1.1 | CHD mortality | 6643 | 186 | 2.8
Milne R81 | 2003 | New Zealand | People from workforce of nationwide multi-industry corporation (Fletcher Challenge, Ltd. [72%]) and general electoral rolls of Auckland metro region (28%) | | All | 27 | | CVD 2 (5 yrs) | 6354 | 411 | 6.5
Empana JP80 | 2003 | Northern Ireland | PRIME cohort study (Belfast cohort) | PRIME | All | 0 | | Hard CHD 1 (5 yr) | 2399 | 61 | 2.5
Empana JP80 | 2003 | Northern Ireland | PRIME cohort study (Belfast cohort) | PRIME | All | 0 | | Total CHD 1 (5 yr) | 2399 | 120 | 5
Empana JP80 | 2003 | France | PRIME cohort study | PRIME-France | All | 0 | | Hard CHD 1 (5 yr) | 7359 | 106 | 1.4
Empana JP80 | 2003 | France | PRIME cohort study | PRIME-France | All | 0 | | Total CHD 1 (5 yr) | 7359 | 197 | 2.7
Folsom A13 | 2161 | US | Atherosclerosis Risk in Communities | ARIC | All | 56.8 | | Hard CHD 2 | 14054 | 1064 | 7.6
Hense HW61 | 2003 | Germany | PROCAM cohort; drawn from 52 companies and local govt authorities | PROCAM | All | 36.3 | 2.8 | Hard CHD 1 | 8682 | 338 | 3.9
Hense HW61 | 2003 | Germany | MONICA Augsburg cohort; 1984/1985 and 1989/1990 surveys | MONICA-Augsburg | All | 50.6 | 3.6 | Hard CHD 1 | 5786 | 178 | 3.1
Simons LA56 | 2003 | Australia | Dubbo Study cohort of elderly Australians (ages 60-79) (with DM) | DUBBO-All | All | 58 | 19 | CVD 4 (10 yrs) | 2102 | 459 | 21.8
Simons LA56 | 2003 | Australia | Dubbo Study cohort of elderly Australians (ages 60-79) (with DM) | DUBBO-All | All | 58 | 19 | CVD 4 (5 yrs) | 2102 | 211 | 10
Simons LA56 | 2003 | Australia | Dubbo Study cohort of elderly Australians (ages 60-79) without DM | DUBBO-NoDM | All | 58 | 0 | CVD 4 (10 yrs) | 1800 | 192 | 10.7
Bastuji-Garin S37 | 2002 | W. Europe and Israel | INSIGHT trial cohort of middle-aged patients with hypertension | INSIGHT | All | 55.3 | 19 | Stroke 4 | 4147 | 96 | 2.3
Bastuji-Garin S37 | 2002 | W. Europe and Israel | INSIGHT trial cohort of middle-aged patients with hypertension | INSIGHT | All | 55.3 | 19 | CVD 14 | 4147 | 231 | 5.6
Bastuji-Garin S37 | 2002 | W. Europe and Israel | INSIGHT trial cohort of middle-aged patients with hypertension | INSIGHT | All | 55.3 | 19 | Total CHD 1 | 4147 | 124 | 3
Suka M90 | 2002 | Japan | Employee health management center in a Japanese company | | All | 0 | | Total CHD 1 | 5611 | 384 | 6.8
Kothari V54 | 2002 | United Status | Wisconsin Epidemiologic Study of Diabetic Retinopathy | WESDR | All | 41.3 | 100 | Stroke Mortality | 4549 | 59 | 1.3
Orford JL67 | 2002 | US | Normative Aging Study - male veterans | NAS | All | 0 | 2.9 | Total CHD 1 | 1393 | 206 | 14.8
Assmann G27 | 2002 | Germany | PROCAM cohort; employees of 52 companies and local govt authorities with f/u every 2 years | PROCAM | All | 0 | 6.7 | Hard CHD 1 | 5159 | 325 | 6.3
Suka M89 | 2001 | Japan | Males aged 30-59 completing annual health examinations between 1991-1993 | | All | 0 | 8.5 | Total CHD 1 | 5611 | 80 | 1.4
D'Agostino RB4 | 2001 | US | Framingham Study (11th Exam) or Framingham Offspring Study (1st Exam) | FRS, FRS-O | All | 53.6 | 4.5 | Hard CHD 1 (5 yr) | 5251 | 130 | 2.5
D'Agostino RB4 | 2001 | US | Atherosclerosis Risk in Communities Study | ARIC | All | 56.7 | 8.6 | Hard CHD 1 (5 yr) | 14178 | 279 | 2
D'Agostino RB4 | 2001 | US | Honolulu Heart Program | HHP | All | 0 | 14 | Hard CHD 1 (5 yr) | 2755 | 77 | 2.8
D'Agostino RB4 | 2001 | Puerto Rico | Puerto Rico Heart Health Program | PRHHP | All | 0 | 7 | Hard CHD 1 (5 yr) | 8713 | 107 | 1.2
D'Agostino RB4 | 2001 | US | Strong Heart Study (area of OK and Aberdeen area of ND and SD) | SHS | All | 59.6 | 47.3 | Hard CHD 1 (5 yr) | 3782 | 69 | 1.8
D'Agostino RB4 | 2001 | US | Cardiovascular Health Study | CHS | All | 62.6 | 11.9 | Hard CHD 1 (5 yr) | 2557 | 115 | 4.5
Grover SA68 | 2000 | Canada | Lipid Research Clinics Prevalence Study cohort | LRCPS | All | 33 | 4.6 | CHD Mortality | 2218 | 62 | 2.8
Detrano RC18 | 1999 | US | South Bay Heart Watch | SBHW | All | 11 | 18 | Hard CHD 2 | 1194 | 64 | 5.4
Detrano RC18 | 1999 | US | South Bay Heart Watch | SBHW | All | 11 | 18 | Hard CHD 1 | 1194 | 46 | 3.9
Liao Y3 | 1999 | US | First National Heatlh and Nutrition Examination Survey | NHANES I | All | 58.4 | | CHD Mortality | 6611 | 588 | 8.9
Liao Y3 | 1999 | US | Framingham Heart Study (4th Exam) | FRS | All | 55.7 | | CHD Mortality | 4169 | 406 | 9.7
Liao Y3 | 1999 | US | Second National Heatlh and Nutrition Examination Survey | NHANES II | All | 53.5 | | CHD Mortality | 5705 | 275 | 4.8
Paynter N55 | 2009 | US | Women's Genome Health Study | WGHS | All | 100 | 2.6 | CVD 3 | 22129 | 715 | 3.2
de Ruijter W42 | 2009 | Netherlands | Leiden 85-plus Study | L85 | All | 70.7 | 14.2 | CVD Mortality | 302 | 35 | 11.6
Ridker P59 | 2008 | US | Physicians Health Study II | PHS-II | All | 0 | 0 | Hard CHD 2 | 10724 | 1072 | 10
Ridker P59 | 2008 | US | Physicians Health Study II | PHS-II | All | 0 | 0 | CVD 15 | 10724 | 1294 | 12.1
Becker A87 | 2008 | Germany | Munich | M-DM | All | 39.9 | 100 | Hard CHD 1 | 716 | 76 | 10.6
Becker A87 | 2008 | Germany | Munich | M-DM | All | 39.9 | 100 | MI | 716 | 40 | 5.6
Becker A87 | 2008 | Germany | Munich | M-DM | All | 39.9 | 100 | Hard CHD 2 | 716 | 163 | 22.8
Mainous A11 | 2008 | US | Atherosclerosis Risk in Communities Study | ARIC | All | 58 | 0 | Hard CHD 2 (6 yr) | 9307 | 430 | 4.6
Scheltens T77 | 2008 | Netherlands | Monitoring Project on Cardiovascular Disease Risk Factors; persons randomly selected from 3 cities in Netherlands, aged 20-59 and no CVD | MP-CVDRF | All | 53 | | CVD Mortality (10 yr) | 39719 | 256 | 0.6
Cederholm J43 | 2008 | Sweden | Swedish National Diabetes Register | | All | 43.1 | 100 | CVD 5 | 11646 | 1482 | 12.7
Elkeles RS88 | 2008 | UK | Patients with type 2 diabetes diagnosed by standard criteria and on standard diabetic therapy (diet, tablets, insulin) and aged 50-75 yrs, recruited from outpatient clinics in Central and West London | PREDICT | All | 36.7 | 100 | | 589
Assmann G28 | 2008 | Germany | Cohort of men and women employed in northwest Germany | PROCAM cohort | All | 0 | | Hard CHD 1 | 7134 | 404 | 5.7
Vergnaud AC36 | 2008 | France | Participants in Supplementation en Vitamines et Mineraux Antioxydants randomized primary prevention trial, followed annually since 1994/1995 | SU.VI.MAX | All | 0 | 2.4 | Total CHD 1 | 3440 | 128 | 3.7
Wilson PWF2 | 1998 | US | Framingham Coorth (11th Exam) Or Framingham Offspring (1st Exam) | FRS, FRS-O | All | 53.4 | 4.5 | Total CHD 1 | 5345 | 610 | 11.4
Liao Y1 | 1999 | US | NHANES I and II (pooled) | NHANES I and II (pooled) | All | 57.5 | | CHD death | 18542 | 1451 | 7.8

Table 9b Outcome Incidence Rates – Men

Study 1^st^ Author | Study Yr Pub | Country | Cohort | Cohort Abbrev | Group Name | Female % | Diabetes % | Outcome Name | Enrollment | Outcomes | Event %
Wilson PWF2 | 2008 | US | Framingham Offspring Study | FRS-O | Men | | | | 2313
Vergnaud AC36 | 2008 | France | Participants in Supplementation en Vitamines et Mineraux Antioxydants randomized primary prevention trial, followed annually since 1994/1995 | SU.VI.MAX | Men | | | Total CHD 1 | 3440 | 128 | 3.7
Vaidya D10 | 2007 | US | John Hopkins Sibling Study | JHSS | Men | | | Total CHD 1 | 404 | 81 | 20
Becker A41 | 2008 | Germany | Munich | M-DM | Men | | 100 | | 430
Gaizano TA8 | 2008 | US | National Health and Nutrition Examination Survey I Epidemiologic Follow-Up Study | NHANES-I EFS | Men | | 3.56 | | 2837
Hippisley-Cox J34 | 2008 | UK | Members of the QRESEARCH database | QRESEARCH | Men | | | CVD 1 | 1136761 | 55667 | 4.9
Simmons RK35 | 2008 | UK | European Prospective Investigation of Cancer [EPIC]–Norfolk | EPIC-Norfolk | Men | | | Total CHD 1 | 4513 | 430 | 9.5
Mainous A11 | 2008 | US | Atherosclerosis Risk in Communities Study | ARIC | Men | | 0 | Hard CHD 2 (6 yr) | 3901 | 299 | 7.7
D'Agostino RB6 | 2008 | US | Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87) | FRS, FRS-O | Men | | | CVD 2 | 3969 | 718 | 18.1
Becker A87 | 2008 | Germany | Consecutive patients referred by primary care provider for preventive cardiological examination | | Men | | | Hard CHD 1 | 1018 | 110 | 10.8
Becker A87 | 2008 | Germany | Consecutive patients referred by primary care provider for preventive cardiological examination | | Men | | | Hard CHD 2 | 1018 | 237 | 23.3
Hippisley-Cox JC62 | 2008 | UK | THIN cohort; data from 288 UK practices using e INPS Vision system (~20%); including 24 practices (54709 patients) from Scotland and 14 practices (36904) from Northern Ireland | THIN | Men | | 0 | CVD 10 (10 yr) | 529813 | 52292 | 9.9
Lindman AS71 | 2007 | Norway | Norwegian Counties Study (ages 40-59) | NCS | Men | | 0 | CVD Mortality | 24359 | 423 | 1.7
Weiner DE64 | 2007 | US | Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD | ARIC, CHS | Men | | 14.6 | Hard CHD 1 (10yr) | 357 | 74 | 20.7
Weiner DE64 | 2007 | US | Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD | ARIC, CHS | Men | | 14.6 | Hard CHD 1 (5yr) | 357 | 35 | 9.8
Hippisley-Cox JC40 | 2007 | UK | QRESEARCH database, constructed from 160 UK general practices; validation cohort | QRESEARCH (Validation) | Men | | 0 | CVD 4 (10 yr) | 305140 | 28317 | 9.3
Jee SH46 | 2008 | Korea | Koreans insured by National Health Insurance Corporation (NHIC) | | Men | | 4.8 | Stroke 6 (10 yr) | 767885 | 27007 | 3.5
Koller MT84 | 2007 | Netherlands | Rotterdam Study | | Men | | | Hard CHD 1 | 2452 | 351 | 14.3
Berry JD5 | 2007 | US | Chicago young adults | CHA | Men | | | Hard CHD 1 (10 yr) | 10375 | 24 | 0.2
Berry JD5 | 2007 | US | Chicago young adults | CHA | Men | | | Hard CHD 1 (30 yr) | 10375 | 271 | 2.6
Strom Moller C23 | 2007 | Sweden | Uppsala Longitudinal Study of Adult Men (baseline age 70 cohort) | ULSAM | Men | | | CVD Mortality | 1221 | 139 | 11.4
Mainous AG14 | 2007 | US | Atherosclerosis Risk In Communities Study | ARIC | Men | | | | 6239
Buyken AE74 | 2007 | Germany | Men at work in public authorities and large companies in the region of Munster, Germany | | Men | | | Hard CHD 1 | 4818 | 325 | 6.7
Miyasaka Y9 | 2007 | US | Adult residents of Olmsted County, MN | | Men | | | Total CHD 1 | 1318 | 227 | 17.2
Barzi F45 | 2007 | China | Asia Pacific Cohort Studies Collaboration - Total Chinese Cohort | APCSC China | Men | | | CVD 8 | 15046 | 418 | 2.8
Reissigova J25 | 2007 | Czech Republic | Study of Atherosclerotic Risk Factors | STULONG | Men | | | Total CHD 1 | 646 | 106 | 16.4
Marrugat J38 | 2007 | Spain | Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidencts Cohort | VERIFICA | Men | | 18.8 | Total CHD 1 | 2447 | 112 | 4.6
Woodward M30 | 2007 | Scotland | Scottish Hearth Health Extended Cohort | SHHEC | Men | | 1.5 | CVD 11 (10 yr) | 6540 | 743 | 11.4
Macfarlane PW32 | 2007 | Scotland | West of Scotland Coronary Prevention Study | WOSCOPS | Men | | | | 6595
Lee ET16 | 2006 | US | Strong Heart Study | SHS | Men | | 39.7 | Hard CHD 1 | 1722 | 349 | 20.3
Donnan PT39 | 2006 | UK | Patients with type 2 diabetes registered with a Tayside GP | DARTS | Men | | | | 2403
Wannamethee SG72 | 2005 | UK | British Regional Heart Study; men aged 40-59 yrs | BRHS | Men | | | Hard CHD 1 (20 yrs) | 5077 | 763 | 15
Wannamethee SG72 | 2005 | UK | British Regional Heart Study; men aged 40-59 yrs | BRHS | Men | | | Stroke 1 (20 yrs) | 5077 | 291 | 5.7
Wannamethee SG72 | 2005 | UK | British Regional Heart Study; men aged 40-59 yrs | BRHS | Men | | | Diabetes type 2 (20 yrs) | 5077 | 299 | 5.9
Brindle PM70 | 2005 | Scotland | Renfrew and Paisley Study | | Men | | 1.4 | | 5626
Silventoinen K78 | 2005 | Finland | Persons aged 25-65 yrs identified from Finnish population register & participating in 3 cross-sectional risk factor surveys in Finland in 1987, 1992, and 1997 | | Men | | 2 | Stroke 1 | 8268 | 177 | 2.1
Silventoinen K78 | 2005 | Finland | Persons aged 25-65 yrs identified from Finnish population register & participating in 3 cross-sectional risk factor surveys in Finland in 1987, 1992, and 1997 | | Men | | 2 | Total CHD 1 | 8268 | 480 | 5.8
Silventoinen K78 | 2005 | Finland | Persons aged 25-65 yrs identified from Finnish population register & participating in 3 cross-sectional risk factor surveys in Finland in 1987, 1992, and 1997 | | Men | | 2 | All-Cause Mortality | 8268 | 499 | 6
Cooper JA31 | 2005 | UK | Second Northwick Park Heart Study | NPHS-II | Men | | | Hard CHD 2 | 2732 | 219 | 8
Bhopal R83 | 2005 | UK | Newcastle Heart Project: Europeans | NHP Europe | Men | | 5 | | 362
McNeill AM15 | 2005 | US | Atherosclerosis Risk in Communities Study | ARIC | Men | | | | 5208
Ferrario M29 | 2005 | Italy | CUORE | CUORE | Men | | | Hard CHD 2 | 6865 | 312 | 4.5
Wang Z82 | 2005 | Australia | Aboriginal community | | Men | | 9.3 | Total CHD 1 | 356 | 30 | 8.4
Stephens JW33 | 2004 | UK | Diabetes clinic at University College London Hospitals NHS Trust | | Men | | 100 | | 504
Chambless LE12 | 2004 | US | Atherosclerosis Risk in Communities Study | ARIC | Men | | | Stroke 3 | 5887 | 155 | 2.6
Liu J47 | 2004 | China | Chinese Multi-Provincial Cohort Study; individuals aged 35-64 yrs from 16 centers in 11 provinces (1992-1993) and Beijing (1996-1999) | MUCA | Men | | 6.9 | Hard CHD 1 | 16065 | 137 | 0.9
Erikssen G24 | 2004 | Norway | Apparently healthy Norwegian men aged 40-60 yrs recruited from 5 govt agencies | | Men | | | CHD Mortality | 2014 | 300 | 14.9
McEwan P85 | 2004 | UK | Cardiff Diabetes Database (type 1 and type 2) | | Men | | | CVD 2 | 542 | 105 | 19.4
Koenig W75 | 2004 | Germany | Men randomly selected from general pop-ulation in 1984-5, 1989-90, and 1994-5 | | Men | | | Hard CHD 1 | 3435 | 191 | 5.6
Brindle P73 | 2003 | UK | British Regional Heart Study; men aged 40-59 yrs randomly selected from registers of one general practice in each town | BRHS | Men | | | Total CHD 1 | 6643 | 677 | 10.2
Brindle P73 | 2003 | UK | British Regional Heart Study; men aged 40-59 yrs randomly selected from registers of one general practice in each town | BRHS | Men | | | CHD mortality | 6643 | 186 | 2.8
Milne R81 | 2003 | New Zealand | People recruited from workforce of nation-wide multi-industry corporation (Fletcher Challenge, Ltd. [72%]) & general electoral rolls of Auckland metro region (28%) | | Men | | | CVD 2 (5 yrs) | 4638 | 325 | 7
Empana JP80 | 2003 | Northern Ireland | PRIME cohort study (Belfast cohort) | PRIME | Men | | | Total CHD 1 (5 yr) | 2399 | 120 | 5
Empana JP80 | 2003 | Northern Ireland | PRIME cohort study (Belfast cohort) | PRIME | Men | | | Hard CHD 1 (5 yr) | 2399 | 61 | 2.5
Simons LA56 | 2003 | Australia | Dubbo Study cohort of elderly Australians (ages 60-79) (with DM) | DUBBO-All | Men | | | CVD 4 (10 yrs) | 878 | 222 | 25.3
Simons LA56 | 2003 | Australia | Dubbo Study cohort of elderly Australians (ages 60-79) (with DM) | DUBBO-All | Men | | | CVD 4 (5 yrs) | 878 | 106 | 12.1
Suka M90 | 2002 | Japan | Employee health management center in a Japanese company | | Men | | | Total CHD 1 | 5611 | 384 | 6.8
Orford JL67 | 2002 | US | Normative Aging Study - male veterans | NAS | Men | | | Total CHD 1 | 1393 | 206 | 14.8
Assmann G27 | 2002 | Germany | PROCAM; cohort of employees of 52 companies and local govt authorities with f/u every 2 yrs | PROCAM | Men | | | Hard CHD 1 | 5159 | 325 | 6.3
Suka M89 | 2001 | Japan | Males aged 30-59 completing annual health examinations between 1991-1993 | | Men | | | Total CHD 1 | 5611 | 80 | 1.4
D'Agostino RB4 | 2001 | US | Framingham Study (11th Exam) or Framingham Offspring Study (1st Exam) | FRS, FRS-O | Men | | 5 | Hard CHD 1 (5 yr) | 2439 | 91 | 3.7
Grover SA68 | 2000 | Canada | Lipid Research Clinics Prevalence Study cohort | LRCPS | Men | | 4.7 | | 1484
Liao Y3 | 1999 | US | Framingham Heart Study (4th Exam) | FRS | Men | | | CHD Mortality | 1846 | 253 | 13.7
Ulmer HB76 | 2005 | Austria | Vorarlberg Health Monitoring and Promotion Program (VHM&PP); cohort of individuals undergoing general health examinations in Vorarlberg province | VHM&PP | Men | | | CHD Mortality | 20168 | 244 | 1.2
Ulmer HB76 | 2005 | Austria | Vorarlberg Health Monitoring and Promotion Program (VHM&PP); cohort of individuals undergoing general health examinations in Vorarlberg province | VHM&PP | Men | | | CVD Mortality | 20168 | 371 | 1.8
Liao Y1 | 1999 | US | First National Heatlh and Nutrition Examination Survey | NHANES I | Men | | | CHD Mortality | 2753 | 331 | 12
Liao Y1 | 1999 | US | First National Heatlh and Nutrition Examination Survey | NHANES I | Men | | | CHD Mortality (15 yr) | 2753 | 286 | 10.4
Liao Y3 | 1999 | US | Second National Heatlh and Nutrition Examination Survey | NHANES II | Men | | | CHD Mortality | 2655 | 176 | 6.6
Lindman AS71 | 2007 | Norway | Cardiovascular Program in Norway (ages 60-69) | CP-Norway | Men | | 0 | CVD Mortality | 3740 | 295 | 7.9
Hippisley-Cox JC34 | 2008 | UK | QRESEARCH | QRESEARCH | Men | | 0 | CVD 10 (10 yr) | 301622 | 27629 | 9.2
Hense HW61 | 2003 | Germany | PROCAM cohort; drawn from 52 companies and local govnt authorities | PROCAM | Men | | 2.9 | Hard CHD 1 | 5527 | 307 | 5.6
Hense HW61 | 2003 | Germany | MONICA Augsburg cohort, 1984/1985 and 1989/1990 surveys | MONICA-Augsburg | Men | | 4.2 | Hard CHD 1 | 2861 | 146 | 5.1
Bhopal R83 | 2005 | South Asia | Newcastle Heart Project - South Asians | NHP-South Asia | Men | | 21 | | 262
Bhopal R83 | 2005 | India | Newcastle Heart Project - Indian | NHP-India | Men | | 16 | | 85
Bhopal R83 | 2005 | Pakistan | Newcastle Heart Project - Pakistani | NHP-Pakistan | Men | | 26 | | 129
D'Agostino RB4 | 2001 | US | Atherosclerosis Risk in Communities Study | ARIC | Men | | | Hard CHD 1 (5 yr) | 6133 | 195 | 3.2
D'Agostino RB4 | 2001 | US | Honolulu Heart Program | HHP | Men | | | Hard CHD 1 (5 yr) | 2755 | 77 | 2.8
D'Agostino RB4 | 2001 | Puerto Rico | Puerto Rico Heart Health Program | PRHHP | Men | | | Hard CHD 1 (5 yr) | 8713 | 107 | 1.2
D'Agostino RB4 | 2001 | US | Strong Heart Study (OK and Aberdeen area of ND and SD) | SHS | Men | | 42 | Hard CHD 1 (5 yr) | 1527 | 46 | 3
D'Agostino RB4 | 2001 | US | Cardiovascular Health Study | CHS | Men | | 15 | Hard CHD 1 (5 yr) | 956 | 71 | 7.4
Empana JP80 | 2003 | France | PRIME cohort study | PRIME-France | Men | | | Hard CHD 1 (5 yr) | 7359 | 106 | 1.4
Empana JP80 | 2003 | France | PRIME cohort study | PRIME-France | Men | | | Total CHD 1 (5 yr) | 7359 | 197 | 2.7
Kothari V54 | 2002 | United Status | Wisconsin Epidemiologic Study of Diabetic Retinopathy | WESDR | Men
Wilson PWF2 | 1998 | US | Framingham Coorth (11th Exam) Or Framingham Offspring (1st Exam) | FRS, FRS-O | Men | | 5.2 | Total CHD 1 | 2489 | 383 | 15.4
Cederholm J43 | 2008 | Sweden | Swedish National Diabetes Register | | Men | | 100 | | 6628
Scheltens T77 | 2008 | Netherlands | Monitoring Project on Cardiovascular Disease Risk Factors; persons randomly selected from 3 cities in Netherlands, aged 20-59 and no CVD | MP-CVDRF | Men | | | CVD Mortality (10 yr) | 18217 | 189 | 1
Assmann G28 | 2008 | Germany | Cohort of men and women employed in northwest Germany | PROCAM cohort | Men | | | Hard CHD 1 | 7134 | 404 | 5.7
Ridker P20 | 2008 | US | Physicians Health Study II | PHS-II | Men | | 0 | CVD 15 | 10724 | 1294 | 12.1
Ridker P20 | 2008 | US | Physicians Health Study II | PHS-II | Men | | 0 | Hard CHD 2 | 10724 | 1072 | 10
Folsom A13 | 2003 | US | Atherosclerosis Risk in Communities | ARIC | Men | | | Hard CHD 2 | 6071 | 719 | 11.8
Liao Y1 | 1999 | US | NHANES I and II (pooled) | NHANES I and II (pooled) | Men | | | CHD death | 7877 | 778 | 9.9
Simons LA56 | 2003 | Australia | Dubbo Study cohort of elderly Australians (ages 60-79) without DM | DUBBO-NoDM | Men | | | CVD 4 (10 yrs) | 755 | 105 | 13.9

Table 9c Outcome Incidence Rates – Women

Study 1st Author | Study Yr Pub | Country | Cohort | Cohort Abbrev | Group Name | Female % | Diabetes % | Outcome Name | Enrollment | Outcomes | Event %
Wilson PWF7 | 2008 | US | Framingham Offspring Study | FRS-O | Women | | | | 2467
Vaidya D10 | 2007 | US | John Hopkins Sibling Study | JHSS | Women | | | Total CHD 1 | 380 | 27 | 7.1
Becker A41 | 2008 | Germany | Munich | M-DM | Women | | 100 | | 286
Gaizano TA8 | 2008 | US | National Health and Nutrition Examination Survey I Epidemiologic Follow-Up Study | NHANES-I EFS | Women | | 4.09 | | 3349
Paynter N55 | 2009 | US | Women's Genome Health Study | WGHS | Women | | | CVD 3 | 22129 | 715 | 3.2
Hippisley-Cox J34 | 2008 | UK | Members of the QRESEARCH database | QRESEARCH | Women | | | CVD 1 | 1149054 | 41042 | 3.6
Simmons RK35 | 2008 | UK | European Prospective Investigation of Cancer [EPIC]–Norfolk | EPIC-Norfolk | Women | | | Total CHD 1 | 5782 | 250 | 4.3
Mainous A11 | 2008 | US | Atherosclerosis Risk in Communities Study | ARIC | Women | | 0 | Hard CHD 2 (6 yr) | 5406 | 131 | 2.4
D'Agostino RB6 | 2008 | US | Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87) | FRS, FRS-O | Women | | | CVD 2 | 4522 | 456 | 10.1
Becker A87 | 2008 | Germany | Consecutive patients referred by primary care provider for preventive cardiological examination | | Women | | | Hard CHD 2 | 708 | 144 | 20.3
Becker A87 | 2008 | Germany | Consecutive patients referred by primary care provider for preventive cardiological examination | | Women | | | Hard CHD 1 | 708 | 70 | 9.9
Hippisley-Cox JC62 | 2008 | UK | THIN cohort; data from 288 UK practices using INPS Vision system (~20%); including 24 practices (54709 patients) from Scotland and 14 practices (36904) from Northern Ireland | THIN | Women | | 0 | CVD 10 (10 yr) | 542987 | 35566 | 6.6
Lindman AS71 | 2007 | Norway | Norwegian Counties Study (ages 40-59) | NCS | Women | | 0 | CVD Mortality | 24785 | 94 | 0.4
Weiner DE64 | 2007 | US | Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD | ARIC, CHS | Women | | 13.7 | Hard CHD 1 (10yr) | 577 | 56 | 9.7
Weiner DE64 | 2007 | US | Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD | ARIC, CHS | Women | | 13.7 | Hard CHD 1 (5yr) | 577 | 30 | 5.2
Hippisley-Cox JC40 | 2007 | UK | QRESEARCH database, constructed from 160 UK general practices; validation cohort | QRESEARCH (Validation) | Women | | 0 | CVD 4 (10 yr) | 309413 | 20421 | 6.6
Jee SH46 | 2008 | Korea | Koreans insured by National Health Insurance Corporation (NHIC) | | Women | | 4.1 | Stroke 6 (10 yr) | 437383 | 15988 | 3.7
Koller MT84 | 2007 | Netherlands | Rotterdam Study | | Women | | | Hard CHD 1 | 4343 | 448 | 10.3
Mainous AG14 | 2007 | US | Atherosclerosis Risk In Communities Study | ARIC | Women | | | | 8104
Miyasaka Y9 | 2007 | US | Adult residents of Olmsted County, MN | | Women | | | Total CHD 1 | 1450 | 236 | 16.3
Denes P63 | 2007 | US | Women's Health Initiative study | WHI | Women | | | CVD 15 | 14749 | 595 | 4
Denes P63 | 2007 | US | Women's Health Initiative study | WHI | Women | | | Hard CHD 1 | 14749 | 246 | 1.7
Ridker PM93 | 2007 | US | Women's Health Study (Validation Cohort) | WHS | Women | | | CVD 3 | 8158 | 262 | 3.2
Barzi F45 | 2007 | China | Asia Pacific Cohort Studies Collaboration - Total Chinese Cohort | APCSC China | Women | | | CVD 8 | 10636 | 124 | 1.2
Marrugat J38 | 2007 | Spain | Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidencts Cohort | VERIFICA | Women | | 14.6 | Total CHD 1 | 3285 | 68 | 2.1
Woodward M30 | 2007 | Scotland | Scottish Hearth Health Extended Cohort | SHHEC | Women | | 1.4 | CVD 11 (10 yr) | 6757 | 422 | 6.2
Woodward M30 | 2007 | Scotland | Scottish Hearth Health Extended Cohort | SHHEC | Women | | 1.3 | CVD 11 (10 yr) | 6757 | 422 | 6.2
Cook NR19 | 2006 | US | Women's Health Study | WHS | Women | | | CVD 3 | 15048 | 498 | 3.3
Lee ET16 | 2006 | US | Strong Heart Study | SHS | Women | | 46.7 | Hard CHD 1 | 2650 | 375 | 14.2
Donnan PT39 | 2006 | UK | Patients with type 2 diabetes registered with a Tayside GP | DARTS | Women | | | | 2166
May MD44 | 2006 | UK | British Women's Heart and Health Cohort | BWHH | Women | | | CVD 11 | 3582 | 240 | 6.7
May MD44 | 2006 | UK | British Women's Heart and Health Cohort | BWHH | Women | | | Total CHD 3 | 3582 | 198 | 5.5
Brindle PM70 | 2005 | Scotland | Renfrew and Paisley Study | | Women | | 1.1 | | 6678
Silventoinen K78 | 2005 | Finland | Individuals aged 25-65 yrs identified from Finnish population register & participating in 3 cross-sectional risk factor surveys in Finland in 1987, 1992, and 1997 | | Women | | 1 | Total CHD 1 | 9457 | 219 | 2.3
Silventoinen K78 | 2005 | Finland | Individuals aged 25-65 yrs identified from Finnish population register & participating in 3 cross-sectional risk factor surveys in Finland in 1987, 1992, and 1997 | | Women | | 1 | Stroke 1 | 9457 | 147 | 1.6
Silventoinen K78 | 2005 | Finland | Individuals aged 25-65 yrs identified from Finnish population register & participating in 3 cross-sectional risk factor surveys in Finland in 1987, 1992, and 1997 | | Women | | 1 | All-Cause Mortality | 9457 | 266 | 2.8
Bhopal R83 | 2005 | UK | Newcastle Heart Project: Europeans | NHP Europe | Women | | 3 | | 363
McNeill AM15 | 2005 | US | Atherosclerosis Risk in Communities Study | ARIC | Women | | | | 6881
Wang Z82 | 2005 | Australia | Aboriginal community | | Women | | 16 | Total CHD 1 | 331 | 38 | 11.5
Stephens JW33 | 2004 | UK | Diabetes clinic at University College London Hospitals NHS Trust | | Women | | 100 | | 294
Chambless LE12 | 2004 | US | Atherosclerosis Risk in Communities Study | ARIC | Women | | | Stroke 3 | 7274 | 221 | 3
Liu J47 | 2004 | China | Chinese Multi-Provincial Cohort Study; individuals aged 35-64 from 16 centers in 11 provinces (1992-3) and Beijing (1996-9) | MUCA | Women | | 5 | Hard CHD 1 | 14056 | 54 | 0.4
McEwan P85 | 2004 | UK | Cardiff Diabetes Database (type 1 and 2) | | Women | | | CVD 2 | 396 | 67 | 16.9
Milne R81 | 2003 | New Zealand | People recruited from workforce of nation-wide multi-industry corporation (Fletcher Challenge, Ltd. [72%]) and general elector-al rolls of Auckland metro region (28%) | | Women | | | CVD 2 (5 yrs) | 1716 | 86 | 5
Simons LA56 | 2003 | Australia | Dubbo Study cohort of elderly Australians (ages 60-79) (with DM) | DUBBO-All | Women | | | CVD 4 (5 yrs) | 1224 | 105 | 8.6
Simons LA56 | 2003 | Australia | Dubbo Study cohort of elderly Australians (ages 60-79) (with DM) | DUBBO-All | Women | | | CVD 4 (10 yrs) | 1224 | 237 | 19.4
D'Agostino RB4 | 2001 | US | Framingham Study (11th Exam) or Framingham Offspring Study (1st Exam) | FRS, FRS-O | Women | | 4 | Hard CHD 1 (5 yr) | 2812 | 39 | 1.4
Grover SA68 | 2000 | Canada | Lipid Research Clinics Prevalence Study cohort | LRCPS | Women | | 4.2 | | 734
Liao Y1 | 1999 | US | Framingham Heart Study (4th Exam) | FRS | Women | | | CHD Mortality | 2323 | 153 | 6.6
Ulmer HB76 | 2005 | Austria | Vorarlberg Health Monitoring and Promotion Program (VHM&PP); cohort of individuals undergoing general health examinations in Vorarlberg province | VHM&PP | Women | | | CVD Mortality | 24481 | 116 | 0.5
Ulmer HB76 | 2005 | Austria | Vorarlberg Health Monitoring and Promotion Program (VHM&PP); cohort of individuals undergoing general health examinations in Vorarlberg province | VHM&PP | Women | | | CHD Mortality | 24481 | 56 | 0.2
Liao Y3 | 1999 | US | First National Heatlh and Nutrition Examination Survey | NHANES I | Women | | | CHD Mortality | 3858 | 257 | 6.7
Liao Y3 | 1999 | US | Second National Heatlh and Nutrition Examination Survey | NHANES II | Women | | | CHD Mortality | 3050 | 99 | 3.2
Lindman AS71 | 2007 | Norway | Cardiovascular Program in Norway (ages 60-69) | CP-Norway | Women | | 0 | CVD Mortality | 4345 | 132 | 3
Hippisley-Cox JC34 | 2008 | UK | QRESEARCH | QRESEARCH | Women | | 0 | CVD 10 (10 yr) | 306111 | 19928 | 6.5
Hense HW61 | 2003 | Germany | PROCAM cohort; drawn from 52 companies and local govt authorities | PROCAM | Women | | 2.6 | Hard CHD 1 | 3155 | 31 | 1
Hense HW61 | 2003 | Germany | MONICA Augsburg cohort; 1984/1985 and 1989/1990 surveys | MONICA-Augsburg | Women | | 3 | Hard CHD 1 | 2925 | 32 | 1.1
Bhopal R83 | 2005 | South Asia | Newcastle Heart Project - South Asians | NHP-South Asia | Women | | 20 | | 314
Bhopal R83 | 2005 | India | Newcastle Heart Project - Indian | NHP - India | Women | | 16 | | 145
Bhopal R83 | 2005 | Pakistan | Newcastle Heart Project - Pakistani | NHP-Pakistan | Women | | 28 | | 135
D'Agostino RB4 | 2001 | US | Atherosclerosis Risk in Communities Study | ARIC | Women | | | Hard CHD 1 (5 yr) | 8045 | 84 | 1
D'Agostino RB4 | 2001 | US | Strong Heart Study (OK and Aberdeen area of ND and SD) | SHS | Women | | 51 | Hard CHD 1 (5 yr) | 2255 | 23 | 1
D'Agostino RB4 | 2001 | US | Cardiovascular Health Study | CHS | Women | | 10 | Hard CHD 1 (5 yr) | 1601 | 44 | 2.7
Kothari V54 | 2002 | United Status | Wisconsin Epidemiologic Study of Diabetic Retinopathy | WESDR | Women
Wilson PWF2 | 1998 | US | Framingham Coorth (11th Exam) Or Framingham Offspring (1st Exam) | FRS, FRS-O | Women | | 4 | Total CHD 1 | 2856 | 227 | 7.9
Cederholm J43 | 2008 | Sweden | Swedish National Diabetes Register | | Women | | 100 | | 5018
Scheltens T77 | 2008 | Netherlands | Monitoring Project on Cardiovascular Disease Risk Factors; persons randomly selected from 3 cities in Netherlands, aged 20-59 and no CVD | MP-CVDRF | Women | | | CVD Mortality (10 yr) | 21502 | 67 | 0.3
Folsom A13 | 2161 | US | Atherosclerosis Risk in Communities | ARIC | Women | | | Hard CHD 2 | 7983 | 345 | 4.3
Liao Y1 | 1999 | US | NHANES I and II (pooled) | NHANES I and II (pooled) | Women | | | CHD death | 10665 | 673 | 6.3
Simons LA56 | 2003 | Australia | Dubbo Study cohort of elderly Australians (ages 60-79) without DM | DUBBO-NoDM | Women | | | CVD 4 (10 yrs) | 1045 | 87 | 8.3