# Summary Table 8

Table 8a CVD Model Details – Americas

Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | HLGOF
Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | χ^2^ | P
Framingham Offspring Study7 | FRS-O | All | CVD 12 | Wilson AFT Model A No BMI CVD | CVD 12 | 0.775
Framingham Offspring Study7 | FRS-O | All | CVD 12 | Wilson AFT Model A CVD | CVD 12 | 0.784
Framingham Offspring Study7 | FRS-O | All | CVD 12 | Wilson AFT Model B CVD | CVD 12 | 0.801
Framingham Offspring Study7 | FRS-O | All | CVD 12 | Wilson AFT Model B No BMI CVD | CVD 12 | 0.8
National Health and Nutrition Examination Survey I Epidemiologic Follow-Up Study8 | NHANES-I EFS | Men | CVD 7 | Gaziano Lab-Based Model | CVD 7 | 0.784 | 0.766-0.801 | 6.7 | 0.57
National Health and Nutrition Examination Survey I Epidemiologic Follow-Up Study8 | NHANES-I EFS | Women | CVD 7 | Gaziano Lab-Based Model | CVD 7 | 0.829 | 0.813-0.845 | 6.62 | 0.579
National Health and Nutrition Examination Survey I Epidemiologic Follow-Up Study8 | NHANES-I EFS | Men | CVD 7 | Gaziano Non-Lab-Based Model | CVD 7 | 0.783 | 0.765-0.800 | 6.61 | 0.579
National Health and Nutrition Examination Survey I Epidemiologic Follow-Up Study8 | NHANES-I EFS | Women | CVD 7 | Gaziano Non-Lab-Based Model | CVD 7 | 0.831 | 0.816-0.847 | 3.45 | 0.903
Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87)6 | FRS, FRS-O | Men | CVD 2 | D'Agostino CVD MALE | CVD 2 | 0.763 | 0.746-0.780 | 13.48 | 0
Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87)6 | FRS, FRS-O | Women | CVD 2 | D'Agostino CVD FEMALE | CVD 2 | 0.793 | 0.772-0.814 | 7.79 | 0.56
Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87)6 | FRS, FRS-O | Men | Total CHD 1 | D'Agostino CVD MALE | CVD 2 | 0.733 | 0.712-0.754 | 18.2 | 0
Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87)6 | FRS, FRS-O | Women | Total CHD 1 | D'Agostino CVD FEMALE | CVD 2 | 0.787 | 0.762-0.812 | 14.79 | 0
Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87)6 | FRS, FRS-O | Men | Stroke 4 | D'Agostino CVD MALE | CVD 2 | 0.826 | 0.789-0.863 | 26.11 | 0
Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87)6 | FRS, FRS-O | Women | Stroke 4 | D'Agostino CVD FEMALE | CVD 2 | 0.769 | 0.715-0.822 | 5.26 | 0.811
Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87)6 | FRS, FRS-O | Men | CHF | D'Agostino CVD MALE | CVD 2 | 0.841 | 0.799-0.883 | 27.23 | 0
Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87)6 | FRS, FRS-O | Women | CHF | D'Agostino CVD FEMALE | CVD 2 | 0.847 | 0.803-0.891 | 9.32 | 0
Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87)6 | FRS, FRS-O | Men | PVD | D'Agostino CVD MALE | CVD 2 | 0.813 | 0.780-0.847 | 19.05 | 0
Framingham Cohort (11th) (68-71) & Offspring 1st (71-75) & Offspring (3rd 84-87)6 | FRS, FRS-O | Women | PVD | D'Agostino CVD FEMALE | CVD 2 | 0.829 | 0.786-0.872 | 11.33 | 0
Lipid Research Clinics Prevalence Study cohort68 | LRCPS | All | CHD Mortality | FRS (1991) | CVD 2 | 0.83 | 0.02
Lipid Research Clinics Prevalence Study cohort68 | LRCPS | Men | CHD Mortality | FRS (1991) | CVD 2 | 0.83
Lipid Research Clinics Prevalence Study cohort68 | LRCPS | Women | CHD Mortality | FRS (1991) | CVD 2 | 0.82
Atherosclerosis Risk in Communities Study4 | ARIC | White Men | Hard CHD 1 (5 yr) | FRS (1991) | CVD 2 | 0.75 | | 13.8
Atherosclerosis Risk in Communities Study4 | ARIC | White Women | Hard CHD 1 (5 yr) | FRS (1991) | CVD 2 | 0.83 | | 6.2
Atherosclerosis Risk in Communities Study4 | ARIC | Black Men | Hard CHD 1 (5 yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.67 | | 5.3
Atherosclerosis Risk in Communities Study4 | ARIC | Black Women | Hard CHD 1 (5 yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.79 | | 5
Honolulu Heart Program4 | HHP | Men | Hard CHD 1 (5 yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.72 | | 66
Puerto Rico Heart Health Program4 | PRHHP | Men | Hard CHD 1 (5 yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.69 | | 142
Strong Heart Study (area of Oklahoma and Aberdeen area of North and South Dakota)4 | SHS | Men | Hard CHD 1 (5 yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.69 | | 10.6
Strong Heart Study (area of Oklahoma and Aberdeen area of North and South Dakota)4 | SHS | Women | Hard CHD 1 (5 yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.75 | | 22.7
Women's Health Study (Validation Cohort)20 | WHS (Val) | All | CVD 3 | Ridker Model A | CVD 3 | 0.809 | | | 0.38
Women's Health Study (Validation Cohort)20 | WHS (Val) | All | CVD 3 | Ridker Model B | CVD 3 | 0.808 | | | 0.62
Women's Health Study (Validation Cohort)20 | WHS (Val) | All | CVD 3 | FRS (Wilson TC) Remodel | CVD 3 | 0.791 | | | 0.18
Women's Health Study (Validation Cohort)20 | WHS (Val) | All | CVD 3 | FRS (Wilson LDL) Remodel | CVD 3 | 0.791 | | | 0.16
Women's Health Study19 | WHS | All | CVD 3 | WHS Model with hsCRP | CVD 3 | 0.815 | | | 0.23
Women's Health Study19 | WHS | All | CVD 3 | WHS Model without hsCRP | CVD 3 | 0.813 | | | 0.039
Cardiovascular Health Study4 | CHS | Men | Hard CHD 1 (5 yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.63 | | 13.2
Cardiovascular Health Study4 | CHS | Women | Hard CHD 1 (5 yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.66 | | 10.4
Women's Genome Health Study55 | WGHS | All | CVD 3 | FRS (ATP) WGHS Remodel | CVD 3 | 0.803 | 0.019 | 6.24 | 0.62
Women's Health Study55 | WHS | All | CVD 3 | FRS (ATP) WHS Cook Remodel | CVD 3 | 0.814 | | | 0.25
Women's Genome Health Study55 | WGHS | All | CVD 3 | Reynolds Risk Score Remodel | CVD 3 | 0.807 | 0.019 | 7.75 | 0.46
Women's Genome Health Study55 | WGHS | All | CVD 3 | ATP-III (Remodel) + genotype | CVD 3 | 0.805 | 0.019 | 5.96 | 0.65
Women's Genome Health Study55 | WGHS | All | CVD 3 | Reynolds Risk Score (Remodel) + genotype | CVD 3 | 0.809 | 0.019 | 7.43 | 0.49
Physicians Health Study II59 | PHS-II | All | CVD 15 | Ridker Model A, PHS-II | CVD 15 | 0.699 | | 11.3
Physicians Health Study II59 | PHS-II | All | CVD 15 | Reynolds Risk Score + CRP + parental history | CVD 15 | 0.708 | | 12.9
Physicians Health Study II59 | PHS-II | All | Hard CHD 2 | Ridker Model A, PHS-II | CVD 15 | 0.689
Physicians Health Study II59 | PHS-II | All | Hard CHD 2 | Reynolds Risk Score + CRP + parental history | CVD 15 | 0.7

Table 8b CHD Model Details – Americas

Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | HLGOF | | O/E Ratio
Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | χ^2^ | P | O/E Ratio
Framingham Offspring Study7 | FRS-O | All | Total CHD 1 | Wilson AFT Model E CHD | Total CHD 1 | 0.813
Framingham Offspring Study7 | FRS-O | All | Total CHD 1 | Wilson AFT Model D CHD | Total CHD 1 | 0.812
Framingham Offspring Study7 | FRS-O | All | Total CHD 1 | Wilson AFT Model B CHD | Total CHD 1 | 0.808
Framingham Offspring Study7 | FRS-O | All | Total CHD 1 | Wilson AFT Model A CHD | Total CHD 1 | 0.791
Framingham Offspring Study7 | FRS-O | All | Total CHD 1 | Wilson AFT Model A No BMI CHD | Total CHD 1 | 0.784
Framingham Offspring Study7 | FRS-O | All | Total CHD 1 | Wilson AFT Model C CHD | Total CHD 1 | 0.796
Framingham Offspring Study7 | FRS-O | All | Total CHD 1 | Wilson AFT Model E No BMI CHD | Total CHD 1 | 0.814
Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD64 | ARIC, CHS | Men | Hard CHD 1 (10yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.6 | | 72.3 | 0 | 1.492
Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD64 | ARIC, CHS | Women | Hard CHD 1 (10yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.73 | | 75.1 | 0 | 2.022
Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD64 | ARIC, CHS | Women | Hard CHD 1 (10yr) | FRS CKD Best Cox, females | Hard CHD 1 | 0.81 | | 2.5
Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD64 | ARIC, CHS | Men | Hard CHD 1 (10yr) | FRS CKD Best Cox, males | Hard CHD 1 | 0.68 | | 4
Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD64 | ARIC, CHS | Men | Hard CHD 1 (5yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.62 | | 33.4 | 0 | 1.636
Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD64 | ARIC, CHS | Women | Hard CHD 1 (5yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.77 | | 61.2 | 0 | 2.727
Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD64 | ARIC, CHS | Women | Hard CHD 1 (5yr) | FRS CKD Best Cox, females | Hard CHD 1 | 0.82 | | 0.8
Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD64 | ARIC, CHS | Men | Hard CHD 1 (5yr) | FRS CKD Best Cox, males | Hard CHD 1 | 0.72 | | 4.2
Atherosclerosis Risk in Communities and Cardiovascular Health Study trials with CKD64 | ARIC, CHS | Women | Hard CHD 1 (5 yr) | FRS CKD recal | Hard CHD 1 | | | 8.7
Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD64 | ARIC | Women | Hard CHD 1 (10 yr) | FRS CKD recal | Hard CHD 1 | | | 8.9
Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD64 | ARIC, CHS | Men | Hard CHD 1 (5 yr) | FRS CKD recal | Hard CHD 1 | | | 13.7
Atherosclerosis Risk In Communities and Cardiovascular health Study trials with CKD64 | ARIC, CHS | Men | Hard CHD 1 (10 yr) | FRS CKD recal | Hard CHD 1 | | | 32.3
Women's Health Initiative study63 | WHI | All | Hard CHD 1 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.69
Women's Health Initiative study63 | WHI | Women | Hard CHD 1 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.69
Women's Health Initiative study63 | WHI | All | CVD 15 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.68
Women's Health Initiative study63 | WHI | Women | CVD 15 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.68
San Antonio Heart Study66 | SAHS | All | CVD 15 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.816
St Francis Heart Study91 | SFHS | All | Hard CHD 2 | FRS (ATP) | Hard CHD 1 | 0.68 | 0.62-0.74
Atherosclerosis Risk in Communities Study15 | ARIC | Men | Hard CHD 2 | Metabolic Syndrome Model | Hard CHD 2 | 0.631
Atherosclerosis Risk in Communities Study15 | ARIC | Women | Hard CHD 2 | Metabolic Syndrome Model | Hard CHD 2 | 0.729
Atherosclerosis Risk in Communities Study15 | ARIC | Men | Hard CHD 2 | FRS (ATP) | Hard CHD 1 | 0.634
Atherosclerosis Risk in Communities Study15 | ARIC | Women | Hard CHD 2 | FRS (ATP) | Hard CHD 1 | 0.731
Strong Heart Study16 | SHS | Men | Hard CHD 1 | SHS Model | Hard CHD 1 | 0.71 | | 7.18 | 0.51
Strong Heart Study16 | SHS | Women | Hard CHD 1 | SHS Model | Hard CHD 1 | 0.73 | | 7.25 | 0.45
South Bay Heart Watch cohort17 | SBHW | All | Hard CHD 1 | FRS (ATP) | Hard CHD 1 | 0.63
South Bay Heart Watch cohort17 | SBHW | All | Hard CHD 1 | FRS (2001 ATP) + CACS | Hard CHD 1 | 0.68
Normative Aging Study - male veterans67 | NAS | All | Total CHD 1 | European Society of Cardiology (ESC) | Total CHD 1 | 0.58
Normative Aging Study - male veterans67 | NAS | All | Total CHD 1 | FRS [TC] (1998) | Total CHD 1 | 0.63 | | | | 0.928
Atherosclerosis Risk In Communities Study14 | ARIC | Men | Hard CHD 2 | FRS [TC] (Wilson) | Hard CHD 1 | 0.691 | 0.670-9.712
Atherosclerosis Risk In Communities Study14 | ARIC | Women | Hard CHD 2 | FRS [TC] (Wilson) | Hard CHD 1 | 0.808 | 0.792-0.823
Atherosclerosis Risk In Communities Study14 | ARIC | Men | Hard CHD 2 | Personal HEART | Hard CHD 2 | 0.649
Atherosclerosis Risk In Communities Study14 | ARIC | Men | Hard CHD 2 | Personal HEART | Hard CHD 2 | 0.649 | 0.627-0.671
Atherosclerosis Risk In Communities Study14 | ARIC | Women | Hard CHD 2 | Personal HEART | Hard CHD 2 | 0.788 | 0.772-0.804
Atherosclerosis Risk In Communities Study14 | ARIC | Women | Hard CHD 2 | Personal HEART | Hard CHD 2 | 0.788
South Bay Heart Watch18 | SBHW | All | Hard CHD 1 | FRS (1991) | Hard CHD 1 | 0.69 | 0.05 | | | 1.165
South Bay Heart Watch18 | SBHW | All | Hard CHD 1 | Detrano - Data Derived | Hard CHD 1 | 0.68 | 0.05
South Bay Heart Watch18 | SBHW | All | Hard CHD 1 | Detrano - Data Derived + Ca | Hard CHD 1 | 0.71 | 0.04
First National Health and Nutrition Examination Survey3 | NHANES I | Men | CHD Mortality | FRS (Custom 4 Variable) | CHD Mortality | 0.71 | | | | 0.90
First National Health and Nutrition Examination Survey3 | NHANES I | Women | CHD Mortality | FRS (Custom 4 Variable) | CHD Mortality | 0.8
First National Health and Nutrition Examination Survey3 | NHANES I | Men | CHD Mortality | NHANES I (4 Variables) | CHD Mortality | 0.71
First National Health and Nutrition Examination Survey3 | NHANES I | Women | CHD Mortality | NHANES I (4 Variables) | CHD Mortality | 0.81
Second National Health and Nutrition Examination Survey3 | NHANES II | Men | CHD Mortality | FRS (Custom 4 Variable) | CHD Mortality | 0.74 | | | | 0.649
Second National Health and Nutrition Examination Survey3 | NHANES II | Women | CHD Mortality | FRS (Custom 4 Variable) | CHD Mortality | 0.76
Second National Health and Nutrition Examination Survey3 | NHANES II | Men | CHD Mortality | NHANES II (4 Variable) | CHD Mortality | 0.75
Second National Health and Nutrition Examination Survey3 | NHANES II | Women | CHD Mortality | NHANES II (4 Variable) | CHD Mortality | 0.77
Framingham Study (11th Exam) or Framingham Offspring Study (1st Exam)4 | FRS, FRS-O | Men | Hard CHD 1 (5 yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.79
Framingham Study (11th Exam) or Framingham Offspring Study (1st Exam) 4 | FRS, FRS-O | Women | Hard CHD 1 (5 yr) | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.83
Framingham Study (11th Exam) or Framingham Offspring Study (1st Exam) 4 | FRS, FRS-O | Men | Hard CHD 1 (5 yr) | FRS White Male Best Cox Model | Hard CHD 1 | 0.79 | | 3.3
Framingham Study (11th Exam) or Framingham Offspring Study (1st Exam) 4 | FRS, FRS-O | Women | Hard CHD 1 (5 yr) | FRS White Female Best Cox Model | Hard CHD 1 | 0.83 | | 3.7
Atherosclerosis Risk in Communities Study4 | ARIC | Black Men | Hard CHD 1 (5 yr) | ARIC Black Male Best Cox Model | Hard CHD 1 | 0.7 | | 7.2
Atherosclerosis Risk in Communities Study4 | ARIC | White Men | Hard CHD 1 (5 yr) | ARIC White Male Best Cox Model | Hard CHD 1 | 0.76 | | 5.4
Atherosclerosis Risk in Communities Study4 | ARIC | Black Women | Hard CHD 1 (5 yr) | ARIC Black Female Best Cox Model | Hard CHD 1 | 0.85 | | 3.4
Atherosclerosis Risk in Communities Study4 | ARIC | White Women | Hard CHD 1 (5 yr) | ARIC White Female Best Cox Model | Hard CHD 1 | 0.84 | | 5.2
Honolulu Heart Program4 | HHP | Men | Hard CHD 1 (5 yr) | HHP Male Best Cox Model | Hard CHD 1 | 0.74 | | 2.6
Puerto Rico Heart Health Program4 | PRHHP | Men | Hard CHD 1 (5 yr) | PR Male Best Cox Model | Hard CHD 1 | 0.72 | | 7.2
Strong Heart Study (area of Oklahoma and Aberdeen area of North and South Dakota)4 | SHS | Men | Hard CHD 1 (5 yr) | SHS Native American Male Best Cox Model | Hard CHD 1 | 0.77 | | 2.7
Strong Heart Study (area of Oklahoma and Aberdeen area of North and South Dakota)4 | SHS | Women | Hard CHD 1 (5 yr) | SHS Native American Female Best Cox Model | Hard CHD 1 | 0.86 | | 3.5
Women's Health Study (Validation Cohort)20 | WHS (Val) | All | CVD 3 | FRS [TC] (1998) | Total CHD 1 | 0.752 | | | <0.001
Women's Health Study (Validation Cohort)20 | WHS (Val) | All | CVD 3 | FRS (ATP) | Hard CHD 1 | 0.787 | | | <0.001
Women's Health Study (Validation Cohort)20 | WHS (Val) | All | CVD 3 | FRS [LDL] (1998) | Total CHD 1 | 0.751 | | | <0.001
Framingham Cohort (11th Exam) Or Framingham Offspring (1st Exam)2 | FRS, FRS-O | Men | Total CHD 1 | FRS [LDL] (1998) | Total CHD 1 | 0.74
Framingham Cohort (11th Exam) Or Framingham Offspring (1st Exam)2 | FRS, FRS-O | Women | Total CHD 1 | FRS [LDL] (1998) | Total CHD 1 | 0.77
South Bay Heart Watch18 | SBHW | All | Hard CHD 2 | FRS (1991) | Total CHD 1 | 0.67 | 0.04
South Bay Heart Watch18 | SBHW | All | Hard CHD 2 | Detrano - Data Derived | Hard CHD 1 | 0.69 | 0.04
South Bay Heart Watch18 | SBHW | All | Hard CHD 2 | Detrano - Data Derived + Ca | Hard CHD 1 | 0.72 | 0.04
Cardiovascular Health Study4 | CHS | Men | Hard CHD 1 (5 yr) | CHS White Male Best Cox Model | Hard CHD 1 | 0.69 | | 6.8
Cardiovascular Health Study4 | CHS | Women | Hard CHD 1 (5 yr) | CHS White Female Best Cox Model | Hard CHD 1 | 0.68 | | 6.8
Atherosclerosis Risk in Communities Study15 | ARIC | Men | Hard CHD 2 (6 yr) | FRS (ATP) | Hard CHD 1 | 0.646
Atherosclerosis Risk in Communities Study15 | ARIC | Women | Hard CHD 2 (6 yr) | FRS (ATP) | Hard CHD 1 | 0.667
Atherosclerosis Risk in Communities Study15 | ARIC | All | Hard CHD 2 (6 yr) | FRS (ATP) | Hard CHD 1 | 0.72
Atherosclerosis Risk in Communities13 | ARIC | Diabetic men | Hard CHD 2 | ARIC, diabetes-specific basic risk factors, liberal definition of diabetes | Hard CHD 2 | 0.672
Atherosclerosis Risk in Communities13 | ARIC | Diabetic women | Hard CHD 2 | ARIC, diabetes-specific basic risk factors, liberal definition of diabetes | Hard CHD 2 | 0.721
Atherosclerosis Risk in Communities13 | ARIC | Non-diabetic men | Hard CHD 2 | ARIC, diabetes-specific basic risk factors, liberal definition of diabetes | Hard CHD 2 | 0.786
Atherosclerosis Risk in Communities13 | ARIC | Non-diabetic women | Hard CHD 2 | ARIC, diabetes-specific basic risk factors, liberal definition of diabetes | Hard CHD 2 | 0.688
Atherosclerosis Risk in Communities13 | ARIC | Diabetic men | Hard CHD 2 | ARIC, diabetes-specific basic risk factors, restrictive definition of diabetes (only drug-treated diabetes) | Hard CHD 2 | 0.75
Atherosclerosis Risk in Communities13 | ARIC | Diabetic women | Hard CHD 2 | ARIC, diabetes-specific basic risk factors, restrictive definition of diabetes (only drug-treated diabetes) | Hard CHD 2 | 0.7
Atherosclerosis Risk in Communities13 | ARIC | Diabetic men | Hard CHD 2 | ARIC, combined model, basic risk factors | Hard CHD 2 | 0.65
Atherosclerosis Risk in Communities13 | ARIC | Diabetic women | Hard CHD 2 | ARIC, combined model, basic risk factors | Hard CHD 2 | 0.71
Atherosclerosis Risk in Communities13 | ARIC | Diabetic men | Hard CHD 2 | ARIC, diabetes-specific basic + multiple risk factors, liberal definition of diabetes | Hard CHD 2 | 0.74
Atherosclerosis Risk in Communities13 | ARIC | Diabetic women | Hard CHD 2 | ARIC, diabetes-specific basic + multiple risk factors, liberal definition of diabetes | Hard CHD 2 | 0.771
Atherosclerosis Risk in Communities13 | ARIC | Non-diabetic men | Hard CHD 2 | ARIC, diabetes-specific basic + multiple risk factors, liberal definition of diabetes | Hard CHD 2 | 0.711
Atherosclerosis Risk in Communities13 | ARIC | Non-diabetic women | Hard CHD 2 | ARIC, diabetes-specific basic + multiple risk factors, liberal definition of diabetes | Hard CHD 2 | 0.796
Atherosclerosis Risk in Communities13 | ARIC | Diabetic men | Hard CHD 2 | ARIC, diabetes-specific basic markers | Hard CHD 2 | 0.68
Atherosclerosis Risk in Communities13 | ARIC | Diabetic women | Hard CHD 2 | ARIC, diabetes-specific basic markers | Hard CHD 2 | 0.711
Atherosclerosis Risk in Communities13 | ARIC | Non-diabetic men | Hard CHD 2 | ARIC, diabetes-specific basic markers | Hard CHD 2 | 0.679
Atherosclerosis Risk in Communities13 | ARIC | Non-diabetic women | Hard CHD 2 | ARIC, diabetes-specific basic markers | Hard CHD 2 | 0.777
Atherosclerosis Risk in Communities13 | ARIC | Diabetic men | Hard CHD 2 | ARIC, diabetes-specific basic+multiple markers | Hard CHD 2 | 0.702
Atherosclerosis Risk in Communities13 | ARIC | Diabetic women | Hard CHD 2 | ARIC, diabetes-specific basic+multiple markers | Hard CHD 2 | 0.723
Atherosclerosis Risk in Communities13 | ARIC | Non-diabetic men | Hard CHD 2 | ARIC, diabetes-specific basic+multiple markers | Hard CHD 2 | 0.702
Atherosclerosis Risk in Communities13 | ARIC | Non-diabetic women | Hard CHD 2 | ARIC, diabetes-specific basic+multiple markers | Hard CHD 2 | 0.781
Atherosclerosis Risk in Communities13 | ARIC | Diabetic men | Hard CHD 2 | ARIC, diabetes-specific basic risk factors, restrictive definition of diabetes (only physician-diagnosed or -treated diabetes) | Hard CHD 2 | 0.72
Atherosclerosis Risk in Communities13 | ARIC | Diabetic women | Hard CHD 2 | ARIC, diabetes-specific basic risk factors, restrictive definition of diabetes (only physician-diagnosed or -treated diabetes) | Hard CHD 2 | 0.7
NHANES I and II (pooled)1 | NHANES I and II (pooled) | White men | CHD death | NHANES I and II, pooled | CHD Mortality | 0.77
NHANES I and II (pooled)1 | NHANES I and II (pooled) | Black men | CHD death | NHANES I and II, pooled | CHD Mortality | 0.76
NHANES I and II (pooled)1 | NHANES I and II (pooled) | White women | CHD death | NHANES I and II, pooled | CHD Mortality | 0.84
NHANES I and II (pooled)1 | NHANES I and II (pooled) | Black women | CHD death | NHANES I and II, pooled | CHD Mortality | 0.82
Johns Hopkins Sibling Study10 | JHSS | Women | Total CHD 1 | FRS [TC] (1998) | Total CHD 1 | | | 8 | | 1.128
Johns Hopkins Sibling Study10 | JHSS | Men | Total CHD 1 | FRS Wilson-D'Agostino Recal | Total CHD 1 | | | 9
Johns Hopkins Sibling Study10 | JHSS | Men | Total CHD 1 | FRS [TC] (1998) | Total CHD 1 | | | 7.5 | | 1.671
Johns Hopkins Sibling Study10 | JHSS | Women | Total CHD 1 | FRS Wilson-D'Agostino Recal | Total CHD 1 | | | 8
Chicago young adults5 | CHA | Men | Hard CHD 1 (10 yr) | FRS [TC] (1998) | Total CHD 1 | | | | | 0.046
Chicago young adults5 | CHA | Men | Hard CHD 1 (10 yr) | FRS (ATP) | Hard CHD 1 | | | | | 0.072
Chicago young adults5 | CHA | Men | Hard CHD 1 (30 yr) | CHA | CHD Mortality | | | | | 0.95
Adult residents of Olmsted County, Minnesota9 | Mayo | Men | Total CHD 1 | Miyasaka CHD Post-AF | Total CHD 1 | | | | | 0.783
Adult residents of Olmsted County, Minnesota9 | Mayo | Women | Total CHD 1 | Miyasaka CHD Post-AF | Total CHD 1 | | | | | 0.857

Table 8c Stroke Model Details – Americas

Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | O/E Ratio
Framingham Offspring Study7 | FRS-O | All | Stroke 2 | Wilson AFT Model A No BMI CeVD | Stroke 2 | 0.772
Framingham Offspring Study7 | FRS-O | All | Stroke 2 | Wilson AFT Model A CeVD | Stroke 2 | 0.792
Framingham Offspring Study7 | FRS-O | All | Stroke 2 | Wilson AFT Model B CeVD | Stroke 2 | 0.798
Framingham Offspring Study7 | FRS-O | All | Stroke 2 | Wilson AFT Model C CeVD | Stroke 2 | 0.8
Framingham Offspring Study7 | FRS-O | All | Stroke 2 | Wilson AFT Model D CeVD | Stroke 2 | 0.804
Framingham Offspring Study7 | FRS-O | All | Stroke 2 | Wilson AFT Model D No BMI CeVD | Stroke 2 | 0.798
Atherosclerosis Risk in Communities Study12 | ARIC | Men | Stroke 3 | Chambless Basic Men | Stroke 3 | 0.756
Atherosclerosis Risk in Communities Study12 | ARIC | Women | Stroke 3 | Chambless Basic Women | Stroke 3 | 0.792
Atherosclerosis Risk in Communities Study12 | ARIC | Men | Stroke 3 | Chambless BM + Age + Race | Stroke 3 | 0.789
Atherosclerosis Risk in Communities Study12 | ARIC | Men | Stroke 3 | Chambless BM + NTRF + Age + Race | Stroke 3 | 0.803
Atherosclerosis Risk in Communities Study12 | ARIC | Women | Stroke 3 | Chambless BW + Age + Race | Stroke 3 | 0.813
Atherosclerosis Risk in Communities Study12 | ARIC | Women | Stroke 3 | Chambless BW + NTRF + Age + Race | Stroke 3 | 0.837
Wisconsin Epidemiologic Study of Diabetic Retinopathy54 | WESDR | All | Stroke Mortality | UKPDS 60 | Stroke 1 | | 1.135
Wisconsin Epidemiologic Study of Diabetic Retinopathy54 | WESDR | All | Stroke Mortality | FRS (1991) | CVD 2 | | 1.788

Table 8d CVD Model Details – Europe

Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | HLGOF | | O/E Ratio
Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | χ^2^ | P | O/E Ratio
Consecutive patients referred by primary care provider for preventive cardiological exam41 | LudwigU | All | Hard CHD 1 | SCORE (Unknown Version) | CVD Mortality | 0.66 | 0.62-0.68
Members of the QRESEARCH database34 | QRESEARCH | Validation-Men | CVD 1 | QRISK | CVD 4 | 0.788 | 0.786-0.791
Members of the QRESEARCH database34 | QRESEARCH | Validation-Women | CVD 1 | QRISK | CVD 4 | 0.814 | 0.811-0.817
Members of the QRESEARCH database34 | QRESEARCH | Validation-Men | CVD 1 | QRISK2 | CVD 1 | 0.792 | 0.789-0.794
Members of the QRESEARCH database34 | QRESEARCH | Validation-Women | CVD 1 | QRISK2 | CVD 1 | 0.817 | 0.814-0.820
Members of the QRESEARCH database34 | QRESEARCH | Validation-Men | CVD 1 | FRS (1991), NICE-Modified | CVD | 0.779 | 0.776-0.782
Members of the QRESEARCH database34 | QRESEARCH | Validation-Women | CVD 1 | FRS (1991), NICE-Modified | CVD | 0.8 | 0.797-0.803
Scottish Hearth Health Extended Cohort30 | SHHEC | Men | CVD 11 (10 yr) | ASSIGN | CVD 11 | 0.727 | | | | 0.789
Scottish Hearth Health Extended Cohort30 | SHHEC | Women | CVD 11 (10 yr) | ASSIGN | CVD 11 | 0.765 | | | | 0.672
Scottish Hearth Health Extended Cohort30 | SHHEC | Men | CVD 11 (10 yr) | FRS (1991) | CVD 2 | 0.716 | | | | 0.71
Scottish Hearth Health Extended Cohort30 | SHHEC | Women | CVD 11 (10 yr) | FRS (1991) | CVD 2 | 0.741 | | | | 0.651
Diabetes clinic at University College London Hospitals NHS Trust33 | NHS Trust | All | CVD 18 | JBSRC | CVD | 0.8 | 0.75-0.85
Diabetes clinic at University College London Hospitals NHS Trust33 | NHS Trust | All | CVD 18 | CRM | CVD | 0.76 | 0.72-0.79 | | | 2.301
Diabetes clinic at University College London Hospitals NHS Trust33 | NHS Trust | All | Total CHD 2 | JBSRC | CVD | 0.77 | 0.74-0.80
Diabetes clinic at University College London Hospitals NHS Trust33 | NHS Trust | All | Total CHD 2 | CRM | CVD | 0.73 | 0.70-0.77 | | | 1.74
Uppsala Longitudinal Study of Adult Men (Baseline Age 70 Cohort)23 | ULSAM (70) | All | CVD Mortality | FRS (Wilson 1998) + ECG | CVD Mortality | 0.67
Poole Diabetes Study86 | PDS | All | Total CHD 3 | FRS (1991) | Total CHD 1 | 0.657 | 0.581-0.732 | 19.8 | 0 | 1.471
Poole Diabetes Study86 | PDS | All-excluding LVH | Total CHD 3 | FRS (1991) | Total CHD 1 | 0.665 | 0.591-0.740 | 22.6 | 0
Poole Diabetes Study86 | PDS | Men | Total CHD 3 | FRS (1991) | Total CHD 1 | 0.726 | 0.643-0.810
Poole Diabetes Study86 | PDS | Women | Total CHD 3 | FRS (1991) | Total CHD 1 | 0.697 | 0.635-0.760
Poole Diabetes Study86 | PDS | Pretreated blood pressure | Total CHD 3 | FRS (1991) | Total CHD 1 | 0.666 | 0.538-0.795
Poole Diabetes Study86 | PDS | Untreated blood pressure | Total CHD 3 | FRS (1991) | Total CHD 1 | 0.663 | 0.568-0.758
Poole Diabetes Study86 | PDS | All | CVD 13 | FRS (1991) | CVD 2 | 0.673 | 0.612-0.734 | 32.8 | 0 | 1.517
Poole Diabetes Study86 | PDS | All-excluding LVH | CVD 13 | FRS (1991) | CVD 2 | 0.678 | 0.618-0.739 | 39.5 | 0
Poole Diabetes Study86 | PDS | Men | CVD 13 | FRS (1991) | CVD 2 | 0.669 | 0.590-0.747
Poole Diabetes Study86 | PDS | Women | CVD 13 | FRS (1991) | CVD 2 | 0.678 | 0.580-0.776
Poole Diabetes Study86 | PDS | Pretreated blood pressure | CVD 13 | FRS (1991) | CVD 2 | 0.634 | 0.530-0.739
Poole Diabetes Study86 | PDS | Untreated blood pressure | CVD 13 | FRS (1991) | CVD 2 | 0.69 | 0.613-0.767
Cardiff Diabetes Database (type 1 and type 2)85 | Cardiff DM | Men | CVD 2 | FRS (1991) | CVD 2 | 0.64 | | | | 0.815
Cardiff Diabetes Database (type 1 and type 2)85 | Cardiff DM | Women | CVD 2 | FRS (1991) | CVD 2 | 0.66 | | | | 0.86
Cardiff Diabetes Database (type 1 and type 2)85 | Cardiff DM | Men | CVD 2 | FRS (1991) Cardiff Diabetes Remodel | CVD 2 | 0.65
Cardiff Diabetes Database (type 1 and type 2)85 | Cardiff DM | Women | CVD 2 | FRS (1991) Cardiff Diabetes Remodel | CVD 2 | 0.68
Vorarlberg Health Monitoring and Promotion Program (VHM&PP) cohort undergoing general health exams in Vorarlberg province76 | VHM&PP | All | CVD Mortality | SCORE (Low Risk TC) | CVD Mortality | 0.8 | 0.79-0.82 | | | 0.731
Vorarlberg Health Monitoring and Promotion Program (VHM&PP) cohort undergoing general health exams in Vorarlberg province76 | VHM&PP | Men | CVD Mortality | SCORE (Low Risk TC) | CVD Mortality | 0.76 | 0.74-0.79 | | | 0.836
Vorarlberg Health Monitoring and Promotion Program (VHM&PP) cohort undergoing general health exams in Vorarlberg province76 | VHM&PP | Women | CVD Mortality | SCORE (Low Risk TC) | CVD Mortality | 0.78 | 0.74-0.82 | | | 0.523
Vorarlberg Health Monitoring and Promotion Program (VHM&PP) cohort undergoing general health exams in Vorarlberg province76 | VHM&PP | Men | CHD Mortality | SCORE (Low Risk TC) | CVD Mortality | 0.75 | 0.72-0.78 | | | 0.79
Vorarlberg Health Monitoring and Promotion Program (VHM&PP) cohort undergoing general health exams in Vorarlberg province76 | VHM&PP | Women | CHD Mortality | SCORE (Low Risk TC) | CVD Mortality | 0.84 | 0.80-0.88 | | | 0.463
Individuals recruited from workforce of a nationwide multi-industry corporation (Fletcher Challenge, Ltd. [72%]) and general electoral rolls of Auckland metro region (28%)81 | NZWork | Men | CVD 2 (5 yrs) | New Zealand risk charts | CVD | 0.73 | 0.72-0.74
Individuals recruited from workforce of a nationwide multi-industry corporation (Fletcher Challenge, Ltd. [72%]) and general electoral rolls of Auckland metro region (28%)81 | NZWork | Women | CVD 2 (5 yrs) | New Zealand risk charts | CVD | 0.78 | 0.75-0.81
Individuals recruited from workforce of a nationwide multi-industry corporation (Fletcher Challenge, Ltd. [72%]) and general electoral rolls of Auckland metro region (28%)81 | NZWork | Men | CVD 2 (5 yrs) | FRS (1991) | CVD 2 | 0.74 | 0.73-0.75 | | | 1.173
Individuals recruited from workforce of a nationwide multi-industry corporation (Fletcher Challenge, Ltd. [72%]) and general electoral rolls of Auckland metro region (28%)81 | NZWork | Women | CVD 2 (5 yrs) | FRS (1991) | CVD 2 | 0.77 | 0.74-0.80 | | | 1.089
British Regional Heart Study, men aged 40-59 years72 | BRHS | Men | Hard CHD 1 + Stroke 1 + DM2 (20 yrs) | FRS (1991) | Total CHD 1 | 0.67 | 0.65-0.69
British Regional Heart Study, men aged 40-59 years72 | BRHS | Men | Hard CHD 1 (10 yrs) | FRS (1991) | Total CHD 1 | 0.73 | 0.71-0.75
British Regional Heart Study, men aged 40-59 years72 | BRHS | Men | Hard CHD 1 (20 yrs) | FRS (1991) | Total CHD 1 | 0.68 | 0.66-0.70 | | | 2.5
British Regional Heart Study, men aged 40-59 years72 | BRHS | Men | Stroke 1 (10 yrs) | FRS (1991) | Total CHD 1 | 0.71 | 0.65-0.77
British Regional Heart Study, men aged 40-59 years72 | BRHS | Men | Stroke 1 (20 yrs) | FRS (1991) | Total CHD 1 | 0.66 | 0.62-0.70
British Regional Heart Study, men aged 40-59 years72 | BRHS | Men | Diabetes, Type 2 (10 yrs) | FRS (1991) | Total CHD 1 | 0.61 | 0.55-0.67
British Regional Heart Study, men aged 40-59 years72 | BRHS | Men | Diabetes, Type 2 (20 yrs) | FRS (1991) | Total CHD 1 | 0.6 | 0.56-0.64
QRESEARCH database, constructed from 160 UK general practices; validation cohort40 | QRESEARCH (Val) | Men | CVD 4 (10 yr) | ASSIGN | CVD 11 | 0.764 | | | | 0.734
QRESEARCH database, constructed from 160 UK general practices; validation cohort40 | QRESEARCH (Val) | Women | CVD 4 (10 yr) | ASSIGN | CVD 11 | 0.784 | | | | 0.727
QRESEARCH database, constructed from 160 UK general practices; validation cohort40 | QRESEARCH (Val) | Men | CVD 4 (10 yr) | FRS (1991) | CVD 2 | 0.76 | | | | 0.681
QRESEARCH database, constructed from 160 UK general practices; validation cohort40 | QRESEARCH (Val) | Women | CVD 4 (10 yr) | FRS (1991) | CVD 2 | 0.774 | | | | 0.83
QRESEARCH database, constructed from 160 UK general practices; validation cohort40 | QRESEARCH (Val) | Men | CVD 4 (10 yr) | QRISK | CVD 4 | 0.767 | | | | 1.002
QRESEARCH database, constructed from 160 UK general practices; validation cohort40 | QRESEARCH (Val) | Women | CVD 4 (10 yr) | QRISK | CVD 4 | 0.788 | | | | 0.98
British Women's Heart and Health Cohort44 | BWHH | All | Total CHD 1 | FRS (1991) | CVD 2 | 0.63 | 0.59-0.67 | | | 0.97
British Women's Heart and Health Cohort44 | BWHH | All | CVD 11 | FRS (1991) | CVD 2 | 0.64 | 0.61-0.68 | | | 0.65
INSIGHT trial cohort of middle-aged patients with hypertension37 | INSIGHT | All | CVD 14 | INSIGHT CVD | CVD 14 | 0.661 | | | | 1.25
INSIGHT trial cohort of middle-aged patients with hypertension37 | INSIGHT | All | CVD 14 | FRS (1991) | CVD 2 | | | | | 0.385
Cardiovascular Program in Norway (Ages 60-69)71 | CP-Norway | Men | CVD Mortality | SCORE (High Risk TC) | CVD Mortality | 0.65 | | | | 0.448
Cardiovascular Program in Norway (Ages 60-69)71 | CP-Norway | Women | CVD Mortality | SCORE (High Risk TC) | CVD Mortality | 0.68 | | | | 0.372
Norwegian Counties Study (ages 40-59)71 | NCS | Men (40-49 years) | CVD Mortality | SCORE (High Risk TC) | CVD Mortality | 0.67 | | | | 0.53
Norwegian Counties Study (ages 40-59)71 | NCS | Men (50-59 years) | CVD Mortality | SCORE (High Risk TC) | CVD Mortality | 0.68 | | | | 0.53
Norwegian Counties Study (ages 40-59)71 | NCS | Women (40-49 years) | CVD Mortality | SCORE (High Risk TC) | CVD Mortality | 0.66 | | | | 0.60
Norwegian Counties Study (ages 40-59)71 | NCS | Women (50-59 years) | CVD Mortality | SCORE (High Risk TC) | CVD Mortality | 0.72 | | | | 0.45
Renfrew and Paisley Study70 | Renfrew-Paisley | All | CVD Mortality | FRS (1991) | CVD 2 | 0.733 | 0.715-0.750 | | | 1.714
Renfrew and Paisley Study70 | Renfrew-Paisley | Manual class (social classes IIIM, IV, V) | CVD Mortality | FRS (1991) | CVD 2 | 0.72 | 0.699-0.741
Renfrew and Paisley Study70 | Renfrew-Paisley | Non-manual class (social classes I, II, IIIN) | CVD Mortality | FRS (1991) | CVD 2 | 0.744 | 0.710-0.777
QRESEARCH62 | QRESEARCH | Men | CVD 10 (10 yr) | FRS (1991) | CVD 2 | 0.762 | 0.759-0.765
QRESEARCH62 | QRESEARCH | Women | CVD 10 (10 yr) | FRS (1991) | CVD 2 | 0.776 | 0.772-0.780
QRESEARCH62 | QRESEARCH | Men | CVD 10 (10 yr) | QRISK | CVD 4 | 0.77 | 0.767-0.773
QRESEARCH62 | QRESEARCH | Women | CVD 10 (10 yr) | QRISK | CVD 4 | 0.788 | 0.784-0.792
THIN Cohort; data from 288 UK practices using INPS Vision system (~20%); including 24 practices (54709 patients) from Scotland & 14 practices (36904) from Northern Ireland62 | THIN | Men | CVD 10 (10 yr) | FRS (1991) | CVD 2 | 0.737 | 0.734-0.739 | | | 0.758
THIN Cohort; data from 288 UK practices using INPS Vision system (~20%); including 24 practices (54709 patients) from Scotland & 14 practices (36904) from Northern Ireland62 | THIN | Women | CVD 10 (10 yr) | FRS (1991) | CVD 2 | 0.76 | 0.756-0.763 | | | 0.909
THIN Cohort; data from 288 UK practices using INPS Vision system (~20%); including 24 practices (54709 patients) from Scotland & 14 practices (36904) from Northern Ireland62 | THIN | Men | CVD 10 (10 yr) | QRISK | CVD 4 | 0.762 | 0.759-0.765 | | | 1.149
THIN Cohort; data from 288 UK practices using INPS Vision system (~20%); including 24 practices (54709 patients) from Scotland & 14 practices (36904) from Northern Ireland62 | THIN | Women | CVD 10 (10 yr) | QRISK | CVD 4 | 0.789 | 0.786-0.792 | | | 1.111
PROCAM cohort; drawn from 52 companies and local government authorities61 | PROCAM | Men | Hard CHD 1 | FRS (1991) | CVD 2 | 0.73 | 0.70-0.75 | | | 0.564
PROCAM cohort; drawn from 52 companies and local government authorities61 | PROCAM | Women | Hard CHD 1 | FRS (1991) | CVD 2 | 0.88 | 0.80-0.96 | | | 0.347
MONICA Augsburg cohort; 1984/1985 and 1989/1990 surveys61 | MONICA-Augsburg | Men | Hard CHD 1 | FRS (1991) | CVD 2 | 0.78 | 0.73-0.84 | | | 0.501
MONICA Augsburg cohort; 1984/1985 and 1989/1990 surveys61 | MONICA-Augsburg | Women aged 55-64 years | Hard CHD 1 | FRS (1991) | CVD 2 | 0.88 | 0.80-0.96
Swedish National Diabetes Register43 | SNDR | Participants grouped by predicted risk | CVD 5 | Swedish NDR | CVD 5 | 0.7 | | 4.29 | 0.83
Swedish National Diabetes Register43 | SNDR | Subgroup B | CVD 5 | Swedish NDR | CVD 5 | 0.69
Monitoring Project on Cardiovascular Disease Risk Factors; cohort randomly selected from 3 cities in Netherlands (aged 20-59 & no CVD)77 | MP-CVDRF | All | CVD Mortality (10 yr) | FRS (1991) | CVD 2 | 0.86 | 0.84-0.88
Monitoring Project on Cardiovascular Disease Risk Factors; cohort randomly selected from 3 cities in Netherlands (aged 20-59 & no CVD)77 | MP-CVDRF | All high risk participants | CVD Mortality (10 yr) | FRS (1991) | CVD 2 | 0.8 | 0.77-0.82
Monitoring Project on Cardiovascular Disease Risk Factors; cohort randomly selected from 3 cities in Netherlands (aged 20-59 & no CVD)77 | MP-CVDRF | Participants with SBP >140 mmHg | CVD Mortality (10 yr) | FRS (1991) | CVD 2 | 0.79 | 0.75-0.83
Monitoring Project on Cardiovascular Disease Risk Factors; cohort randomly selected from 3 cities in Netherlands (aged 20-59 & no CVD)77 | MP-CVDRF | Participants with TC >6.5 mmol/L | CVD Mortality (10 yr) | FRS (1991) | CVD 2 | 0.81 | 0.77-0.85
Monitoring Project on Cardiovascular Disease Risk Factors; cohort randomly selected from 3 cities in Netherlands (aged 20-59 & no CVD)77 | MP-CVDRF | Smokers (men >50 yrs, women >55 yrs) | CVD Mortality (10 yr) | FRS (1991) | CVD 2 | 0.69 | 0.65-0.74
Monitoring Project on Cardiovascular Disease Risk Factors; cohort randomly selected from 3 cities in Netherlands (aged 20-59 & no CVD)77 | MP-CVDRF | All | CVD Mortality (10 yr) | SCORE (Unknown Version) | CVD Mortality | 0.85 | 0.83-0.87
Monitoring Project on Cardiovascular Disease Risk Factors; cohort randomly selected from 3 cities in Netherlands (aged 20-59 & no CVD)77 | MP-CVDRF | All high risk participants | CVD Mortality (10 yr) | SCORE (Unknown Version) | CVD Mortality | 0.75 | 0.72-0.78
Monitoring Project on Cardiovascular Disease Risk Factors; cohort randomly selected from 3 cities in Netherlands (aged 20-59 & no CVD)77 | MP-CVDRF | Participants with SBP > 140 mm Hg | CVD Mortality (10 yr) | SCORE (Unknown Version) | CVD Mortality | 0.76 | 0.72-0.81
Monitoring Project on Cardiovascular Disease Risk Factors; cohort randomly selected from 3 cities in Netherlands (aged 20-59 & no CVD)77 | MP-CVDRF | Participants with TC >6.5 mmol/L | CVD Mortality (10 yr) | SCORE (Unknown Version) | CVD Mortality | 0.78 | 0.73-0.82
Monitoring Project on Cardiovascular Disease Risk Factors; cohort randomly selected from 3 cities in Netherlands (aged 20-59 & no CVD)77 | MP-CVDRF | Smokers (men >50 yrs, women >55 yrs) | CVD Mortality (10 yr) | SCORE (Unknown Version) | CVD Mortality | 0.62 | 0.55-0.68
Leiden 85-plus Study42 | L85 | All | CVD Mortality | FRS (1991) | CVD 2 | 0.53 | 0.42-0.63
Dubbo Study; cohort of elderly Australians (ages 60-79) without DM56 | DUBBO-NoDM | Men | CVD 4 (10 yrs) | FRS (ATP) | Hard CHD 1 | | | | | 0.914
Dubbo Study; cohort of elderly Australians (ages 60-79) without DM56 | DUBBO-NoDM | Women | CVD 4 (10 yrs) | FRS (ATP) | Hard CHD 1 | | | | | 0.925
Dubbo Study; cohort of elderly Australians (ages 60-79) with DM56 | DUBBO-All | All | CVD 4 (5 yrs) | Dubbo model | CVD 4 | | | | 107
Dubbo Study; cohort of elderly Australians (ages 60-79) with DM56 | DUBBO-All | All | CVD 4 (10 yrs) | Dubbo model | CVD 4 | | | | 167

Table 8e CHD Model Details – Europe

Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | HLGOF | | O/E Ratio
Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | χ^2^ | P | O/E Ratio
European Prospective Investigation of Cancer [EPIC]–Norfolk 35 | EPIC-Norfolk | Men | Total CHD 1 | FRS [TC] (1998) | Total CHD 1 | 0.71 | 0.69-0.73
European Prospective Investigation of Cancer [EPIC]–Norfolk 35 | EPIC-Norfolk | Women | Total CHD 1 | FRS [TC] (1998) | Total CHD 1 | 0.71 | 0.68-0.74
European Prospective Investigation of Cancer [EPIC]–Norfolk 35 | EPIC-Norfolk | Men | Total CHD 1 | FRS (1998) EPIC Remodel | Total CHD 1 | 0.72 | 0.70-0.75
European Prospective Investigation of Cancer [EPIC]–Norfolk 35 | EPIC-Norfolk | Women | Total CHD 1 | FRS (1998) EPIC Remodel | Total CHD 1 | 0.8 | 0.78-0.83
European Prospective Investigation of Cancer [EPIC]–Norfolk 35 | EPIC-Norfolk | Men | Total CHD 1 | FRS (1998) + EPIC + HbA1c | Total CHD 1 | 0.73 | 0.70-0.75
European Prospective Investigation of Cancer [EPIC]–Norfolk 35 | EPIC-Norfolk | Women | Total CHD 1 | FRS (1998) + EPIC + HbA1c | Total CHD 1 | 0.8 | 0.78-0.83
European Prospective Investigation of Cancer [EPIC]–Norfolk 35 | EPIC-Norfolk | Men | Total CHD 1 | FRS (1998) + EPIC w/o DM + HbA1c | Total CHD 1 | 0.73 | 0.70-0.74
European Prospective Investigation of Cancer [EPIC]–Norfolk 35 | EPIC-Norfolk | Women | Total CHD 1 | FRS (1998) + EPIC w/o DM + HbA1c | Total CHD 1 | 0.8 | 0.77-0.82
Consecutive patients referred by primary care provider for preventive cardiological exam41 | LudwigU | All | Hard CHD 1 | PROCAM CHD (Cox model) | Hard CHD 1 | 0.65 | 0.62-0.68
Consecutive patients referred by primary care provider for preventive cardiological exam41 | LudwigU | All | Hard CHD 1 | FRS (ATP) | Hard CHD 1 | 0.63 | 0.59-0.65
Rotterdam Study84 | Rotterdam | Men | Hard CHD 1 | FRS (ATP) | Hard CHD 1 | 0.63 | 0.52-0.74 | | | 0.723
Rotterdam Study84 | Rotterdam | Women | Hard CHD 1 | FRS (ATP) | Hard CHD 1 | 0.73 | 0.65-0.83 | | | 1.021
Study of Atherosclerotic Risk Factors25 | STULONG | All | Total CHD 1 | FRS [TC] (1998) | Total CHD 1 | 0.638 | 58.4-69.1 | | | 1.282
Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidents Cohort38 | VERIFICA | Men | Total CHD 1 | FRS [TC] (1998) | Total CHD 1 | 0.68 | | 110.1 | 0 | 0.451
Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidents Cohort38 | VERIFICA | Women | Total CHD 1 | FRS [TC] (1998) | Total CHD 1 | 0.73 | | 64.3 | 0 | 0.44
Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidents Cohort38 | VERIFICA | Men | Total CHD 1 | FRS (1998 Wilson) REGICOR Remodel | Total CHD 1 | 0.69 | | 5.1 | 0 | 1.256
Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidents Cohort38 | VERIFICA | Women | Total CHD 1 | FRS (1998 Wilson) REGICOR Remodel | Total CHD 1 | 0.81 | | 2.7 | 0 | 1.03
Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidents Cohort38 | VERIFICA | Diabetics | Total CHD 1 | FRS (1998 Wilson) REGICOR Remodel | Total CHD 1 | | | 1.4 | 0
Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidents Cohort38 | VERIFICA | Diabetics | Total CHD 1 | FRS (1998 Wilson) | Total CHD 1 | | | 54.2 | 0
West of Scotland Coronary Prevention Study32 | WOSCOPS | All | Hard CHD 1 | QT Dispersion | Hard CHD 1 | 0.52
Lyon, France21 | Lyon | All | CVD 6 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.72 | | | | 1.36
Diabetes clinic at University College London Hospitals NHS Trust33 | NHS Trust | All | CVD 18 | PROCAM CHD (Cox model) | Hard CHD 1 | 0.67 | 0.62-0.73 | | | 2.79
Diabetes clinic at University College London Hospitals NHS Trust33 | NHS Trust | All | CVD 18 | UKPDS 56 | Hard CHD 1 | 0.74 | 0.70-0.78 | | | 1.201
Diabetes clinic at University College London Hospitals NHS Trust33 | NHS Trust | All | Total CHD 2 | PROCAM CHD (Cox model) | Hard CHD 1 | 0.65 | 0.59-0.71 | | | 2.05
Diabetes clinic at University College London Hospitals NHS Trust33 | NHS Trust | All | Total CHD 2 | UKPDS 56 | Hard CHD 1 | 0.76 | 0.72-0.80 | | | 1.6
Uppsala Longitudinal Study of Adult Men (Baseline Age 70 Cohort)23 | ULSAM (70) | All | CVD Mortality | FRS [Unknown Version] (1998) | Total CHD 1 | 0.58
Uppsala Longitudinal Study of Adult Men22 | ULSAM | Men (Prediction Data) | MI | PROCAM CHD (Cox model) | Hard CHD 1 | 0.63
Uppsala Longitudinal Study of Adult Men22 | ULSAM | Men (Prediction Data) | MI | FRS (ATP) | Hard CHD 1 | 0.61
Uppsala Longitudinal Study of Adult Men22 | ULSAM | All | Hard CHD 1 (10 yrs) | FRS (ATP) | Hard CHD 1 | | | | | 0.213
Uppsala Longitudinal Study of Adult Men22 | ULSAM | All | Hard CHD 1 (10 yrs) | PROCAM CHD (Cox model) | Hard CHD 1 | | | | | 0.271
Poole Diabetes Study86 | PDS | All | Total CHD 3 | UKPDS 56 | Hard CHD 1 | 0.67 | 0.598-0.742 | 17.1 | 0
Poole Diabetes Study86 | PDS | Men | Total CHD 3 | UKPDS 56 | Hard CHD 1 | 0.673 | 0.585-0.761
Poole Diabetes Study86 | PDS | Women | Total CHD 3 | UKPDS 56 | Hard CHD 1 | 0.618 | 0.491-0.746
Poole Diabetes Study86 | PDS | Pretreated blood pressure | Total CHD 3 | UKPDS 56 | Hard CHD 1 | 0.696 | 0.575-0.817
Poole Diabetes Study86 | PDS | Untreated blood pressure | Total CHD 3 | UKPDS 56 | Hard CHD 1 | 0.648 | 0.559-0.736
CUORE29 | CUORE | Men | Hard CHD 2 | CUORE | Hard CHD 2 | 0.742 | 0.684-0.796 | 15.5
CUORE29 | CUORE | Men | Hard CHD 2 | FRS (Wilson 1998 TC) CUORE D'Ag Remodel | Hard CHD 2 | 0.723 | 0.670-0.779 | 27.1 | | 0.765
CUORE29 | CUORE | Men | Hard CHD 2 | PROCAM (Cox) CUORE D'Ag Remodel | Hard CHD 2 | 0.735 | 0.678-9.790 | 220.3 | | 0.87
CUORE29 | CUORE | Men | Hard CHD 2 | FRS [TC] (1998) | Total CHD 1 | 0.723 | 0.670-0.779 | | | 0.328
CUORE29 | CUORE | Men | Hard CHD 2 | FRS (Wilson 1998 TC) CUORE Chamb Remodel | Hard CHD 2 | 0.723 | 0.670-0.779 | | | 1.01
CUORE29 | CUORE | Men | Hard CHD 2 | PROCAM (Cox) CUORE Chamb Remodel | Hard CHD 2 | 0.735 | 0.678-9.790 | | | 1.01
Subjects with type 2 diabetes registered with a Tayside GP39 | DARTS | All | Hard CHD 1 | DARTS | Hard CHD 1 | 0.71 | 0.63-0.79
Rotterdam Coronary Calcification Study79 | RCC | All | CVD 3 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.73
Rotterdam Coronary Calcification Study79 | RCC | age > 70 years | CVD 3 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.682
Men randomly selected from general population in 1984-5, 1989-90, and 1994-5^75^ | MONICA-Augsburg | All | Hard CHD 1 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.735
PROCAM; cohort of employees of 52 companies and local government authorities with f/u every 2 years27 | PROCAM | All | Hard CHD 1 | PROCAM CHD (Cox model) | Hard CHD 1 | 0.829 | | 6.5 | 0.3
PROCAM; cohort of employees of 52 companies and local government authorities with f/u every 2 years27 | PROCAM | All | Hard CHD 1 | FRS (ATP) | Hard CHD 1 | 0.778 | | 43.8 | 0.001
PROCAM; cohort of employees of 52 companies and local government authorities with f/u every 2 years27 | PROCAM | All | Hard CHD 1 | PROCAM CHD (Point Score) | Hard CHD 1 | 0.824
Individuals with diabetes receiving care in Salford39 | Salford | All | Hard CHD 1 | DARTS | Hard CHD 1 | 0.69 | 0.58-0.78
Second Northwick Park Heart Stud31 | NPHS-II | All | Hard CHD 2 | PROCAM CHD (Cox model) | Hard CHD 1 | 0.63 | 0.59-0.67 | | | 0.46
Second Northwick Park Heart Study31 | NPHS-II | All | Hard CHD 2 | NPHS-II score 1 (basic) | Hard CHD 2 | 0.64 | 0.58-0.70
Second Northwick Park Heart Study31 | NPHS-II | All | Hard CHD 2 | NPHS-II score 2 (basic + DM + fam hx) | Hard CHD 2 | 0.66 | 0.60-0.71
Second Northwick Park Heart Study31 | NPHS-II | All | Hard CHD 2 | NPHS-II score 3 (basic + DM) | Hard CHD 2 | 0.63 | 0.58-0.69
Second Northwick Park Heart Study31 | NPHS-II | All | Hard CHD 2 | NPHS-II score 4 (basic + fam hx) | Hard CHD 2 | 0.64 | 0.59-0.69
Second Northwick Park Heart Study31 | NPHS-II | All | Hard CHD 2 | NPHS-II score 5 (basic + fibrinogen) | Hard CHD 2 | 0.66 | 0.60-0.71
Second Northwick Park Heart Study31 | NPHS-II | All | Hard CHD 2 | NPHS-II score 6 (basic + Lp(a)) | Hard CHD 2 | 0.67 | 0.61-0.72
Second Northwick Park Heart Study31 | NPHS-II | All | Hard CHD 2 | NPHS-II score 7 (basic + ApoAI + ApoB) | Hard CHD 2 | 0.66 | 0.60-0.72
Second Northwick Park Heart Study31 | NPHS-II | All | Hard CHD 2 | FRS (ATP) | Hard CHD 1 | 0.62 | 0.58-0.66 | | | 0.47
PRIME cohort study (Belfast Cohort)80 | PRIME-Belfast | All | Total CHD 1 (5 yr) | FRS (ATP) | Hard CHD 1 | 0.66 | | | | 0.746
PRIME cohort study (Belfast Cohort)80 | PRIME-Belfast | All | Hard CHD 1 (5 yr) | PROCAM CHD (Cox model) | Hard CHD 1 | 0.61 | | | | 0.562
PRIME cohort study80 | PRIME-France | All | Total CHD 1 (5 yr) | FRS (ATP) | Hard CHD 1 | 0.68 | | | | 0.673
PRIME cohort study80 | PRIME-France | All | Hard CHD 1 (5 yr) | PROCAM CHD (Cox model) | Hard CHD 1 | 0.64 | | | | 0.229
Cohort of men and women employed in NW Germany28 | PROCAM | All | Hard CHD 1 | PROCAM (BMI-modified) | Hard CHD 1 | 0.82 | | | | 0.881
Cohort of men and women employed in NW Germany28 | PROCAM | All | Hard CHD 1 | PROCAM CHD (Cox model) | Hard CHD 1 | 0.821
Individuals with type 2 diabetes diagnosed by standard criteria and on standard diabetic therapy (diet, tablets, insulin) and aged 50-75 years, recruited from outpatient clinics in Central and West London88 | PREDICT | All | CVD 19 | FRS (1991) | CVD 2 | 0.63 | 0.55-0.71
Individuals with type 2 diabetes diagnosed by standard criteria and on standard diabetic therapy (diet, tablets, insulin) and aged 50-75 years, recruited from outpatient clinics in Central and West London88 | PREDICT | All | CVD 19 | UKPDS 56 | Hard CHD 1 | 0.67 | 0.60-0.75
Individuals with type 2 diabetes diagnosed by standard criteria and on standard diabetic therapy (diet, tablets, insulin) and aged 50-75 years, recruited from outpatient clinics in Central and West London88 | PREDICT | All | Total CHD 2 | UKPDS 56 | Hard CHD 1 | 0.63 | 0.56-0.71
Participants in Supplementation en Vitamines et Mineraux Antioxydants randomized primary prevention trial, followed annually since 1994/1995^36^ | SU.VI.MAX | All | Total CHD 1 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.74 | | | | 0.497
Participants in Supplementation en Vitamines et Mineraux Antioxydants randomized primary prevention trial, followed annually since 1994/1995^36^ | SU.VI.MAX | All | Total CHD 1 | SU.VI.MAX | Total CHD 1 | 0.75
Munich87 | MunichDM | All | MI | UKPDS 56 | Hard CHD 1 | 0.66 | 0.62-0.68
Munich87 | MunichDM | All | MI | FRS [Unknown Version] (1998) | Total CHD 1 | 0.63 | 0.59-0.66
PROCAM cohort; employees of 52 companies and local government authorities in Germany, aged 20-78 years26 | PROCAM | All | Hard CHD 1 (10 Year) | PROCAM CHD (Cox model) | Hard CHD 1 | 0.824
PROCAM cohort; employees of 52 companies and local government authorities in Germany, aged 20-78 years26 | PROCAM | All | Hard CHD 1 (10 Year) | PROCAM CHD (Weibull model) | Hard CHD 1 | 0.824
Men at work in public authorities and large companies in the region of Munster, Germany74 | MunsterWork | Men | Hard CHD 1 | PROCAM CHD (Cox model) | Hard CHD 1 | | | | | 0.781
Aboriginal community82 | Aboriginal | Men | Total CHD 1 | FRS (1991) | Total CHD 1 | | | | | 2
Aboriginal community82 | Aboriginal | Women | Total CHD 1 | FRS (1991) | Total CHD 1 | | | | | 3.918
INSIGHT trial cohort of middle-aged patients with hypertension 37 | INSIGHT | All | Total CHD 1 | FRS (1991) | Total CHD 1 | | | | | 0.435
British Regional Heart Study; men aged 40-59 years randomly selected from registers of one general practice in each town73 | BRHS | Men | CHD Mortality | FRS (1991) BRHS Recal | CHD Mortality | | | 3.4
British Regional Heart Study; men aged 40-59 years randomly selected from registers of one general practice in each town73 | BRHS | Men | Total CHD 1 | FRS (1991) BRHS Recal | Total CHD 1 | | | 24.6
British Regional Heart Study; men aged 40-59 years randomly selected from registers of one general practice in each town73 | BRHS | Men | CHD Mortality | FRS (1991) CHD Mortality | CHD Morality | | | 30.2 | | 0.683
British Regional Heart Study; men aged 40-59 years randomly selected from registers of one general practice in each town73 | BRHS | Men | Total CHD 1 | FRS (1991) | Total CHD 1 | | | 155.3 | | 0.637
Consecutive renal transplant patients69 | FrRenal | All | Total CHD 1 | FRS [Unknown Version] (1998) | Total CHD 1 | | | | | 1.688

Table 8f Stroke Model Details – Europe

Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | O/E Ratio
INSIGHT trial cohort of middle-aged patients with hypertension37 | INSIGHT | All | Stroke 4 | INSIGHT Stroke | Stroke 4 | 1
INSIGHT trial cohort of middle-aged patients with hypertension37 | INSIGHT | All | Stroke 4 | FRS (1991) Stroke | Stroke 4 | 1
Apparently healthy Norwegian men aged 40-60 years recruited from 5 governmental agencies24 | NorGov | All | CHD Mortality | Erikssen - CRF-X Model | CHD Mortality | 0.999
Apparently healthy Norwegian men aged 40-60 years recruited from 5 governmental agencies24 | NorGov | All | CHD Mortality | Erikssen – CRF Model | CHD Mortality | 1
Apparently healthy Norwegian men aged 40-60 years recruited from 5 governmental agencies24 | NorGov | All | CHD Mortality | Erikssen – X Model | CHD Mortality | 1
Newcastle Heart Project: Europeans83 | NHP-Europe | All | Stroke Mortality | FRS (1991) Stroke | Stroke 4 | 3.913
Newcastle Heart Project: Europeans83 | NHP-Europe | All | CHD Mortality | SCORE [Unknown Version] | CHD Mortality | 3.235

Table 8g CVD Model Details – Asia

Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | HLGOF | | O/E Ratio
Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | χ^2^ | P | O/E Ratio
Asia Pacific Cohort Studies Collaboration - Total Chinese Cohort45 | APCSC China | Men | CVD 8 | Asian Pacific | CVD 8 | 0.76 | 0.73-0.79 | 16.7 | 0.033
Asia Pacific Cohort Studies Collaboration - Total Chinese Cohort45 | APCSC China | Women | CVD 8 | Asian Pacific | CVD 8 | 0.8 | 0.75-0.84 | 12.2 | 0.15
Asia Pacific Cohort Studies Collaboration - Total Chinese Cohort45 | APCSC China | Men | CVD 8 | FRS (2007 Barzi) | CVD 8 | 0.75 | 0.72-0.78 | 557.5 | 0.0001 | 0.266
Asia Pacific Cohort Studies Collaboration - Total Chinese Cohort45 | APCSC China | Women | CVD 8 | FRS (2007 Barzi) | CVD 8 | 0.79 | 0.74-0.83 | 608 | 0.0001 | 0.495
MUCA II48 | MUCA-II | Men | CVD 17 | FRS (1998 Hard CHD1) MUCA-II Remodel | CVD 17 | 0.796 | 0.762-0.829
MUCA II48 | MUCA-II | Women | CVD 17 | FRS (1998 Hard CHD1) MUCA-II Remodel | CVD 17 | 0.791 | 0.755-0.828
MUCA II48 | MUCA-II | Men | CVD 17 | USA-PRC (Simplified) | CVD 17 | 0.792 | 0.758-0.825
MUCA II48 | MUCA-II | Women | CVD 17 | USA-PRC (Simplified) | CVD 17 | 0.783 | 0.746-0.821
MUCA II48 | MUCA-II | Men | CVD 17 | USA-PRC (Point Scoring) | CVD 17 | 0.791 | 0.757-0.825
MUCA II48 | MUCA-II | Women | CVD 17 | USA-PRC (Point Scoring) | CVD 17 | 0.779 | 0.741-0.817

Table 8h CHD Model Details – Asia

Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | HLGOF | | O/E Ratio
Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | χ^2^ | P | O/E Ratio
Hong Kong Diabetes Registry49 | HKD Registry | All | Hard CHD 1 | UKPDS 56 | Hard CHD 1 | 0.61 | 0.581-0.639
Hong Kong Diabetes Registry49 | HKD Registry | All | Total CHD 1 | Hong Kong Total CHD Score | Total CHD 1 | 0.737
Hong Kong Diabetes Registry49 | HKD Registry | All | Total CHD 1 | Hong Kong Total CHD Score | Total CHD 1 | 0.704 | 0.675-0.733
Employee health management center in a Japanese company90 | Japan Work | Men | Total CHD 1 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.62 | | | | 0.579
Chinese Multi-Provincial Cohort Study; persons aged 35-64 years from 16 centers in 11 provinces (1992-3) and Beijing (1996-9)47 | MUCA | Women | Hard CHD 1 | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.742 | 0.686-0.798 | 147.6
Chinese Multi-Provincial Cohort Study; persons aged 35-64 years from 16 centers in 11 provinces (1992-3) and Beijing (1996-9)47 | MUCA | Men | Hard CHD 1 | FRS Hard CHD [TC] (1998) | Hard CHD 1 | 0.705 | 0.665-0.746 | 645.9 | 0.0001
Chinese Multi-Provincial Cohort Study; persons aged 35-64 years from 16 centers in 11 provinces (1992-3) and Beijing (1996-9)47 | MUCA | Women | Hard CHD 1 | CMCS Cox Model | Hard CHD 1 | 0.759 | 0.699-0.818 | 14.2 | 0.08
Chinese Multi-Provincial Cohort Study; persons aged 35-64 years from 16 centers in 11 provinces (1992-3) and Beijing (1996-9)47 | MUCA | Women | Hard CHD 1 | CMCS Cox Model | Hard CHD 1 | 0.759 | 0.699-0.818 | 14.2 | 0.0001
Chinese Multi-Provincial Cohort Study; persons aged 35-64 years from 16 centers in 11 provinces (1992-3) and Beijing (1996-9)47 | MUCA | Men | Hard CHD 1 | CMCS Cox Model | Hard CHD 1 | 0.736 | 0.696-0.776 | 12.6 | 0.13
Chinese Multi-Provincial Cohort Study; persons aged 35-64 years from 16 centers in 11 provinces (1992-3) and Beijing (1996-9)47 | MUCA | Women | Hard CHD 1 | FRS (1998 TC Hard CHD) MUCA Remodel | Hard CHD 1 | 0.759 | 0.699-0.818 | 16.9 | 0.03
Chinese Multi-Provincial Cohort Study; persons aged 35-64 years from 16 centers in 11 provinces (1992-3) and Beijing (1996-9)47 | MUCA | Men | Hard CHD 1 | FRS (1998 TC Hard CHD) MUCA Remodel | Hard CHD 1 | 0.736 | 0.696-0.776 | 31.5 | 0.0001
Males aged 30-59 completing annual health exams between 1991-3^89^ | JapanWork | All | Total CHD 1 | FRS [Unknown Version] (1998) | Total CHD 1 | 0.71 | | | | 0.382
Newcastle Heart Project–South Asians83 | NHP-South Asia | All | CHD Mortality | SCORE (Unknown Version) | CVD Mortality | | | | | 4.419

Table 8i Stroke Model Details – Asia

Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | HLGOF | | O/E Ratio
Cohort | Cohort Abbrev | Group Name | Cohort Outcome | Model Name | Model Outcome | AUC | AUC Var | χ^2^ | P | O/E Ratio
Hong Kong Diabetes Registry50 | HKD Registry | All | Stroke 1 | Hong Kong Diabetes Risk Score | Stroke 1 | 0.79 | 0.716-0.782
Hong Kong Diabetes Registry50 | HKD Registry | All | Stroke 1 | UKPDS 60 | Stroke 1 | 0.588 | 0.549-0.626 | | | 0.514
Hong Kong Diabetes Registry50 | HKD Registry | All | Stroke 5 | Hong Kong Diabetes Risk Score | Stroke 1 | 0.77
Koreans insured by National Health Insurance Corporation (NHIC)46 | NHIC | Men | Stroke 6 (10 yr) | Korean Stroke Risk Prediction (KSRP) | Stroke 6 | 0.817 | 0.799-0.834 | 7.71 | 0.56
Koreans insured by National Health Insurance Corporation (NHIC)46 | NHIC | Women | Stroke 6 (10 yr) | Korean Stroke Risk Prediction (KSRP) | Stroke 6 | 0.81 | 0.788-0.832 | 14.26 | 0.16
Hong Kong Diabetes Registry50 | HKD Registry | All | Stroke 3 | Hong Kong Diabetes Risk Score | Stroke 1 | 0.785
Newcastle Heart Project–South Asians83 | NHP-South Asia | All | Stroke Mortality | FRS (1991) Stroke | Stroke 4 | | | | | 1.875