# Summary Table 7

Table 7a Data Sources Details (External Validations) – Americas All

Study 1 Author | Study Yr Pub | Cohort Abbrev | Group Name | Age (yrs) | Race | Female % | Smoker (Current) % | Mean Cholesterol Levels (mg/dL) | Diabetes % | SBP (mmHg) | DBP (mmHg) | HTN Measured % | HTN Med Use % | HTN Med Use Or Measured %
Weiner DE64 | 2007 | ARIC, CHS | All | 64.7 | W: 84.4 B: 15.6 | 61.8 | 17 | | 14 | | | 31.2
Orford JL67 | 2002 | NAS | All | 58.2 | W: 98 | 0 | | LDL: 166.6 HDL: 47.4 Tot: 245.6 | 2.9 | 127.6 [Mean] | 77.3 [Mean]
Grover SA68 | 2000 | LRCPS | All | 53.1 | | 33 | 32.7 | LDL: 144.3 Tot: 218.4 | 4.6 | 128.4 [Mean] | 81.5 [Mean]
Stern MP66 | 2004 | SAHS | All | | W: 32 H: 68 | 58 | | | 12.6
Kothari V54 | 2002 | WESDR | All | 52 | W: 82.5 O: 17.5 | 41.3 | 30.3 | | 100
Paynter N55 | 2009 | WGHS | All | 52.4 | W: 100 | 100 | 11.5 | | 2.6 | 125 [Median] | | | 12.2
Denes P63 | 2007 | WHI | All | 62.9 | W: 84.3 B: 6.4 H: 5.4 | 100 | 10.5 | | 3.9 | 127.3 [Mean] | 75.8 [Mean] | | | 57.5
Arad Y91 | 2005 | SFHS | All | 59 | W: 88 | 35 | 10 | LDL: 143 HDL: 52 Tot: 224 | 6 | | | 34

Table 7b Data Sources Details (External Validations) – Americas Men

Study 1 Author | Study Yr Pub | Cohort Abbrev | Group Name | Age (yrs) | Race | Smoker (Current) % | Mean Cholesterol Levels (mg/dL) | Diabetes % | SBP (mmHg) | DBP (mmHg) | HTN Measured %
Weiner DE64 | 2007 | ARIC, CHS | Men | 65.8 | W: 86.6 B: 13.4 | 15.1 | | 14.6 | | | 35.5
Grover SA68 | 2000 | LRCPS | Men | 50.8 | | 35.4 | LDL: 144.3 Tot: 214.5 | 4.7 | 127 [Mean] (17.8 SD) | 82.2 [Mean] (10.6 SD)
Kothari V54 | 2002 | WESDR | Men | 51.5
Ridker P20 | 2008 | PHS-II | Men | 63 | | 3.2 | | | 128 [Median] (120-135)

Table 7c Data Sources Details (External Validations) – Americas Women

Study 1^st^ Author | Study Yr Pub | Cohort Abbrev | Group Name | Age (yrs) | Race | Smoker (Current) % | Mean Cholesterol Levels (mg/dL) | Diabetes % | SBP (mmHg) | DBP (mmHg) | HTN Measured %
Weiner DE64 | 2007 | ARIC, CHS | Women | 64 | W: 83 B:17 | 18.2 | | 13.7 | | | 28.4
Grover SA68 | 2000 | LRCPS | Women | 57.8 | | 27.2 | LDL: 148.2 Tot: 226.2 | 4.2 | 131.3 [Mean] (20.4 SD) | 80 [Mean] (10.3 SD)
Kothari V54 | 2002 | WESDR | Women | 52.6

Table 7d Data Sources Details (External Validations) – Europe All

Study 1st Author | Study Yr Pub | Cohort Abbrev | Group Name | Age (yrs) | Race | Female % | Smoker (Current) % | Mean Cholesterol Levels (mg/dL) | Diabetes % | SBP (mmHg) | DBP (mmHg) | HTN Measured % | HTN Med Use %
Ducloux D69 | 2004 | FrRenal | All | 51 | | 36.9 | 23.3 | | 10.8 | 136 [Mean] (19 [SD]) | 81 [Mean] (10 [SD])
Brindle PM70 | 2005 | Renfrew-Paisley | All | | | 54.3 | 50.7 | | 1.2
Lindman AS71 | 2007 | NCS | All | 47 | | 50.9 | 40.7 | Tot: 248.04 | 0 | 132.4 [Mean] | 81 [Mean]
Wannamethee SG72 | 2005 | BRHS | All | 50.3 | | 0 | 42.1 | HDL: 44.4 Tot: 241.3 | 0 | 145.7 [Mean] (20.7 [SD]) | 83 [Mean] (13.2 [SD]) | 78.5
Brindle P73 | 2003 | BRHS | All | | | 0 | 41.9 | | 1.1 | 143 [Median] (115-182 [95% CI]) | 81 [Median] (62-104 [95% CI])
Buyken AE74 | 2007 | MunsterWork | All | | | 0 | 30.6 | LDL: 152.1 Tot: 227.37 | | 124.7 [Mean] | 86.2 [Mean]
Hense HW61 | 2003 | PROCAM | All | 46.5 | | 36.3 | 30.6 | | 2.8 | 131.5 [Mean]
Hense HW61 | 2003 | MONICA-Augsburg | All | 49.5 | | 50.6 | 26.4 | | 3.6 | 131.8 [Mean]
Koenig W75 | 2004 | MONICA-Augsburg | All | 56.4 | W: 100 | 0 | 27.4 | HDL: 51.6 Tot: 245.7 | 5.8 | 138.7 [Mean] (derived) | 83.3 [Mean] (derived)
Ulmer HB76 | 2005 | VHM&PP | All | 57.3 | | 54.8
Lindman AS71 | 2007 | CP-Norway | All | 65.7 | | 53.7 | 28.5 | Tot: 258.57 | | 149.8 [Mean] | 83.9 [Mean]
Scheltens T77 | 2008 | MP-CVDRF | All | 40.8 | | 53 | 39.5 | Tot: 214.5 | | 120.1 [Mean] (15.4 [SD]) | 76 [Mean] (10.3 [SD]) | 6.9
Silventoinen K78 | 2005 | FinCross | All | 44.5 | | 53.4 | | Tot: 222.3 | 1.5 | 135.8 [Mean] | 82.3 [Mean] | 64.3
Simons LA56 | 2003 | DUBBO | All | 64.1 | | 58 | 32 | | 19 | 166 [Mean] (15 [SD])
Vliegenthart R79 | 2005 | RCC | All | 71.1 | | 57.5 | 16.4 | Tot: 230.1 | 12.3 | | | 59.8
Milne R81 | 2003 | NZWork | All | | W: 85 O: 15 | 27
Wang Z82 | 2005 | Aboriginal | All | 34.4 | O: 100 | 48.2 | 77.6 | Tot: 183.3 | 12.5 | 121.1 [Mean] | 74.7 [Mean]
Donnan PT39 | 2006 | DARTS | All | 59.5 | W: 99 O: 1 | 47.4 | 23.5 | | 100 | 144 [Mean] (21 [SD]) | 82 [Mean] (11 [SD])
Bhopal R83 | 2005 | NHP - Europe | All | | O: 100 | 50 | 30.1 | Tot: 222.3 | 4 | 127.5 [Mean]
Koller MT84 | 2007 | Rotterdam | All | 70.2 | | 63.9 | 21.5 | | | | | 30.8 | 21.5
Hippisley-Cox JC34 | 2008 | QRESEARCH | All | | | 50.4 | 25.5 | Tot: 226.2 | 0 | 133.7 [Mean] | | | 10.1
Hippisley-Cox JC62 | 2008 | THIN | All | | | 50.6 | 24.7 | Tot: 222.3 | 0 | 133.8 [Mean] | | | 8.6
McEwan P85 | 2004 | Cardiff DM | All | 59.6 | | 42.2 | 22 | Tot: 226.2 | 100 | 144 [Mean] (21 [SD])
Guzder RN86 | 2005 | PDS | All | 58.6 | | 43.7 | | LDL: 140.4 Tot: 230.1 | 100 | 142 [Mean] (21.4 [SD]) | 81 [Mean] (12.1 [SD]) | | 31.8
Becker A87 | 2008 | MunichDM | All | 55.2 | | 39.9 | | | 100
Elkeles RS88 | 2008 | PREDICT | All | 63.1 | W: 71.1 | 36.7 | 15.1 | | 100 | 131 [Median] (121-142 [IQ Range]) | 78 [Median] (72-84 [IQ Range])

Table 7e Data Sources Details (External Validations) – Europe Men

Study 1st Author | Study Yr Pub | Cohort Abbrev | Group Name | Age (yrs) | Smoker (Current) % | Mean Cholesterol Levels (mg/dL) | Diabetes % | SBP (mmHg) | DBP (mmHg) | HTN Measured % | HTN Med Use %
Brindle PM70 | 2005 | Renfrew-Paisley | Men | | 55.3 | | 1.4 | 145 [Median] (116-190 [95th percentile])
Bhopal R83 | 2005 | NHP-Europe | Men | | | Tot: 219.96 | 5 | 131 [Mean]
Hense HW61 | 2003 | MONICA-Augsburg | Men | | 33.7 | | 4.2
Scheltens T77 | 2008 | MP-CVDRF | Men | | | | | | | 8
Wang Z82 | 2005 | Aboriginal | Men | 32.8 | 83.7 | Tot: 191.1 | 9.3 | 125.5 [Mean] (17.1 [SD]) | 77.7 [Mean] (13.6 [SD])
Silventoinen K78 | 2005 | FinCross | Men | 45 | | Tot: 224.64 | 2 | 139 [Mean] | 85 [Mean] | 75
Hense HW61 | 2003 | PROCAM | Men | 46.5 | 33.8 | | 2.9 | 131.6 [Mean] (0.25 [SD])
Hippisley-Cox JC34 | 2008 | QRESEARCH | Men | 47 | 28.2 | Tot: 222.3 | 0 | 135.3 [Mean] (19.6 [SD]) | | | 8
Lindman AS71 | 2007 | NCS | Men | 47 | 44.2 | Tot: 248.43 | 0 | 135.3 [Mean] | 83 [Mean]
Hippisley-Cox JC62 | 2008 | THIN | Men | 48 | 26.6 | Tot: 222.3 | 0 | 135.6 [Mean] (19.4 [SD]) | | | 6.6
Hense HW61 | 2003 | MONICA-Augsburg | 1984-85 Survey Men | 49.4 | 35.4 | | 3.5 | 134.9 [Mean] (0.44 [SD])
Hense HW61 | 2003 | MONICA-Augsburg | 1989-90 Survey Men | 49.6 | 31.9 | | 5.1 | 135.1 [Mean] (0.48 [SD])
Becker A87 | 2008 | MunichDM | Men | 55.5 | | | 100
Koenig W75 | 2004 | MONICA-Augsburg | Men without coronary event | 56.2 | 26.4 | HDL: 51.8 Tot: 244.4 | 5.4 | 138.5 [Mean] | 83.3 [Mean]
Koenig W75 | 2004 | MONICA-Augsburg | Men without coronary event | 56.2 | 26.4 | HDL: 51.8 Tot: 246.48 | 5.4 | 138.5 [Mean] | 83.3 [Mean]
Ulmer HB76 | 2005 | VHM&PP | Men | 56.5
Koenig W75 | 2004 | MONICA-Augsburg | Men with coronary event | 59.2 | 44.2 | HDL: 48.4 Tot: 257.4 | 12 | 142.6 [Mean] | 83.8 [Mean]
McEwan P85 | 2004 | Cardiff DM | Men | 59.2 | 24 | Tot: 218.4 | | 142 [Mean] (19 [SD])
Koenig W75 | 2004 | MONICA-Augsburg | Men with coronary event | 59.2 | 44.2 | HDL: 48.4 Tot: 257.4 | 12 | 142.6 [Mean] | 83.8 [Mean]
Koenig W75 | 2004 | MONICA-Augsburg | Men with coronary event | 59.2 | 44.2 | HDL: 48.4 Tot: 259.35 | 12 | 142.6 [Mean] | 83.8 [Mean]
Lindman AS71 | 2007 | CP-Norway | Men | 65.6 | 37.4 | Tot: 242.58 | 0 | 150 [Mean] (20.2 [SD]) | 85 [Mean] (12.2 [SD])
Koller MT84 | 2007 | Rotterdam | Men | 68.5 | 30.1 | | | | | 25.3

Table 7f Data Sources Details (External Validations) – Europe Women

Study 1st Author | Study Yr Pub | Cohort Abbrev | Group Name | Age (yrs) | Smoker (Current) % | Mean Cholesterol Levels (mg/dL) | Diabetes % | SBP (mmHg) | DBP (mmHg) | HTN Measured % | HTN Med Use %
Brindle PM70 | 2005 | Renfrew-Paisley | Women | | 46.9 | | 1.1 | 147 [Median] (114-196 95th percentile)
Lindman AS71 | 2007 | NCS | Women | 46.9 | 37.3 | Tot: 247.26 | 0 | 129.6 [Mean] | 79 [Mean]
Hense HW61 | 2003 | PROCAM | Women | 46.6 | 24.9 | | 2.6 | 131.2 [Mean] (0.36 [SD])
Hense HW61 | 2003 | MONICA-Augsburg | Women | | 19.3 | | 3 | 128. 6 [Mean]
Ulmer HB76 | 2005 | VHM&PP | Women | 58
Lindman AS71 | 2007 | CP-Norway | Women | 65.7 | 20.9 | Tot: 272.22 | | 149.6 [Mean] (21.8 [SD]) | 83 [Mean] (12.7 [SD])
Scheltens T77 | 2008 | MP-CVDRF | Women | | | | | | | 6
Silventoinen K78 | 2005 | FinCross | Women | 44 | | Tot: 218.4 | 1 | 133 [Mean] | 80 [Mean] | 55
Wang Z82 | 2005 | Aboriginal | Women | 36.1 | 71 | Tot: 175.5 | 16 | 116.4 [Mean] (18.7 [SD]) | 71.5 [Mean] (12.9 [SD])
Bhopal R83 | 2005 | NHP - Europe | Women | | | Tot: 224.25 | 3 | 124 [Mean]
Koller MT84 | 2007 | Rotterdam | Women | 71.1 | 16.7 | | | | | 33.8
Hippisley-Cox JC34 | 2008 | QRESEARCH | Women | 49 | 22.9 | Tot: 226.2 | | 132.2 [Mean] (21.6 [SD]) | | | 12.1
Hippisley-Cox JC62 | 2008 | THIN | Women | 49 | 22.9 | Tot: 226.2 | 0 | 132.1 [Mean] (21.0 [SD]) | | | 10.5
McEwan P85 | 2004 | Cardiff DM | Women | 60.2 | 19 | Tot: 234 | | 146 [Mean] (23 [SD])
Becker A87 | 2008 | MunichDM | Women | 54.8 | | | 100

Table 7g Data Sources Details (External Validations) – Asia All

Study 1^st^ Author | Study Yr Pub | Cohort Abbrev | Group Name | Age (yrs) | Race | Female % | Smoker (Current) % | Mean Cholesterol Levels (mg/dL) | Diabetes % | SBP (mmHg) | DBP (mmHg)
Suka M89 | 2001 | JapanWork | All | 44.7 | O:100 | 0 | 59.8 | Tot: 198.9 | 8.5 | 129 [Mean] (17.1 [SD]) | 80.3 [Mean] (10.6 [SD])
Bhopal R83 | 2005 | NHP–Pakistan | All | | O:100 | 51.1 | 17 | Tot: 218.4 | 27 | 122 [Mean]
Bhopal R83 | 2005 | NHP–India | All | | O:100 | 63 | 6.1 | Tot: 216.84 | 16 | 125.9 [Mean]
Bhopal R83 | 2005 | NHP–South Asia | All | | O:100 | 54.5 | 15.6 | Tot: 216.84 | 20.5 | 122.5 [Mean]

Table 7h Data Sources Details (External Validations) – Asia Men

Study 1^st^ Author | Study Yr Pub | Cohort Abbrev | Group Name | Race | Mean Cholesterol Levels (mg/dL) | Diabetes % | SBP (mmHg)
Bhopal R83 | 2005 | NHP–Pakistan | Men | O:100 | Tot: 219.18 | 26 | 123 [Mean]
Bhopal R83 | 2005 | NHP–India | Men | O:100 | Tot: 219.57 | 16 | 124 [Mean]
Bhopal R83 | 2005 | NHP–South Asia | Men | O:100 | Tot: 217.23 | 21 | 122 [Mean]

Table 7i Data Sources Details (External Validations) – Asia Women

Study 1^st^ Author | Study Yr Pub | Cohort Abbrev | Group Name | Race | Mean Cholesterol Levels (mg/dL) | Diabetes % | SBP (mmHg)
Bhopal R83 | 2005 | NHP–Pakistan | Women | O:100 | Tot: 218.01 | 28 | 121 [Mean]
Bhopal R83 | 2005 | NHP–India | Women | O:100 | Tot: 215.28 | 16 | 127 [Mean]
Bhopal R83 | 2005 | NHP–South Asia | Women | O:100 | Tot: 216.45 | 20 | 123 [Mean]