# Summary Table 6

Table 6a Data Sources Summary (External Validation) – Americas

Study Yr Pub | Enroll Start | Enroll End | Study 1st Author | Country | Cohort | Cohort Abbrev | Enrollment Base | Enrollment Final | Follow Up (yrs)
2007 | 1/1/1993 | 12/31/1998 | Denes P63 | United States | Women's Health Initiative study | WHI | 14749 | | 5.6 (mean)
2007 | | | Weiner DE64 | United States | Atherosclerosis Risk In Communities and Cardiovascular Health Study trials with CKD | ARIC, CHS | 934
2005 | 7/1/1996 | 3/31/1999 | Arad Y65 | United States | St Francis Heart Study | SFHS | 4903 | 4613 | 4.3 (other)
2004 | 1/1/1979 | 12/31/1988 | Stern MP66 | United States | San Antonio Heart Study | SAHS | 5158 | 2570 | 7.5 (other)
2002 | 1/1/1961 | | Orford JL67 | United States | Normative Aging Study - male veterans | NAS | 1393 | | 10 (other)
2000 | 1/1/1972 | 12/31/1976 | Grover SA68 | Canada | Lipid Research Clinics Prevalence Study cohort | LRCPS | 2218 | | 12.2 (mean)
2002 | 7/1/1979 | 6/30/1980 | Kothari V54 | United Status | Wisconsin Epidemiologic Study of Diabetic Retinopathy | WESDR | 4549 | | 8.3 (mean)
2009 | 1/1/1992 | 3/31/2004 | Paynter N55 | United States | Women's Genome Health Study | WGHS | 22129 | | 10.2 (median)
2007 | 12/1/1995 | | Ridker P20 | United States | Physicians Health Study II | PHS-II | 10724 | | 10.8 (median)

Table 6b Data Sources Summary (External Validation) – Europe

Study Yr Pub | Enroll Start | Enroll End | Study 1st Author | Country | Cohort | Cohort Abbrev | Enrollment Base | Enrollment Final | Follow Up (yrs)
2004 | | | Lindman AS71 | France | Consecutive renal transplant patients | | 344 | | 6 [1.17] (mean)
2005 | 1/1/1972 | 12/31/1976 | Scheltens T77 | Scotland | Renfrew and Paisley Study | | | 12304 | 10 (other)
2007 | 1/1/1974 | 12/31/1988 | Silventoinen K78 | Norway | Norwegian Counties Study (ages 40-59) | NCS | | 49144
2005 | 1/1/1978 | 7/31/1980 | Simons LA56 | UK | British Regional Heart Study, men ages 40-59 | BRHS | 5128 | 5077 | 21.3 (mean)
2003 | 1/1/1978 | 12/31/1980 | Simons LA56 | UK | British Regional Heart Study; men aged 40-59 years at study entry, randomly selected from registers of one general practice in each town | BRHS | | 6643 | 12 (other)
2007 | 1/1/1979 | | Vliegenthart R79 | Germany | in men at work in public authorities and large companies in the region of Munster, Germany | | 4818
2003 | 1/1/1979 | 12/31/1985 | Empana JP80 | Germany | PROCAM cohort, drawn from 52 companies and local government authorities | PROCAM | 8682
2003 | 1/1/1984 | 12/31/1990 | Empana JP80 | Germany | MONICA Augsburg cohort, 1984/1985 and 1989/1990 surveys | MONICA-Augsburg | 5786 | | 7.8 (median)
2004 | 1/1/1984 | 12/31/1995 | Milne R81 | Germany | Men randomly selected from the general population in 1984-5, 1989-90, and 1994-5 | | 3435 | | 6.6 (mean)
2005 | 1/1/1985 | 12/31/1991 | Wang Z82 | Austria | Vorarlberg Health Monitoring and Promotion Program (VHM&PP) cohort of individuals undergoing general health examinations in Vorarlberg province | VHM&PP | | 44649 | 10 (other)
2007 | 1/1/1985 | 12/31/1994 | Donnan PT39 | Norway | Cardiovascular Program in Norway (Ages 60-69) | CP-Norway | 8085 | | 10
2008 | 1/1/1987 | 12/31/1992 | Bhopal R83 | Netherlands | Participants randomly selected from 3 cities in the Netherlands, aged 20-59 and free from CVD, Monitoring Project on Cardiovascular Disease Risk Factors | MP-CVDRF | | 39719 | 10 (other)
2005 | 1/1/1987 | 12/31/1997 | Koller MT84 | Finland | Individuals aged 25-65 years identified from Finnish population register and participating in 3 cross-sectional risk factor surveys in Finland in 1987, 1992, and 1997 | | 17725 | | 9.9 (median)
2003 | 1/1/1988 | | Hippisley-Cox JC34 | Australia | Dubbo Study cohort of elderly Australians (Ages 60-79) | DUBBO | | 2102
2003 | 1/1/1988 | | Hippisley-Cox JC62 | Australia | Dubbo Study cohort of elderly Australians (Ages 60-79) without Diabetes | DUBBO (No DM) | | 1800
2005 | 1/1/1990 | 12/31/1993 | McEwan P85 | Netherlands | Rotterdam Coronary Calcification Study | RCC | | 1795 | 3.3 [0.8] (mean)
2003 | 1/1/1991 | 12/31/1993 | Guzder RN86 | France | PRIME cohort study | PRIME | 7359 | | 5 (other)
2003 | 1/1/1991 | 12/31/1993 | Becker A87 | Northern Ireland | PRIME cohort study (Belfast Cohort) | PRIME | 2399 | | 5 (other)
2003 | 1/1/1992 | 12/31/1993 | Elkeles RS88 | New Zealand | Individuals recruited from the workforce ofa nationwide multi-industry corporation (Fletcher Challenge Ltd 72%) and the general electoral rolls of the Auckland metropolitan region (28%) | | | 6354 | 5 (other)
2005 | 1/1/1992 | 12/31/1995 | Lindman AS71 | Australia | Aboriginal community | | 687
2006 | 1/1/1993 | 12/31/1998 | Scheltens T77 | UK | Individuals with diabetes receiving care in Salford | DARTS | 6544 | 3472
2005 | 4/1/1993 | 10/31/1994 | Silventoinen K78 | UK | Newcastle Heart Project: Europeans | NHP Europe | 725 | | 9.6 (median)
2007 | 12/31/1993 | 1/1/2006 | Simons LA56 | Netherlands | Rotterdam Study | | 6795 | | 12.9 (median)
2008 | 1/1/1995 | | Simons LA56 | UK | QRESEARCH | QRESEARCH | | 607733 | 12 (other)
2008 | 1/1/1995 | 3/31/2006 | Vliegenthart R79 | UK | THIN Cohort; data from 288 practices in the UK using the INPS Vision system (~20% of UK practices); including 24 practices (54709 patients) from Scotland and 14 practices (36904) from Northern Ireland | THIN | | 1072800 | 11 (other)
2004 | 1/1/1996 | 12/31/1996 | Empana JP80 | UK | Cardiff Diabetes Database (type 1 and type 2) | | | 938 | 4 (other)
2005 | 5/1/1996 | 6/30/1998 | Empana JP80 | UK | Poole Diabetes Study | PDS | 428 | | 4.2 [0.62] (median)
2008 | 1/1/1998 | 4/3/1999 | Milne R81 | Germany | Munich | MunichDM | 716 | | 8.1 [1.1] (mean)
2008 | 11/1/2000 | 11/30/2003 | Wang Z82 | UK | Individuals with type 2 diabetes aged 50-75 years, recruited from outpatient clinics in Central and West London | PREDICT | 589 | | 4 (median)

Table 6c Data Sources Summary (External Validation) – Asia

Study Yr Pub | Enroll Start | Enroll End | Study 1st Author | Country | Cohort | Cohort Abbrev | Enrollment Base | Enrollment Final | Follow Up (yrs)
2001 | 1/1/1991 | 12/31/1993 | Suka M89 | Japan | Males aged 30-59 completing annual health examinations between 1991-1993 | JapanWork | 5611
2002 | 1/1/1991 | 12/31/1993 | Suka M90 | Japan | Employee health management center in a Japanese Company | JapanWork | 5611
2005 | 5/1/1995 | 3/31/1997 | Bhopal R83 | Pakistan | Newcastle Heart Project - Pakistani | NHP - Pakistan | 264 | | 7.1 (median)
2005 | 5/1/1995 | 3/31/1997 | Bhopal R83 | India | Newcastle Heart Project - Indian | NHP - India | 230 | | 7.1 (median)
2005 | 5/1/1995 | 3/31/1997 | Bhopal R83 | South Asia | Newcastle Heart Project - South Asians | NHP - South Asia | 576 | | 7.1 (median)