# Summary Table 5

Table 5a Model Parameters – Accelerated Failure Time (First CHD)7

Model* | AFT (A, No BMI) | AFT (A) | AFT (B) | AFT (C) | AFT (D) | AFT (E) | AFT (E, No BMI)
Outcome | First CHD | First CHD | First CHD | First CHD | First CHD | First CHD | First CHD
Age | 1.57 (1.49 - 1.64) (yrs) | 1.55 (1.47 - 1.62) (yrs) | 1.53 (1.46 - 1.61) (yrs) | 1.50 (1.43 - 1.58) (yrs) | 1.49 (1.42 - 1.57) (yrs) | 1.48 (1.40 - 1.56) (yrs) | 1.48 (1.40 - 1.56) (yrs)
Female | 0.35 (0.29 - 0.43) | 0.38 (0.31 - 0.47) | 0.48 (0.39 - 0.59) | 0.40 (0.33 - 0.49) | 0.49 (0.40 - 0.60) | 0.49 (0.40 - 0.61) | 0.49 (0.40 - 0.60)
Total Cholesterol | | | 1.38 (1.30 - 1.47) (TotChol/HDL mg/dL) | | 1.38 (1.30 - 1.46) (TotChol/HDL mg/dL) | 1.37 (1.29 0 1.46) (TotChol/HDL mg/dL) | 1.39 (1.31 - 1.47) (TotChol/HDL mg/dL)
Body Mass Index | | 1.28 (1.17 - 1.39) | 1.17 (1.07 - 1.28) | 1.21 (1.11 - 1.33) | 1.11 (1.01 - 1.23) | 1.10 (1.00 - 1.21)
Systolic BP | | | | 1.18 (1.08 - 1.27) (mmHg) | 1.18 (1.09 - 1.28) (mmHg) | 1.17 (1.08 - 1.28) (mmHg) | 1.20 (1.11 - 1.30) (mmHg)
Diabetes Mellitus | | | | | | 1.60 (1.16 - 2.21) (fasting glucose ≥126 or Med use) | 1.66 (1.20 - 2.28) (fasting glucose ≥126 or Med use)
Smoker | 2.01 (1.68 - 2.41) (Current) | 2.09 (1.74 - 2.50) (Current) | 1.91 (1.60 - 2.29) (Current) | 2.13 (1.78 - 2.55) (Current) | 1.97 (1.64 - 2.36) (Current) | 1.97 (1.64 - 2.36) (Current) | 1.95 (1.63 - 2.33) (Current)

Table 5b Model Parameters – Accelerated Failure Time (First CeVD)7

Model | AFT (A, No BMI) | AFT (A) | AFT (B) | AFT (C) | AFT (D) | AFT (D, No BMI)
Outcome | First CeVD | First CeVD | First CeVD | First CeVD | First CeVD | First CeVD
Age | 1.70 (1.53 - 1.89) (yrs) | 1.66 (1.49 - 1.85) (yrs) | 1.64 (1.48 - 1.83) (yrs) | 1.59 (1.42 - 1.78) (yrs) | 1.58 (1.41 - 1.77) (yrs) | 1.58 (1.42 - 1.77) (yrs)
Total Cholesterol | | | 1.20 (1.03 - 1.40) (TotChol/HDL mg/dL) | | 1.19 (1.03 - 1.39) (TotChol/HDL mg/dL) | 1.23 (1.07 - 1.42) (TotChol/HDL mg/dL)
Body Mass Index | | 1.35 (1.15 - 1.59) | 1.29 (1.09 - 1.54) | 1.26 (1.06 - 1.49) | 1.21 (1.01 - 1.44)
Systolic BP | | | | 1.25 (1.06 - 1.47) (mmHg) | 1.24 (1.05 - 1.47) (mmHg) | 1.30 (1.11 - 1.52) (mmHg)
Smoker | 1.56 (1.07 - 2.26) (Current) | 1.62 (1.12 - 2.36) (Current) | 1.54 (1.06 - 2.24) (Current) | 1.67 (1.15 - 2.44) (Current) | 1.60 (1.10 - 2.32) (Current) | 1.56 (1.07 - 2.27) (Current)

Table 5c Model Parameters – Accelerated Failure Time (Total CVD)7

Model | AFT (A, No BMI) | AFT (A) | AFT (B) | AFT (B, No BMI)
Outcome | Total CVD | Total CVD | Total CVD | Total CVD
Age | 1.59 (1.52 - 1.65) (yrs) | 1.56 (1.50 - 1.63) (yrs) | 1.49 (1.42 - 1.55) (yrs) | 1.49 (1.43 - 1.55) (yrs)
Female | 0.42 (0.36 - 0.49) | 0.46 (0.39 - 0.54) | 0.58 (0.49 - 0.69) | 0.57 (0.49 - 0.68)
Total Cholesterol | | | 1.32 (1.25 - 1.40) (TotChol/HDL mg/dL) | 1.34 (1.27 - 1.41) (TotChol/HDL mg/dL)
Body Mass Index | | 1.27 (1.18 - 1.37) | 1.09 (1.01 - 1.18)
Systolic BP | | | 1.23 (1.15 - 1.32) (mmHg) | 1.25 (1.17 - 1.33) (mmHg)
Diabetes Mellitus | | | 1.66 (1.26 - 2.20) (fasting glucose ≥126 or Med use) | 1.73 (1.31 - 2.28) (fasting glucose ≥126 or Med use)
Smoker | 2.01 (1.73 - 2.34) (Current) | 2.08 (1.79 - 2.42) (Current) | 2.01 (1.72 - 2.34) (Current) | 1.99 (1.70 - 2.31) (Current)

Table 5d Model Parameters – Atherosclerosis Risk in Communities4,11-13,15

Model | ARIC 87-00 (Men) | ARIC 87-00 (Women)
Outcome | Ischemic Stroke | Ischemic Stroke
Age | 2.24 (1.76 - 2.86) (Age/10) | 1.99 (1.52 - 2.62) (Age/10)
Race (Black) | 1.42 (1.07 - 1.89) | 1.52 (1.10 - 2.08)
Systolic BP | 1.45 (1.28 - 1.63) (mmHg) | 1.42 (1.25 - 1.61) (mmHg)
Hypertension | 1.58 (1.21 - 2.06) (Med use) | 1.50 (1.10 - 2.06) (Med use)
Diabetes Mellitus | 2.43 (1.83 - 3.23) (fasting glucose ≥126, nonfasting ≥200) | 3.12 (2.26 - 4.29) (fasting glucose ≥126, nonfasting ≥200)
Smoker | 2.00 (1.54 - 2.60) (Current) | 2.23 (1.64 - 3.03) (Current)
Left Ventricular Hypertropy | 1.47 (0.84 - 2.57) | 2.24 (1.35 - 3.74)
Previous Coronary Heart Disease | 2.08 (1.47 - 2.95) | 1.88 (0.98 - 3.58)

Table 5e Model Parameters – Adult Treatment Panel/Agatston Calcium Score60

Model | ATP/Agatston Calcium Score
Hyperlipidemia (Undefined) | 2.89 (1.49 - 2.28)
Hypertension | 1.97 (1.53 - 2.10) (Arterial, undefined)
Diabetes Mellitus | 3.21 (2.11 - 3.89) (Undefined)
Smoker | 2.31 (1.59 - 2.71) (Current)
Agatston > 75th percentile | 5.2 (4.03 - 6.37)

Table 5f Model Parameters – CUORE29

Model | CUORE (Men)
Age | 1.065 (1.050 - 1.081) (yrs)
Total Cholesterol | 1.093 (1.091 - 1.096) (mg/dL)
HDL | 0.884 (0.876 - 0891) (mg/dL)
Systolic BP | 1.092 (1.086 - 1.098) (mmHg)
Hypertension | 1.833 (1.354 - 2.483) (Med use)
Diabetes Mellitus | 1.521 (1.034 - 2.238) (self report, FBG ≥126 or Med use)
Smoker | 1.876 (1.495 - 2.353) (Current)
Family History | 1.377 (1.059 - 1.791) (CVD)

Table 5g Model Parameters – Framingham Risk Score4,6

Model | FRS D'Agostino (Men) | FRS D'Agostino (Women)
Age | 21.35 (14.03 - 32.48) (Natural Log Age yrs) | 10.27 (5.65 - 18.64) (Natural Log Age yrs)
Total Cholesterol | 3.08 (2.05 - 4.62) (Natural Log Total mg/dL) | 3.35 (2.00 - 5.62) (Natural Log Total mg/dL)
HDL | 0.39 (0.30 - 0.52) (Natural Log HDL mg/dL) | 0.49 (0.35 - 0.69) (Natural Log HDL mg/dL)
Systolic BP | 6.91 (3.91 - 12.20) (Natural Log SBP mmHg NoMedTx) 7.38 (4.22 - 12.92) (Natural Log SBP mmHg MedTx) | 15.82 (7.86 - 31.87) (Natural Log SBP mmHg NoMedTx) 16.82 (8.46 - 33.46) (Natural Log SBP mmHg MedTx)
Diabetes Mellitus | 1.78 (1.43 - 2.20) (≥140 mg/dL orig, ≥126 offspring, or Med use) | 2.00 (1.49 - 2.67) (≥140 mg/dL orig, ≥126 offspring, or Med use)
Smoker | 1.92 (1.65 - 2.24) (Current) | 1.70 (1.40 - 2.06) (Current)

Table 5h Model Parameters – HEART (ARIC)14

Model | HEART [ARIC] (Men) | HEART [ARIC] (Women)
Age | REF (45-49) 1.15 (0.87 - 1.52) (50-54) 1.63 (1.26 - 2.12) (55-59) 1.94 (1.50 - 2.51) (60-64) | REF (45-49) 1.57 (1.07 - 2.30) (50-54) 2.04 (1.40 - 2.96) (55-59) 2.27 (1.55 - 3.32) (60-64)
Hx of Hypercholesterolemia (Pt Report) | 1.54 (1.26 - 1.88) | 1.58 (1.22 - 2.06)
Body Mass Index | | REF (<30) 1.47 (1.14 - 1.90) (≥30)
Hypertension | 1.44 (1.20 - 1.72) (Hx, Pt Report) | 2.43 (1.86 - 3.16) (Hx, Pt Report)
Diabetes Mellitus | 1.86 (1.42 - 2.44) (Self report) | 3.68 (2.74 - 4.96) (Self report)
Smoker | REF (Never) 1.60 (1.26 - 2.02) (Current) 1.15 (0.92 - 1.44) (Former) | REF (Never) 3.22 (2.47 - 4.22) (Current) 0.99 (0.69 - 1.42) (Former)
Family History | 1.52 (1.09 - 2.10) (CVD)
Physical Activity | REF (Often/Very Often) 1.16 (0.88 - 1.55) (Sometimes) 1.39 (1.08 - 1.79) (Seldom/Never)

Table 5i Model Parameters – Hong Kong49,50

Model | Hong Kong | Hong Kong
Outcome | CHD | CHD
Age | 1.03 (1.01 - 1.04) (yrs) | 1.07 (1.05 - 1.08) (yrs)
Female | 0.70 (0.51 - 0.97)
non-HDL Cholesterol (mmol/L) | 1.30 (1.15 - 1.48)
Diabetes Mellitus | 1.04 (1.02 - 1.06) (yrs Dx) | 1.09 (1.02 - 1.18) (HgbA1c %)
log10 | 0.62 (0.40 - 0.95) (EGFR) 1.13 (1.03 - 1.25) (1+albumin/creatinine ratio) | 1.70 (1.45 - 2.00) (albumin/creatinine ratio)
Smoker | 1.55 (1.08 - 2.22) (Current)
Previous Coronary Heart Disease | | 1.76 (1.15 - 2.69)

Table 5j Model Parameters – Intervention as a Goal in Hypertension Treatment37

Model | INSIGHT (Italy) | INSIGHT (Spain) | INSIGHT (France) | INSIGHT (Scandinavia) | INSIGHT (Netherlands) | INSIGHT (UK)
Age | 1.034 (0.961 - 1.113) (yrs) | 1.067 (0.981 - 1.160) (yrs) | 1.066 (0.997 - 1.141) (yrs) | 0.991 (0.893 - 1.100) (yrs) | 1.096 (1.016 - 1.181) (yrs) | 1.011 (0.975 - 1.049) (yrs)
Female | 0.720 (0.302 - 1.717) | 0.411 (0.159 - 1.059) | 0.478 (0.223 - 1.025) | 0.421 (0.135 - 1.311) | 0.376 (0.161 - 0.877) | 0.807 (0.539 - 1.208)
Total Cholesterol | 1.303 (1.045 - 1.625) (TotChol/HDL mg/dL) | 1.364 (1.002 - 1.858) (TotChol/HDL mg/dL) | 1.083 (0.866 - 1.354) (TotChol/HDL mg/dL) | 0.919 (0.630 - 1.340) (TotChol/HDL mg/dL) | 1.295 (1.063 - 1.578) (TotChol/HDL mg/dL) | 1.221 (1.099 - 1.356) (TotChol/HDL mg/dL)
Systolic BP | 1.000 (0.972 - 1.028) (mmHg) | 1.014 (0.987 - 1.042) (mmHg) | 0.988 (0.960 - 1.018) (mmHg) | 1.000 (0.970 - 1.031) (mmHg) | 0.999 (0.977 - 1.022) (mmHg) | 1.011 (0.999 -1.024) (mmHg)
Diabetes Mellitus | 1.270 (0.496 - 3.254) (Med use or FBG ≥140 mg/dL) | 1.174 (0.449 - 3.071) (Med use or FBG ≥140 mg/dL) | 2.850 (1.351 - 6.013) (Med use or FBG ≥140 mg/dL) | 1.187 (0.319 - 4.423) (Med use or FBG ≥140 mg/dL) | 0.925 (03.09 - 2.773) (Med use or FBG ≥140 mg/dL) | 1.640 (0.983 - 2.733) (Med use or FBG ≥140 mg/dL)
Smoker | 2.214 (0.912 - 4.946) (Current) | 1.256 (0.404 - 3.910) (Current) | 1.482 (0.670 - 3.275) (Current) | 1.783 (0.579 - 5.490) (Current) | 1.444 (0.643 - 3.242) (Current) | 1.248 (0.811 - 1.920) (Current)

Table 5k Model Parameters – Korean Stroke Risk Prediction46

Model | KSRP (Men) | KSRP (Women)
Age | 1.085 (1.083 - 1.086) (yrs) | 1.082 (1.079 - 1.084) (yrs)
Total Cholesterol | REF (<200 mg/dL) 1.062 (1.023 - 1.104) (200-239 mg/dL) 1.193 (1.133 - 1.256) (≥240 mg/dL) | REF (<200 mg/dL) 1.023 (0.973 - 1.076) (200-239 mg/dL) 1.131 (1.065 - 1.202) (≥240 mg/dL)
Body Mass Index | 1.032 (1.025 - 1.038) | 1.022 (1.015 - 1.029)
Systolic BP | 1.022 (1.021 - 1.023) (mmHg) | 1.016 (1.015 - 1.017) (mmHg)
Diabetes Mellitus | 1.800 (1.710 - 1.895) (fasting glucose ≥126 mg/dL) | 1.943 (1.813 - 2.083) (fasting glucose ≥126 mg/dL)
Smoker | REF (Never) 1.319 (1.261 - 1.380) (Current) 0.976 (0.926 - 1.029) (Former) | REF (Never) 1.368 (1.268 - 1.476) (Current) 1.112 (1.005 - 1.231) (Former)
Alcohol Intake | 1.070 (1.002 - 1.144) (0g/day) 0.972 (0.915 - 1.033) (1-24g/day) REF (25-49g/day) 1.116 (1.017 - 1.224) (50-99g/day) 1.179 (1.030 - 1.349) (100+g/day) | REF (0g/day) 1.016 (0.954 - 1.083)25-49g/day)
Physical Activity | 1.072 (1.034 - 1.111) (“Do you exercise regularly?” Yes/No) | 1.074 (1.014 - 1.139) (“Do you exercise regularly?” Yes/No)

Table 5l Model Pparameters – Miyasaka Post-Arterial Fibrillation9

Model | Miyasaka Post-AF (Men) | Miyasaka Post-AF (Women)
Outcome | CHD | CHD
Age | 1.32 (1.18 - 1.46) (Age/10) | 1.29 (1.13 - 1.47) (Age/10)
Systolic BP | 1.04 (0.96 - 1.13) (BP/10 mmHg) | 1.07 (0.99 - 1.14) (BP/10 mmHg)
Hypertension | 1.47 (1.02 - 2.12) (Dx, Med use, or ≥HTN Grade 1) | 2.23 (1.33 - 3.73) (Dx, Med use, or ≥HTN Grade 1)
Diabetes Mellitus | 1.50 (1.04 - 2.17) (Dx, Med use) | 2.04 (1.47 - 2.82) (Dx, Med use)
Chronic Renal Disease (Diagnosed) | 1.34 (0.91 - 1.96) | 1.79 (1.17 - 2.72)
Peripheral Artery Disease (Diagnosed) | 1.39 (0.85 - 2.28) | 1.67 (1.12 - 2.50)
Valvular Heart Disease (>than mild stenosis/regurg by Echo OR prior valve repair/replacement) | 1.39 (0.98 - 1.97) | 1.44 (1.06 - 1.95)
Obstructive Sleep Apnea (Diagnosed) | 1.97 (0.99 - 3.89) | 2.43 (0.59 - 9.97)

Table 5m Model Parameters – National Health and Nutrition Examination Survey Followup8

Model | NHANES I F/U Lab | NHANES I F/U Lab | NHANES I F/U Non-Lab | NHANES I F/U Non-Lab
Outcome | Men | Women | Men | Women
Age | 31.311 (22.003 - 44.558) (Natural Log Age yrs) | 40.528 (26.024 - 63.115) (Natural Log Age yrs) | 35.163 (24.613 - 50.235) (Natural Log Age yrs) | 49.6 (32.353 - 76.041) (Natural Log Age yrs)
Total Cholesterol | 2.153 (1.504 - 3.082) (Natural Log Total mg/dL) | 1.78 (1.191 - 2.661) (Natural Log Total mg/dL)
Body Mass Index | | | 2.068 (1.287 - 3.324) | 2.332 (1.582 - 3.438)
Systolic BP | 5.506 (3.393 - 8.936) (Natural Log BP mmHg) | 6.309 (3.79 - 10.502) (Natural Log BP mmHg) | 5.088 (3.111 - 8.322) (Natural Log BP mmHg) | 4.687 (2.777 - 7.911) (Natural Log BP mmHg)
Hypertension | 1.278 (1.041 - 1.571) (Med use) | 1.465 (1.221 - 1.758) (Med use) | 1.246 (1.014 - 1.53) (Med use) | 1.443 (1.205 - 1.728) (Med use)
Diabetes Mellitus | 1.989 (1.497 - 2.643) (Self report) | 2.036 (1.574 - 2.632) (Self report) | 1.898 (1.428 - 2.522) (Self report) | 1.913 (1.483 - 2.468) (Self report)
Smoker | 1.728 (1.5 - 1.989) (Current) | 1.734 (1.474 - 2.041) (Current) | 1.764 (1.529 - 2.036) (Current) | 1.77 (1.504 - 2.082) (Current)

Table 5n Model Parameters – National Health and Nutrition Examination Survey Men/Women1,3

Model | NHANES I (Men) | NHANES I (Women) | NHANES II (Men) | NHANES II (Women)
Age | 1.081 (1.067 - 1.095) (yrs) | 1.117 (1.097 - 1.137) (yrs) | 1.124 (1.098 - 1.152) (yrs) | 1.094 (1.06 - 1.13) (yrs)
Total Cholesterol | 1.003 (1.002 - 1.003) (mg/dL) | 1.002 (1 - 1.005) (mg/dL) | 1.001 (0.998 - 1.005) (mg/dL) | 1.002 (0.998 - 1.006) (mg/dL)
Systolic BP | 1.014 (1.008 - 1.019) (mmHg) | 1.017 (1.012 - 1.022) (mmHg) | 1.016 (1.009 - 1.023) (mmHg) | 1.023 (1.015 - 1.03) (mmHg)
Smoker | 1.64 (1.311 - 2.051) (Current) | 2.241 (1.713 - 2.932) (Current) | 2.437 (1.791 - 3.316) (Current) | 2.505 (1.648 - 3.807) (Current)

Table 5o Model Parameters – Second Northwick Park Heart Study31

Model | NPHS-II
Age | 1.19 (0.90 - 1.56) (yrs)
Total Cholesterol | 1.26 (1.04 - 1.52) (mmol/L)
Triglycerides (mmol/L) | 1.23 (1.02 - 1.48)
Systolic BP | 1.23 (1.02 - 1.48) (mmHg)
Diabetes Mellitus | 3.10 (1.41 - 6.80) (Undefined)
Smoker (Never) | 1.61 (1.10 - 2.35) (Current)
Family History | 1.67 (1.15 - 2.44) (CVD)
Fibrinogen (g/L) | 1.29 (1.07 - 1.55)
Lipoprotein a (mg/dL) | 1.60 (1.05 - 2.42)

Table 5p Model Parameters – Prospective Cardiovascular Münster26-28,61

Model | PROCAM
Outcome | Stroke
Age | 1.12 (1.08 - 1.15) (yrs)
Female | 0.54 (0.31 - 0.93)
Systolic BP | 1.02 (1.01 - 1.03) (mmHg)
Diabetes Mellitus | 2.07 (1.03 - 3.33) (Undefined)
Smoker | 2.34 (1.52 - 3.60) (Current)

Table 5q Model Parameters – QRISK34,40,62

Model | QRISK (Men) | QRISK (Women)
Age | 50.634 (47.792 - 53.646) [Log (Age/10)] | 87.75 (81.34 - 94.66) [Log (Age/10)]
Total Cholesterol | 1.001 (0.999 - 1.003) (TotChol/HDL mg/dL) | 1.001 (0.999 - 1.002) (TotChol/HDL mg/dL)
Body Mass Index | 1.022 (1.019 - 1.025) | 1.015 (1.013 - 1.018)
Systolic BP | 1.004 (1.004 - 1.005) (mmHg) | 1.005 (1.004 - 1.005) (mmHg)
Hypertension | 1.847 (1.788 - 1.908) (Med use) 0.993 (0.992 - 0.995) [Interaction {SBP*HTN Med Use)] | 1.734 (1.674 - 1.796) (Med use) 0.996 (0.995 - 0.997) [Interaction (SBP*HTN Med Use)]
Smoker | 1.417 (1.385 - 1.449) (Current) | 1.530 (1.487 - 1.574) (Current)
Family History | 1.300 (1.257 - 1.344) (CVD) | 1.229 (1.187 - 1.273) (CVD)
Townsend Score | 1.017 (1.014 - 1.020) | 1.035 (1.031 - 1.038)

Table 5r Model Parameters – Registre Gironí del Cor38

Model | REGICOR (Men) | REGICOR (Women)
Age | 1.044 (1.020 - 1.069) (yrs) | 1.338 (0.866 - 2.067) (yrs) 0.998 (0.994 - 1.002) (>2 yrs)
Total Cholesterol | 1.000 (0.996 - 1.008) (mg/dL) | 0.999 (0.991 - 1.007) (mg/dL)
HDL | 0.980 (0.963 - 0.998) (mg/dL) | 0.953 (0.931 - 0.976) (mg/dL)
Optimal BP (SBP < 120 & DBP < 80) | 0.555 (0.199 - 1.544) | 0.986 (0.248 - 3.919)
Normal BP (SBP 120-129, DBP 80-84) | (REF) | (REF)
High Normal BP (SBP 130-139, DBP 85-89) | 0.863 (0.428 - 1.741) | 0.958 (0.363 - 2.527)
Hypertension Grade 1 (SBP 140-159, DBP 90-99) | 1.404 (0.748 - 2.633) | 0.955 (0.400 - 2.280)
Hypertension Grades 2-4 (SBP >=160, DBP >=100) | 1.134 (0.510 - 2.524) | 1.176 (0.442 - 3.127)
Diabetes Mellitus | 1.017 (0.612 - 1.690) (Dx) | 2.221 (1.234 - 3.999) (Dx)
Smoker | 1.758 (1.153 - 2.679) (Current) | 3.983 (1.681 - 9.435) (Current)

Table 5s Model Parameters – Strong Heart Study4,16

Model | SHS (Men) | SHS (Women)
Age | REF (45-54) 1.70 (1.33 - 2.17) (55-64) 2.58 (1.92 - 3.46) (65-74) | REF (45-54) 1.40 (1.09 - 1.80) (55-64) 2.03 (1.53 - 2.70) (65-74)
LDL | REF (<100 mg/dL) 1.03 (0.76 - 1.39) (100-129 mg/dL) 1.67 (1.23 - 2.26) (130-159 mg/dL) 2.44 (1.72 - 3.47) (≥160 mg/dL) | REF (<100 mg/dL) 1.53 (1.15 - 2.04) (100-129 mg/dL) 1.61 (1.17 - 2.22) (130-159 md/dL) 2.17 (1.51 - 3.12) (≥160 mg/dL)
HDL | 1.31 (1.04 - 1.64) (<40 mg/dL) REF (40-59 mg/dL) 0.84 (0.53 - 1.33) (≥60 mg/dL) | 1.10 (0.86 - 1.40) (<40 mg/dL) REF (40-59 mg/dL) 0.96 (0.69 - 1.33) (≥60 mg/dL)
Optimal BP (SBP < 120 & DBP < 80) | REF (no Med use) | REF (no Med use)
Pre-Hypertension (SBP 120 - 139, DBP 80-89) And No HTN Med Use | 1.78 (1.26 - 2.51) | 1.15 (0.83 - 1.59)
Hypertension Grades 1-4 (SBP >=140, DBP>=90) Or HTN Med Use | 2.01 (1.43 - 2.83) | 1.69 (1.25 - 2.28)
Diabetes Mellitus | 1.66 (1.30 - 2.12) (fasting glucose ≥126 or Med use) | 2.26 (1.73 - 2.96) (fasting glucose ≥126 or Med use)
Normal albuminuria (<30 albumin/creatinine urine ratio) | (REF) | (REF)
Microalbuminuria (ratio of urine albumin/creatinine was >30 and <300) | 1.39 (1.04 - 1.85) | 1.33 (1.00 - 1.77)
Macroalbuminuria (ratio of urine albumin/creatinine was >300) | 2.11 (1.51 - 2.95) | 2.69 (2.02 - 3.59)
Smoker | 1.38 (1.10 - 1.72) (Current) | 1.44 (1.14 - 1.83) (Current)

Table 5t Model Parameters – Uppsala Longitudinal Study of Adult Men22, 23

Model | ULSAM
Systolic BP | 1.27 (1.08-1.47) (mmHg)
Smoker (Never) | 1.23 (1.03 - 1.48) (Current)
Family History | 1.34 (1.09-1.62) (MI)
Apo B/Apo A1 Ratio | 1.46 (1.24 - 1.71)
Intact proinsulin (pmol/L) | 1.46 (1.20 - 1.76)

Table 5u Model Parameters – USA-People's Republic of China48

Model | USA-PRC (men) | USA-PRC (women)
Age | 1.07 (1.04 - 1.10) (yrs) | 1.09 (1.05 - 1.13) (yrs)
Total Cholesterol | 1 (<140 mg/dL) 0.99 (0.59 - 1.69) (140-200 mg/dL) 1.36 (0.79 - 2.34) (200+ mg/dL) | 1 (<140 mg/dL) 0.92 (0.44 - 1.93) (140-200 mg/dL) 1.30 (0.62 - 2.73) (200+ mg/dL)
Body Mass Index | 1 (<24) 1.33 (1.00 - 1.78) (≥24) | 1 (<24) 1.97 (1.34 - 2.88) (≥24)
Systolic BP | 0.58 (0.36 - 0.92) (<120 mmHg) REF (120-129 mmHg) 1.49 (0.93 - 2.41) (130-139 mmHg) 2.24 (1.43 - 3.51) (140-159 mmHg) 5.50 (3.43 - 8.80) (160-179 mmHg) 12.59 (7.45 - 21.28) (≥180 mmHg) | 0.44 (0.24 - 0.82) (<120 mmHg) REF (120-129 mmHg) 1.26 (0.68 - 2.32) (130-139 mmHg) 2.22 (1.28 - 3.84) (140-159 mmHg) 3.93 (2.23 - 6.91) (160-179 mmHg) 6.35 (3.42 - 11.80) (≥180 mmHg)
Diabetes Mellitus | 1.07 (0.58 - 1.98) (fasting glucose ≥126 or Med use) | 2.61 (1.57 - 4.33) (fasting glucose ≥126 or Med use)
Smoker (Never) | 2.03 (1.42 - 2.90) (Current) | 1.60 (1.11 - 2.32) (Current)

Table 5v Model Parameters – Women's Health Study19,20

Model | WHS
Age | 1.076 (1.064 - 1.089) (yrs)
Total Cholesterol | 4.801 (2.834 - 8.135) (Natural Log Total mg/dL)
HDL | 0.288 (0.192 - 0.43) (Natural Log HDL mg/dL)
Systolic BP | 1.032 (1.02 - 1.044) (SBP-125) 0.999 (0.999 - 1) [(SBP-125)ˆ2]
Hypertension | 1.302 (1.023 - 1.657) (Med use)
Smoker (Never) | 2.624 (2.086 - 3.301) (Current)
Natural Log of hsCRP (mg/L) | 1.216 (1.102 - 1.341)