# Summary Table 4

Primary Models With at Least One External Validation^*^

Model Name | Model Outcome | Model Pub Year | Study Count | Cohort Abbrev | Enroll Start | Enroll End | Enrollment | Followup Duration
ASSIGN30 | CVD 11 | 2007 | 2 | SHHEC | 01/01/1984 | 12/31/1995 | 13297
DARTS39 | Hard CHD 1 | 2006 | 2 | DARTS | 01/01/1995 | 06/30/2004 | 4569 | 4.1
FINRISK | CVD | 2005 | 4 | FINRISK | | | 14694
FRS (1991)51, 52 | CVD 2 | 1991 | 26 | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5573 | 12
FRS (1991)51, 52 | Total CHD 1 | 1991 | 5 | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5573 | 12
FRS (1991) Stroke51, 52 | Stroke 4 | 1991 | 3 | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5573 | 12
FRS (ATP)4 | Hard CHD 1 | 2001 | 16 | FRS, FRS-O
FRS (Custom 4 Variable)3 | CHD Mortality | 1999 | 3 | FRS | 01/01/1954 | 12/31/1958 | 4169 | 24
FRS [LDL] (1998)2 | Total CHD 1 | 1998 | 2 | FRS, FRS-O | 01/01/1948 | 12/31/1974 | 5345 | 12
FRS [TC] (1998)2 | Total CHD 1 | 1998 | 10 | FRS, FRS-O | 01/01/1948 | 12/31/1974 | 5345 | 12
FRS [Unknown Version] (1998)2 | Total CHD 1 | 1998 | 12 | FRS, FRS-O | 01/01/1948 | 12/31/1974 | 5345 | 12
FRS Hard CHD [TC] (1998)2 | Hard CHD 1 | 1998 | 3 | FRS, FRS-O | 01/01/1948 | 12/31/1974 | 5345 | 12
PROCAM CHD (Cox model)27 | Hard CHD 1 | 2002 | 11 | PROCAM | 01/01/1979 | 12/31/1985 | 5159 | 10
QRISK40 | CVD 4 | 2007 | 4 | QRESEARCH | 01/01/1995 | 04/01/2007 | 614553 | 6.5
SCORE (High Risk TC)53 | CVD Mortality | 2003 | 2 | SCORE | | | 205178
SCORE (Low Risk TC)53 | CVD Mortality | 2003 | 3 | SCORE | | | 205178
SCORE (Unknown Version) 53 | CVD Mortality | 2003 | 6 | SCORE | | | 205178
UKPDS 56^54^ | Hard CHD 1 | 2001 | 5 | UKPDS | | | 4540
UKPDS 60^54^ | Stroke 1 | 2002 | 2 | UKPDS | 01/01/1977 | 12/31/1991 | 4549 | 10.5

* Models in italics are not counted as separate models as they were underspecified in the source manuscript; thus, the exact version of the model that was used could not be determined.

Primary Models With No External Validation^*^

Model Name | Model Outcome | Model Pub Year | Cohort Abbrev | Enroll Start | Enroll End | Enrollment | Follow-up Duration
ARIC13; - Version 1: Basic risk factors; - Version 2: Basic & DM-Specific risk factors; - SubVersion A: liberal definition of DM; - SubVersion B: restrictive definition of DM; - Version 3: DM-Specific risk factors; - SubVersion A: liberal definition of DM; - SubVersion B: restrictive definition of DM | Hard CHD 2 | 2003 | ARIC | 01/01/1987 | 12/31/1989 | 14054 | 10.2
ATP-III (Remodel) + genotype55 | CVD 3 | 2009 | WGHS | 01/01/1992 | 03/31/2004 | 22129 | 10.2
Chicago Young Adults5 | CHD Mortality | 2007 | CHA | 01/01/1967 | 01/31/1973 | 10375 | 32
ARIC Stroke (Chambless)12; - Version 1: Basic; - Version 2: Basic + Age + Race; - Version 3: Basic + NTRF + Age + Race | Stroke 3 | 2004 | ARIC | 01/01/1987 | 12/31/1989 | 13161 | 12.3
CMCS Cox Model47 | Hard CHD 1 | 2004 | MUCA | 01/01/1992 | 12/31/1999 | 30121
CRM33 | CVD | 1999 | NHS Trust | 01/01/1990 | 12/31/1991 | 798
CUORE29 | Hard CHD 2 | 2005 | CUORE | 01/01/1983 | 12/31/1996 | 6865 | 9.1
D'Agostino CVD FEMALE6 | CVD 2 | 2008 | FRS, FRS-O | 01/01/1968 | 12/31/1987 | 8491
SBHW (Detrano)18; - Version 1: Data Derived; - Version 2: Data Derived + Ca | Hard CHD 1 | 1999 | SBHW | 12/01/1990 | 12/31/1992 | 1194 | 3.42
Dubbo model56 | CVD 4 | 2003 | DUBBO-All | 01/01/1988 | | 2102
WOSCOPS32; - Version 1: ECG + Age, smoking only; - Version 2: ECG + Clinical Vars; - Version 3: ECG + Age | MI | 2007 | WOSCOPS | 01/01/1989 | 12/31/1991 | 6595 | 4.9
Erikssen NorGov24; - Version 1: CRF Model; - Version 2: CRF-X Model; - Version 3: X Model | CHD Mortality | 2004 | NorGov | 08/28/1972 | 03/30/1975 | 2014 | 26
European Society of Cardiology (ESC)57 | Total CHD 1 | 1994 | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5573 | 12
FRS (1991) CHD Mortality51, 52 | CHD Mortality | 1991 | FRS, FRS-O | 01/01/1948 | 12/31/1975 | 5573 | 12
EPIC-Norfolk HgbA1c35; - Version 1: FRS ‘98 Vars + HgbA1c; - Version 2: FRS ’98 Vars w/o DM + HgbA1c | Total CHD 1 | 2008 | EPIC-Norfolk | 03/01/1993 | 02/28/1998 | 10295 | 8.5
FRS (2001 ATP) + CACS17 | Hard CHD 1 | 2004 | SBHW | 01/01/1990 | 12/31/1992 | 1029 | 7
FRS (2007 Barzi)45 | CVD 8 | 2007 | FRS, FRS-O | 01/01/1948 | 12/31/1974 | 5345 | 12
FRS (Wilson 1998) + ECG23 | CVD Mortality | 2007 | ULSAM (70) | 01/01/1970 | 12/31/1973 | 1221 | 23
NHANES-EFS I (Gaziano)8; - Version 1: Lab-Based Model; - Version 2: Non-Lab Based Model | CVD 7 | 2008 | NHANES-I EFS | 01/01/1971 | 12/31/1992 | 6186 | 21
Hong Kong Diabetes Risk Score50 | Stroke 1 | 2007 | HKD Registry | 01/01/1995 | 07/30/2005 | 3541 | 5.37
Hong Kong Total CHD Score49 | Total CHD 1 | 2008 | HKD Registry | 01/01/1995 | | 7067 | 5.4
JBSRC33 | CVD | 1998 | NHS Trust | 01/01/1990 | 12/31/1991 | 798
Korean Stroke Risk Prediction (KSRP)46 | Stroke 6 | 2008 | NHIC | 01/01/1992 | 12/31/1995 | 1205268 | 13
Metabolic Syndrome Model15 | Hard CHD 2 | 2005 | ARIC | 01/01/1987 | 12/31/1989 | 12089 | 11
Miyasaka CHD Post-AF9 | Total CHD 1 | 2007 | Mayo | 01/01/1980 | 12/31/2000 | 2768 | 6
New Zealand risk charts58 | CVD | 1996
NHANES I (4 Variables)3 | CHD Mortality | 1999 | NHANES I | 01/01/1971 | 12/31/1975 | 6611 | 20
NHANES I and II, pooled3 | CHD Mortality | 1999 | NHANES I and II (pooled) | | | 18542
NHANES II (4 Variable)3 | CHD Mortality | 1999 | NHANES II | 01/01/1976 | 12/31/1980 | 5705 | 15
NPHS-II31; - Score 1 (basic); - Score 2 (basic + DM + Fam Hx); - Score 3 (basic + DM); - Score 4 (basic + Fam Hx); - Score 5 (basic + Fibrinogen); - Score 6 (basic + Lipoprotein A); - Score 7 (basic + ApoAI + ApoB) | Hard CHD 2 | 2005 | NPHS-II | 01/01/1989 | | 2732 | 10.8
Personal HEART14 | Hard CHD 2 | 2007 | ARIC | 01/01/1987 | 12/31/1989 | 14343
PROCAM (BMI-modified)28 | Hard CHD 1 | 2008 | PROCAM | 01/01/1979 | 12/31/1999 | 7134 | 10
PROCAM CHD (Point Score)27 | Hard CHD 1 | 2002 | PROCAM | 01/01/1979 | 12/31/1985 | 5159 | 10
PROCAM CHD (Weibull model)26 | Hard CHD 1 | 2007 | PROCAM | 01/01/1978 | 12/31/1995 | 7295 | 12
PROCAM Stroke (Cox model)26 | Stroke 2 | 2007 | PROCAM | 01/01/1978 | 12/31/1995 | 7295 | 12
QRISK2^34^ | CVD 1 | 2008 | QRESEARCH | 01/01/1993 | 03/31/2008 | 2285815 | 15
QT Dispersion32 | Hard CHD 1 | 2007 | WOSCOPS | 01/01/1989 | 12/31/1991 | 6595 | 4.9
Reynolds Risk Score (Remodel) + genotype55 | CVD 3 | 2009 | WGHS | 01/01/1992 | 03/31/2004 | 22129 | 10.2
Ridker Model A20 | CVD 3 | 2007 | WHS (Val) | 09/01/1992 | | 8158 | 10.2
Ridker Model A, PHS-II59 | CVD 15 | 2008 | PHS-II | 12/01/1995 | | 10724 | 10.8
Ridker Model B25 | CVD 3 | 2007 | STULONG | 01/01/1975 | 12/31/1979 | 646
SCORE (High Risk TC-HDL Ratio)53 | CVD Mortality | 2003 | SCORE | | | 205178
SHS Model16 | Hard CHD 1 | 2006 | SHS | 01/01/1989 | 12/01/2001 | 4372
Swedish NDR43 | CVD 5 | 2008 | SNDR | 01/01/1998 | 12/31/2003 | 11646 | 5.64
ULSAM22 | MI | 2004 | ULSAM | 01/01/1970 | 12/31/1973 | 1108 | 28.7
USA-PRC (Point Scoring)48 | CVD 17 | 2006 | USA-PRC | 09/01/1983 | 10/31/1984 | 9903 | 15.1
USA-PRC (Simplified)48 | CVD 17 | 2006 | USA-PRC | 09/01/1983 | 10/31/1984 | 9903 | 15.1
WHS Model 19; - Version 1: Basic; - Version 2: Basic + hsCRP | CVD 3 | 2006 | WHS | 09/01/1992 | | 15048 | 10
Wilson AFT CeVD7; - Model A; - Model A No BMI; - Model B; - Model C; - Model D; - Model D No BMI | Stroke 2 | 2008 | FRS-O | 01/01/1971 | | 4780 | 24
Wilson AFT CHD7; - Model A; - Model A No BMI; - Model B; - Model C; - Model D; - Model E; - Model E No BMI | Total CHD 1 | 2008 | FRS-O | 01/01/1971 | | 4780 | 24
Wilson AFT CVD7; - Model A; - Model A No BMI; - Model B; - Model B No BMI | CVD 12 | 2008 | FRS-O | 01/01/1971 | | 4780 | 24

* Some studies have grouped models in which various variables were added and removed from candidate models in that evaluation.