# Summary Table 3

Table 3a Data Sources Details (Primary Models) – Americas All

First Author | Year Published | Cohort Abbreviation | Group | Mean Age (yrs) | Race (%) | Female (%) | Smoker (%) | Cholesterol Level (mg/dL) | Diabetes (%) | Mean SBP (mmHg) | Mean DBP (mmHg) | HTN (%) | HTN Med Use (%) | HTN or HTN Med Use (%)
Liao Y1 | 1999 | NHANES I and II (pooled) | All | | | 57.5
Wilson PWF2 | 1998 | FRS, FRS-O | All | | | 53.4 | 39 | LDL: 141.8 HDL: 51.7 | 4.5 | | | 32.8 | 8.9
Liao Y3 | 1999 | FRS | All | 49.8 | | 55.7 | 47.7 | Tot: 238 | | 132.9^**^ | 83.3^**^
D'Agostino RB4 | 2001 | PRHHP | All | 54.1 | H: 100 | 0 | 44 | | 7 | | | 34
Berry JD5 | 2007 | CHA | All | 29.8 | | 0 | 47 | Tot: 189.8 | 0 | 134.4^**^ | 78.1^**^
D'Agostino RB6 | 2008 | FRS, FRS-O | All | 48.8 | | 53.3 | 34.7 | HDL: 51.7 Tot: 213.9 | 5 | 127.6 | | | 11
Wilson PWF7 | 2008 | FRS-O | All | 36.7 (9.75 [SD]) | W: 100 | 51.6 | 45.2 | HDL: 50.7 Tot: 196.8 | 2.8 | 122.2 (16.67 [SD])
D'Agostino RB4 | 2001 | FRS, FRS-O | All | 49 | W: 100 | 53.6 | 22.2 | | 4.5 | | | 32.2
Liao Y1 | 1999 | NHANES I | All | 52 | W: 100 | 58.4 | 35.2 | | | 134.6 | 84.4
Gaizano TA8 | 2008 | NHANES-I EFS | All | 47.8 | | 54.1 | 42.9 | Tot: 220.8 | 3.8 | 132.3 | | | 9.7
Liao Y1 | 1999 | NHANES II | All | 54.5 | W: 100 | 53.5 | | | | 132.4 | 82.9
D'Agostino RB4 | 2001 | HHP | All | 61.9 | | 0 | 32 | | 14 | | | 33
Miyasaka Y9 | 2007 | Mayo | All | | | 52.4 | 52 | | 12.8 | | | | 43.9 | 73.7
Vaidya D10 | 2007 | JHSS | All | 45.6 | W: 83.3 B: 16.7 | 48.5 | 33 | LDL: 152.4 HDL: 50.3 Tot: 232.6 | 6.3 | 133.1 | 84.7 | | | 45.2
Mainous AG11 | 2008 | ARIC | All | 59.7 | | 58 | 17.7 | HDL: 53.9 Tot: 207.6 | 0 | 122.8
Chambless LE12 | 2004 | ARIC | All | | | 55.3
D'Agostino RB4 | 2001 | ARIC | All | 54 | W: 73.5 B: 26.5 | 56.7 | 26 | | 8.6 | | | 16.8
Folsom A13 | 2003 | ARIC | Diabetes | | W: 55 B: 45
Folsom A13 | 2003 | ARIC | All | | | 56.8 | | | 10.7
Mainous AG14 | 2007 | ARIC | All | 54.1 | W: 73.7 B: 26.3 | 56.5 | 26 | | 6.9 | | | 14.8 | 28.2
McNeill AM15 | 2005 | ARIC | All | 54 | W: 74.6 B: 25.6 | 100 | 26.6 | LDL: 136.7 | 0 | | | 39.1
D'Agostino RB4 | 2001 | CHS | All | 69.4 | W: 100 | 62.6 | 13.9 | | 11.9 | | | 33.7
D'Agostino RB4 | 2001 | SHS | All | 56.1 | O: 100 | 59.6 | 34.1 | | 47.3 | | | 25.2
Lee ET16 | 2006 | SHS | All | 56.2 | | 60.6 | 33.7 | LDL: 118.2 Tot: 191.1 | 44 | 127.6 | 76.7
Greenland P17 | 2004 | SBHW | All | 65.7 (7.8 [SD]) | W: 84.9 B: 5.3 H: 4.5 O: 5.2 | 10.2 | 17.7 | | 0 | | | 41.4
Detrano RC18 | 1999 | SBHW | All | 66 (8 [SD]) | | 11 | | HDL: 45.3 | 18 | 142 (20 [SD]) | 80 (11 [SD]) | 32
Cook NR19 | 2006 | WHS | All | 54 (8 [SD]) | | 100 | | | 0 | | | | 12
Ridker PM20 | 2007 | WHS (Val) | All | 52^*^ (49-59 [IQR]) | W: 94.5 B: 1.9 H: 1 O: 1.8 | 100 | 11.5 | | 2.9 | 125^*^ (115-135 [IQR]) | 80^*^ (70-80 [IQR]) | 25.3

* Median.

** Derived.

Table 3b Data Sources Details (Primary Models) – Americas Men

First Author | Year Published | Cohort Abbreviation | Group | Mean Age (yrs) | Race (%) | Smoker (%) | Cholesterol Level (mg/dL) | Diabetes (%) | Mean SBP (mmHg) | Mean DBP (mmHg) | HTN (%) | HTN Med Use (%) | HTN or HTN Med Use (%)
Liao Y1 | 1999 | NHANES I and II (pooled) | Men
Liao Y1 | 1999 | NHANES I and II (pooled) | Black men | 54.5 (13.4 [SD]) | | 46.7 | | 5.9 | 141.7 (25.0 [SD]) | 89.2 (14.3 [SD]) | 61.6
Liao Y1 | 1999 | NHANES I and II (pooled) | White men | 53.5 (13.2 [SD]) | | 38.6 | | 3.8 | 134.9 (20.1 [SD]) | 85 (11.5 [SD]) | 49.1
Wilson PWF2 | 1998 | FRS, FRS-O | Men | | | 40.4 | LDL: 142.9 HDL: 44.8 | 5.2 | | | 36 | 6.8
Liao Y3 | 1999 | FRS | Men | 49.6 (8.5 [SD]) | | 59.7 | | | 132 (20 [SD]) | 84 (11.7 [SD])
D'Agostino RB4 | 2001 | PRHHP | Men
Berry JD5 | 2007 | CHA | Men | | | | Tot: 189.8 | | | 78.1
Berry JD5 | 2007 | CHA | Older (30-39) | 34.5 (2.9 [SD]) | | 44.7 | Tot: 199.4 | 0 | 134.8 (15.7 [SD]) | 79.8 (10.5 [SD])
Berry JD5 | 2007 | CHA | Younger (18-29) | 25 (3 [SD]) | | 49.4 | Tot: 180 | 0 | 133.9 (14.8 [SD]) | 76.3 (10 [SD])
D'Agostino RB6 | 2008 | FRS, FRS-O | Men | 48.5 (10.8 [SD]) | | 35.2 | HDL: 44.9 Tot: 212.5 | | 129.7 (17.6 [SD]) | | | 10.1
D'Agostino RB4 | 2001 | FRS, FRS-O | Men | 48.3 | | 40 | | 5 | | | 40
Liao Y1 | 1999 | NHANES I | Men | 53.2 (10.5 [SD]) | | 41.6 | | | 135.6 (19.7 [SD]) | 86.2 (11.5 [SD])
Gaizano TA8 | 2008 | NHANES-I EFS | Men | 48.3 (14 [SD]) | | 36.2 | Tot: 218.9 | 3.56 | 133.8 (19.8) | | | 7.65
Liao Y1 | 1999 | NHANES II | Men | 54.3 (10.5 [SD]) | | 37.7 | | | 133.4 (19.3 [SD]) | 84.6 (11.4 [SD])
Miyasaka Y9 | 2007 | Mayo | Men | | | | | | | | | 35.2 | 65.5
Vaidya D10 | 2007 | JHSS | Men | 45.2 (7.3 [SD]) | W: 88.7 B: 11.3 | | LDL: 149.9 HDL: 44.6 Tot: 232.8 | | 131.7 (16.8 [SD]) | 82.6 (9.9 [SD]) | | | 39.9
Mainous AG11 | 2008 | ARIC | Men | 60 | | 18.7 | HDL: 45.5 Tot: 200 | 0 | 124
Chambless LE12 | 2004 | ARIC | Men
D'Agostino RB4 | 2001 | ARIC | Men | | | | | | | | 17.9
D'Agostino RB4 | 2001 | ARIC | White men | 54.6 | | 24 | | 6 | | | 13
D'Agostino RB4 | 2001 | ARIC | Black men | 53.7 | | 38 | | 14 | | | 34
Mainous AG14 | 2007 | ARIC | Men | 54.4 (5.7 [SD]) | W: 77 B: 23 | 27.5 | | | | | 14.7 | 23.5
McNeill AM15 | 2005 | ARIC | Men | 54 (5.7 [SD]) | | 29.6 | LDL: 139 | | | | 39.9
D'Agostino RB4 | 2001 | CHS | Men | 69.7 | | 12 | | 15 | | | 35
D'Agostino RB4 | 2001 | SHS | Men | 55.4 | | 40 | | 42 | | | 27
Lee ET16 | 2006 | SHS | Men | 55.5 | | | LDL: 118.9 Tot: 189.3 | 39.7 | 128 | 79.4

Table 3c Data Sources Details (Primary Models) – Americas Women

First Author | Year Published | Cohort Abbreviation | Group | Mean Age (yrs) | Race (%) | Smoker (%) | Cholesterol Level (mg/dL) | Diabetes (%) | Mean SBP (mmHg) | Mean DBP (mmHg) | HTN (%) | HTN Med Use (%) | HTN or HTN Med Use (%)
Liao Y1 | 1999 | NHANES I and II (pooled) | White women | 52.2 (13.8 [SD]) | | 29.3 | | 4.3 | 132.5 (23.7 [SD]) | 81.7 (11.9 [SD]) | 42.7
Liao Y1 | 1999 | NHANES I and II (pooled) | Black women | 50.9 (13.8 [SD]) | | 32.8 | | 7.1 | 141.2 (27.9 [SD]) | 87.2 (14.1 [SD]) | 62.5
Wilson PWF2 | 1998 | FRS, FRS-O | Women | | | 37.7 | LDL: 140.8 HDL: 57.7 | 4 | | | 30 | 10.7
Liao Y1 | 1999 | FRS | Women | 49.9 (8.5 [SD]) | | 38.1 | | | 133.6 (24.7 [SD]) | 82.7 (12.3 [SD])
D'Agostino RB6 | 2008 | FRS, FRS-O | Women | 49.1 (11.1 [SD]) | | 34.2 | HDL: 57.6 Tot: 215.1 | | 125.8 (20 [SD]) | | | 11.8
D'Agostino RB4 | 2001 | FRS, FRS-O | Women | 49.6 | | 38 | | 4 | | | 29
Liao Y1 | 1999 | NHANES I | Women | 51.2 (11.0 [SD]) | | 30.7 | | | 133.9 (23.4 [SD]) | 83.2 (11.9 [SD])
Gaizano TA8 | 2008 | NHANES-I EFS | Women | 47.4 (14.1[SD]) | | 48.5 | Tot: 222.5 | 4.09 | 131 (23.3) | | | 11.41
Liao Y1 | 1999 | NHANES II | Women | 54.7 (10.5 [SD]) | | 29.7 | | | 131.5 (22 [SD]) | 81.4 (11.7 [SD])
Miyasaka Y9 | 2007 | Mayo | Women | | | | | | | | | 51.7 | 81.1
Vaidya D10 | 2007 | JHSS | Women | 46.1 (7.4 [SD]) | W: 77.6 B: 22.4 | | LDL: 155.1 HDL: 56.3 Tot: 232.3 | | 134.5 (13.8 [SD]) | 86.9 (9.4 [SD]) | | | 50.8
Mainous AG11 | 2008 | ARIC | Women | 59.5 | | 17 | HDL: 60.3 Tot: 213 | 0 | 122
D'Agostino RB4 | 2001 | ARIC | White women | 53.9 | | 25 | | 6 | | | 11
D'Agostino RB4 | 2001 | ARIC | Black women | 53.3 | | 25 | | 17 | | | 28
D'Agostino RB4 | 2001 | ARIC | Women | | | | | | | | 15.9
Mainous AG14 | 2007 | ARIC | Women | 53.8 (5.7 [SD]) | W: 71.1 B: 28.9 | 24.8 | | | | | 14.9 | 32
McNeill AM15 | 2005 | ARIC | Women | 54 (5.7 [SD]) | | 24.7 | LDL: 135 | | | | 38.5
D'Agostino RB4 | 2001 | CHS | Women | 69.3 | | 15 | | 10 | | | 33
D'Agostino RB4 | 2001 | SHS | Women | 56.5 | | 30 | | 51 | | | 24
Lee ET16 | 2006 | SHS | Women | 56.6 | | | LDL: 117.7 Tot: 192.3 | 46.7 | 127.3 | 75

Table 3d Data Sources Details (Primary Models) – Europe All

First Author | Year Published | Cohort Abbreviation | Group | Mean Age (yrs) | Race (%) | Female (%) | Smoker (%) | Cholesterol Level (mg/dL) | Diabetes (%) | Mean SBP (mmHg) | Mean DBP (mmHg) | HTN (%) | HTN Med Use (%) | HTN or HTN Med Use (%)
Assmann G26 | 2007 | PROCAM | All | | | 29.4 | | | 6.2
Assmann G27 | 2002 | PROCAM | All | 46.7 (7.5 [SD]) | | 0 | 31.1 | LDL: 148.5 HDL: 45.7 | 6.7 | 131.4 (18.4 [SD])
Bastuji-Garin S37 | 2002 | INSIGHT | All | 64.1 (1.6 [SD]) | | 55.3 | 32 | | 19 | 166 (15 [SD]) | | 100
Becker A41 | 2008 | LudwigU | All | 57.7 (13.3 [SD]) | | 41 | 34.1 | | 17 | | | 52
Bernard S21 | 2005 | Lyon | All | 55.5 [%] | | 35.4 | 23.1 | LDL: 136.5 Tot: 74.1 | 100 | | | 47.6 | 25.8
Cederholm J43 | 2008 | SNDR | All | | | 43.1 | 17.8 | | 100 | 144.5 (18.1 [SD])
Cooper JA31 | 2005 | NPHS-II | All | | W: 100 | 0 | | | 2.1
de Ruijter W42 | 2009 | L85 | All | | | 70.7 | | | 14.2 | 154^*^ (144, 167 [IQR])
Donnan PT39 | 2006 | DARTS | All | 59.5 (12.1 [SD]) | W: 99 O: 1 | 47.4 | 23.5 | Tot: 210.6 | 100 | 144 (21 [SD]) | 82 (11 [SD]) | | 61.9
Dunder K22 | 2004 | ULSAM | All | | | 0 | 54.5 | LDL: 208.65 Tot: 277.29 | 1.5 | 132 (18 [SD]) | 83 (11 [SD])
Erikssen G24 | 2004 | NorGov | All | 49.8 (5.5 [SD]) | | 0 | 43.8 | Tot: 261.3 | 0 | 130.1 (17.9 [SD]) | | | 0
Ferrario M29 | 2005 | CUORE | All | 50.8 (9.2 [SD]) | | 0 | 39 | HDL: 50.2 | 5 | 138.5 (20.5 [SD]) | | | 10
Hippisley-Cox J34 | 2008 | QRESEARCH | All | | W: 95.8 B: 0.8 O: 3.4 | 75.4 | 25.3 | | 2.9 | | | | 6.3
Hippisley-Cox JC40 | 2007 | QRESEARCH (Val) | All | | | 50.3 | 25.5 | Tot: 226.2 | 0 | 133.9 | | | 10.6
Macfarlane PW32 | 2007 | WOSCOPS | All | 55.2 | | 0 | 44 | LDL: 192 HDL: 44 | 1.2 | 135.5 | 84 | 15.7
Marrugat J38 | 2007 | VERIFICA | All | 56.3 | | 57.3 | 24.7 | HDL: 53.7 | 16.4 | 135.1 | 81.3 | 44.8 | 30.9
May MD44 | 2006 | BWHH | All | 68.6 (5.5 [SD]) | | 100 | | Tot: 257.4 | 4.4 | 148 (25 [SD])
Reissigova J25 | 2007 | STULONG | All | 51.2 (3.7 [SD]) | | 0 | | | 0 | | | 54.8
Simmons RK35 | 2008 | EPIC-Norfolk | All | 57.9 | | 56.2 | 11.9 | HDL: 56.7 Tot: 235.9 | 2.8 | 134.5
Stephens JW33 | 2004 | NHS Trust | All | | W: 69 B: 5 O: 26 | 36 | 19.5 | | 100
Strom Moller C23 | 2007 | ULSAM (70) | All | 71 (0.6 [SD]) | | 0 | 20.8 | LDL: 152.1 Tot: 226.2 | | 146.8 (18.5 [SD])
Vergnaud AC36 | 2008 | SU.VI.MAX | All | 52 (4.7 [SD]) | | 0 | | LDL: 152.1 Tot: 241.8 | 2.4 | 129.4 (13.8 [SD]) | 83.5 (8.5 [SD])
Woodward M30 | 2007 | SHHEC | All | 48.8 | | 50.8 | 41 | Tot: 245.7 | 1.4 | 131.9

* Median.

Table 3e Data Sources Details (Primary Models) – Europe Men

First Author | Year Published | Cohort Abbreviation | Mean Age (yrs) | Smoker (%) | Mean Cholesterol Level (mg/dL) | Diabetes (%) | Mean SBP (mmHg) | Mean DBP (mmHg) | HTN (%) | HTN Med Use (%)
Cederholm J43 | 2008 | SNDR | | 18.5 | | 100 | 143.9 (17.4 [SD])
Hippisley-Cox J34 | 2008 | QRESEARCH (Derivation) | 48^*^ (40-58 [IQR]) | | | | | | | 5.6
Hippisley-Cox J34 | 2008 | QRESEARCH | | 27.6
Hippisley-Cox J34 | 2008 | QRESEARCH (Validation) | 47^*^ (40-57 [IQR]) | | | | | | | 5.4
Hippisley-Cox JC40 | 2007 | QRESEARCH Validation) | 47^*^ (40-57 [IQR]) | | Tot: 222.3 | 0 | 135.4 (19.7 [SD]) | | | 8.5
Marrugat J38 | 2007 | VERIFICA | 55.7 (10.6 [SD]) | 43.8 | HDL: 48.5 Tot: 228.8 | 18.8 | 135 (17.8 [SD]) | 81.9 (10.3 [SD]) | 41.6 | 27.1
Simmons RK35 | 2008 | EPIC-Norfolk | 58.3 (9.7 [SD]) | | HDL: 50 Tot: 232 | | 136.8 (17 [SD])
Stephens JW33 | 2004 | NHS Trust | | | | 100
Woodward M30 | 2007 | SHHEC | 48.9 | | Tot: 242.97 | 1.5 | 133.8 (0.2 [SD])

* Median.

Table 3f Data Sources Details (Primary Models) – Europe Women

First Author | Year Published | Cohort Abbreviation | Mean Age (yrs) | Smoker (%) | Mean Cholesterol Level (mg/dL) | Diabetes (%) | Mean SBP (mmHg) | Mean DBP (mmHg) | HTN (%) | HTN Med Use (%)
Woodward M30 | 2007 | SHHEC | 48.8 | | Tot: 249.99 | 1.4 | 130.1 (0.3 [SD])
Woodward M30 | 2007 | SHHEC | 48.8 | | Tot: 249.99 | 1.3 | 130.1 (0.3 [SD])
Stephens JW33 | 2004 | NHS Trust | | | | 100
Hippisley-Cox J34 | 2008 | QRESEARCH | | 23.1
Hippisley-Cox J34 | 2008 | QRESEARCH (Validation) | 49^*^ (41-59 [IQR]) | | | | | | | 6.9
Hippisley-Cox J34 | 2008 | QRESEARCH (Derivation) | 49^*^ (41-60 [IQR]) | | | | | | | 7.1
Simmons RK35 | 2008 | EPIC-Norfolk | 57.6 (9.6 [SD]) | | HDL: 62 Tot: 239 | | 132.7 (18.7 [SD])
Marrugat J38 | 2007 | VERIFICA | 56.8 (10.4 [SD]) | 10.6 | HDL: 57.6 Tot: 234.1 | 14.6 | 135.2 (18.8 [SD]) | 80.9 (10.8 [SD]) | 47.2 | 33.7
Hippisley-Cox JC40 | 2007 | QRESEARCH Validation) | 49^*^ (41-59 [IQR]) | | Tot: 230.1 | 0 | 132.4 (21.6 [SD]) | | | 12.6
Cederholm J43 | 2008 | SNDR | | 16.8 | | 100 | 145.2 (19.0 [SD])

* Median.

Table 3g Data Sources Details (Primary Models) – Asia All

First Author | Year Published | Cohort Abbreviation | Group | Mean Age (yrs) | Race (%) | Female (%) | Smoker (%) | Mean Cholesterol Level (mg/dL) | Diabetes (%) | Mean SBP (mmHg) | Mean DBP (mmHg) | HTN (%) | HTN Med Use (%)
Barzi F45 | 2007 | APCSC China | All | 46.6 | O: 100 | 41.4 | 42.8 | Tot: 175.5 | | 120.6
Jee SH46 | 2008 | NHIC | All | 46.6 | O: 100 | 36.5 | 39 | Tot: 192.5 | 4.5 | 123.4 | | 33.3
Liu J47 | 2004 | MUCA | All | | O: 100 | 46.7 | 33.3 | | 5.5 | | | 25.7
Wu Y48 | 2006 | MUCA II | All | 46 (6 [SD]) | 50.6 | 45 | | | | 119 (19 [SD]) | 77 (11 [SD])
Yang X49 | 2008 | HKD Registry | All | 57^*^ (21 [IQR]) | O: 100 | 54.6 | 20.6 | | 100 | 134^*^ (27 [IQR]) | 76^*^ (14 [IQR]) | | 33.7
Yang X50 | 2007 | HKD Registry | Stroke | 68^*^ (12 [IQR]) | | | | | | 144^*^ (30 [IQR]) | 77^*^ (14 [IQR]) | | 34.2
Yang X50 | 2007 | HKD Registry | Non-stroke | 56^*^ (20 [IQR]) | | | | | | 133^*^ (27 [IQR]) | 76^*^ (14 [IQR]) | | 46
Yang X50 | 2007 | HKD Registry | All | | O: 100 | 54.5 | 20.3 | | 100 | | | | 45.4

* Median.

Table 3h Data Sources Details (Primary Models) – Asia Men

First Author | Year Published | Cohort Abbreviation | Group | Mean Age (yrs) | Race (%) | Smoker (%) | Mean Cholesterol Level (mg/dL) | Diabetes (%) | Mean SBP (mmHg) | HTN (%)
Barzi F45 | 2007 | APCSC China | Men | 47 (8 [SD]) | O:100 | 68.4 | Tot: 175.5 | | 121 (18 [SD])
Jee SH46 | 2008 | NHIC | Men | 45 (11.0 [SD]) | O:100 | 59.1 | Tot: 191.3 | 4.8 | 124.5 (16.0 [SD]) | 35.7
Liu J47 | 2004 | MUCA | Men | | O:100 | 59 | | 6.9 | | 29

Table 3i Data Sources Details (Primary Models) – Asia Women

First Author | Year Published | Cohort Abbreviation | Group | Mean Age (yrs) | Race (%) | Smoker (%) | Mean Cholesterol Level (mg/dL) | Diabetes (%) | Mean SBP (mmHg) | HTN (%)
Barzi F45 | 2007 | APCSC China | Women | 46 (8 [SD]) | O:100 | 6.5 | Tot: 171.6 | | 120 (20 [SD])
Jee SH46 | 2008 | NHIC | Women | 49.4 (12.1 [SD]) | O:100 | 4.1 | Tot: 194.5 | 4.1 | 121.5 (19.1 [SD]) | 29.2
Liu J47 | 2004 | MUCA | Women | | O:100 | 4 | | 5 | | 22