# Summary Table 2

Table 2a Data Sources Summary (Primary Models) – Americas

Enroll Start Date | Enroll End Date | First Author | Year Published | Country | Cohort | Cohort Abbreviation | Enrollment Base | Enrollment Final | Follow- Up (yrs)
| | Liao Y1 | 1999 | U.S. | NHANES I and II (pooled) | NHANES I and II (pooled) | | 18542
01/01/1948 | 12/31/1974 | Wilson PWF2 | 1998 | U.S. | Framingham Cohort (11th exam) or Framingham Offspring (1st exam) | FRS, FRS-O | 5345 | | 12
01/01/1954 | 12/31/1958 | Liao Y3 | 1999 | U.S. | Framingham Heart Study (4th exam) | FRS | 4169 | | 24
01/01/1965 | 12/31/1968 | D'Agostino RB4 | 2001 | Puerto Rico | Puerto Rico Heart Health Program | PRHHP | | 8713
01/01/1967 | 01/31/1973 | Berry JD5 | 2007 | U.S. | Chicago Young Adults | CHA | 10375 | | 32^*^
01/01/1968 | 12/31/1987 | D'Agostino RB6 | 2008 | U.S. | Framingham Cohort (11th exam) (68-71) & Offspring (1st exam) (71-75) & Offspring (3rd exam) (84-87) | FRS, FRS-O | 8491
01/01/1971 | | Wilson PWF7 | 2008 | U.S. | Framingham Offspring Study | FRS-O | 5124 | 4780 | ~24
01/01/1971 | 12/31/1974 | D'Agostino RB4 | 2001 | U.S. | Framingham Study (11th exam) or Framingham Offspring Study (1st exam) | FRS, FRS-O | | 5251 | 12^**^
01/01/1971 | 12/31/1975 | Liao Y1 | 1999 | U.S. | First National Health and Nutrition Examination Survey | NHANES I | 6611 | | 20
01/01/1971 | 12/31/1992 | Gaizano TA8 | 2008 | U.S. | First National Health and Nutrition Examination Survey Epidemiologic Follow-Up Study | NHANES-I EFS | 14407 | 6186 | 21
01/01/1976 | 12/31/1980 | Liao Y1 | 1999 | U.S. | Second National Health and Nutrition Examination Survey | NHANES II | 5705 | | 15
01/01/1980 | 12/31/1982 | D'Agostino RB4 | 2001 | U.S. | Honolulu Heart Program | HHP | | 2755
01/01/1980 | 12/31/2000 | Miyasaka Y9 | 2007 | U.S. | Adult Residents of Olmsted County, MN | Mayo | 2768 | | 6^*^ [5.2]
01/01/1983 | 12/31/1996 | Vaidya D10 | 2007 | U.S. | John Hopkins Sibling Study | JHSS | | 784
01/01/1986 | 12/31/1989 | Mainous AG11 | 2008 | U.S. | Atherosclerosis Risk in Communities Study | ARIC | 9307
01/01/1987 | 12/31/1989 | Chambless LE12 | 2004 | U.S. | Atherosclerosis Risk in Communities Study | ARIC | 13161 | | 12.3^†^
01/01/1987 | 12/31/1989 | D'Agostino RB4 | 2001 | U.S. | Atherosclerosis Risk in Communities Study | ARIC | 14178
01/01/1987 | 12/31/1989 | Folsom A13 | 2003 | U.S. | Atherosclerosis Risk in Communities Study | ARIC | | 14054 | 10.2^†^
01/01/1987 | 12/31/1989 | Mainous AG14 | 2007 | U.S. | Atherosclerosis Risk In Communities Study | ARIC | 14343
01/01/1987 | 12/31/1989 | McNeill AM15 | 2005 | U.S. | Atherosclerosis Risk in Communities Study | ARIC | | 12089 | 11^*^
01/01/1989 | 12/31/1990 | D'Agostino RB4 | 2001 | U.S. | Cardiovascular Health Study | CHS | | 2557
01/01/1989 | 12/31/1991 | D'Agostino RB4 | 2001 | U.S. | Strong Heart Study (OK and Aberdeen area of ND and SD) | SHS | | 3782
01/01/1989 | 12/01/2001 | Lee ET16 | 2006 | U.S. | Strong Heart Study | SHS | 4372
01/01/1990 | 12/31/1992 | Greenland P17 | 2004 | U.S. | South Bay Heart Watch | SBHW | | 1029 | 7^†^
12/01/1990 | 12/31/1992 | Detrano RC18 | 1999 | U.S. | South Bay Heart Watch | SBHW | 1196 | 1194 | 3.42
09/01/1992 | | Cook NR19 | 2006 | U.S. | Women's Health Study | WHS | | 15048 | 10^*^
09/01/1992 | | Ridker PM20 | 2007 | U.S. | Women's Health Study (Validation Cohort) | WHS (Val) | | 8158 | 10.2^†^

* Mean.

** Other.

† Median.

Table 2b Data Sources Summary (Primary Models) – Europe

Enroll Start Date | Enroll End Date | First Author | Year Published | Country | Cohort | Cohort Abbreviation | Enrollment Base | Enrollment Final | Follow-Up (yrs)
| | Bernard S21 | 2005 | France | Lyon, France | Lyon | 229 | | 5^**^
01/01/1970 | 12/31/1973 | Dunder K22 | 2004 | Sweden | Uppsala Longitudinal Study of Adult Men | ULSAM | 1108 | | 28.7
01/01/1970 | 12/31/1973 | Strom Moller C23 | 2007 | Sweden | Uppsala Longitudinal Study of Adult Men (baseline age 70 cohort) | ULSAM (70) | | 1221 | 23
08/28/1972 | 03/30/1975 | Erikssen G24 | 2004 | Norway | Healthy Norwegian men aged 40-60 years recruited from 5 government agencies | NorGov | | 2014 | 26^**^
01/01/1975 | 12/31/1979 | Reissigova J25 | 2007 | Czech Republic | Study of Atherosclerotic Risk Factors | STULONG | 646
01/01/1978 | 12/31/1995 | Assmann G26 | 2007 | Germany | PROCAM cohort; employees of 52 companies and local government authorities in Germany, aged 20-78 years | PROCAM | | 7295 | 12^*^ [6]
01/01/1979 | 12/31/1985 | Assmann G27 | 2002 | Germany | PROCAM cohort; employees with followup every 2 years | PROCAM | 5389 | 5159 | 10^**^
01/01/1979 | 12/31/1999 | Assmann G28 | 2008 | Germany | Cohort of men and women employed in Germany | PROCAM | | 7134 | 10^**^
01/01/1983 | 12/31/1996 | Ferrario M29 | 2005 | Italy | CUORE | CUORE | 6865 | | 9.1^†^
01/01/1984 | 12/31/1995 | Woodward M30 | 2007 | Scotland | Scottish Hearth Health Extended Cohort | SHHEC | 13297
01/01/1989 | | Cooper JA31 | 2005 | UK | Second Northwick Park Heart Study | NPHS-II | | 2732 | 10.8^†^
01/01/1989 | 12/31/1991 | Macfarlane PW32 | 2007 | Scotland | West of Scotland Coronary Prevention Study | WOSCOPS | 6595 | | 4.9^*^
01/01/1990 | 12/31/1991 | Stephens JW33 | 2004 | UK | Diabetes clinic at University College London Hospitals NHS Trust | NHS Trust | 798
01/01/1993 | 03/31/2008 | Hippisley-Cox J34 | 2008 | UK | Members of the QRESEARCH database | QRESEARCH | 2285815 | | 15
03/01/1993 | 02/28/1998 | Simmons RK35 | 2008 | UK | European Prospective Investigation of Cancer–Norfolk | EPIC-Norfolk | 10295 | | 8.5^*^
01/01/1994 | 12/31/1995 | Vergnaud AC36 | 2008 | France | Participants in Supplementation en Vitamines et Mineraux Antioxydants randomized primary prevention trial followed annually since 1994/5 | SU.VI.MAX | | 3440 | 10^**^
01/01/1994 | 12/31/1996 | Bastuji-Garin S37 | 2002 | Western Europe and Israel | INSIGHT trial cohort of middle-aged patients with hypertension | INSIGHT | 4407 | 4147 | 3.7^†^
01/01/1995 | 12/31/1998 | Marrugat J38 | 2007 | Spain | Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidents cohort | VERIFICA | 5732
01/01/1995 | 06/30/2004 | Donnan PT39 | 2006 | UK | Subjects with type 2 diabetes registered with a Tayside general practitioner | DARTS | | 4569 | 4.1^†^ [9.5]
01/01/1995 | 04/01/2007 | Hippisley-Cox JC40 | 2007 | UK | QRESEARCH database, constructed from 160 general practices in UK; validation cohort | QRESEARCH (Val) | 614553 | | 6.5^†^
01/01/1997 | 12/31/1999 | Becker A41 | 2008 | Germany | Consecutive patients referred by primary care provider for preventive cardiological exam | LudwigU | 1726 | | 3.36^*^ [0.61]
09/01/1997 | 09/30/1999 | de Ruijter W42 | 2009 | Netherlands | Leiden 85-plus study | L85 | 302 | | 5
01/01/1998 | 12/31/2003 | Cederholm. J43 | 2008 | Sweden | Swedish National Diabetes Register | SNDR | 11646 | | 5.64^*^
01/01/1999 | 12/31/2001 | May MD44 | 2006 | UK | British Women's Heart and Health Cohort | BWHH | 3582 | | 4.7^*^

* Mean.

** Other.

† Median.

Table 2c Data Sources Summary (Primary Models) – Asia

Enroll Start Date | Enroll End Date | First Author | Year Published | Country | Cohort | Cohort Abbreviation | Enrollment Base | Enrollment Final | Follow-Up (yrs)
01/01/1974 | 12/31/1993 | Barzi F45 | 2007 | China | Asia Pacific Cohort Studies Collaboration; total Chinese cohort | APCSC China | 25682 | | 8.3^*^
01/01/1992 | 12/31/1995 | Jee SH46 | 2008 | Korea | Koreans insured by National Health Insurance Corporation (NHIC) | NHIC | 1223740 | 1205268 | 13^**^
01/01/1992 | 12/31/1999 | Liu J47 | 2004 | China | Chinese Multi-Provincial Cohort study; aged 35-64 years from 16 centers in 11 provinces (1992-1993) and Beijing (1996-1999) | MUCA | 30121
01/01/1993 | 12/31/1994 | Wu Y48 | 2006 | China | MUCA II | MUCA II | 9903 | | 11
01/01/1995 | | Yang X49 | 2008 | China | Hong Kong Diabetes Registry | HKD Registry | 7067 | | 5.4^*^ [4.94]
01/01/1995 | 07/30/2005 | Yang X50 | 2007 | China | Hong Kong Diabetes Registry | HKD Registry | 7209 | 3541 | 5.37^*^ [4.9]

* Median.

** Other.