# Summary Table 1: Online Tools

Model | Model Description | URL Accessed | Date of URL Access
Framingham | Based upon ATP III and Framingham Heart Study | http://hp2010.nhlbihin.net/atpiii/calculator.asp?usertype=prof | 6/30/2009
Framingham | Based upon Framingham Heart Study and ATP III | https://www.americanheart.org/gglRisk/locale/en_US/index.html?gtype=health | 6/30/2009
Framingham | Based upon Framingham Heart Study | http://www.cardiacriskcalculator.org/ | 6/30/2009
Framingham | Based upon Framingham Heart Study (1998) | http://www.statcoder.com/cardiac.htm | 6/30/2009
Framingham | Based upon Framingham Heart Study (1998) and ATP III | https://www.heartdecision.org/chdrisk/v_hd/main?p=__home__home&urlstring= | 6/30/2009
Framingham | Based upon Framingham Heart Study | http://calculators.epnet.com/?docid=healthcalculators/chd/precalcdoc&token=8ce583c0-2d91-46f6-af0a-aa4c845a0528&DeliveryContext=coe&CollectionIID=347&frame=parent | 7/1/2009
Framingham | Based upon Framingham Heart Study and ATP III | http://www.americanheart.org/presenter.jhtml?identifier=3003499 | 7/1/2009
Framingham | Based upon Framingham Heart Study (2001) and ATP III | http://www.chd-taskforce.com/framingham.php?iSprache=1&iversion=1&SiVersion=0 | 7/1/2009
Framingham | Based upon Framingham Heart Study | https://www.heartagecalculator.com/HeartHealth/HeartAgeCalculator.aspx?hostID=1503 | 7/1/2009
Framingham | Based upon Framingham Heart Study, JBS Calculator | http://www.patient.co.uk/showdoc/40000133/ | 7/1/2009
Framingham | Based upon Framingham Heart Study | http://cvrisk.mvm.ed.ac.uk/calculator/calc.asp | 7/1/2009
Framingham | Based upon Framingham Heart Study (ETHRISK) | http://www.epi.bris.ac.uk/CVDethrisk/CHD_CVD_form.html | 7/1/2009
Framingham | Based upon Framingham Heart Study | http://www.cardiosmart.org/CardioSmart/Default.aspx?id=298, https://www.itsmyhealthrecord.com/ACCriskform2008.lasso | 7/2/2009
Framingham | Based upon Framingham Heart Study | http://my.clevelandclinic.org/ccforms/Heart_Center_Risk_Tool.aspx | 7/2/2009
Framingham | Calculators based upon Framingham Heart Study | http://www.framinghamheartstudy.org/risk/index.html | 6/30/2009
ATP III | Based upon Framingham Heart Study and ATP III | https://www.americanheart.org/gglRisk/locale/en_US/index.html?gtype=health | 6/30/2009
ATP III | Based upon ATP III and Framingham Heart Study | http://hp2010.nhlbihin.net/atpiii/calculator.asp?usertype=prof | 6/30/2009
ATP III | Based upon ATP III | http://www.mayoclinic.com/health/heart-disease-risk/HB00047 | 6/30/2009
ATP III | Based upon Framingham Heart Study (1998) and ATP III | https://www.heartdecision.org/chdrisk/v_hd/main?p=__home__home&urlstring= | 6/30/2009
ATP III | Based upon Framingham Heart Study and ATP III | http://www.americanheart.org/presenter.jhtml?identifier=3003499 | 7/1/2009
ATP III | Based upon Framingham Heart Study (2001) and ATP III | http://www.chd-taskforce.com/framingham.php?iSprache=1&iversion=1&SiVersion=0 | 7/1/2009
Other | Pocock SJ (2001) multivariate Cox model | http://www.riskscore.org.uk/ | 6/30/2009
Other | N/A | http://doctorwidget.com/cvd/cvd_mathv2.htm | 6/30/2009
Other | National Vascular Disease Prevention Alliance (NVDPA) for Australia (did not give a mathematical model) | http://www.cvdcheck.org.au/playerProductInstall2.html | 7/2/2009
Other | FDS model for 5-year risk of major CVD (Australia) | http://www.medicine.uwa.edu.au/download.cfm?DownloadFile=75841E31-96BA-5DAE-B9B5B5B8E85E85C3 | 7/2/2009
Other | N/A | http://ww2.heartandstroke.ca/hs_Risk.asp?media=hsf_hmpg | 7/2/2009
Other | N/A | http://www.goredforwomen.org/index.aspx | 7/2/2009
Other | N/A | https://www.beverlyhospital.org/services/online-tools/health-risk-assessments/heart-health | 7/2/2009
Other | HeartScore (no other model listed) | https://escol.escardio.org/heartscore3/calc.aspx?model=europehigh | 7/2/2009
Other | HeartScore | https://escol.escardio.org/heartscore3/calc.aspx?model=europelow | 7/2/2009
Other | JBS/BNF | http://cvrisk.mvm.ed.ac.uk/calculator/calc.asp | 7/1/2009
Other | BVN RISK does not purport to forecast a vascular event; instead, it offers a tangible prediction that a vascular study may uncover significant evidence of vascular disease | http://www.csun.edu/studenthealthcenter/online/BVN_calculator/BVN_calculator.php | 7/2/2009
Other | Based upon 2002 NHANES and ATP III | http://www.csun.edu/studenthealthcenter/online/BVN_calculator/BVN_calculator.php | 7/2/2009
Other | QRISK2 Men | http://www.qrisk.org | 6/30/2009
Other | QRISK2 Women | http://www.qrisk.org | 6/30/2009
Other | ASSIGN Men | http://assign-score.com/estimate-the-risk/ | 6/30/2009
Other | ASSIGN Women | http://assign-score.com/estimate-the-risk/ | 6/30/2009
Other | SHS Men | http://strongheart.ouhsc.edu/CHDcalculator/calculator.html | 6/30/2009
Other | SHS Women | http://strongheart.ouhsc.edu/CHDcalculator/calculator.html | 6/30/2009
Other | REGICOR model | http://www.regicor.org/conttemp?idioma=angles | 6/30/2009
Other | CUORE | http://www.cuore.iss.it/sopra/calc-rischio_en.asp | 7/1/2009
Other | UKPDS | http://www.dtu.ox.ac.uk/index.php?maindoc=/riskengine/ | 7/1/2009
Other | PROCAM | http://www.scopri.ch/riskalgorithms.htm | 7/1/2009
Other | ASSIGN | http://cvrisk.mvm.ed.ac.uk/calculator/calc.asp | 7/1/2009