# Inclusion/Exclusion Forms

Abstract Review Form

Full Text Review Form