# Literature Search Terms and Results

SEARCH STRATEGY
Cardiovascular Diseases
1 | cardiovascular disease*[tiab] | 53,927
2 | cardiovascular diseases[majr:noexp] | 40,508
3 | myocardial infarction[majr] | 87,024
4 | coronary disease[majr] | 111,322
5 | stroke[majr] | 34,282
6 | brain ischemia[majr:noexp] | 19,070
7 | cerebrovascular accident[tiab] | 2,344
8 | death, sudden, cardiac[majr] | 3,973
9 | heart diseases[majr:noexp] | 31,459
10 | cardiovascular mortality[tiab] | 4,367
11 | coronary[tiab] | 224,553
12 | artery[tiab] | 283,473
13 | disease[tiab] | 1,398,642
14 | #11 AND (#12 OR #13) | 151,293
15 | stroke[tiab] | 88,070
16 | brain[tiab] | 480,737
17 | cerebrovascular[tiab] | 27,374
18 | cerebral[tiab] | 210,834
19 | brainstem[tiab] | 25,684
20 | #15 AND (#16 OR #17 OR #18 OR #19) | 26,438
21 | intracranial hemorrhages[majr] | 29,154
22 | intracranial hemorrhage, traumatic[majr] | 5,957
23 | #21 NOT #22 | 23,197
24 | #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #14 OR #20 OR #23 | 449,543
Risk Assessment
25 | risk assessment[mh] | 93,552
26 | Risk Assess*[tiab] | 18,610
27 | Risk Function*[tiab] | 314
28 | Risk Equation*[tiab] | 164
29 | Risk Calc*[tiab] | 506
30 | Risk Scor*[tiab] | 2,957
31 | Risk Predict*[tiab] | 1,641
32 | Risk Factor Calc*[tiab] | 8
33 | Risk Chart*[tiab] | 71
34 | Risk Engine*[tiab] | 40
35 | Risk Appraisal*[tiab] | 363
36 | Prediction Model*[tiab] | 2,107
37 | Risk algorithm[tiab] | 43
38 | Scoring* Method*[tiab] | 13,615
39 | Scoring Scheme*[tiab] | 335
40 | #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 | 122,344
Modeling Measurements
41 | roc curve[mh] | 13,045
42 | Roc curve[tiab] | 4,402
43 | Area Under Curve[mh] | 14,816
44 | receiver WITH operating WITH curve[tiab] | 7,349
45 | c-statistic*[tiab] | 510
46 | C index*[tiab] | 230
47 | C indices*[tiab] | 23
48 | hosmer WITH lemeshow[tiab] | 383
49 | validation studies[pt] | 35,385
50 | hazard ratio[tiab] | 12,036
51 | forecasting[mh] | 56,935
52 | models, statistical[mh] | 141,871
53 | observ* WITH predict*[tiab] | 90,609
54 | Predictive Value of Tests[mh] | 84,827
55 | concordance[tiab] | 15,712
56 | #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51 OR #52 OR #53 OR #54 OR #55 | 425,065
Coronary Artery Disease Risk Models
57 | assign score*[tiab] | 22
58 | brhs[tiab] | 13
59 | British regional heart[tiab] | 91
60 | British national heart[tiab] | 12
61 | busselton[tiab] | 160
62 | decode study[tiab] | 18
63 | Dundee risk score*[tiab] | 4
64 | erica risk[tiab] | 14
65 | findris*[tiab] | 5
66 | framingham equation*[tiab] | 117
67 | framingham estim*[tiab] | 5
68 | framingham heart study algorithm[tiab] | 2
69 | Framingham algorithm[tiab] | 24
70 | Framingham guideline*[tiab] | 232
71 | Framingham risk[tiab] | 572
72 | Framingham score*[tiab] | 102
73 | Framingham function*[tiab] | 28
74 | Framingham model*[tiab] | 44
75 | Glostrup[tiab] | 260
76 | New Zealand chart*[tiab] | 198
77 | precard[tiab] | 4
78 | PROCAM[tiab] | 131
79 | Reynolds risk score*[tiab] | 11
80 | score project[tiab] | 21
81 | Sheffield table*[tiab] | 34
82 | shaper score*[tiab] | 13
83 | Systematic Coronary Risk Evaluation[tiab] | 40
84 | #57 OR #58 OR #59 OR #60 OR #61 OR #62 OR #63 OR #64 OR #65 OR #66 OR #67 OR #68 OR #69 OR #70 OR #71 OR #72 OR #73 OR #74 OR #75 OR #76 OR #77 OR #78 OR #79 OR #80 OR #81 OR #82 OR #83 | 1,863
Summation
85 | #40 OR #84 | 123,397
86 | #24 AND #56 AND #85 AND English[la] AND humans[mh] AND 1999:2008[dp] | 3,317
87 | #88 AND letter[pt] | 51
88 | #88 AND comment[pt] | 131
89 | #88 AND editorial[pt] | 71
90 | #87 OR #88 OR #89 | 157
91 | #86 NOT #90 | 3,160