# Appendixes

Appendix A Literature Search Terms and Results

Appendix B Inclusion/Exclusion Forms

Appendix C Sample Data Extraction Form

Appendix D Summary Table 1: Online Tools

Appendix E Summary Table 2

Appendix F Summary Table 3

Appendix G Summary Table 4

Appendix H Summary Table 5

Appendix I Summary Table 6

Appendix J Summary Table 7

Appendix K Summary Table 8

Appendix L Summary Table 9

Appendix M Summary Table 10

Appendix N References for Summary Tables

Appendix O List of Excluded Studies