# Acronyms/Abbreviations

A/C: Albumin/creatinine ratio
Abbrev.: Abbreviation
AFT: Accelerated failure time
AHRQ: Agency for Healthcare Research and Quality
AIC: Akaike information criterion
APCSC: Asia Pacific Cohort Studies Collaboration
Apo A1: Apolipoprotein A1
Apo B: Apolipoprotein B
ARIC: Atherosclerosis Risk in Communities
ASSIGN: Assessing Cardiovascular Risk Using SIGN Guidelines
ATP-III: Adult Treatment Panel III
AUC: Area under the curve
Avg.: Average
BIC: Bayesian information criterion
BMI: Body mass index
BP: Blood pressure
BRHS: British Regional Heart Study
BWHH: British Women's Heart and Health cohort
Ca: Calcium
CABG: Coronary artery bypass graft
CACS: Coronary artery calcium score
CAD: Coronary artery disease
Cardiff DM: Cardiff Diabetes Database
CeVD: Cerebrovascular disease
CHA: Chicago Heart Association
Chb: Chambless
CHD: Coronary heart disease
CHF: Congestive heart failure
CHS: Cardiovascular Health Study
CI: Confidence interval
CMCS: Chinese Multi-Provincial Cohort Study
CP-Norway: Cardiovascular Program–Norway
CRF-X: Classical risk factors
CRM: CardioRisk Manager
CRP: C-reactive protein
CVA: Cardiovascular accident
CVD: Cardiovascular disease
CYA: Chicago Young Adults
D'Ag: D'Agostino
DARTS: Diabetes Audit and Research in Tayside, Scotland
DBP: Diastolic blood pressure
DM: Diabetes mellitus
DPCGI: Diverse Populations Collaborative Group Investigation
Dx: Diagnosis
ECG: Echocardiography
eGFR: Epidermal growth factor receptor
EKG: Electrocardiography
EPC: Evidence-based Practice Center
EPIC: European Prospective Investigation of Cancer
ESC: European Society of Cardiology
F/U: Followup
FamHx: Family history
FrRenal: French Renal cohort
FRS: Framingham Study
FRS-0: Framingham Offspring Study
HDFP: Hypertension Detection and Follow-Up Program
HDL: High-density lipoprotein
HgbA_1c_: Hemoglobin A_1c_
HHP: Honolulu Heart Program
HKD: Hong Kong Diabetes Registry cohort
HLGOF: Hosmer-Lemeshow Goodness-of-Fit
hsCRP: High-sensitivity C-reactive protein
HTN: Hypertension
INSIGHT: Intervention as a Goal in Hypertension Treatment
IQR: Interquartile range
JBSRC: Joint British Societies Risk Prediction Chart
JHSS: Johns Hopkins Sibling Study
L85: Leiden-85 cohort
LDL: Low-density lipoprotein
LpA: Lipoprotein(a)
LRCPS: Lipid Research Clinics Prevalence Study
LudwigU: Ludwig-Maximilians University
LVH: Left ventricular hypertrophy
MI: Myocardial infarction
MONICA: MONICA Augsburg cohort
MP-CVDRF: Monitoring Project on Cardiovascular Disease Risk Factor
MRFIT: Multiple Risk Factor Intervention Trial
MUCA-I: Chinese Multi-Provincial Study I
MUCA-II: Chinese Multi-Provincial Study II
N, n: number
N/A: Not available
NAS: Normative Aging Study
NCS: Norwegian Counties Study
NDR: National Diabetes Registry
NHANES I: National Health and Nutrition Examination Survey I
NHANES I-EFS: National Health and Nutrition Examination Survey I Epidemiological Follow-up Study
NHANES II: National Health and Nutrition Examination Survey II
NHIC: National Health Insurance Corporation
NHLBI: National Heart Lung and Blood Institute
NHP: Newcastle Heart Project
NHS: National Health Service
NICE: Nationwide Instruction for Cardiovascular Education
NIH: National Institutes of Health
NorGov: Norwegian Government Study
NPHS-I: First Northwick Park Heart Study
NPHS-II: Second Northwick Park Heart Study
NSW: New South Wales
NTRF: Non-traditional risk factors
NZwork: New Zealand workers cohort
O/E: Observed-to-expected ratio
P, p: p value
PCI: Percutaneous coronary intervention
PDS: Poole Diabetes Study
PHS: Physicians Health Study
Post-AF: Post-atrial fibrillation
PREDICT: Prospective Evaluation of Diabetic Ischaemic Disease by Computed Tomography
PRHHP: Puerto Rico Heart Health Program
PRHS: Puerto Rico Heart Study
PRIME: Prospective Epidemiological Study of Myocardial Infarction
PROCAM: Prospective Cardiovascular Münster cohort
Pub.: Publication
PVD: Peripheral vascular disease
RCC: Rotterdam Coronary Calcification Study
REGICOR: Registre Gironi del Cor
RRS: Reynolds Risk Score
SAHS: San Antonio Heart Study
SBHW: South Bay Heart Watch
SBP: Systolic blood pressure
SCORE: Systematic Coronary Risk Evaluation
SFHS: St. Francis Heart Study
SHHEC: Scottish Heart Health Extended Cohort
SHS: Strong Heart Study
SMR: Standard mortality ratio
SNDR: Swedish National Diabetes Registry
Spec.: Specific
STULONG: Study of Atherosclerotic Risk Factors
SU.VI.MAX: Supplementation en Vitamines et Mineraux Antioxydants
TC: Total cholesterol
TC-HDL: Total cholesterol and high-density lipoprotein
TEP: Technical Expert Panel
THIN: The Health Improvement Network
TIA: Transient ischemic attack
UK: United Kingdom
UKPDS: United Kingdom Prospective Diabetes Study
ULSAM: Uppsala Longitudinal Study of Adult Men
US: United States
USA-PRC: United States of America–People's Republic of China Collaborative Study of Cardiovascular and Cardiopulmonary Epidemiology Research Group
USPSTF: U.S. Preventive Services Task Force
val: Value
vars.: Variables
VERIFICA: Validez de la Ecuación de Riesgo Individual de Framingham de Incidentes Coronarios Adaptada (Validity of the Adapted Framingham Individual Risk Equation for Coronary Incidents Cohort)
VHM&PP: Vorarlberg Health Monitoring and Promotion Program
w/o: without
WESDR: Wisconsin Epidemiologic Study of Diabetic Retinopathy
WGHS: Women's Genome Health Study
WHI: Women's Health Initiative
WHS: Women's Health Study
wk(s): weeks
WOSCOPS: West of Scotland Coronary Prevention Study
X: times
yr(s): Years