# References

1 Gerstorf D, Ram N, Rocke C, et al. Decline in life satisfaction in old age: longitudinal evidence for links to distance-to-death. Psychol Aging. 2008;23(1):154-68. [pmid: 18361663].
2 Berkman LF. The changing and heterogeneous nature of aging and longevity: a social and biomedical perspective. Annu Rev Gerontol Geriatr. 1988;8:37-68. [pmid: 3148317].
3 Freidson E. Professional Dominance: The Social Structure of Medical Care. 1st ed. New York. Atherton Press. 1970.
4 Whitney SN, Holmes-Rovner M, Brody H, et al. Beyond shared decision making: an expanded typology of medical decisions. Med Decis Making. 2008;28(5):699-705. [pmid: 18556639].
5 Cornford CS, Morgan M. Elderly people’s beliefs about influenza vaccination. Br J Gen Pract. 1999;49(441):281-4. [pmid: 10736905].
6 Evans MR, Prout H, Prior L, et al. A qualitative study of lay beliefs about influenza immunisation in older people. Br J Gen Pract. 2007;57:352-8. [pmid: 17504584].
7 Santibanez TA, Nowalk MP, Zimmerman RK, et al. Knowledge and beliefs about influenza, pneumococcal disease, and immunizations among older people. J Am Geriatr Soc. 2002;50(10):1711-6. [pmid: 12366627].
8 Chapple A, Ziebland S, Hewitson P, et al. What affects the uptake of screening for bowel cancer using a faecal occult blood test (FOBT): a qualitative study. Soc Sci Med. 2008;66(12):2425-35. [pmid: 18358581].
9 Beeker C, Kraft JM, Southwell BG, et al. Colorectal cancer screening in older men and women: qualitative research findings and implications for intervention. J Community Health. 2000;25(3):263-78. [pmid: 10868818].
10 Lewis CL, Kistler CE, Amick HR, et al. Older adults’ attitudes about continuing cancer screening later in life: a pilot study interviewing residents of two continuing care communities. BMC Geriatr. 2006;6:10. [pmid: 16887040].
11 Black ME, Stein KF, Loveland-Cherry CJ. Older women and mammography screening behavior: do possible selves contribute?. Health Educ Behav. 2001;28(2):200-16. [pmid: 11265829].
12 Borrayo EA, Jenkins SR. Feeling healthy: so why should Mexican-descent women screen for breast cancer?. Qual Health Res. 2001;11(6):812-23. [pmid: 11710079].
13 Feeley TH, Cooper J, Foels T, et al. Efficacy expectations for colorectal cancer screening in primary care: identifying barriers and facilitators for patients and clinicians. Health Commun. 2009;24(4):304-15. [pmid: 19499424].
14 Katapodi MC, Dodd MJ, Lee KA, et al. Underestimation of breast cancer risk: influence on screening behavior. Oncol Nurs Forum. 2009;36(3):306-14. [pmid: 19403452].
15 Hay J, Coups E, Ford J. Predictors of perceived risk for colon cancer in a national probability sample in the United States. J Health Commun. 2006;11(Suppl 1):71-92. [pmid: 16641075].
16 Han PKJ, Moser RP, Klein WM. Perceived ambiguity about cancer prevention recommendations: relationship to perceptions of cancer preventability, risk, and worry. J Health Commun. 2006;11(Suppl 1):51-69. [pmid: 16641074].
17 von Wagner C, Halligan S, Atkin WS, et al. Choosing between CT colonography and colonoscopy in the diagnostic context: a qualitative study of influences on patient preferences. Health Expect. 2009;12(1):18-26. [pmid: 19250149].
18 Glasgow RE, Whitlock EP, Valanis BG, et al. Barriers to mammography and Pap smear screening among women who recently had neither, one or both types of screening. Ann Behav Med. 2000;22(3):223-8. [pmid: 11126467].
19 Boustani M, Perkins AJ, Monahan P, et al. Measuring primary care patients’ attitudes about dementia screening. Int J Geriatr Psychiatry. 2008;23(8):812-20. [pmid: 18232061].
20 Courneya KS. Understanding readiness for regular physical activity in older individuals: an application of the theory of planned behavior. Health Psychol. 1995;14(1):80-7. [pmid: 7737078].
21 Estabrooks P, Carron AV. The influence of the group with elderly exercisers. Small Group Res. 1999;30(4):438-52.
22 Gretebeck KA, Black DR, Blue CL, et al. Physical activity and function in older adults: theory of planned behavior. Am J Health Behav. 2007;31(2):203-14. [pmid: 17269910].
23 Lucidi F, Grano C, Barbaranelli C, et al. Social-cognitive determinants of physical activity attendance in older adults. J Aging Phys Act. 2006;14(3):344-59. [pmid: 17090810].
24 LaPelle N, Costanza ME, Luckmann R, et al. Staging mammography nonadherent women: a qualitative study. J Cancer Educ. 2008;23(2):114-21. [pmid: 18569247].
25 van Dam L, Hol L, de Bekker-Grob EW, et al. What determines individuals’ preferences for colorectal cancer screening programmes? A discrete choice experiment. Eur J Cancer. 2010;46(1):150-9. [pmid: 19683432].
26 Frosch DL, Kaplan RM, Felitti V. The evaluation of two methods to facilitate shared decision making for men considering the prostate-specific antigen test. J Gen Intern Med. 2001;16(6):391-8. [pmid: 11422636].
27 Pignone M, Bucholtz D, Harris R. Patient preferences for colon cancer screening. J Gen Intern Med. 1999;14(7):432-7. [pmid: 10417601].
28 Smith DM, Brown SL, Ubel PA. Are subjective well-being measures any better than decision utility measures?. Health Econ Policy Law. 2008;3(Pt 1):85-91. [pmid: 18634635].
29 O’Connor AM, Wennberg JE, Legare F, et al. Toward the “tipping point”: decision aids and informed patient choice. Health Aff (Millwood). 2007;26(3):716-25. [pmid: 17485749].
30 Stacey D, Murray MA, Legare F, et al. Decision coaching to support shared decision making: a framework, evidence, and implications for nursing practice, education, and policy. Worldviews Evid Based Nurs. 2008;5(1):25-35. [pmid: 18266768].
31 Reuben DB, Herr KA, Pacala JT, et al. Geriatrics at Your Fingertips. 12th ed. New York. American Geriatrics Society. 2010.
32 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Comm Health. 1998;52(6):377-84.
33 Goldsmith MR, Bankhead CR, Austoker J. Synthesising quantitative and qualitative research in evidence-based patient information. J Epidemiol Comm Health. 2007;61(3):262-70.
34 Horne M, Speed S, Skelton D, et al. What do community-dwelling Caucasian and South Asian 60–70 year olds think about exercise for fall prevention?. Age Ageing. 2009;38(1):68-73. [pmid: 19039019].
35 Weeks LE, Profit S, Campbell B, et al. Participation in physical activity: influences reported by seniors in the community and in long-term care facilities. J Gerontol Nurs. 2008;34(7):36-43.
36 Schonberg MA, McCarthy EP, York M, et al. Factors influencing elderly women’s mammography screening decisions: implications for counseling. BMC Geriatrics. 2007;7:26. [pmid: 18021402].
37 Oliffe J. Being screened for prostate cancer: a simple blood test or a commitment to treatment?. Cancer Nurs. 2006;29(1):1-8. [pmid: 16557114].
38 Benyamini Y, McClain CS, Leventhal EA, et al. Living with the worry of cancer: health perceptions and behaviors of elderly people with self, vicarious, or no history of cancer. Psychooncology. 2003;12(2):161-72. [pmid: 12619148].
39 Dassow P. Setting educational priorities for women’s preventive health: measuring beliefs about screening across disease states. J Womens Health (Larchmt). 2005;14(4):324-30. [pmid: 15916506].
40 Rutten LF, Hesse BW, Moser RP, et al. Public perceptions of cancer prevention, screening, and survival: comparison with state-of-science evidence for colon, skin, and lung cancer. J Cancer Educ. 2009;24(1):40-8. [pmid: 19259865].
41 Chapman GB, Brewer NT, Coups EJ, et al. Value for the future and preventive health behavior. J Exp Psychol Appl. 2001;7(3):235-50. [pmid: 11676102].
42 Chapman GB, Elstein AS, Kuzel TM, et al. Prostate cancer patients’ utilities for health states: how it looks depends on where you stand. Med Decis Making. 1998;18(3):278-86. [pmid: 9679992].
43 Meropol NJ, Egleston BL, Buzaglo JS, et al. Cancer patient preferences for quality and length of life. Cancer. 2008;113(12):3459-66. [pmid: 18988231].
44 Bowling A, Dieppe P. What is successful ageing and who should define it?. BMJ. 2005;331(7531):1548-51. [pmid: 16373748].
45 Rowe JW, Kahn RL. Successful aging. Gerontologist. 1997;37(4):433-40. [pmid: 9279031].
46 Sarkisian CA, Hays RD, Mangione CM. Do older adults expect to age successfully? The association between expectations regarding aging and beliefs regarding healthcare seeking among older adults. J Am Geriatr Soc. 2002;50(11):1837-43. [pmid: 12410903].
47 Appelt CJ, Burant CJ, Siminoff LA, et al. Arthritis-specific health beliefs related to aging among older male patients with knee and/or hip osteoarthritis. J Gerontol A Biol Sci Med Sci. 2007;62(2):184-90. [pmid: 17339644].
48 Phelan EA, Anderson LA, LaCroix AZ, et al. Older adults’ views of “successful aging”— how do they compare with researchers’ definitions?. J Am Geriatr Soc. 2004;52(2):211-6. [pmid: 14728629].
49 Corwin SJ, Laditka JN, Laditka SB, et al. Attitudes on aging well among older African Americans and whites in South Carolina. Prev Chronic Dis. 2009;6(4):A113. [pmid: 19754989].
50 Laakkonen ML, Pitkala KH, Strandberg TE, et al. Older people’s reasoning for resuscitation preferences and their role in the decision-making process. Resuscitation. 2005;65(2):165-71. [pmid: 15866396].
51 Covinsky KE, Wu AW, Landefeld CS, et al. Health status versus quality of life in older patients: does the distinction matter?. Am J Med. 1999;106(4):435-40. [pmid: 10225247].
52 Ouwehand C, de Ridder DT, Bensing JM. A review of successful aging models: proposing proactive coping as an important additional strategy. Clin Psychol Rev. 2007;27(8):873-84. [pmid: 17328997].
53 Baltes PB, Baltes MM. Psychological perspectives on successful aging: the model of selective optimization with compensation, Successful Aging: Perspectives From the Behavioral Sciences. New York. Cambridge University Press. 1990:1-34.
54 Thoolen BJ, de Ridder D, Bensing J, et al. Beyond good intentions: the role of proactive coping in achieving sustained behavioural change in the context of diabetes management. Psychol Health. 2009;24(3):237-54. [pmid: 20204991].
55 Wenger NS, Solomon DH, Amin A, et al. Application of Assessing Care of Vulnerable Elders-3 quality indicators to patients with advanced dementia and poor prognosis. J Am Geriatr Soc. 2007;55(Suppl 2):S457-63. [pmid: 17910571].
56 Benyamini Y, Idler EL, Leventhal H, et al. Positive affect and function as influences on self-assessments of health. J Gerontol B Psychol Sci Soc Sci. 2000;55(Part 2):P107-P16. [pmid: 10794189].
57 Crossley ML. Could you please pass one of those health leaflets along?: exploring health, morality and resistance through focus groups. Soc Sci Med. 2002;55(8):1471-83. [pmid: 12231023].
58 Crossley ML. Would you consider yourself a healthy person?: using focus groups to explore health as a moral phenomenon. J Health Psychol. 2003;8(5):501-14. [pmid: 19177713].
59 Benyamini Y, Roziner I. The predictive validity of optimism and affectivity in a longitudinal study of older adults. Pers Individ Dif. 2008;44(4):853-64. [pmid: 19255603].
60 Sommers BD, Zeckhauser R. Probabilities and preferences: what economics can teach doctors and patients making difficult treatment decisions. Urol Oncol. 2008;26(6):669-73. [pmid: 18996317].
61 O’Connor PJ, Crabtree BF, Yanoshik MK. Differences between diabetic patients who do and do not respond to a diabetes care intervention: a qualitative analysis. Fam Med. 1997;29(6):424-8. [pmid: 9193915].
62 Johnson PE, Veazie PJ, Kochevar L, et al. Understanding variation in chronic disease outcomes. Health Care Manag Sci. 2002;5(3):175-89. [pmid: 12363045].
63 van den Akker M, Buntinx F, Metsemakers JF, et al. Multimorbidity in general practice: prevalence, incidence, and determinants of co-occurring chronic and recurrent diseases. J Clin Epidemiol. 1998;51(5):367-75. [pmid: 9619963].
64 Bayliss EA, Ellis JL, Steiner JF. Barriers to self-management and quality-of-life outcomes in seniors with multimorbidities. Ann Fam Med. 2007;5(5):395-402. [pmid: 17893380].
65 Wolff JL, Starfield B, Anderson G. Prevalence, expenditures, and complications of multiple chronic conditions in the elderly. Arch Intern Med. 2002;162(20):2269-76. [pmid: 12418941].
66 Grimby A, Svanborg A. Morbidity and health-related quality of life among ambulant elderly citizens. Aging (Milano). 1997;9(5):356-64. [pmid: 9458996].
67 Pearlman RA, Uhlmann RF. Quality of life in elderly, chronically ill outpatients. J Gerontol. 1991;46(2):M31-8. [pmid: 1997570].
68 Bryant LL, Beck A, Fairclough DL. Factors that contribute to positive perceived health in an older population. J Aging Health. 2000;12(2):169-92. [pmid: 11010695].
69 Fortin M, Lapointe L, Hudon C, et al. Multimorbidity and quality of life in primary care: a systematic review. Health Qual Life Outcomes. 2004;2:51. [pmid: 15380021].
70 van den Akker M, Buntinx F, Knottmerus JA. Comorbidity or multimorbidity: what’s in a name? A review of literature. Eur J Gen Pract. 1996;2:65-70.
71 Bayliss EA, Edwards AE, Steiner JF, et al. Processes of care desired by elderly patients with multimorbidities. Fam Pract. 2008;25(4):287-93. [pmid: 18628243].
72 Fried TR, McGraw S, Agostini JV, et al. Views of older persons with multiple morbidities on competing outcomes and clinical decision-making. J Am Geriatr Soc. 2008;56(10):1839-44. [pmid: 18771453].
73 Kassirer JP, Pauker SG. The toss-up. N Engl J Med. 1981;305:1467-9. [pmid: 7300866].
74 Woolf SH, Chan EC, Harris R, et al. Promoting informed choice: transforming health care to dispense knowledge for decision making. Ann Intern Med. 2005;143(4):293-300. [pmid: 16103473].
75 Bayliss EA, Ellis JL, Steiner JF. Seniors’ self-reported multimorbidity captured biopsychosocial factors not incorporated into two other data-based morbidity measures. J Clin Epidemiol. 2009;62(5):550-7. [pmid: 18757178].
76 Lewis CL, Griffith J, Pignone MP, et al. Physicians decisions about continuing or stopping colon cancer screening in the elderly: a qualitative study. J Gen Intern Med. 2009;24(7):816-21. [pmid: 19437080].
77 Stalbrand IS, Svensson T, Elmstahl S, et al. Subjective health and illness, coping and life satisfaction in an 80-year-old Swedish population—implications for mortality. Int J Behav Med. 2007;14(3):173-80. [pmid: 18062060].
78 Nobrega TC, Jaluul O, Machado AN, et al. Quality of life and multimorbidity of elderly outpatients. Clinics (Sao Paulo). 2009;64(1):45-50. [pmid: 19142551].
79 Bandura A. Self-Efficacy: the Exercise of Control. New York. WH Freeman. 1997.
80 Ajzen I. The theory of planned behavior. Organ Behav Hum Decis Process. 1991;50(2):179-211.
81 Rosenstock IM. Why people use health services. Milbank Mem Fund Q. 1966;44(3):94-127. [pmid: 5967464].
82 Rosenstock IM, Strecher VJ, Becker MH. Social learning theory and the health belief model. Health Educ Q. 1988;15(2):175-83. [pmid: 3378902].
83 Leventhal H, Meyer D, Nerenz D. The Common-Sense Representation of Illness Danger. New York. Pergamon Press. 1980;2.
84 Diefenbach MA, Leventhal EA, Leventhal H, et al. Negative affect relates to cross-sectional but not longitudinal symptom reporting: data from elderly adults. Health Psychol. 1996;15(4):282-8. [pmid: 8818674].
85 Prochaska JO, Velicer WF, Rossi JS, et al. Stages of change and decisional balance for 12 problem behaviors. Health Psychol. 1994;13(1):39-46. [pmid: 8168470].
86 Weinstein ND, Sandman PM. A model of the precaution adoption process: evidence from home radon testing. Health Psychol. 1992;11(3):170-80. [pmid: 1618171].
87 Glanz K, Rimer BK, Viswanath K, editors. Health Behavior and Health Education: Theory, Research, and Practice. 4th ed. San Francisco. Jossey-Bass. 2008.
88 Strecher VJ, Kreuter M, Den Boer DJ, et al. The effects of computer-tailored smoking cessation messages in family practice settings. J Fam Pract. 1994;39(3):262-70. [pmid: 8077905].
89 Albert DA. Decision theory in medicine: a review and critique. Milbank Mem Fund Q. 1978;56(3):362-401.
90 von Neumann J, Morgenstern O. Theory of Games and Economic Behavior. 3rd ed. Princeton. Princeton University Press. 1953.
91 Llewellyn-Thomas HA. Investigating patients’ preferences for different treatment options. Can J Nurs Res. 1997;29(3):45-64. [pmid: 9505582].
92 Man-Son-Hing M, Laupacis A, O’Connor AM, et al. Patient preference-based treatment thresholds and recommendations: a comparison of decision-analytic modeling with the probability-tradeoff technique. Med Decis Making. 2000;20(4):394-403. [pmid: 11059472].
93 Ryan M, Watson V, Entwistle V. Rationalising the “irrational”: a think aloud study of discrete choice experiment responses. Health Econ. 2009;18(3):321-36. [pmid: 18651601].
94 Winter L, Moss MS, Hoffman C. Affective forecasting and advance care planning: anticipating quality of life in future health statuses. J Health Psychol. 2009;14(3):447-56. [pmid: 19293306].
95 Chin MH, Drum ML, Jin L, et al. Variation in treatment preferences and care goals among older patients with diabetes and their physicians. Med Care. 2008;46(3):275-86. [pmid: 18388842].
96 Dolan P. Developing methods that really do value the “Q” in the QALY. Health Econ Policy Law. 2007;3(1).
97 Phillips KA, Johnson FR, Maddala T. Measuring what people value: a comparison of “attitude” and “preference” surveys. Health Serv Res. 2002;37(6):1659-79. [pmid: 12546291].
98 Llewellyn-Thomas HA, Williams JI, Levy L, et al. Using a trade-off technique to assess patients’ treatment preferences for benign prostatic hyperplasia. Med Decis Making. 1996;16(3):262-82. [pmid: 8818125].
99 Simon HA. A behavioral model of rational choice. Q J Econ. 1955;69:99-118.
100 Gigerenzer G, Brighton H. Homo heuristicus: why biased minds make better inferences. Topic Cogn Sci. 2009;1:107-43.
101 Arana JE, Leon CJ, Hanemann MW. Emotions and decision rules in discrete choice experiments for valuing health care programmes for the elderly. J Health Econ. 2008;27(3):753-69. [pmid: 18241944].
102 Carstensen LL. The influence of a sense of time on human development. Science. 2006;312(5782):1913-5. [pmid: 16809530].
103 Lockenhoff CE, Carstensen LL. Decision strategies in health care choices for self and others: older but not younger adults make adjustments for the age of the decision target. J Gerontol B Psychol Sci Soc Sci. 2008;63(2):P106-9. [pmid: 18441264].
104 Sprangers MA, Schwartz CE. Integrating response shift into health-related quality of life research: a theoretical model. Soc Sci Med. 1999;48(11):1507-15. [pmid: 10400253].
105 Razmjou H, Schwartz CE, Yee A, et al. Traditional assessment of health outcome following total knee arthroplasty was confounded by response shift phenomenon. J Clin Epidemiol. 2009;62(1):91-6. [pmid: 19095168].
106 Makoul G, Clayman ML. An integrative model of shared decision making in medical encounters. Patient Educ Couns. 2006;60(3):301-12. [pmid: 16051459].
107 Galesic M, Gigerenzer G, Straubinger N. Natural frequencies help older adults and people with low numeracy to evaluate medical screening tests. Med Decis Making. 2009;29(3):368-71. [pmid: 19129155].
108 Kehler D, Christensen B, Lauritzen T, et al. Cardiovascular-risk patients’ experienced benefits and unfulfilled expectations from preventive consultations: a qualitative study. Qual Prim Care. 2008;16(5):315-25. [pmid: 18973712].
109 Greenlund KJ, Keenan NL, Anderson LA, et al. Does provider prevention orientation influence female patients’ preventive practices?. Am J Prev Med. 2000;19(2):104-10. [pmid: 10913900].
110 Sheridan SL, Harris RP, Woolf SH, et al. Shared decision making about screening and chemoprevention: a suggested approach from the U.S. Preventive Services Task Force. Am J Prev Med. 2004;26(1):56-66. [pmid: 14700714].
111 Paulos J. Innumeracy: Mathematical Illiteracy and Its Consequences. New York. Hill and Wang. 1988.
112 Fagerlin A, Ubel PA, Smith DM, et al. Making numbers matter: present and future research in risk communication. Am J Health Behav. 2007;31(Suppl 1):S47-56. [pmid: 17931136].
113 Hawley ST, Zikmund-Fisher B, Ubel P, et al. The impact of the format of graphical presentation on health-related knowledge and treatment choices. Patient Educ Couns. 2008;73(3):448-55. [pmid: 18755566].
114 Epstein RM, Peters E. Beyond information: exploring patients’ preferences. JAMA. 2009;302(2):195-7. [pmid: 19584351].
115 Thaler R, Sunstein C. Libertarian paternalism. Am Econ Rev. 2003;93(2):175-9.
116 Ubel PA. Is information always a good thing? Helping patients make “good” decisions. Med Care. 2002;40(9 Suppl):V39-44. [pmid: 12226584].
117 Levinson W, Kao A, Kuby A, et al. Not all patients want to participate in decision making. A national study of public preferences. J Gen Intern Med. 2005;20(6):531-5. [pmid: 15987329].
118 Arora NK, McHorney CA. Patient preferences for medical decision making: who really wants to participate?. Med Care. 2000;38(3):335-41. [pmid: 10718358].
119 Cassel CK. The patient-physician covenant: an affirmation of Asklepios. Conn Med. 1996;60(5):291-3. [pmid: 8998907].
120 Quill TE, Cassel CK. Nonabandonment: a central obligation for physicians. Ann Intern Med. 1995;122(5):368-74. [pmid: 7847649].
121 Briss P, Rimer B, Reilley B, et al. Promoting informed decisions about cancer screening in communities and healthcare systems. Am J Prev Med. 2004;26(1):67-80. [pmid: 14700715].
122 Fried TR, O’Leary J, Van Ness P, et al. Inconsistency over time in the preferences of older persons with advanced illness for life-sustaining treatment. J Am Geriatr Soc. 2007;55(7):1007-14. [pmid: 17608872].
123 O’Connor AM, Bennett CL, Stacey D, et al. Decision aids for people facing health treatment or screening decisions. Cochrane Database Syst Rev. 2009:CD001431.
124 Kutner M, Greenberg E, Jin Y, Paulsen C. The Health Literacy of America’s Adults: Results From the 2003 National Assessment of Adult Literacy. Washington, DC. National Center for Education Statistics, U.S. Department of Education. 2006.
125 Elwyn G, O’Connor A, Stacey D, et al. Developing a quality criteria framework for patient decision aids: online international Delphi consensus process. BMJ. 2006;333(7565):417. [pmid: 16908462].
126 Legare F, Stacey D, Graham ID, et al. Advancing theories, models and measurement for an interprofessional approach to shared decision making in primary care: a study protocol. BMC Health Serv Res. 2008;8:2. [pmid: 18173848].
127 O’Connor AM. Validation of a decisional conflict scale. Med Decis Making. 1995;15(1):25-30. [pmid: 7898294].