# Executive Summary

## Introduction

Prevention implies a future orientation. By engaging in preventive actions, individuals attempt to affect the likelihood of developing a health problem, delaying the development of a health problem, or reducing the severity of the health problem when it develops. An investment in preventive care today is expected to change a person’s future health trajectory.

At first glance, how expected trajectories impact how various preventive actions are viewed by older adults may seem relatively straightforward. Older persons have shorter life expectancies and hence may view the likelihood of benefit differently from younger people. The differences in perceived possible benefits between the age groups would logically lead to differences in how the age groups value preventive services. Organizations like the U.S. Preventive Services Task Force (USPSTF), charged with making recommendations about preventive services, would likely want to consider the values older people place on various preventive activities as part of the process of formulating recommendations.

Setting out to understand how older people value preventive services raises a number of questions regarding how age should be viewed and considered in clinical context. One question is how we determine age. Typically, age is assessed in terms of chronological years since birth; however, gerontologists measure age in terms of the force of mortality, the likelihood of dying. The gerontological definition of age gives great weight to factors like illness, health status, and physical and cognitive function. An example of the importance of the difference between the definitions can be found in research by Gerstorf and colleagues,1 who found that decline in life satisfaction in old age is more predictive of death than chronological age itself.

When we talk about older people’s attitudes to prevention, the chronological and gerontological definitions of age take on special salience. In fact, shorter expected life spans, increased comorbidities, and competing causes of death can be present in a variety of populations and may affect their preferences for preventive services in ways similar to the older adult. So chronological age may not be the best indicator for differences in attitudes and preferences for preventive care.

Another question is how aging shapes beliefs about preventive services. Understanding the role of aging requires separating intertwined themes: intergenerational differences from intragenerational differences, and the influence of historical forces. Some differences in beliefs about preventive services may occur because people of one generation hold different social values than those of the following generation, perhaps, in part, influenced by their experiences growing up (e.g., the Great Depression). Alternatively, people in a given cohort may change their values as they age, perhaps as a function of their life experiences or their changing physical state. Cross-sectional comparisons of people at a single point in time cannot separate these effects.

Generational differences in aging also bring up the issue of the age span encompassed in the term “older adult.” Given that the age range within this segment of the population covers 30 years and ages 65 and older, the term does not accurately reflect the heterogeneity of the older adult population. Neugarten first coined the term “young-old,” the age group 55 to 75 years, to differentiate from the “old-old” those older adults who are younger, generally healthier, relatively free from traditional work and family responsibilities, and socially and politically active. So, the developmental spectrum of aging has enormous variation, and individuals may not place such emphasis on decreasing life expectancy until their later years of aging.

Yet another question lies in the role of differences between people at the individual level in shaping beliefs about preventive services. An aphorism familiar in geriatrics is that age is a useful predictor for groups but very poor for predicting individual outcomes.2 Hence, one might expect considerable variation in attitudes and opinions among older persons.

Just as gerontological and chronological age definitions distinguish clinical and lay perspectives of age, there are factors that differentiate clinical and lay perspectives of preventive services at the individual level as well. Clinicians characterize a preventive service by whether it avoids disease, identifies disease at early stages, or reduces the negative impact of an established disease. Patients may characterize preventive services using different qualities. For example, preventive services can differ by the patient’s anticipated effort and/or burden. Some preventive actions require considerable discomfort (e.g., colonoscopy); others are simple and relatively painless (e.g., immunizations); still others require sustained behavior change (e.g., diet). Other factors such as time, money, cultural beliefs, and pain can also influence an individual’s attitudes about and preferences for a preventive behavior.

This project was requested by the USPSTF because clinical preventive services are increasing in importance as the U.S. population ages. However, there are challenges in evaluating the evidence for preventive services in older adults and in applying the evidence to developing recommendations specific to older adults; perceived benefits and harms may differ from the general population due to decreasing life expectancy, increasing comorbidities, and competing causes of death in older adults. A specific challenge is determining when the net balance of perceived benefits and harms turns negative; that is, when do the harms begin to outweigh the benefits? One important consideration is how patient values affect the determination of benefits and harms of clinical preventive services.

Uncertainty is a critical issue facing patients and providers in deciding a course of action for prevention. There is uncertainty regarding the potential benefits and harms an older person may receive from any particular preventive service. There is also uncertainty regarding the place of a particular preventive service, or the array of preventive services, within the context of other health concerns older persons may face. Such uncertainty may arise from the physiology of aging, the presence of a single chronic illness or multiple conditions, or the risk for mortality. The presence of uncertainty amplifies the importance of understanding values and preferences, because those values and preferences may end up mattering more, potentially driving the choices in directions different from what would have transpired in the case of certainty.

To the extent that there is uncertainty regarding medical outcomes and variability in how people value different outcomes, there is a growing need for decisionmaking processes that are more attentive to the needs and values of the patient. Recent decades have witnessed a decided shift in the philosophy of care away from a model of professional dominance to one of patient-centeredness. 3 A hallmark of this approach is the concept of shared decisionmaking. Shared decisionmaking is viewed as vital when no particular course of action presents itself as a prevailing option.4

The enthusiasm for shared decisionmaking is worth closer examination. Although studies have shown that patients often make very different clinical decisions when given full exposure to the risks and benefits of alternative treatments for a given disease, it is not altogether clear just how much older patients want to be the locus of decisionmaking, or how well some can process complex information surrounding choices.

The aim of this review is to provide to the USPSTF a compendium of general information that can be used as a resource when the Task Force is deliberating recommendations on preventive care for older persons and the decision to engage or not engage in a preventive behavior.

## Key Questions and Conceptual Model

The following key questions are the basis for this review.

KQ1 How do older adults value the potential benefits of primary and secondary clinical preventive services, including reductions in morbidity and mortality, improvements in quality of life, maintenance of independence, and functional ability? Does cognitive ability or functional limitation affect how older adults value the potential benefits?
KQ2 What attitudes do older adults have about potential harms of clinical preventive services?
KQ3 What value do older adults place on the receipt of clinical preventive services?
KQ4 How do older adults understand the balance of risks and benefits from clinical preventive services?
KQ6 How should clinicians engage in shared decisionmaking related to clinical preventive services in older adults?

We approached the key questions through the rubric of shared decisionmaking, rather than through any particular psychological or behavioral model. The conceptualization acknowledges the overarching context of experience, individual attributes, information, and environmental factors that contribute to the development of individual preferences and attitudes. Essentially, the older adult has values, preferences, and attitudes toward the preventive services and the outcomes and harms these preventive services may provide. The older adult, through cognitive and emotional processes, then develops a net balance of benefits and harms, in which a negative benefit is possible if the benefits are outweighed by the harms. These same values, preferences, and harms impact the desire for, and process of, shared decisionmaking with providers.

## Methods

The review focuses on older adults’ perceptions of, preferences for, and attitudes about prevention. Preferences for the actual services, such as whether patients prefer colonoscopy or fecal occult blood tests for colon cancer screening, is outside the scope of this review. The review also does not address the evidence for preventive services’ effectiveness. Community-dwelling adults ages 65 years and older are the population of interest. We were specifically instructed not to examine literature on younger groups with the goal of extrapolating the findings to older persons. We were unable to locate empirical literature to guide “adequate representation” of older persons to judge applicability of the prevention literature.

Our search process varied from a traditional systematic literature review process, as databases are not well indexed for “soft” topics such as values and preferences. We augmented traditional search practices with multiple, iterative searches of the literature as material was reviewed and possible new searches were suggested. We conducted electronic searches of Ovid MEDLINE, the Cumulative Index to Nursing and Allied Health Literature, PsychINFO, the Cochrane Database of Systematic Reviews, and EconLit. Searches were conducted on keywords such as “preferences” or “lay understanding.” We also used search terms that captured qualitative research techniques and search terms that captured the patient/provider relationship and processes involved in shared decisionmaking, such as “choice behavior,” “patient/provider relationship,” and “shared decisionmaking.” The literature was focused with MeSH terms that identified primary and secondary prevention, and limited to the English language and ages 65 years and older. We identified longitudinal studies on aging and national panel surveys that would allow for examining differences in attitudes and preferences based on age, and searched the literature for any related articles. Literature searches were conducted from inception of the database to between mid-October 2009 and March 2010. Supplemental hand searches were also conducted, and experts in the field were polled for relevant articles.

## Results

Though initial searches yielded thousands of articles, few matched our criteria, and fewer still directly targeted the questions of interest. We identified 28 studies related to older people’s perceived benefits and harms of preventive services and their decisional balance. We also identified two studies that examined shared decisionmaking interventions for preventive service decisions by older people. These studies largely used qualitative or descriptive analysis methods with small purposive samples. The majority of the citations located during preliminary searches were discarded because the minimum age of the population was set much lower than 65 years. Investigated populations tended to be those targeted for a particular preventive behavior, such as women aged 40 years and older for breast cancer screening. Moreover, when study populations contained some individuals aged 65 years and over, older adults were often not adequately represented or distinctions between younger and older participants were not made. The studies that remained addressed populations that were generally white, educated, female, and had a higher income.

This literature set can only be considered a sampling of articles that may contain information regarding perceived benefits, risks, harms, or other factors that may contribute to the formation of preferences. Such concepts are often examined within a multitude of health behavior topics but are not aggregated as such. What is clear from the literature is the lack of focused attention on the specific topic of older adults’ perceptions of preventive care, particularly those adults within the oldest-old age categories.

Given the above, the reader is cautioned to avoid drawing sweeping conclusions from this literature set.

### Key Question 1 How Do Older Adults Value the Potential Benefits of Primary and Secondary Clinical Preventive Services?

Nineteen studies identified the perceived benefits of primary and secondary preventive services and behaviors.

Perceived benefits for primary prevention. The three studies in this area dealt with influenza and pneumococcal disease vaccination. Identified perceived benefits are largely related to expected improvements in health state, such as avoiding influenza or other respiratory illness, and are interpreted differently by those who have and have not been vaccinated; those who are vaccinated tend to associate more health-state benefits with vaccination than those who have not been vaccinated.5–7

Perceived benefits for secondary prevention. The four studies in this area dealt with cancer screening and dementia screening. The identified perceived benefits tend to focus on both health-state outcomes and psychological benefits derived from peace of mind stemming from knowledge of test results and believed absence or reduction of risk for the problem.8–11

Primary prevention and perceived risk. In general, older adults in these studies did not believe themselves to be at risk for serious complications associated with influenza or pneumococcal disease, regardless of immunization status.5–7 Older adults viewed their independent status and active engagement as evidence of good health status5 and believed that other behaviors, such as diligent self-care6 and good nutrition habits,6 were effective in reducing risk. Interestingly, one study found the perception among older adults that health providers demonstrate an ageist attitude with blanket recommendations for vaccination based on age to be a prominent theme.6

Secondary prevention and perceived risk. More articles, seven in all, addressed perceived risk rather than perceived benefits in the literature on secondary prevention. Three articles indicated that participants felt that there was no need to screen for breast cancer if one felt healthy.8,12,13 Age appears to be a factor in personal risk perception for developing cancer in four articles.11,14–16

### Key Question 2 What Attitudes Do Older Adults Have About Potential Harms of Clinical Preventive Services?

Perceived harms for primary prevention. The three studies in this area dealt with influenza and pneumococcal disease vaccination. Older adults who have not been vaccinated tend to perceive the vaccine as more harmful than those who have been vaccinated.5,6 Specific perceived harms identified in this literature were clinical in nature and focused on side effects.5–7 In one study, older people who were vaccinated tended to counterbalance perceived harms of influenza vaccinations across multiple time periods.5

Perceived harms for secondary prevention. The eight studies identified in this area dealt with cancer and dementia screening. Perceived clinical harms associated with screening behaviors were fear of the test,8,13 pain,11 discomfort,13 side effects,17 and a view that treatment would be worse than living with the disease.18 Psychological harms were similar for breast and colon cancer screening.8,9,11–13,17,18

Dementia screening had unique perceived harms. These included social stigma, emotional and practical hardships, and loss of independence if diagnosed with Alzheimer’s disease.19

### Key Question 3 What Value Do Older Adults Place on the Receipt of Clinical Preventive Services?

Primary prevention. No studies were found that directly addressed this area. Four related studies indicate that some older adults have positive attitudes toward physical activity.20–23 However, we were unable to find literature to inform our understanding of how older people view the role of physical activity counseling by their health providers, or how they view the receipt of clinical preventive services for primary prevention in general.

Secondary prevention. The four studies identified in this area dealt with cancer screening. Two studies indicated that the value of breast cancer screening is unclear to people who are unwilling to risk losing feeling healthy should cancer or some other diagnosis be discovered.8,12 Skepticism of medical recommendations and a sense of civic obligation were also implicated as factors that affect one’s decisions to engage in breast cancer and colon cancer screening, respectively.8,24

One study directly asked how older people view preventive services.10 The researchers interviewed 116 residents of a North Carolina long-term care facility’s independent living quarters regarding their attitudes and beliefs about cancer screening. Of particular note is that 50 percent of participants felt that other health issues are more important than cancer screening, although older people with a history of cancer were less likely to express this opinion. Interestingly, the percentage of older adults reporting that they, personally, would continue prostate, breast, and colon cancer screening for as long as they live was larger than the percentage who agreed that everyone should get screened for these cancers as long as they live. This suggests that attitudes toward cancer screening can differ across screening targets (self versus others).

### Key Question 4 How Do Older Adults Understand the Balance of Risks and Benefits From Clinical Preventive Services?

Two articles were located that provided some insight into how patients understand balance. In one study, individuals valued screening outcomes, especially mortality reduction, more than process features of the test when stating their preferences for a colon cancer screening procedure.25 Likewise, another study, using focus groups, found that participants valued test sensitivity more than discomfort during a test procedure.17 Little is known about how the benefits and harms of preventive behaviors are balanced by older adults and influence behavioral decisions. There is a scarcity of theory/models available to guide this work.

Issues of valuing prevention. Several leading decisionmaking models relevant to health decisions are detailed in Chapter 4. Issues that come to bear on aging and the value of prevention include: understanding the goals of prevention, such as successful aging; the processes of proactive coping, and selective optimization and compensation; heterogeneity in elderly populations and preventive services; and competing demands created by comorbidity, multimorbidity, and habits. Understanding can be gained through many disciplinary lenses, including health psychology models, economic theory, decision theory, and decision analytics; behavioral economics examinations of bounded rationality, use of heuristics, and cognitive biases; and socioemotional selectivity theory. Response shift phenomenon may interfere with accurate measurement of study outcomes.

### Key Question 5 How Should Clinicians Engage in Shared Decisionmaking Related to Clinical Preventive Services in Older Adults?

Two articles evaluated shared decisionmaking interventions for preventive services for older adults. There is nothing in these studies to indicate whether older adults have a different level of interest in engaging in shared decisionmaking. Even though neither study included all the essential elements of shared decisionmaking, they were able to influence patient decisions. That is, improved knowledge led to a reduction in the number of older men receiving prostate-specific antigen (PSA) screening26 and increased older men’s preference for colorectal cancer screening.27 Both studies used research assistants to implement the interventions, suggesting shared decisionmaking can be provided by someone other than the physician and still influence choices. The outcome measures focused on improving knowledge about the disease being screened, the benefits and risks associated with the screening procedure, and concern about developing the disease. Missing were outcomes related to decision quality (i.e., decisional conflict and congruency of patients’ decisions with their values). Another important outcome omission was the lack of followup on actual screening behavior.

Older people appear to respond favorably to shared decisionmaking interventions, and participation in shared decisionmaking interventions increased older people’s awareness of the opportunity to share their decision with their care providers. Interventions with just a few shared decisionmaking elements change older people’s knowledge on disease, risk perception, and motivation to engage in behavior change. Older people may prefer more time in the encounter to discuss their individual circumstances to provide a tailored recommendation. However, it appears life expectancy may not be an important factor for some older adults, and some would prefer to not discuss life expectancy with their provider. Clinicians need to determine how much the patient wants to be involved with decisionmaking.

Issues of shared decisionmaking. Theories of medical decisionmaking are evolving and the current emphasis is on empowering patient involvement through shared decisionmaking. While this idea has strong face validity and is congruent with optimizing patient autonomy, there is little empirical evidence to guide its implementation as it relates to preventive services for older adults. There appears to be agreement that shared decisionmaking does not need to occur in all clinical encounters. It is most appropriate to use when there is more than one reasonable treatment option or when there is considerable uncertainty about the strength of evidence for a given screening option (as is the case with PSA screening). Challenges with implementing shared decisionmaking arise from a lack of consensus on what elements should be included in the process, on relevant outcome measures, when to incorporate decision aids, and when shared decisionmaking should expand beyond the patient-physician dyad to include other health care professionals or be offered at the population level through public health promotions. Other concerns include how to adequately represent risk to older adults in ways that develop accurate knowledge and the provider’s role in shared decisionmaking.

## Discussion

Preferences are not stable over time, and may not be elicited as much as constructed. Cognitive, emotional, and relationship factors contribute to how preferences are shaped. Given this, providers need to be sensitive to unintentional undue influences on the patient’s preferences.

Both aging and prevention are challenging, complex topics. Taken singularly, they often do not lend themselves to simple solutions based on one easily defined mechanism. Together they create a complex system and a decisionmaking environment that requires acknowledging complexity and the challenge of balancing multiple inputs, attentional demands, and choices among an array of possible actions. It is, in other words, a domain that is ripe with uncertainty.

Simply put, peoples’ values for preventive services and their attendant benefits, risks, and harms reflect all sorts of inputs. People bring their past, beliefs, prior experiences, habits, strengths, and personal idiosyncrasies with them as they age. This individual variation makes generalizations dangerous.

Patient-centered care may not always require shared decisionmaking; clinicians need to better understand the appropriate role for patients in deciding their own role in decisionmaking. The congruence of decisionmaking philosophies across groups, much less individuals, is a conversation that should continue, given the underdeveloped nature of this area. We should not assume too much.

## Future Research Recommendations

There has been little work regarding preferences in the arena of preventive care, and there is no strong body of evidence informing the topic of how older people value preventive services. In fact, the field is underdeveloped, and much of the available information is in the form of indirect evidence. The overwhelming majority of the current literature on preferences is disease-specific and treatment focused, and does not directly address aging and its effect on preferences for preventive health. Nor has a community of colleagues fully formed to address the topic directly. Similarly, older adults are poorly represented in the shared decisionmaking literature, and this area too is underdeveloped. Other, more specific suggestions are listed below:

- Research that examines differences between the age groups within the older adult population, particularly the oldest old, is strongly needed. Similarly, it is also important to understand how prevention preferences change over time. This includes whether and how prevention values and practices change as middle-aged adults transition to older ages, as well as how preferences change as people advance from young-old to oldest-old.
- Continuing research into tools to measure values and preferences is critical to the field. We support Smith and Ubel’s call for expanded research into both decision-based utility methods, such as stated preferences, and subjective well-being, as well as for measurement tools that are more sensitive to health changes and less biased.28
- Furthermore, we need to understand how the presentation of the number of choice options or number of potential side effects impacts decisionmaking through potential for cognitive biases and other heuristics.
- Older adults are also poorly represented in the shared decisionmaking literature. Although shared decisionmaking is an evolving concept, work in this field is progressing. Most decision aids were developed for younger populations and address disease treatment rather than preventive services. Future research needs to investigate how well these decision aids work for older adults.
- Future researchers need to identify what facilitates and hinders older adults’ ability to engage in shared decisionmaking.
- Future research needs to determine if relevant outcome measures, such as improvement in patient knowledge of the benefits and harms of preventive services and realistic expectations of outcomes, benefits and harms, certainty of choice, feelings of being informed, and being clear about values, are also valid and reliable for older people.
- The decisional conflict scale needs to be validated with older adults. Outcomes for decisional quality need to measure consistency between eligible patient treatment uptake rates and the underlying distribution of patients’ informed values and make sure there is no unresolved decisional conflict.29,30
- Further synthesis reviews for preferences by disease or function may assist the field with aggregating what information is currently available in the literature. Restricting searches to relatively easily defined search scope and algorithms, such as is found with strictly defined diseases or functions, would make it easier to locate relevant articles. Most of the articles located for this review were only indirectly related, but useful nonetheless. Pulling articles together across disease categories, and linking them together with searchable keywords, would help avoid inefficient use of research resources.