# Conclusion

## Bringing Preferences and Shared Decisionmaking Together

Preferences are not always stable over time. Epstein and Peters give a thoughtful commentary in which they point out that patient preferences may not be elicited as much as constructed, particularly in situations that are unfamiliar, have high stakes, or are uncertain, “with potential outcomes that have not been considered or cannot be imagined.”114 Yet, this is precisely the context for which medical shared decisionmaking is most advocated. Epstein and Peters state that cognitive, emotional, and relationship factors can impact how patients construct their preferences, citing framing effects (e.g., presenting information in positive or negative terms), information overload, the role of emotions in cognitive executive functions, and the patient-provider relationship. The literature on selective optimization and compensation theory, socioemotional selectivity theory, and response shift that was discussed previously is consistent with the factors raised by Epstein and Peters. As was mentioned previously, the use of stated preference and probability tradeoff techniques has been found to be a helpful process to participants as they deliberate on the health choices available.91,97

Preference instability has been documented in the literature. One study examined whether older adults’ preferences for future attempts at life-sustaining treatment change over time in a consistent and predictable manner. Community-dwelling older adults older than 60 years with advanced cancer, heart failure, or chronic obstructive pulmonary disease were interviewed every 4 months for 2 years.122 Thirty-five percent of participants had inconsistent preference trajectories (e.g., becoming more or less willing over time) when asked to trade high-burden therapy for prolonged life; the proportions increased to 48 percent when participants were asked to risk physical disability, and 49 percent when participants were asked to risk cognitive disability.122 Those with variable health states were more likely to have inconsistent trajectories, although participants with stable health states also commonly demonstrated inconsistent trajectories. The finding that trajectories were unstable in both directions is particularly noteworthy.

Preventive services may seem to represent a relatively tame scenario for preferences, compared to high-stakes health situations or questions regarding life-sustaining treatments. However, it should be noted that the oldest old are the least represented group in prevention literature, but the fastest growing demographic group of older adults. The level of uncertainty they face regarding the potential benefits and harms of preventive services is certainly not trivial. As mentioned in previously, providers need to be aware of their role in the shared decisionmaking process in order to avoid unintentional undue influence on the patient’s preferences.

## Recommendations for Future Research

There has been little work regarding preferences in the arena of preventive care, and there is no strong body of evidence informing the topic of how older people value preventive services. In fact, much of the available information is in the form of indirect evidence. Older adults are also poorly represented in the shared decisionmaking literature. The following sections discuss potential research topics that would help develop our understanding in these areas.

### Values, Attitudes, and Preferences

The overwhelming majority of the current literature on preferences is disease specific and treatment focused, and does not directly address aging and its effect on preferences for preventive health, either for primary or secondary prevention. Nor has a community of colleagues fully formed to address the topic directly. What literature currently exists tends to focus on the young old.

Given the more than 30-year span that covers the aging community, research that examines differences between the age groups within the older adult population, particularly the oldest old, is strongly needed. This research needs to take into account both the possibility of differences that arise between one age cohort versus changes that occur over time as people move from middle age to young-old age to the oldest ages. This would help focus efforts on age groups that are based on evidence rather than a socially constructed chronology. For example, it may be that the young-old have more in common with the generally healthy middle-aged than the old-old with regard to prevention, and certainly the frail old.

One other important question that needs attention is whether research in a patient-centered environment would differ from research in a professional-dominant environment. This research area is primed for consumer stakeholder involvement in research planning to assure that the questions asked, and the outcomes measured, represent how older adults approach and measure questions of value and preference. Given the heterogeneity of the older adult population, it is likely that the only valid way of using preference research in preventive services is through eliciting individual preferences in individual decisionmaking processes.

Continuing research into tools to measure values and preferences is critical to the field. We support Smith and Ubel’s call for expanded research into both decision-based utility methods, such as stated preferences, and subjective well-being, as well as for measurement tools that are more sensitive to health changes and less biased.28

Further synthesis reviews for preferences by disease or function may assist the field by aggregating what information is currently available in the literature. Restricting searches to a relatively easily defined search scope and algorithm, such as the type found with strictly defined diseases or functions, would make it easier to locate relevant articles. Most of the articles located for this review were only indirectly related, but useful nonetheless. Pulling these together across disease categories, and tying them together with searchable keywords, would help future researchers avoid inefficient use of research resources.

### Shared Decisionmaking

Although shared decisionmaking is an evolving concept, work in this field is progressing. The most developed areas are on decision aids that can be used during shared decisionmaking.123 However, most of these decision aids were developed for younger populations and address disease treatment rather than preventive services. Future research needs to investigate how well these decision aids work for older adults making decisions about prevention services. Decision aids should account for lower health literacy and numeracy found in this population124 and provide balanced and accurate information that will help older adults make choices that reflect their goals and concerns. Resources for developing decision aids are available from the Ottawa Hospital Research Institute (http://decisionaid.ohri.ca/odsf.html) and from the Dartmouth- Hitchcock Medical Center’s Center for Shared Decision Making (http://www.dhmc.org). International standards for the development of decision aids have also been developed and should be used to guide the creation of decision aids relevant to older adults’ preventive services.125

Other researchers are beginning to investigate ways to support health care professionals in shared decisionmaking.126 Future researchers need to identify what facilitates and hinders older adults’ ability to engage in shared decisionmaking. The limited evidence we found suggests that older adults are willing to engage in shared decisionmaking.26

Researchers are also beginning to develop and validate relevant shared decisionmaking outcome measures.126 Future research needs to determine if these measures are also valid and reliable for older people. The Ottawa Decision Support Framework describes types of relevant outcomes. Outcomes related to decisional needs should demonstrate improvement in patient knowledge of the benefits and harms of preventive services and realistic expectations of outcomes, benefits and harms, certainty of choice, feelings of being informed, and being clear about values. Decisional conflict should be decreased. The decisional conflict scale needs to be validated with older adults.127 Outcomes for decisional quality need to measure consistency between eligible patient treatment uptake rates and the underlying distribution of patients’ informed values and make sure there is no unresolved decisional conflict.29,30

To date, most of the shared decisionmaking literature has focused on the physician-patient dyad. Several lines of research are needed to improve our understanding of this dynamic. Research regarding the influence caregivers or family members may have on an older person’s desired role in shared decisionmaking would be useful. It is also important to understand how physician framing (how the physician presents information verbally) shapes preferences.

Researchers are beginning to explore how to use other health care professionals (i.e., nurses and social workers) in the process.126 Older people experiencing multimorbidity and functional limitations make good candidates for interventions that expand shared decisionmaking beyond the physician-patient dyad. The scant literature that we identified indicates that older people generally want more time to discuss their individual health needs with providers and want these needs to be considered in health care decisions.108 Given the limited time physicians have available for patient consultation, these interdisciplinary shared decisionmaking interventions may provide a more cost effective way of providing information when there is uncertainty in the decisionmaking process. The two studies we found on shared decisionmaking interventions in older adults did not involve the physician and demonstrate that part of shared decisionmaking interventions (i.e., provision of knowledge on the risks/benefits provided by a given preventive service) can be provided by other health care professionals and still influence patient decisions. However, research that would inform a physician as to whether a patient’s preference is “good” or “bad” is still vital.

## Conclusion

Both aging and prevention are challenging, complex topics. Taken singularly, they often do not lend themselves to simple solutions based on one easily defined mechanism. Together they create a complex system and a decisionmaking environment that requires acknowledging complexity and the challenge of balancing multiple inputs, attentional demands, and choices among an array of possible actions. It is, in other words, a domain that is ripe with uncertainty. Simply put, peoples’ values for preventive services and their attendant benefits, risks, and harms reflect all sorts of inputs. People bring their past, beliefs, prior experiences, habits, strengths, and personal idiosyncrasies with them as they age. This individual variation makes generalizations dangerous.

Patient-centered care may not always require shared decisionmaking; clinicians need to better understand the appropriate role for patients in deciding their own role in decisionmaking. The congruence of decisionmaking philosophies across groups, much less individuals, is a conversation that should continue, given the underdeveloped nature of this area. One should not assume too much.