# Shared Decisionmaking

## Review of Empirical Literature

The literature search identified only two studies that examined shared decisionmaking interventions for preventive service decisions by older people. In addition to the literature identified for Chapter 2, three additional articles were identified that informed the review regarding shared decisionmaking. These studies also largely used qualitative or descriptive analysis methods with small purposive samples.

### Key Question 5 How Should Clinicians Engage in Shared Decisionmaking Related to Clinical Preventive Services in Older Adults?

Definition and key elements of shared decisionmaking. Shared decisionmaking is defined as the process by which practitioners and patients reach health care choices together.30 It is an evolving concept with no agreed upon operational definition. We compiled a list of key elements of shared decisionmaking based on a review of 161 articles containing definitions by Makoul and Clayman106 and work done on the Ottawa Decision Support Framework.30 We used this list of key elements to evaluate the comprehensiveness of the shared decisionmaking interventions we found on preventive services in older adults. These elements are summarized in Table 8.

Table 8 Summary of Key Shared Decisionmaking Definitions^*^

Essential Elements | Ideal Elements | General Qualities
Define/explain problem | Presentation of unbiased information | Deliberation/negotiation
Present options | Reach mutual agreement | Flexibility/individualized approach
Discuss benefits, risks, costs | Present evidence | Information exchange
Explication of patient values/preferences | Define roles (desire for involvement) | Involves at least two people Middle ground
Discuss patient ability/self-efficacy | | Mutual respect
Presentation of doctor knowledge/recommendation | | Partnership Patient education
Check/clarify understanding | | Patient participation
Assess level of uncertainty in decision or decisional conflict | | Process/stages
Make or explicitly defer decision
Ensure decision is congruent with patient’s values and goals | | Patient participation
Arrange followup

* Based on Makoul and Clayman106 and the Ottawa Decision Support Framework30.

The Ottawa Decision Support Framework, available at http://decisionaid.ohri.ca/odsf.html, provides a description of the shared decisionmaking process and relevant outcome measures, and expands the process to include a role for health care professionals beyond the patient-physician dyad.30 The Ottawa Decision Support Framework suggests that during the shared decisionmaking process, practitioners must assess the patient’s decisional needs and decision quality and provide decision support. Decisional needs include decisional conflict (uncertainty about the course of action to take when choice among options involves risk, loss, regret, challenge to personal life or values), knowledge of the health condition, expectations of the treatment outcomes, values, support, and resources. A patient’s decisional needs will affect decision quality. The goal is to reach a high-quality decision, one that is informed with the best evidence and based on the patient’s values. When assessing decision support, the practitioner provides facts about the treatment choices and probabilities associated with treatment outcomes and clarifies the patient’s decisions, needs, and values. Decision support can be provided with clinical counseling, decision aids, and coaching. Additionally, the practitioner must monitor and facilitate progress of the patient’s final decision.

Outcomes of shared decisionmaking. Shared decisionmaking interventions need to measure relevant outcomes. Good outcomes related to decisional needs include improved knowledge, improved realistic expectations of outcomes, including benefits and harms, improved certainty of choice, improved feelings of being informed, improved feelings of being clear about values, and decreased decisional conflict. Decision quality outcomes include consistency between eligible patient treatment uptake rates and the underlying distribution of patient’s informed values.

Intervention studies. We found two articles on shared decisionmaking interventions for secondary preventive services for older adults. These studies looked at prostate-specific antigen (PSA) screening for prostate cancer26 and colorectal cancer screening.27 Each intervention took a different approach to shared decisionmaking, contained different elements of shared decisionmaking, and had different outcome measures. See Table 9 for a summary of the shared decisionmaking elements included in the interventions. See Table 10 for a summary evidence table of included studies.

Table 9 Shared Decisionmaking Elements Included in Intervention Studies

Decisionmaking Element | Frosch et al, 2001^26^ | Pignone et al, 1999^27^
Essential Elements
Define/explain problem | Present | Present
Present options | Present | Present
Discuss benefits, risks, costs | Present | Present
Patient values/preferences | Present | Present (participants asked why they preferred the option they selected)
Discuss patient ability/self-efficacy | Present | Not present
Doctor knowledge/recommendation | Not present, performed by research assistant | Not present, performed by research assistant
Check/clarify understanding | | Present
Assess level of decisional conflict
Make or explicitly defer decision
Ensure decision is congruent with patient’s values and goals
Arrange followup
Ideal Elements
Unbiased information | Present
Mutual agreement
Present evidence | Present | Present
Define roles (desire for involvement) | Present
General Qualities
Deliberation/negotiation
Flexibility/individualized approach
Information exchange | Present | Present
Involves at least two people | Present | Present
Middle ground
Mutual respect
Partnership
Patient education | Present | Present
Patient participation | Present | Present
Decision Aids
| None used | Simple flip charts on risk, benefit

Table 10 Summary Evidence Table for Literature on Shared Decisionmaking

First Author, Year, Study Location | Relevant Study Aim | Sample | Age | Design/Methods/Models | Relevant Measures
Cancer Screening
Frosch, 2001^26^ United States | Evaluate the most effective means to present information and guidance about PSA testing to patients | N=176 Men from the Health Appraisal Screening Program in the Department of Preventive Medicine | ≥50 yrs | Intervention 2x2 factorial comparison of discussion and video formats; questionnaire Logistic regression | Participant ratings of interventions; concern about prostate cancer; personal or family/friend history of cancer; participant opinion of who should choose medical treatments for patients: doctor only, patient only, or both; whether participant requested a PSA test; participant confidence in personal decision about PSA testing
Pignone, 1999^27^ United States | Measure patient preferences for various screening methods | N=148 No previous history of colon cancer; 58% female; 52% white; 43% black; 53% had not completed high school | Range: 50–75 yrs | Survey | Participant preference for colorectal cancer screening method (before and after information was given); reasons for preference; perception of personal risk for colorectal cancer; perception of seriousness of colorectal cancer as a disease; personal or friend/family experience with colorectal cancer; past discussion of colorectal cancer screening
Cardiovascular Disease Prevention
Galesic, 2009^107^ Germany | Explore the efficacy of icon arrays in explaining medical risk, and whether they affect perceptions of risks and benefits of treatment | Sample 1: N=59 49% female; 57% high school or lower education; 43% college education Sample 2: N=112 57% female | Sample 1: range, 62–77 yrs 49% 62–69 yrs 51% 70–77 yrs Sample 2: range, 26–35 yrs 63% 18–25 yrs 37% 26–35 yrs | Icon arrays questionnaire | Accuracy of risk understanding; accuracy of understanding of screening benefits
Kehler, 2008^108^ Denmark | Explore and analyze the experiences of preventive consultations in patients at high cardiovascular risk | N=12 Patients at increased risk for cardiovascular disease; 83% male | Mean age: >57.8 yrs | Individual, semi-structured interview conducted within 2 weeks of preventive consultation Grounded theory | Participant experiences and expectations following preventive consultation regarding cardiovascular disease
General
Greenlund, 2000^109^ United States | Explore whether provider prevention orientation influences women’s preventive practices | N=119 Female primary care patients; Washington; HMO; naive and previously screened, 88% white; 91% high school graduates | Range: 50–80 yrs 60% ≥60 yrs 31% ≥70 yrs | Telephone survey Quantitative Empirical basis | Provider encouragement and engagement; physical activity; postmenopausal hormone use; fecal occult blood test; flexible sigmoidoscopy

Abbreviations: HMO = health maintenance organization; PSA = prostate-specific antigen; yrs = years.

Study 1. Frosch et al26 compared the influence of usual care and three different shared decisionmaking interventions on men’s decision to undergo PSA screening for prostate cancer. The three shared decisionmaking interventions involved: 1) attending a 30-minute lecture and discussion about the risks and benefits of PSA screening, 2) watching a shared decisionmaking video, and 3) watching the video and attending the lecture and discussion. While the shared decisionmaking interventions all used a different format, the same elements were included in each intervention (i.e., define/explain problem; present screening options; discuss benefits, risks, and costs; and assess patient values and preferences). The type of shared decisionmaking intervention influenced older men’s decisions to receive PSA testing. The percentage of men selecting to have subsequent PSA screening was 97.7 percent in the usual care group, 82.2 percent in the lecture and discussion group, 60 percent in the video group, and 50 percent in the video and lecture/discussion group. Older men attending both the video and lecture/discussion session had the highest prostate cancer knowledge scores.26 The study findings also indicate that older men want to engage in shared decisionmaking with health care providers.

Compared to participants in the usual care group, participants in any of the shared decisionmaking interventions (video, discussion, or video plus discussion) were less likely to choose PSA screening and had less concern about prostate cancer, higher knowledge scores on PSA screening and prostate cancer, and lower confidence in their decision regarding PSA screening. While it may seem counterintuitive that these men would have lower confidence in their screening decision, the authors of the original article conclude that the shared decisionmaking interventions challenged their pre-existing perception that PSA screening was a simple and definitive way to alleviate concerns about prostate cancer. Instead, the men learned that a positive screening test led to complex decisions about how to proceed with cancer screening. This finding underscores the importance of assessing personal preference when choosing between uncertain outcomes. The men in the shared decisionmaking interventions were also more likely than those in usual care to want to share their decision with their physician (46 percent in usual care group, 54 percent in discussion group, 66 percent in video group, and 70 percent in video plus discussion group). Men in the shared decisionmaking interventions were also more likely than those in the usual care group to say that they would select watchful waiting over surgery or radiation if they were subsequently diagnosed with prostate cancer (35 percent in usual care group, 81 percent in discussion group, 72 percent in video group, and 67 percent in video plus discussion group). In summary, no matter the format of the shared decisionmaking intervention, men who engaged in shared decisionmaking made different choices about PSA screening, had higher knowledge about PSA screening and prostate cancer, were more likely to want to engage in shared decisionmaking with their physician, had less concern about prostate cancer, and would choose different treatment options if they were diagnosed with prostate cancer. This study did not use a physician in the shared decisionmaking intervention, demonstrating that parts of this process can be delegated, especially in situations where there is significant uncertainty in the evidence to support a preventive service.

Study 2. Pignone et al27 conducted a quasi-experimental study to determine if older men change their preference for the type of colorectal screening procedure based on what type of information was presented. The three colorectal cancer screening options included: 1) annual fecal occult blood tests, 2) flexible sigmoidoscopy every 5 years, or 3) annual fecal occult blood tests with flexible sigmoidoscopy every 5 years. The first stage of information described the different test procedures, the second described the test performance, and the third discussed hypothetical out-of- pocket costs associated with each testing option. The percentage of participants selecting the fecal occult blood test after stage 1 was 45 percent, after stage 2 was 36 percent, and after stage 3 was 53 percent. The percentage of participants selecting the fecal occult blood test and flexible sigmoidoscopy after stage 1 was 38 percent, after stage 2 was 47 percent, and after stage 3 was 31 percent. The patients’ choice of which screening option to select changed based on the type of information they were provided. When they were provided with information about the test procedure, most preferred the fecal occult blood test alone. When they received information about the test performance (efficacy at detecting colorectal cancer), most preferred the fecal occult blood test combined with flexible sigmoidoscopy. However, when presented with cost data, most went back to preferring fecal occult blood test screening alone.

When older men are presented with efficacy and cost information for colorectal cancer screening choices, cost was a stronger influence on their decision. Items not affecting the screening choice included knowing someone close to you that had colorectal cancer, perception of risk, concern about the seriousness of colorectal cancer, education, race, age, or insurance status. The reasons for making their choices were also identified. Those who preferred to have both tests cited increased effectiveness at detecting colorectal cancer. Those preferring the fecal occult blood test alone indicated that the test was easier to perform, could be done alone, and was less expensive. Those preferring flexible sigmoidoscopy indicated that it was easier to perform and viewed it as a more effective test. Receiving knowledge about the risks and benefits of colorectal cancer screening increased the participant’s desire to receive screening. This intervention focused on increasing patient knowledge about the risks for colorectal cancer, benefits of screening, and describing the screening options, their efficacy, and cost. The information was provided by a research assistant and there was no followup on actual screening behavior.

In summary, very few intervention studies focus on shared decisionmaking as it relates to preventive health services for older people. There is nothing in the literature to indicate that older adults have a different level of interest in engaging in shared decisionmaking. Even though neither study included all the essential elements of shared decisionmaking, the interventions were able to influence patient decisions. Both studies used research assistants to implement the interventions, suggesting shared decisionmaking can be provided by someone other than the physician and still influence choices. The outcome measures focused on improving knowledge about the disease being screened, the benefits and risks associated with the screening procedure, and concern about developing the disease. Missing were outcomes related to decision quality (i.e., decisional conflict and congruency of patients’ decisions with their values). Another important outcome omission was the lack of followup on actual screening behavior.

Older people’s preferences for and experiences with shared decisionmaking encounters. A few articles described older adults’ preferred role in shared decisionmaking. In a telephone survey of 200 women ages 65 years and older about screening mammography decisions, around half of the respondents indicated that they wanted to make the final decision about screening mammography (ages 65–79 years: 50.5 percent; ages ≥80 years: 46.6 percent), and the rest were equally split among wanting to make a shared decision (ages 65–79 years: 28 percent; ages ≥80 years: 21.4 percent) and wanting the doctor to make the final decision (ages 65–79 years: 21.5 percent; ages ≥80 years: 32.0 percent).36

Seventy percent of the older men engaged in a clinical trial comparing different shared decisionmaking approaches for PSA screening felt positive about participating in the shared decisionmaking interventions. The shared decisionmaking interventions also influenced older men’s desire to share their PSA screening decision with their primary care provider. Those in the shared decisionmaking group were more likely to want to share their screening decision with their physician than those in the usual care group.26

Older adults at high risk for cardiovascular disease who completed a consultation containing elements of shared decisionmaking reported a change in emotions, thoughts, perceived knowledge related to health and risk, and readiness to change their lifestyle.108 These participants indicated that the physician’s professional competence, communication, and the doctor-patient relationship contributed to having a positive experience during the consultation. They also indicated that the consultation could have been improved by increasing the number of opportunities to contribute their personal perspectives to the consultation, having more time for the consultation, and tailoring the information to their personal situation.108

Other insights. The literature identified for this review offers some insights into how clinicians should engage in shared decisionmaking regarding clinical preventive services. Table 11 provides a brief summary. Specifically, older adults in the study reported that life expectancy is not an important factor in their decision and would prefer to not discuss life expectancy with their provider.10

Table 11 Patient Preferences and Perceptions of Decisionmaking

Prevention Action | Factor/Source of information
Flu vaccination | - Individual prompt from general practitioner was the most significant motivator.6; - Those who had not been vaccinated reported that their physician did not recommend it.7
Pneumococcal vaccination | - Those who had not been vaccinated reported that their physician did not recommend it.7
Physical activity | - Provider encouragement of preventive measures correlated with women’s report of regular physical activity.109
Mammography screening | - Physician recommendation, but not family history, predicted screening.11; - Those aged 65 years or older were more likely than those aged 49–64 to be skeptical of medical recommendations.24; - 60% reported that a physician’s recommendation was essential or very important in their decision to get mammography screening.36; - 16% said that a family member’s recommendation was essential/very important.36; - 17% reported that a friend’s recommendation was essential/very important, but 31% reported that a friend’s experience with breast cancer was essential/very important.36
Colorectal cancer screening | - Reported little or no information from physicians (although important source) or mass media.9; - Reputation (bad) of the tests.13; - The likelihood of having had fecal occult blood test or sigmoidoscopy examination was related to provider encouragement for those procedures, but not related to greater encouragement for other preventive measures.109; - Age was positively associated with provider encouragement for flexible sigmoidoscopy. 109
General cancer screening | - 62% believed their own life expectancy was not important for decisionmaking.10; - 48% preferred not to discuss life expectancy. There was no difference between those younger than 85 and those 85 and older. There was no difference between those that previously had cancer and those that did not.10

Second, older adults may need to be provided with more information about the screening process and the benefits and risks associated with it. In particular, older adults need to know the benefits and risks for people of their specific age group. Evidence suggests that some older adults have little knowledge about colorectal cancer,9 the benefits of screening for it,9 and what the screening procedure entails.13

Finally, health care provider encouragement seems to play a part in patients’ decisions to engage in both primary and secondary preventive services. The likelihood of receiving an influenza vaccination shot,6,7 mammography,11 or screening for colorectal9,13,109 or prostate cancer37 is related to health care provider encouragement and prompts. Interestingly, health care providers’ general prevention orientation may also play a role, especially when it comes to primary, complex behaviors. Among women reporting provider encouragement for physical activity, those who had providers who encouraged additional preventive behaviors were more likely to engage in regular physical activity than women who reported no additional provider encouragement.109 However, conflicting evidence indicates that older patients do not necessarily adopt provider encouragement and opinions. Adult women aged 65 years and older are more skeptical than younger age groups of breast cancer screening recommendations,24 and older adults interviewed by Lewis et al reported that they would consider cancer screening even if their physician recommended against it.10

In summary, older people appear to respond favorably to shared decisionmaking interventions, and participation in shared decisionmaking interventions increased older people’s awareness of the opportunity to share their decision with their care providers. Interventions with just a few shared decisionmaking elements can change older people’s knowledge on disease, risk perception, and motivation to engage in behavior change. Older people may prefer more time in the encounter to discuss their individual circumstances to provide a tailored recommendation. There are no studies investigating the influence caregivers or family members may have on an older person’s desired role in shared decisionmaking.

## Issues of Shared Decisionmaking

As in Chapter 2, this section is intended to expand conceptual understanding of shared decisionmaking, and to examine possible conceptual frameworks. The discussion is not meant to be exhaustive. Our goal is to stimulate curiosity about the larger context of values and decisionmaking, introduce important concepts, and raise questions regarding the limitations of some commonly held views.

### Typology of Shared Decisionmaking

Not every clinical encounter needs to involve shared decisionmaking. The USPSTF “believes that clinicians generally have no obligation to initiate discussion about services that have either no benefit or net harm.”110 However, the USPSTF encourages clinicians to engage in shared decisionmaking for “preventive services for which the balance of potential benefits and harms is a close call, or for which the evidence is insufficient to guide a decision for or against screening.”110 Whitney et al4 argue that the degree to which patients’ preferences are considered and their role in the decisionmaking process is determined by the type and number of treatment options available for a given health situation. Health care providers need to recognize this distinction and take different approaches to engaging patients in medical decisionmaking. Some medical decisions have only one reasonable treatment option, while others offer two or more reasonable choices.

Whitney et al4 proposed a typology for medical decisionmaking based on the type of decisions available. The four types of decisions health care providers can facilitate include: 1) clinician directed, 2) patient controlled, 3) clinician controlled, and 4) shared decisionmaking. The first three involve situations where only one reasonable treatment choice is available. For example, the only reasonable treatment for a melanoma tumor is excision, and it would be unwise for the patient to reject this treatment, given the benefits of excision far outweigh the future potential of harm. In cases where there is only one reasonable treatment option, decisional priority is generally held by the clinician. When a patient listens, asks questions, understands, and agrees with the clinician’s decision, the interaction is agreeable, even though the decision was directed by the clinician. In this situation patients can make an unwise decision by refusing the recommended treatment or by insisting on a useless intervention. In this instance, the interaction is unilateral and the decision is controlled by the patient. In the case where a clinician insists on his or her recommendation (e.g., if the physician refuses to prescribe an antibiotic for a viral infection), the interaction is unilateral and clinician controlled. Only when there are two or more reasonable treatment options can shared decisionmaking occur, in which decisional priority is shared, the interaction is collaborative, and the patient takes an active role in the process. Table 12 summarizes this proposed typology and terminology of medical decisions.

Table 12 Proposed Typology and Terminology of Medical Decisions

Number of Choices | Preference Sensitive | Process | | | Outcome
Number of Choices | Preference Sensitive | Decisional Priority | Patient Role | Interaction | Type of Decision
1 | No | Usually clinician | Listen, ask questions, understand, and agree | Agreeable | Clinician directed
1 | No | Usually patient | Insist on disfavored alternative (including nontreatment) | Unilateral | Patient controlled
1 | No | Usually clinician | Object (unsuccessfully) to plan | Unilateral | Clinician controlled
2 or more | Yes | Usually patient | Active or shared | Collaborative | Shared

It should be noted that the number of choices can itself be an issue of perception. To some people, no treatment is always an option. Regarding preventive services, all services would fall into the category of two or more potential choices.

### Risk Perception in Shared Decisionmaking

Risk and benefit information are often presented numerically in a shared decisionmaking context, yet most people have a poor understanding of probability, causation, and risk.111 People with different levels of numeracy may benefit from different risk communication methods.112 Adults aged 60 years and older were found to have significantly lower ability to correctly read numbers from graphs and lower ability to identify the essential point of the risk information presented than younger adults.113 Presenting information using natural frequencies, or counts of occurrences that preserve the base rate, has been found to improve older adults’ understanding of medical screening information.107 However, 44 percent of older adults with low numeracy skills were unable to accurately complete the task; the proportion improved to 14 percent with the inclusion of icon arrays.107 Icon arrays, which display natural frequencies using visual arrays, have been shown to produce adequate knowledge across numeracy levels.113 However, participants across all levels of numeracy rated tables as the most effective, trustworthy, and scientific visual display.113 Thus, there is still a need for better tools and guidance from providers to help older adults develop accurate knowledge of risks.

### The Provider and Shared Decisionmaking

There are also two major concerns regarding the provider’s role in shared decisionmaking that deserve consideration. The first concern involves the potential unexamined assumptions and biases that a provider may bring to a shared decisionmaking event. Epstein and Peters114 quote Thaler and Sunstein’s “libertarian paternalism” as the current ethos guiding public health policy.115 Libertarian paternalism is a paternalism that does not require coercion, but instead suggests that leaders should influence patients’ preferences to achieve desired goals, while leaving the ultimate choice to the individual. The shadow of this ethos is seen in the literature as the assumption that once the patient understands what the researcher or provider knows about the health benefits and risks of preventive services, then collaborative decisionmaking will lead to a consensus agreement that will necessarily be the “right” decision. Bioethics does not require that patients make “good” decisions; it simply requires that they receive adequate and comprehensible information to satisfy informed consent in order to make an uncoerced decision.116 Leaving aside the question of whether or not such decisions are the “right” ones, fairness would suggest that providers involved in shared decisionmaking should be as aware of their own assumptions, biases, previous experiences, and strengths and foibles as is expected of the patient.

The second major concern is also related to unexamined assumptions. The stated purpose of shared decisionmaking is to empower patients to participate in the decisionmaking process, in this case regarding preventive services. The first decision patients need to make is to what extent they wish to engage in shared decisionmaking. Some studies report that older adults are more likely to delegate decisionmaking to the physician.117,118 Physician-patient covenants119 and the obligation of nonabandonment of the patient by the physician120 make the case that the patient’s preference to participate in choosing a preventive service course, or alternatively, preferring to delegate such choice to the physician, is a viable preference. Providers need to examine their own motivations regarding shared decisionmaking and assure themselves that the motivation does not stem from the desire to shift the burden of dealing with the uncertainties of health care decisions onto the patient.

Theories of medical decisionmaking are evolving and the current emphasis is on empowering patient involvement through shared decisionmaking. While this idea has strong face validity and is congruent with optimizing patient autonomy, there is little empirical evidence to guide its implementation as it relates to preventive services for older adults. There appears to be agreement that shared decisionmaking does not need to occur in all clinical encounters. It is most appropriate to use when there is more than one reasonable treatment option or when there is considerable uncertainty about the strength of evidence for a given screening option (as is the case with PSA screening). Challenges with implementing shared decisionmaking arise from a lack of consensus on what elements should be included in the process, on relevant outcome measures, when to incorporate decision aids, and when shared decisionmaking should expand beyond the patient-physician dyad to include other health care professionals or be offered at the population level through public health promotions.121 Other concerns include how to adequately represent risk to older adults in ways that develop accurate knowledge, and the provider’s role in shared decisionmaking.