# Values, Attitudes, and Preferences

## Review of the Empirical Literature

Overall, we identified only 28 studies related to older people’s perceived benefits and harms of preventive services and their decisional balance. Almost all articles documented studies that were not specifically designed to answer this review’s key questions; however, they did provide information that offered some insights into the questions. These studies largely used qualitative or descriptive analysis methods with small purposive samples. Table 1 provides details on the included studies.

Table 1 Summary Evidence Table for Literature on Values, Attitudes, and Preferences

First Author, Year, Study Location | Relevant Study Aim | Sample | Age | Design/Methods/Models | Relevant Measures
Vaccinations
Cornford, 1999^5^ United Kingdom | Examine beliefs about influenza vaccination in at-risk older patients | N=50 Vaccinated and not vaccinated in previous year; 70% female; generally low to middle class suburban residents | Mean age: 81 yrs; range, ≥75 yrs | Semi-structured interviews Lay perspective | Beliefs about influenza vaccination; “what is health?”; and self-assessed health status
Santibanez, 2002^7^ United States | Identify knowledge, attitudes, and beliefs that facilitate or are barriers to influenza or pneumococcal vaccination | N=1,007 English or Spanish speaking; western or central Pennsylvania; cognitive impairment, primary care patients; 95% white; 57% lower income; 90% less than college graduates | Mean age: 74.6 yrs; range, ≥66 yrs | Computer-assisted telephone interviews Theory of Reasoned Action (Triandis model) | Beliefs about prevention of influenza and pneumonia; attitudes toward vaccination; knowledge of pneumonia vaccination; attitudes toward simultaneous influenza and pneumonia vaccination
Evans, 2007^6^ United Kingdom | Investigate lay beliefs about influenza and influenza vaccination in older people | N=54 Random sample of survey responders; South Wales | Age range: ≥65 yrs | Narrative interviews Lay perspective | Beliefs about influenza immunization; perceived risk; self-assessed health status
Physical Activity
Courneya, 1995^20^ Canada | Examine stage of readiness for physical activity | N=288 Members of community center; 62% female; 69% high school graduates | Mean age: 71 yrs; range, ≥60 yrs | Survey^*^ | Bipolar adjective scales (i.e., beneficial/harmful)
Estabrooks, 1999^21^ Canada | Examine relationship of group cohesion to attitude toward exercise | N=179 Volunteers from the Centre for Activity and Aging; 73% female | Mean age: 67 yrs; range, ≥65 yrs | Survey | Bipolar adjective scales (i.e., beneficial/harmful)
Gretebeck, 2007^22^ United States | Assess intention and self-reported physical activity | N=1,141 Retirees of midwest university receiving health benefits; 54% female | Mean age: 76 yrs; range, 65–98 yrs | Survey | Bipolar adjective scales (i.e., harmful/beneficial)
Horne, 2009^34^ United Kingdom | Identify beliefs that influence uptake and adherence to exercise for falls prevention | Focus Groups: N=87 Interviews: N=40 36% South Asian; 64% female | [underlined: Focus Groups] Mean age: 65.7 yrs; range, 60–70 yrs [underlined: Interviews] Mean age: 64.8 yrs; range, 60–70 yrs | Focus groups and interviews | Beliefs that influence uptake of exercise for falls prevention; history of falls
Lucidi, 2006^23^ Italy | Assess factors predicting physical activity attendance | N=1,095 Italy; exercise class members | Mean age: 69 yrs; range, 65–90 yrs | Survey | Bipolar adjective scales (i.e., beneficial/harmful)
Weeks, 2008^35^ Canada | Identify overarching factors that influence participation in physical activity among seniors | N=24 English or French speaking; ambulatory outside home; community-based organizations; 82% female; 88% high school graduates | Age range: ≥64 yrs 42% 64–74 yrs 29% 75–84 yrs 17% ≥85 yrs | Structured interviews Thematic analysis Life course perspective | Barriers; facilitators; perceptions of physical activity; current activity level
Breast Cancer
Black, 2001^11^ Canada | Explore contribution of self-concepts to older women’s adherence to mammography screening behavior | N=210 Women; modal education college; modal income $40-$60K; 98% white; recruited from social or religious groups | Mean age: 67 yrs; range, 50–75 yrs 40% ≥69 yrs | Self-administered questionnaire/Quantitative PRECEDE Model (Green 1991) Health Belief Model Self Theory (Markus 1986) | Self-concept/possible selves; reinforcing factors; enabling factors; adherence to recommended screening guidelines
Borrayo, 2001^12^ United States | Understand how cultural beliefs about breast cancer influence screening behavior | N=34 Women of Mexican descent; Dallas and Fort Worth, Texas; 44% high school graduates; 50% below federal poverty line | Mean age: 62 yrs; range, 49–81 yrs | Qualitative Focus group interviews (open-ended) Grounded theory | Beliefs about causes/nature of breast cancer; breast screening habits
Katapodi, 2009^14^ United States | Describe perceived breast cancer risk and inaccurate risk perceptions | N=184 Women; West Coast metro area; never had cancer; 57% nonwhite; 32% earn >$40K; 92% high school graduates | Mean age: 47 yrs; range, 30–84 yrs 33% 50–69 yrs 6% 70–85 yrs | Telephone questionnaire/ quantitative Precaution adoption model (optimism bias) Social learning | Comparative perceived risk; verbal (i.e., absolute) perceived risk; objective risk; screening behavior
LaPelle, 2008^24^ United States | Explore rationales used by women overdue for breast cancer screening, and relate rationales to stages of readiness | N=22 Primary care patients; East Coast; no mammography in past 27 months; 85% white; 67% high school graduates | Mean age: 61.5 yrs; range, 45–77 yrs Stratified by age (49–54, 55–64, 65–77) | Scripted interviews and surveys, administered in focus groups or via telephone depending on participant preference; focus groups answered personal questions during followup call Grounded theory Precaution adoption model (social learning, stage-based) | Attitudes toward mammography, breast cancer, and medical recommendations
Schonberg, 2007^36^ United States | Examine factors influencing older women’s mammography screening decisions | N=200 Academic primary care clinic patients; English speaking; 66% white; 84% high school graduates | Age range: ≥65 yrs Stratified by age (65–79, ≥80) | Telephone survey | Factors influencing decision to get screened; screening history
Colorectal Cancer
Beeker, 2000^9^ United States | Identify older adults’ attitudes, beliefs, and behaviors about colorectal cancer screening | N=14 Focus groups; 10–11 people per group; urban Kansas, Georgia, or Pennsylvania; private insurance or Medicare; naive and screened | Age range: ≥50 yrs Stratified by age (50–64, ≥65) and gender | Focus groups Behavioral science theory | Knowledge, attitudes, and beliefs about colorectal cancer and screening
Chapple, 2008^8^ United Kingdom | Examine factors affecting uptake of fecal occult blood test screening | N=44 White; 50% female | Age range: ≥58 yrs 68% ≥65 yrs | Interviews | Reasons for not bring screened for colorectal cancer
Feeley, 2009^13^ United States | Identify barriers and facilitators for colorectal cancer screening | N=103 New York; primary care patients of large managed care organization; most previously screened; 95% white; 70% earn <$35K; 96% high school graduates | Mean age: 63 yrs | Focus groups Self-efficacy theory | Attitudes toward colorectal cancer screening
Hay, 2006^15^ United States | Examine relationship between colon cancer beliefs and perceived risk; assess predictors of comparative + absolute risk perception | N=2,949 HINTS survey (national probability survey) | Mean age: 64 yrs; range, 45–74 yrs 32.3% 65–≥75 yrs | Survey Quantitative | Perceived comparative risk; perceived absolute risk
van Dam, 2010^25^ Netherlands | Assess how procedural characteristics of colorectal cancer screening determine preferences, and how they are weighed against benefits | N=710 Population registry; Netherlands; naive and screened | Mean age: 61 yrs; range, 50–75 yrs | Survey Discrete choice experiment | Preference for scenario: screening pain, risk of complications, screening location, preparation, duration of procedure, screening interval, risk reduction of cancer-related death
von Wagner, 2009^17^ United Kingdom | Examine information needs and patient preferences for CT colonography vs. colonoscopy | N=26 Asymptomatic volunteers from general population; 38% female; predominately white; 80% university degree | Mean age: 64 yrs | Focus groups | Risks and side effects
Prostate Cancer
Oliffe, 2006^37^ Australia | Describe patients’ perspectives of being screened and subsequently diagnosed with prostate cancer | N=35 Anglo-Australian men | Age range: 46–87 yrs | Qualitative design using ethnographic in-depth, semi-structured interviews, participant observation | Patient experiences with screening and diagnosis of prostate cancer
Cancer (General)
Benyamini, 2003^38^ United States | Assess extent to which having cancer affects perceptions of and reactions to current symptoms/diseases in older adults | N=108 Community-based older people; predominantly white, affluent, and well educated (Rutgers aging and health study) | Mean age:77–78 yrs | Interviews Common sense approach to illness model (Leventhal) | Vicarious experience with cancer; direct experience with cancer; health perceptions; health behaviors; reactions to arthritis
Dassow, 2005^39^ United States | Measure women’s screening beliefs about colon cancer, breast cancer, and osteoporosis | N=125 Women; primary care patients; practice-based research network (Kentucky); 94% white; 71% high school graduates | Mean age: 65 yrs; range, ≥52 yrs | Mail survey/quantitative (32% response rate) | Beliefs about colon cancer, breast cancer, and osteoporosis severity and susceptibility; ability to obtain screening (self-efficacy); screening behavior
Glasgow, 2000^18^ United States | Examine relationships among barriers to breast and Pap screening services | N=522 Women; HMO patients; Portland, Oregon; no screening within last 2–3 yrs; 60% any college; 81% white | Mean age: 60 yrs; range, 52–69 yrs | Survey/quantitative Empirical basis (social cognition) | Barriers to mammography and Pap screening
Han, 2006^16^ United States | Examine how perceived ambiguity about cancer prevention recommendations relates to perceived preventability, cancer risk, and cancer-related worry | N=3,375 No history of cancer (HINTS survey) | Age range: ≥40 yrs Stratified by age 18.1% 60–69 yrs 15.8% ≥70 yrs | Survey interviews/quantitative Decision theory (ambiguity) | Perceived preventability of cancer; perceived cancer risk; cancer-related worry; perceived ambiguity of cancer prevention recommendations
Lewis, 2006^10^ United States | Assess older adults’ perspectives about continuing cancer screening later in life | N=116 Community based; North Carolina; low barriers to health care; 100% white; 78% female; 83% college graduates (100% high school) | Mean age: 81.6 yrs; range, 70–96 yrs | Interviews Informed decisionmaking criteria (Braddock) | Attitudes toward cancer screening; attitudes toward continuing cancer screening later in life
Rutten, 2009^40^ United States | Compare state-of-science evidence for colon, skin, and lung cancer with public perceptions | N=5,586 (HINTS survey) | Age range: ≥18 yrs Stratified by age | Interview survey | Beliefs about prevention, detection, and survival for lung, colon, and skin cancer
Dementia
Boustani, 2008^19^ United States | Measure primary care patients’ attitudes about dementia screening | N=315 Convenience samples; clinic patients; English speaking; no dementia or mental illness; Indiana, North Carolina; 70% female; 44% black; 39% high school graduates | Mean age: 72.8 yrs; range, ≥65 yrs | Questionnaire Exploratory factor analysis | Attitudes toward dementia screening

* Note: There were issues with the response rate.

Abbreviations: CT = computed tomography; HMO = health maintenance organization; HINTS = Health Information National Trends Survey; yrs = years.

Though initial searches yielded thousands of articles, few matched our criteria, and fewer still directly targeted the questions of interest. The majority of the citations located during preliminary searches were discarded because the minimum age of the study population was set much lower than 65 years, generally because the study target was the preventive behavior and not the population (e.g., women aged 40 years and older for breast cancer screening). Moreover, when study populations contained some individuals aged 65 years and over, older adults were often not adequately represented or distinctions between younger and older participants were not made. The studies that remained addressed populations that were generally white, educated, female, and had a higher income. However, even with the thousands of articles that were screened, there will be many thousands more that were missed due to the inability to build a search algorithm that efficiently captures the literature. This set of 28 studies should be considered at best a sampling of what may be available in the literature.

The articles discussed in this report come largely from the health psychology and decision analysis literature. There is little overlap between these two areas in the identified articles. Articles from the health psychology literature focus largely on identifying the perceived benefits, risks, and psychological harms of various preventive behaviors but do not examine people’s overall preferences or decisions. Though some of the identified studies and their hypotheses were derived from psychological theories, such as the health belief model or the theory of planned behavior, many of the studies were atheoretical or exploratory. Moreover, shared decisionmaking was largely neglected in this portion of the literature. Conversely, the identified decision analysis literature focused largely on stated preferences, discrete choices, and probability tradeoffs related to the clinical benefits, harms, and various aspects of “cost” associated with preventive behaviors. This body of work also explores how individuals weigh various aspects of a behavior and how these weights influence decisionmaking. Relative to the health psychology literature, discussion of shared decisionmaking was more prominent in this body of literature. Thus, the health psychology and decision analysis literatures focused on divergent aspects of older adults’ valuation of preventive services and behaviors. While these two literatures remained distinct in the identified sources, they collectively provide a necessary and more nuanced depiction of older adults’ valuation of preventive behaviors and services.

This literature set can only be considered a sampling of articles that may contain information regarding perceived benefits, risks, harms, or other factors that may contribute to the formation of preferences. Such concepts are often examined within a multitude of health behavior topics but are not aggregated as such. What is clear from the literature is the lack of focused attention on the specific topic of older adults’ perceptions of preventive care, particularly those adults within the oldest-old age categories.

Another issue is disease focus. If the sample patients were older, articles were often about disease treatment. If the literature dealt with prevention, samples were often composed of patients aged 40 to 64 years, as this is the age group that is typically targeted by preventive services.

Given all of the above, the reader is cautioned to avoid drawing sweeping conclusions from this literature set.

As mentioned in Chapter 1, primary and secondary prevention differ on a number of dimensions, such as purpose and temporal application. These differences could have implications for the value associated with the behaviors in these categories. Accordingly, we distinguish between primary and secondary preventive behaviors in the discussion of each key question. Though both primary and secondary preventive behaviors are represented in the identified citations, the majority of the articles consider secondary preventive services. Of these, breast cancer and colorectal cancer screening were the most frequently studied. The few primary prevention studies that were identified dealt largely with vaccination or physical activity.

### Key Question 1 How Do Older Adults Value the Potential Benefits of Primary and Secondary Clinical Preventive Services?

Nineteen studies identified the perceived benefits of preventive services and behaviors for influenza vaccinations (three studies), physical activity (two studies), breast cancer screening (four studies), colorectal cancer screening (four studies), general cancer screening (five studies), and dementia screening (one study). Table 1 provides details of the included studies.

Perceived benefits in primary prevention. Information regarding older adults’ perceptions of the benefits of primary preventive behaviors comes from three studies on vaccination: two qualitative studies conducted within the United Kingdom5,6 and one cross-sectional survey conducted within the United States.7 This small literature suggests that the perceived benefits of vaccination are largely related to expected improvements in health state, such as avoiding influenza, and are interpreted differently by those who have and have not been vaccinated. Specifically, those who were vaccinated tended to view vaccination as effective,6 believe that the influenza vaccine will reduce the number and severity of colds and influenza bouts,5,6 and believe that it is the best way to prevent disease.7 Conversely, individuals who had not been vaccinated tended to believe that influenza is best prevented by other means (e.g., healthy lifestyle),7 and focused on the harms perceived to be associated with vaccination (see key question 2).5,6 It should be noted that these studies measured participants’ perception of benefits after the behavior was determined.

Perceived benefits in secondary prevention. The extant literature on benefits associated with secondary preventive services is relatively more diverse, although still very limited and based largely on qualitative studies. The perceived benefits that have been identified tend to focus on both health-state outcomes, such as early detection and decreased likelihood of mortality, and psychological benefit derived from the peace of mind that stems from knowledge of test results and believed absence or reduction of risk for the health problem.

Cancer screening. When considering cancer screening as a general topic, the majority of older adults in one study believed that the benefits of cancer screening are immediate, as evidenced by their disagreement with the statement that cancer screening takes several years to benefit a person.10 They also believed that they would live long enough to accrue benefits of cancer screening.10 It should be noted that participants aged 85 years and older in that study were less likely than their younger counterparts to believe that they would live long enough to benefit from screening.10 Beliefs in this study were measured by survey items. Specific benefits were not defined for participants; rather participants were free to consider any number or type of benefit when responding. For colorectal cancer, screening was viewed in one study from the United Kingdom as a chance to perform a civic duty.8 Another perceived benefit of screening for colorectal cancer is that it permits early diagnosis, which is perceived to be beneficial because the disease is treatable if detected early. However, the authors noted that many participants were unaware of this fact, or that precancerous polyps could be removed as a preventive measure.9 Early detection and decreased odds of mortality have also been identified as a benefit associated with breast cancer screening.11 Specifically, perceiving early detection of breast cancer and lowered odds of mortality as benefits of mammography screening predicted adherence to mammography screening guidelines.11

The literature also suggests that screening may be a means used to avoid the feared possibility of developing cancer. Dassow found that older women perceive colon cancer to be a severe disease and that perceived severity of colon cancer was associated with screening behavior.39 Similarly, Black et al11 found that people who readily brought to mind an image of themselves with a debilitating health condition (e.g., being a stroke victim) and were motivated to avoid this imagined situation were more likely to adhere to screening guidelines.11 Black et al suggest that since mammography screening is a preventive behavior, screening acts as an avenue through which one protects oneself from becoming this feared, unhealthy possible self. The authors also note that having a feared health-related possible self is more likely in younger women. Since there were proportionally more younger women (aged 50 to 69 years) in the sample, the authors suggest that the younger women in the sample may have driven this finding. This finding was not analyzed by age and no statistical tests were run to test this prediction. Thus, caution must be exercised when generalizing the results to all age groups.

Dementia screening. Older adults also derive psychological benefit from dementia screening because they report a desire to know of any developing mental health problems.19 Older adults also view early detection of Alzheimer’s disease as beneficial because it allows time to make financial, legal, and health care plans if necessary.19

Germane to the topic of benefits is perceived risk. Preventive services are valued because they aim to prevent, or reduce the impact of, a health problem. Accordingly, value cannot be associated with a preventive service if there is no risk for developing the health problem. Perceived risk is defined as one’s perceived likelihood of experiencing the adverse state in question. We incorporated details on perceived risk into key question 1 because perceived risk can be conceptualized as the likelihood of achieving the benefit associated with the preventive behavior (i.e., avoiding an adverse health state).

Table 2 Older Adults’ Perceptions of Benefits and Risks of Preventive Actions Reported in Studies

Prevention Action | Older Adults’ Perceived Benefits and Risks
Flu vaccination | [underlined: Perceived Benefits]; - Reduced number and severity of colds and influenza-like illnesses.5; - Vaccinated individuals were more likely to perceive vaccination as the best way to prevent the disease.7; - Immunized individuals were more likely to perceive vaccine as effective.6; [underlined: Perceived Risks]; - Few considered themselves at risk, due to independent and active engagement self-assessed health status, regardless of vaccination status.5; - Vaccination side effects were interpreted differently between vaccinated and non-vaccinated individuals.5; - Unvaccinated individuals believed they were at low risk for the disease.7; - Few considered themselves at risk, due to good health status, diligent self-care, and good nutrition.6; - Considered recommendations for vaccination based on age to be ageist attitude.6
Pneumococcal vaccination | [underlined: Perceived Benefits]; - Vaccinated individuals were more likely to perceive vaccination as the best way to prevent the disease.7; [underlined: Perceived Risks]; - Unvaccinated individuals believed they were at low risk for the disease.7
Physical activity | [underlined: Perceived Risks]; - Rarely acknowledged risk for falling.34; - Associated falling with older people.34; - Those who had fallen were more likely to acknowledge risk for future falls.34
Mammography screening | [underlined: Perceived Benefits]; - Feared health-related possible self and perceived self-efficacy in that fear domain predicted screening^*^.11; [underlined: Perceived Risks]; - Did not see a need for screening if one feels healthy.12; - Age inversely predicted perceived comparative risk for developing breast cancer, but not absolute risk perception.14
Colorectal cancer screening | [underlined: Perceived Benefits]; - Generally believed that colorectal cancer is treatable if found early.9; - Fulfilling civic duty.8; - Perceived severity related to colon cancer screening^**^.39; [underlined: Perceived Risks]; - Did not feel at risk because they felt healthy.8; - “No reason to go, I’m in good health.”13; - Persons ages 65–74 years were less likely to perceive relative risk than persons ages 45–54 years. No age difference in ability to perceive absolute risk.15; - Perceived susceptibility predicted colon cancer screening.^**,39^
General cancer screening | [underlined: Perceived Benefits]; - 87% believed they will live long enough to accrue screening benefit.10; - 75% believed that the benefit from cancer screening is immediate. Persons ages ≥85 years were more likely than those ages 70–84 years to believe that they would not live long enough to benefit from screening.10; - 81% believed that they would die of a disease other than cancer.10; [underlined: Perceived Risks]; - Cancer and health worries were lowest for vicarious experience (vs. survivors and non-survivors).38; - Monitoring for bodily signs was similar and highest in both cancer experience groups (vicarious and survivors).38; - Worrying was only related to monitoring for those with no experience with cancer.38; - There was more arthritis vigilance among those who had direct or vicarious experience with cancer.38; - There was more vigilance for ambiguous symptoms among those with direct experience with cancer.38; - Self-efficacy predicted breast cancer and bone density screening.^**,39^; - Older age (especially ≥70 years) predicted lower perceived preventability, lower perceived risk, and lower cancer-related worry.16; - Increased perceived preventability reduced ambiguity aversion. Ambiguity aversion increased with cancer worry. Perceived ambiguity about cancer prevention recommendations increased with cancer worry and perceived risk.16
Dementia screening | [underlined: Perceived Benefits]; - Screening beneficial because participants would like to be aware of any developing memory problems and early detection improves treatment and allows for planning.19

* Increasing age correlated with decreasing screening adherence. Perception of susceptibility was significant for ages 50–69 years but not 70–75 years.

** Age not related to screening behaviors.

Perceived risk in primary prevention. The small literature available on older adults’ risk perception and vaccination indicates that, in general, a number of older adults do not believe themselves to be at risk for serious complications associated with influenza, regardless of immunization status. It appears that they do not see themselves as being at risk for dying of influenza,5 of catching influenza,6 or suffering serious complications if they do contract it.6 Similarly, a single study indicated that older adults do not see themselves as being at risk for contracting pneumococcal disease.7 Studies examining the prospective relationship between older adults’ perception of risk for disease and the decision to be vaccinated were not located.

Self-assessed health status is linked to perceived risk in two studies.5,6 Older adults viewed their independent status and active engagement as evidence of good health status,5 and good health,5 diligent self-care,6 and good nutrition habits6 were perceived to reduce risk. Interestingly, Evans et al6 found the perception that health providers demonstrate an ageist attitude with blanket recommendations for vaccination based on age to be a prominent theme.

In terms of the complex primary preventive behavior of exercising to prevent falls, participants of the sole identified study rarely thought that they were at risk for falling and associated falling with older individuals.34 Accordingly, they were generally not motivated to exercise purely to prevent falls. However, past experience did seem to play a role in risk perception. Those who had fallen in the past were more likely to acknowledge the risk for future falls and engage in exercise to prevent falls.34

Perceived risk in secondary prevention. More articles addressed perceived risk than perceived benefits in the literature on secondary prevention. Three articles indicated that participants felt that there was no need to screen for breast cancer if one felt healthy.8,12,13 Over 80 percent of participants in the study by Lewis et al believed that they would die from a disease other than cancer.10

Age appears to be a factor in personal risk perception. Two studies found that older women see themselves as less likely than their peers to develop breast cancer than did women younger than age 70 years.11,14 Similarly, older age cohorts (ages 64 to 75 years) were less likely to perceive personal comparative risk for colon cancer than those younger than age 55 years.15 That is, they believed that they were less likely to develop the disease than their peers of the same age and sex. Similarly, people older than age 70 years were more likely to perceive lower risk for developing cancer when considering absolute risk (i.e., their risk for developing cancer without reference to other individuals).16 Interestingly, age did not appear to be a factor in people’s ability to perceive absolute risk.14,15 However, there was inconsistency in the links between age factors and screening behaviors. One study found that increasing age was correlated with decreasing breast cancer screening,11 while Dassow found no difference in screening behavior by age.39

There were also inconsistent links between perceived susceptibility or risk and screening behaviors. Katapodi et al did not find that comparative risk assessment predicted breast screening behavior.14 However, colon cancer screening behavior was predicted by perceived susceptibility in Dassow’s study.39

The concept of worry is similar to risk. Benyamini et al38 found that worries about cancer and health were lowest among people with a vicarious experience of cancer due to relationships with people diagnosed with cancer, compared to worries held by cancer survivors or people with no relevant experience of cancer. Interestingly, cancer-related worries predicted checking for bodily signs of cancer only in individuals who had never had personal or vicarious experience with the disease,38 which may suggest a possible moderating effect for the relationship between perceived susceptibility and screening behaviors. Han et al16 also found evidence of an age factor here as well, in that older ages, especially those older than age 70 years, predicted lower cancer-related worry.

Valuation of quality of life versus length of life. We attempted to address older adults’ perceptions of benefits more broadly through literature that assessed how older adults view quality of life, length of life, and the decisional balance or potential tradeoff between them. Again, articles that were directly related to preventive services and older adults were rare; only one article was located41 (Table 3).

Table 3 Summary Evidence Table for Literature on Quality of Life Versus Quantity of Life

First Author, Year | Relevant Study Aim | Sample | Age | Design/Methods/Models | Measures | Findings
Chapman, 2001^41^ | Evaluate relationship between time preference scenarios and preventive health behaviors requiring up-front cost for long-term benefit | Hypertension: N=195; 65% female Cholesterol: N=169; 49% female | Hypertension: mean age: 79 yrs; range, 62–97 yrs Cholesterol: mean age: 67 yrs; range, 36–85 yrs | Hypertension: individual structured interviews, chart review Cholesterol: questionnaire, chart review Time tradeoff preferences | Hypertension adherence: self-report, pill count, blood pressure measures Cholesterol adherence: self-report, most recent low-density lipoprotein level | No relationship between time preferences and adherence to medication for hypertension or hypercholesterolemia medication
Chapman, 1998^42^ | Evaluate impersonal and personal time tradeoff scenarios for differences in willingness to trade quality of life for longevity with poor health due to prostate cancer | N=59 Patients with prostate cancer | Mean age: 71 yrs | Questionnaires Time tradeoff preferences | NR | Framing effect; patients using impersonal time tradeoff version were more likely than those using personal version to “order the three health states appropriately” and be “more willing to trade off length of life for quality of life”
Meropol, 2008^43^ | Evaluate the weight cancer patients place on quality of life and length of life | N=459 Patients with advanced cancer | Mean age: 60 yrs; range, 26–89 yrs | Survey | Sociodemographics; physical and mental health states; quality of life/length of life values; communication preferences; cancer-related distress | Older age associated with preference for quality of life vs. length of life

Abbreviations: NR = not reported; yrs = years.

Literature for disease management or treatment is often only peripherally related to prevention services and preventive behaviors since it is grounded in an experience of a known disease. Even further afield is literature for advanced disease stages. However, we included such articles since they can provide some insight into the larger question of how older adults might view the costs, burden, or investment of preventive care efforts and relate them to the possibility of gaining some extension of life length in return. The disease states included prostate cancer42 and general cancer patients.43

Among 459 patients with advanced cancer aged 26 to 89 years (median age, 60 years), 55 percent equally valued quality of life and length of life, 18 percent preferred length of life, and 27 percent preferred quality of life. Higher preference for quality of life was associated with older age (P=0.001).43

Two studies used time tradeoff measures to evaluate preferences.41,42 Time tradeoff measures assume that decisionmaking involves a tradeoff between something now and something later, and that a decision reflects the decisionmaker’s time preferences. When asked hypothetical questions about time preferences, framing effects were found. Prostate cancer patients given the impersonal versions of time tradeoff scenarios were more likely to order three health state scenarios “appropriately,” by degree of dysfunction, and were more willing to trade quality of life for length of life than patients given personal versions.42 However, no relationship was found between the stated time preferences for quality of life versus length of life and adherence to medication regimes for primary prevention.41

Quality-adjusted life years (QALYs) are a common metric in health economics that combine a patient’s attitude about length of life and quality of life into a single number. There is a considerable body of literature using QALYs; however, given that the number is a combination, there is little information that can be teased out regarding how the person determines the decisional balance. We were unable to locate any qualitative literature that explored the process for older adults regarding preventive services.

Cognitive ability/functional limitation. We were unable to locate any studies that pertained to differences in preventive service valuation that either addressed or controlled for cognitive ability or functional limitations.

Other cross-cutting themes. A point of interest is how well an older person’s perceived risk concurs with risk estimates established through epidemiologically sound research methods. Cornford5 suggests that lay perceptions of risk for influenza do not map to epidemiologically established risk factors. Rutten and colleagues40 found evidence of an age factor here as well; increasing age is associated with lower accuracy in estimating evidence-based cancer risk. The question remains as to whether this is due to cohort effects or the increased proportion of respondents with lower numeracy skills or mild cognitive impairment.

### Key Question 2 What Attitudes Do Older Adults Have About Potential Harms of Clinical Preventive Services?

The harms associated with preventive behaviors and services identified in the literature fall into two categories—clinical harms and psychological harms. See Table 4 for a summary of the findings.

Table 4 Older Adults’ Perceptions of Harms of Preventive Actions Reported in Studies

Prevention Action | Older Adults’ Perceived Harms
Flu vaccination | [underlined: Clinical Harm]; - Perceived side effects: painful arm, feeling unwell, having more colds or severe influenza after vaccination.5; - Vaccination side effects were interpreted differently between vaccinated and non-vaccinated individuals.5; - Developing influenza after vaccination.7; - Adverse reactions.7; - Those who had never had the vaccine and those who had been vaccinated in the past but had defaulted were more likely to believe that the vaccine had serious side effects.6; [underlined: Psychological Harm]; - Few considered themselves at risk, due to independent and active engagement self-assessed health status, regardless of vaccination status.5
Pneumococcal vaccination | [underlined: Clinical Harm]; - Adverse reactions.7
Mammography screening | [underlined: Clinical Harm]; - Pain.11; [underlined: Psychological Harm]; - Harm and fear most likely reasons for not planning on screening.11; - Unlikely to risk feeling ill by seeking to discover breast cancer through screening.12
Colorectal cancer screening | [underlined: Clinical Harm]; - Negative attitudes toward screening procedures.9; - Fear of test (22.1%)*13; - Discomfort (21.3 %)*13; - Side effects of test, such as radiation or perforated bowel.17; [underlined: Psychological Harm]; - Negative attitudes toward screening procedures.9; - Subject matter embarrassing or private.9; - Avoidance of learning diagnosis.9; - Disgust at idea of handling stools.8; - Fear of colonoscopy.8; - Embarrassment (15.1%)*13; - Fear of results (14.3%)*13; - Test could lead to diagnosing unrelated and benign condition, or serious condition with no cure.17; - No benefit to early diagnosis.17
General cancer screening | [underlined: Clinical Harm]; - Pessimism/misinformation (e.g., “cure is worse than disease”) for both Pap and mammography screening.18; [underlined: Psychological Harm]; - Embarrassment/mistrust for both Pap and mammography screening.18
Dementia screening | [underlined: Psychological Harm]; - Stigma of screening.19; - Suffering from screening.19; - Impact of screening on patients’ independence.19

* Reported percentages = # of times that barrier was mentioned/# of times any barrier was mentioned x 100.

Primary prevention. As with perceived benefits, older adults who have and have not been vaccinated for influenza differ in their beliefs about the harms of the vaccine. Two studies indicate that those who have not been vaccinated tend to perceive the vaccine as more harmful than those who have been vaccinated.5,6 Specific perceived harms identified in this literature were clinical in nature and focused on side effects, such as sore arms,5 developing influenza,5,7 frequent colds,5 and feeling generally unwell.5,6

Cornford5 found that older people who have been vaccinated tend to counterbalance perceived harms of influenza vaccinations across multiple time periods. Specifically, side effects experienced after a vaccination in one year would be balanced against experiencing no side effects in other years. Possible lay explanations for side effects included coincidence, in which case the individual suspended judgment, or differences in the viral strain upon which the vaccination is based.

Secondary prevention. Perceived clinical harms associated with screening behaviors were fear of the test,8,13 pain,11 discomfort,13 side effects,17 and a view that treatment would be worse than living with the disease.18 The psychological harms associated with breast and colon cancer screening were similar and included embarrassment,9,11,13,18 disgust at the idea of handling stool,8 fear of results or diagnosis,9,12,13,17 fear of unrelated diagnoses that are incurable,17 and worry.11

Dementia screening had unique perceived harms. These included social stigma, emotional and practical hardships, and loss of independence if diagnosed with Alzheimer’s disease.19

### Key Question 3 What Value Do Older Adults Place on the Receipt of Clinical Preventive Services?

Though identifying the perceived benefits and harms associated with a preventive behavior is useful, benefits and harms are not necessarily weighted equally in the formation of global evaluations, and this weighting differs across individuals. For instance, though both persons X and Y identify embarrassment as a harm associated with colon cancer screening, embarrassment might play a major role in shaping person X’s negative global evaluation of the screening, whereas person Y’s global evaluation of colon cancer screening might be positive and influenced minimally by embarrassment. To circumvent this issue, some researchers have considered older adults’ global evaluations of preventive services. Models provide little insight into how specific beliefs coalesce to form a global evaluation. Assessing global evaluations provides a different perspective from those that have been considered in key questions 1 and 2, and offer the possibility of triangulating evidence. Unfortunately, most of the empirical evidence focuses on older adults’ evaluations of specific benefits and harms. The extant studies that assess global attitudes toward preventive behavior use one of two techniques, proxy measures or bipolar adjective scales, to explore older adults’ global assessments of various preventive behaviors. Proxy measures, such as intention to be screened, are behaviors or beliefs that permit the inference of global attitude. Bipolar adjective scales have respondents indicate where their attitude falls along a continuum that is anchored by two opposing adjectives (e.g., harmfulbeneficial). Coincidentally, identified studies of the value of primary prevention used bipolar scales, while proxy measures were used for secondary prevention studies. Table 5 provides a summary of the findings.

Table 5 Value Placed on the Receipt of Clinical Preventive Services By Older Adults

Prevention Action | Value
Physical activity | - Generally, sample had positive attitude toward physical activity.20; - Attitude became more positive with increased activity (not clinical setting, no physician recommendation).20; - Social cohesion positively related to attitude toward exercise (not clinical setting, no physician recommendation).21; - Global attitude linked to physical activity (not clinical setting, no physician recommendation).22; - Attitude partially contributed to predicting activity; perceived behavioral control and self-efficacy were stronger predictors (not clinical setting, no physician recommendation).23; - “Must account for past experiences, life transitions, and future concerns when trying to understand factors that influence participation in physical activity.” Subthemes include intergenerational influences, establishment of early physical activity patterns, family transitions over the life course, changing health status over time, and future health concerns.35
Mammography screening | - Do not see a need for screening if one feels healthy.12; - Unlikely to risk feeling ill rather than healthy (i.e., no symptoms and no cultural beliefs to support) by seeking to discover breast cancer through screening.12; - Persons ages ≥65 years were more likely than those ages 49–64 years to be against screening mammography.24; - Persons ages ≥65 years more likely than those ages 49–64 years to be skeptical of medical recommendations.24; - Habit, reassurance, and history of breast disease were essential factors in decision to receive mammography screening.36
Colorectal cancer screening | - Reasons to get screened include knowing someone with cancer, being a “good citizen,” and encouragement from others.8; - Reasons to avoid screening include feeling healthy and fear of outcome.8
General cancer screening | - 62% believed their own life expectancy was not important for decisionmaking.10; - 48% preferred not to discuss life expectancy. There was no difference between those younger than 85 and those 85 and older. There was no difference between those that previously had cancer and those that did not.10; - 11% had decided to stop screening entirely.10; - 43% would consider getting screened even if their physicians recommended against it.10; - Those with cancer history were more likely to consider screening even if their doctor recommended against it.10

Primary prevention. Of five articles addressing physical activity for older people, only one was conducted in the United States.22 Four used bipolar scales in their survey methodology.20–23 Collectively, this set of four studies indicates that some older adults can have positive attitudes toward physical activity.20–22 Attitudes toward physical activity appear to increase as one gives more consideration to and becomes more engaged in physical activity.20,21 Evidence regarding the ability of attitudes to predict intention and actual level of physical activity is mixed.20–23

We were unable to find literature to inform our understanding of how older people view the role of physical activity counseling by their health providers. However, Weeks and colleagues suggest that understanding the life history of the older person can help providers improve older adults’ participation in physical activity.35 Identified themes that influenced physical activity participation in their qualitative study of 24 older people included intergenerational influences, establishment of early physical activity patterns, family transitions over the life course, and changing health status over time and future health concerns.35

Secondary prevention. The scant evidence available for global assessments of secondary prevention is mixed. Many of the women who did not adhere to mammography screening guidelines and were interviewed by LaPelle and colleagues were skeptical of medical recommendations.24 Likewise, the value of breast cancer screening is unclear to people who are unwilling to risk losing feeling healthy should some diagnosis be discovered. This doubt regarding the value of breast cancer screening when one does not feel unhealthy was found in a small sample in the United Kingdom of mostly white, white collar, or professional people, and a second of Mexican immigrants.8,12 Conversely, Lewis and colleagues reported that the majority of older adults in their sample had positive attitudes toward cancer screening, as indicated by the general consensus that they would continue cancer screening despite discomfort.10 Interestingly, the percentage of adults reporting that they, personally, would continue prostate, breast, and colon cancer screening for as long as they live (72 percent colon, 83 percent breast/prostate) was larger than the percentage who agreed that everyone should get screened for these types of cancer as long as they live (55 percent colon, 63 percent breast/prostate).10 This suggests that attitudes toward cancer screening can differ across screening targets (self versus others). Some evidence from the United Kingdom suggests that the decision to complete a fecal occult blood test is shaped by a sense of civic responsibility or obligation.8 It is unclear whether this sense of obligation creates a positive attitude toward the test or if this sense of responsibility trumps personal attitudes.8

The Lewis study perhaps most directly speaks to the question of how older people view preventive services, and it bears more detailed reporting. The researchers interviewed 116 residents of the independent living quarters of a long-term care facility in North Carolina regarding their attitudes and beliefs about cancer screening. Table 6 is a reproduction of a table that provides the percentages of older adults who reported statements regarding various potential attitudes toward cancer screening later in life. Of particular note is that 50 percent of older people felt that other health issues are more important than cancer screening, although people with a history of cancer were less likely to express this opinion (36 percent). However, the population of the study should not be considered representative of the general population.

Table 6 Attitudes About Continuing Cancer Screening Later in Life

Statement of Attitude | Number in Agreement (%)
Statement of Attitude | All Ages (n=116) | >85 yrs (n=36) | Cancer^*^ (n=45)
I will likely die of some other disease besides cancer. | 86 (81) | 29 (80) | 33 (73)
I will continue cancer screening no matter how uncomfortable the tests are. | 84 (77) | 28 (78) | 35 (77)
I plan to get screened for colon cancer for as long as I live. | 76 (72)^**^ | 22 (61) | 33 (74)
I plan to get screened for breast/prostate cancer for as long as I live. | 85 (83)^***^ | 29 (80) | 40 (88)
I will consider getting screened for cancer even if my doctor recommends against it. | 47 (43) | 19 (53) | 26 (58)^†^
It takes several years for cancer screening to benefit people. | 28 (25) | 10 (29) | 13 (29)
I will not live long enough to benefit from cancer screening tests. | 15 (13) | 10 (28)^†^ | 5 (11)
I will not get cancer screening even if my doctor recommends it. | 4 (4) | 1 (3) | 1(2)
Cancer screening is not worth the trouble. | 3 (3) | 1 (3) | 1 (2)
Everyone should get screened for colon cancer for as long as they live. | 64 (55) | 22 (61) | 31 (69)^†^
Everyone should get screened for breast/prostate cancer for as long as they live. | 73 (63) | 23 (64) | 41 (91)^†^
Screening for cancer in people older than age 70 years may waste health care time and money. | 34 (30) | 12 (34) | 10 (22)
As people get older, other health issues are more important than cancer screening. | 56 (50) | 18 (50) | 16 (36)^†^
People who live in nursing homes should not get cancer screening. | 30 (26) | 9 (25) | 9 (21)
People older than age 70 years who are totally dependent on someone else for daily functions (such as eating, bathing, and toileting) should not get cancer screening. | 50 (44) | 15 (43) | 18 (40)
People with Alzheimer's disease or dementia should not get cancer screening. | 51 (44) | 18 (50) | 18 (41)

* Participants reporting previous diagnosis of cancer other than skin cancer.

** n=105.

*** n=102.

† p<0.05.

Other cross-cutting themes. Force of habit as a prompt for behavior is seen in both primary and secondary prevention behaviors. As noted above, Weeks and colleagues found that the establishment of early physical activity patterns was identified as an important influence for physical activity behavior later in life.35 Likewise, Schonberg et al found that the largest proportion of women endorsed habit as an essential/very important factor in the decision to get mammography screening.36

### Key Question 4 How Do Older Adults Understand the Balance of Risks and Benefits From Clinical Preventive Services?

Little is known about how the benefits and harms of preventive behaviors are balanced by older adults and influence behavioral decisions. Indeed, there is a scarcity of theories and models available to guide this work. Only three studies were identified that contributed to any understanding. Findings are summarized in Table 7.

Table 7 Decisional Balance of Benefits and Harms

Prevention Action | Decisional Balance
Colorectal cancer screening | - Bowel preparation, risk reduction of cancer-related death, and length of screening interval influence preference for type of procedure.25; - Required a 1% reduction in relative risk for cancer-related death for each additional 10 minutes of test duration; 5% to be exposed to small complication risk; 10% to accept mild pain; and 32% to use extensive bowel preparation.25; - 80% valued test sensitivity over physical comfort during the testing procedure when forming a preference for a test procedure.17
General cancer screening | - 62% believed their own life expectancy was not important for decisionmaking.10; - 11% had decided to stop screening entirely.10; - Those with cancer history were more likely to consider screening even if their doctor recommended against it and were less likely to think that other health issues were more important than cancer screening.10

Lewis and colleagues’ work provides an insight into the decisional balance process; 62 percent of older participants believed that their own life expectancy was not important to the decisionmaking process regarding cancer screening.10 Furthermore, 48 percent preferred not to discuss life expectancy with their physicians. There were no differences in the finding between those older than age 85 years and those younger than age 85 years, or between those who have previously had cancer and those who have not had cancer experiences. Those with a cancer history were in fact more likely to consider screening even if their physician recommended against it. However, 11 percent had decided to stop screening entirely.

Two studies explored this process from a decision science perspective. In one study, individuals valued screening outcomes, especially mortality reduction, more than process features when stating their preferences for a colon cancer screening procedure.25 Specifically, participants were willing to accept longer test duration, greater risk for complications, mild pain, and different bowel preparation procedures in exchange for a reduction in mortality.25 Likewise, van Wagner and colleagues, using focus groups, found that participants valued test sensitivity—which relates to benefits through a stronger likelihood of identifying a disease state, if one exists, at the risk for more false-positive findings—over discomfort during a test procedure.17

## Issues of Valuing Prevention

This section is intended to expand conceptual understanding of values and preferences of older adults, and to provide one possible beginning of a conceptual framework. The discussion is not meant to be exhaustive. Our goal is to stimulate curiosity about the larger context of values and decisionmaking, introduce important concepts, and raise questions regarding the limitations of some commonly held views.

### Goals of Prevention: Successful Aging

Older adults’ evaluations of, and participation in, preventive health reflects their underlying reasons, current understandings, and motivations. What one hopes to achieve or avoid through preventive services is an integral part of the decisionmaking process. Moreover, different functions or behaviors may be differentially important to older adults, who may therefore be particularly interested in incorporating those particular prevention behaviors they feel will protect the needs or functions that they most value. Though the specific benefits achieved by a health behavior are varied, many of the benefits appear to fall under the superordinate category of striving toward successful aging. One may predict that older adults are striving to age successfully. Accordingly, older adults’ views of what it means to age successfully may shape their evaluations of preventive services.

Successful aging has been defined in a variety of ways. Models of successful aging often favor a biomedical or psychosocial perspective.44 Biomedical models of successful aging emphasize longevity, the absence of disease, and good physical and cognitive functioning.44 In contrast, models with a psychosocial perspective emphasize satisfaction with one’s current and past life, social engagement, and personal growth. Rowe and Kahn distinguished between “usual aging” and “successful aging.”45 Individuals in the former category show the epidemiologically expected age-related decline in physical health and cognitive functioning, whereas those in the latter category show little or no evidence of the expected decline. According to this perspective, the three central components of successful aging are the absence of disease and disease risk factors, maintenance of physical and cognitive functioning, and engagement with life.45

Investigating older adults’ perspectives on successful aging yields what they consider to be normative and exceptional health states. Consideration of these perspectives provides a distinction between the health changes that older adults will tolerate and those they may strive to prevent. For example, having lower expectations of aging is associated with placing less importance on seeking health care for age-related issues, such as walking more slowly, having trouble sleeping, and experiencing joint aches.46 According to research done in men with osteoarthritis, older men are more likely than their younger counterparts to view osteoarthritis as a normal part of aging and to endorse the view that one should expect to live with some pain and experience some impairment in walking ability as one gets older.47

Moreover, older adults’ views of successful aging often differ from those of researchers.48 It is important to consider these definitional differences because older adults form their evaluations of preventive services from the vantage point of their own unique perspectives. One major point of divergence between these two groups is that older adults’ definitions of successful aging are more multifaceted than those of researchers. When asked to consider the features central to successful aging, older adults include items that agree with theoretical definitions of successful aging, such as freedom from disease and good physical, psychological, functional, and social health; however, they also include more nuanced items, such as a sense of humor, sense of purpose, productivity, and contribution to life.44,48 Research done with focus groups of older adults indicates that a strong spiritual life, travel, and not taking medication are also associated with aging successfully.49

Quality of life versus length of life. Another point of particular divergence between researchers and lay perspectives on aging is that older adults reduce the emphasis and value placed on longevity. More than 90 percent of the 1,890 respondents to the survey by Phelan et al considered maintaining good health until close to death as important (rather than neutral or unimportant), whereas less than 30 percent rated living for a very long time as important.48 However, extending assumptions regarding older adults’ choices regarding quality of life and length of life universally can be very misleading. As was seen in the study by Lewis and colleagues, stated choices are not always objectively logically consistent,10 and proffered justifications can be highly individualistic, based on the person’s experiences of meaningful life and life fulfillment.50

Nor is it necessarily appropriate to assume that observable health status is always an accurate proxy for estimating another person’s quality of life. Covinsky and colleagues51 found that disagreement between an older patient’s health status and self-assessed global quality of life was common among a group of 493 cognitively intact patients ages 80 years and older. So while health status may function as a proxy for quality of life at the population level, it is inappropriate to use it as such at the individual level.51

Selective optimization and compensation. As the body of work in the area of successful aging has developed, interest has shifted to include articulating a formal definition of successful aging, along with delineating the processes that underlie successful aging.52 A widely cited process model in this area is the “Selective Optimization with Compensation” (SOC) model.53 The SOC self-management model describes the ways that individuals successfully adapt to developmental changes in order to reach their goals. Though it is a lifespan model, SOC has been applied most frequently to the older population because of the functional impairments that frequently occur in this population. According to the SOC framework, older adults who age successfully achieve a positive net balance between gains and losses as they age. The cornerstone of the SOC model is the notion that older adults create environments that are conducive to goal achievement and successful aging. This model posits that individuals prioritize their goals and commit to them accordingly (selection). This prioritization process becomes particularly important when resources begin to decline, as they tend to do as one ages. Individuals then optimize the resources that they have in order to facilitate the achievement of a goal. Optimization of resources can include learning new skills and using one’s energy. As resources decline, one may compensate for these declines using a variety of strategies. For example, individuals may use a wheelchair to compensate for lost mobility.

The goals discussed in the SOC model are determined subjectively. That is, each individual selects goals that are important to the development or maintenance of his or her own life satisfaction. Thus, the SOC model is flexible in that it can account for the different paths taken to achieve life satisfaction. This model has been empirically supported, though some strategies may become more difficult or infrequently used as one ages (see Ouwehand et al52 for review). The model has been criticized for being reactive and neglecting to recognize proactive coping as a path to successful aging.52 Incorporating proactive coping, which involves identifying stressors at an early stage, into the SOC model would be congruent with valuing preventive health measures.

Proactive coping. Proactive coping involves using a future oriented and proactive approach to anticipate and avoid or moderate life problems, which one would conceivably employ in pursuit of successful aging goals. While proactive coping has yet to be tested for preventive behavior in the older population, one randomized controlled trial has examined proactive coping in a sample of 191 adults ages 50 to 70 years with type 2 diabetes residing in the Netherlands.54 Proactive coping was more predictive of successful weight loss maintenance and self-management at 12 months than either intention or self-efficacy.

### Heterogeneity

Understanding how older people value health services is made more complex with the presence of heterogeneity. Heterogeneity enters into deliberations through multiple sources. In this section we expand on the concept of heterogeneity in the older population that was briefly touched on in the introduction. Heterogeneity applies in terms of the elderly designation as a whole and the realization that each older person has a unique collection of life experiences that shapes his or her beliefs.

Heterogeneity in the older population. Currently, heterogeneity in this population is most commonly recognized through designation of three groups based on age (young old, old old, and oldest old).55 Physical and cognitive function may be more important than chronological age in affecting attitudes toward prevention.

Though gender differences in behavior were not frequently addressed in the identified literature, older men and women differ in their perceptions of health. For instance, gender differences in self-assessments of health have been identified. Specifically, men tend to show greater decreases in self-assessments of health over time than women.56 Though these distinctions highlight heterogeneity, diversity within the older population is not developed in the literature. Amongst other issues, the range of evaluations of preventive behaviors that exists within the older population is not fully understood or appreciated.

The heterogeneity in beliefs and attitudes toward preventive behaviors within the older population was touched upon during key question discussions. For instance, within the older population, variance exists in the extent to which health is viewed as a moral issue.57,58 One’s stance on this issue has implications for one’s response to health promotion.58 There is also variance in levels of positive and negative affectivity and optimism and pessimism. These variances are associated with health-relevant outcomes, such as self-rated health, life satisfaction, and somatic depression.59 It is unclear whether these age differences in beliefs are the result of a life span effect, a cohort effect, or an interaction of the two.

Similarly, economics accord particular importance to individual differences in impatience, risk aversion, and anxiety, which shape individual preferences toward preventive behaviors.60 How much people value the present more highly than the future (impatience), prefer to avoid risk, and experience high levels of distress from uncertainty about outcomes are combined into the preference decision.60

Heterogeneity has also been acknowledged through the development of patient archetypes. The term archetype is used here to label a specific cluster of key characteristics that pertain to a particular health state. For instance, diabetes archetypes are based on characteristics such as readiness for behavior change and attitudes toward diabetes.61 Health care providers can classify patients by archetype and tailor health messages appropriately.61 Similarly, patient adaptation to diabetes can be modeled to identify “best practice patients” and archetypes of “inefficient patients.”62

Multimorbidity. Multimorbidity is the simultaneous occurrence of two or more chronic medical conditions within an individual.63 More than 65 percent of adults aged 65 years and older are living with at least two chronic conditions.64–68 This number is projected to grow due to increased life expectancy and medical advances allowing longer life with chronic conditions.69,70

Multimorbidity is germane to a discussion of older adults’ evaluations of preventive services for several reasons. Not only is this state prevalent in the population, but also the many facets of multimorbidity, including concerns surrounding complex treatment, competing outcomes, psychological well-being, and disease burden, coalesce to create heterogeneous patient perspectives that undoubtedly influence the decisionmaking process.

Older patients with multimorbidity have unique needs that must be supported by providers and the health care system. Older patients with multimorbidity desire conveniently accessible care, clear communication of treatment plans (including prevention), continuing relationships with providers, and assistance from a single coordinator who facilitates prioritization of competing demands. These patients also express a desire for a warm provider who acknowledges the dynamic and unique nature of their health.71

The treatment of one condition often conflicts with the treatment of another, or elicits side effects that can be treated. It is often impossible for all desired outcomes to be concurrently recognized, especially without intensifying or complicating treatment.72 Older patients with multimorbidity and their providers thus endeavor to balance the competing outcomes that accompany these conditions. Inherent in the balancing process is prioritizing outcomes and treatments. Given the unique priorities of each individual, calls have been made for patients’ values and preferences to be the context in which treatment decisions are made.72–74

Empirical work has produced some rudimentary insights into how older adults think about and manage competing outcomes. For instance, evidence suggests a positive association between the number of compound effects (i.e., number of interferences between treatments and/or symptoms) and disease burden.75 However, older patients may not recognize or credit the interactions among treatments.72 Data gathered from focus groups of adults aged 65 years and older who were taking at least five medications indicated that participants rarely acknowledged interactions between treatments. However, participants did view the benefits and side effects of their medications as competing outcomes and cited medication side effects as important influences in their medical decisionmaking processes.72

The same study also provides insight into the decisionmaking strategies used by these patients. Though participants described their conditions and treatments in the context of specific diseases, when explicitly asked to consider tradeoffs associated with competing outcomes, their decisionmaking appeared to be guided by global, rather than disease-specific, concerns. Global concerns included survival and maintenance of physical function.72 Moreover, when asked about hypothetical medical situations that involved a tradeoff, they preferred the treatment that aligned with the outcome that was most subjectively desired.

Having to weigh the competing outcomes associated with multimorbidity also appears to affect provider decisionmaking. Physicians play an important role in the encouragement and implementation of preventive care in older adults. Though little is known about how multimorbidity influences physicians’ advocacy of preventive services to older adults, in one study physicians primarily considered whether the patient will live long enough to benefit from screening when deciding whether to recommend colon cancer screening to adults aged 75 years or older.76 Multimorbidity, along with chronological age and functional status, are factored into this calculation.

In addition to creating complicated decisionmaking situations, multimorbidity also elicits particular psychological experiences that may influence preferences and attitudes toward preventive services. Empirical evidence indicates that multimorbidity in older adults is linked to quality of life outcomes, such as self-perceived health status and life satisfaction. Specifically, a study of adults aged 65 years and older who had, at a minimum, concurrent diagnoses of depression, diabetes, and osteoarthritis found that higher levels of morbidity, as well as factors such as low levels of physical functioning, little knowledge about medical conditions, and being male, were associated with lower self-perceived health status.64 Similarly, Stalbrand and colleagues’ examination of a cohort of 80-year-old Swedes found that individuals with at least two chronic diseases who had experienced at least seven different generic symptoms (e.g., nausea, fatigue, coughing) in the past 3 months had lower life satisfaction compared to those who had fewer chronic diseases and more symptoms, those with fewer chronic diseases and fewer symptoms, and those with the same number of chronic diseases and fewer symptoms.77

In an attempt to distinguish between the psychological and physiological impacts of multimorbidity on quality of life outcomes, Nobrega and colleagues surveyed older adults who had at least one chronic illness. In this study, all participants were asymptomatic, free of complications, and were not experiencing any lifestyle or cognitive impairments.78 Multimorbidity was assessed with the Cumulative Illness Rating Scale-Geriatric Version (CIRS-G), which accounts for both severity and number of morbidities. Quality of life was self-reported and was assessed separately for each of several domains of life (e.g., psychological, physical). The researchers found a negative correlation between scores on the CIRS-G and self-rated quality of life in physical domains. The negative correlation between CIRS-G scores and quality of life in psychological domains was marginally significant. Additionally, there were positive associations between self-perceived health status and quality of life in physical, psychological, and environmental domains. The authors concluded that mere knowledge that one has chronic medical conditions influences self-rated quality of life.

Heterogeneity of preventive services. Preventive services characteristics are not homogeneous. Some preventive acts, such as immunizations, are simple. Some are more complex, requiring sustained changes in behavior over time. Some behavior changes, such as smoking cessation and exercise, incur benefits even in older people. Some screening tests require a drop of blood, while others require sedation, such as colonoscopy. Primary prevention may have a different salience from secondary screening. Some effects of prevention are immediate (e.g., immunization). Others take a long time to produce a benefit. Whether a person receives benefits from still other preventive behaviors may never be certain. Similarly, preventive behaviors differ in the patient’s level of independence (e.g., lifestyle changes versus clinical procedure), the amount of clinician involvement (e.g., prescriptions/referrals versus counseling), and frequency (e.g., once a year versus daily).

For example, because it is simple, brief, and requires little preparation, uptake of vaccinations may be as easily affected by the location of vaccination services (e.g., vaccines offered at a neighborhood grocery store) as a person’s beliefs. However, other preventive behaviors, such as undergoing a colonoscopy, require much preparation and time, and are more invasive. It is likely that these types of behaviors are driven more strongly by one’s evaluations of the service and its associated costs and benefits. Similarly, some preventive actions, such as beginning a regular exercise regimen, involve lifestyle changes that require a continuous series of choices and actions in changing environments. These types of preventive behaviors must be maintained on a daily or weekly basis and thus substantially differ from preventive behaviors that are undertaken annually, such as mammography screening.

### Reason-Based Health Decisionmaking Models

As mentioned previously, researchers and health providers have approached understanding people’s health beliefs and behaviors through psychological and decision analysis disciplines. Each applies a particular nuance to their conceptualizations and interpretations. The following section provides a brief survey of the more commonly used models and approaches in each discipline that were found in the literature.

Health psychology models. Several health psychology models have been posited to facilitate the understanding of health-related behaviors. Specifically, they provide insight into how and why individuals come to participate or not participate in preventive services. These models have been extensively studied in many contexts and with many populations, including older adults and preventive health behaviors.21,23 The cornerstones of these models are identification of the psychological processes that are believed to underlie health-related behaviors and/or stages leading to behavioral change or action. Some models combine both of these approaches. Though these models have evolved and generally come to include factors such as demographics and individual differences, only the most central elements of these models will be highlighted here.

Among the most influential psychological models of health behavior change are the self-efficacy theory, the health belief model, and the theory of planned behavior (and its precursor, the theory of reasoned action). Self-efficacy is the belief that one is capable of carrying out specific actions in order to achieve a goal.79 According to the self-efficacy theory, individuals are more likely to be motivated and to engage in a behavior if self-efficacy is high.79 Self-efficacy is derived from a variety of sources, including personal experience with mastery or success, seeing the behavior modeled, social persuasion, and physiological signals.79 The theory of planned behavior is conceptually related to self-efficacy theory in that it includes the construct of perceived behavioral control.80 Perceived behavioral control is the perceived ease or difficulty of performing a behavior. Specifically, the theory of planned behavior purports that behavioral intention, or behavioral readiness, is a function of one’s attitude toward the behavior, social norms, and perceived behavioral control. Finally, the heath belief model proposes that perceived susceptibility, perceived severity of a condition and its consequences, perceived barriers, and perceived benefits of adopting a behavior coalesce to produce the likelihood that one will engage in a particular health behavior.81 Self-efficacy, perceived control, cues to action, and other processes have been incorporated into this model as mediating processes.82

The common sense model of illness representation adds to this set of psychological process models by considering both the perceived reality of a health threat and one’s emotional reaction to the threat.83,84 One’s unique representation, or mental model, of the threat depends on how the individual perceives five attributes—the identity (or label), timeline, cause, controllability, and consequences of the threat. Representations guide how one copes and appraises the outcomes of action paths.

Stage models, such as the transtheoretical model85 and the precaution adoption model,86 delineate stages that individuals move through as they perform health behaviors. These models assert that individuals move from being either unaware of a behavior or not considering changing to contemplating the behavior, from which point they proceed to take action and maintain the behavior. The transtheoretical model includes a preparation stage in which individuals prepare to take action, and discusses processes that facilitate movement through the stages, such as self-efficacy, weighing of pros and cons, and temptation.85 Empirical evidence supports the usefulness of matching the contents of health messages to a target’s behavioral stage.87,88

In summary, health psychology models help describe the internal psychological states and processes associated with health behaviors and were designed with the purpose of identifying leverage points at which interventions could be aimed to facilitate whatever is deemed a better or healthier action. Values, attitudes, perceived benefits and harms, and risk assessments are integral to the models. However, a general critique of the literature is that the link between internal states and processes and external actions are often missing or tenuous. Furthermore, there is always the question as to the ethical basis for health interventions when considering patient agency; that is, a patient’s ability to act with authority for oneself.

Decision analysis. Decision analysis in medicine is a quantitative discipline that derives from decision theory, which is based on mathematics, ethics, game theory, and economics.89 Decision theory uses expected utility theory and describes rational decisionmaking under conditions of uncertainty.90 The decision choice environment is characterized as involving uncertainty, incorporated through probabilities for each possible health outcome, and the individual’s preference for the outcomes. More will be said about people’s ability to understand probabilities in the upcoming section on issues in shared decisionmaking.

With regard to measuring preferences, decision analysis uses stated preferences—what the individual claims is the value of the object—rather than traditional economics’ revealed preferences, the value that is revealed through an object’s price. The choice conditions are presented as discrete choices, such as treatment versus no treatment for a given disease condition, or preferences for one form of screening test versus another (e.g., colonoscopy or fecal occult blood test).25 Choices can be framed as time tradeoff choices, in which the individual indicates the tradeoff they are willing to accept between living with a particular health condition and the risk they would accept to have their health restored.

Another preference measurement technique is probability tradeoff. In contrast to the stated preference technique, which generally employs formal decision analysis methods, probability tradeoff models take the perspective of the patient standing at a particular decision node.91 In these simulations, the stated efficacy of a treatment is systematically varied until the patient switches his or her treatment preference. In these cases, patients are expected to intuitively handle the probability and uncertainty inherent in the choices.

Man-Son-Hing and colleagues compared decision analysis modeling using decision tree analysis with the probability tradeoff technique for 49 patients enrolled in a randomized controlled trial examining the efficacy of aspirin therapy for primary prevention of vascular events (myocardial infarction [MI] and stroke) in older adults aged 65 to 85 years (mean age=71 years).92 They found that major stroke was the least desirable health state, followed by MI, minor stroke, major bleeding, and “taking a pill every day.” Furthermore, 40 of 42 patients were willing to take aspirin for a smaller reduction in the risk for stroke compared with MI. However, patients using the probability tradeoff technique indicated that they were willing to take aspirin for a smaller risk reduction for both MI and stroke than patients indicated through decision analysis techniques. In fact, treatment recommendations were discordant between the two techniques for between 38 and 62 percent of the participants. Finally, 30 of 42 participants (43 percent) reported that they were more likely to base a future decision on whether to take aspirin on the probability tradeoff exercise, five patients (17 percent) preferred the decision analysis approach, and 12 patients (40 percent) equally weighted the two approaches.

Regardless of the stated preference or probability tradeoff technique used, the result is a preference that is without explication of the underlying calculus the person employs, whether rational or intuitive. Some researchers have attempted to extend understanding of the approaches by using qualitative methods.17,93 Perhaps the greatest benefit these approaches provide is an explicit, systematic tool for patients to use in decisionmaking situations, guiding them to think carefully about the uncertainties and tradeoffs inherent in preventive services choices.60,91

Cautions for economic perspectives. There are two concepts in particular for which the reader is advised to retain a healthy skepticism with regard to employing economic theory-based preference research. The first concept is time preference, or intertemporal choices. As stated previously, time preference assumes that a person generally prefers something now rather than something later, and requires a tradeoff to accept a time delay. Whether this is an accurate reflection of the processes employed in making preventive health decisions is open to debate. For example, Chapman and colleagues found that time preferences had little relationship to actual adherence to hypertension or cholesterol-lowering medications.41

The second concept is utility theory, upon which the majority of stated preference approaches and QALYs are based. As mentioned in the results section of key question 4, QALYs combine the patient’s attitude about both quality of life and length of life into one number. The method itself derives from both utility theory and time preferences and essentially asks, “How do you feel about a year with a medical condition compared with the two extremes of perfect health or death?” However, the realism of utility theory is debatable, suggesting that utility depends on framing and context. For example, personal versus impersonal framing affected patient preferences for health states related to prostate cancer.42 Therefore, caution must be exercised when considering these research findings because the results may be strongly influenced by the type of research methodology used. That is, stated preferences could be the product of actual preferences and/or the way that the question is framed. This issue is applicable to any type of research methodology that involves stating preferences or ratings, and is best countered by gathering behavioral data about actual choices.

More challenging is the perspective from which the older adult views the preference question. Individuals are often inaccurate in predicting how they will feel in the future as their reference points change.94 Thus, one’s place along this health continuum can have implications for how one perceives and evaluates current and possible future health states. For instance, Winter and colleagues found that older adults with lower levels of physical functioning reported more years of desired life in worsening hypothetical health scenarios than older adults with higher levels of physical functioning.94 The authors concluded that impaired physical functioning places individuals at a reference point that allows them to more finely distinguish between these worsening states and death. The distinction between the worsening states and death was less refined for higher functioning participants. Thus, the population in which utility is measured is very important.

Even within a population with personal experience with a medical diagnosis, utility is subject to wide variations in responses. While statistical means can always be calculated for a population, the variation in time tradeoff utility identified by patients can span the entire choice range of 0 to 1. For example, Chin et al found much variation existed in the utility that patients with diabetes placed on complications, such as lower leg amputation.95 There is a real problem with using population-level utility scores as a proxy for an individual patient’s self-identified utility, or more simply put, the patient’s own values.

In summary, careful attention should be paid to the base assumptions and techniques applied to elicit preferences. While arguments have been made that subjective well-being, based on real experiences, is a better methodology,96 others suggest that subjective well-being is also beset with problems and call for more research into developing new tools that are more sensitive to change and less subject to bias.28

Psychological attitude research versus decision analysis preference research. Though both psychology and economics are interested in the ways in which people evaluate health states, health behaviors, and health services, the two disciplines differ in their conceptualization and measurement of evaluations. In psychology, evaluations are conceptualized as attitudes that can be measured with Likert rating scales. Economics focuses on measuring preferences by having individuals choose and rank scenarios that systematically differ in features, such as price or time investment. Both attitudes and preferences have been used to study older adults’ valuation of preventive behaviors and services. Though these two measurement strategies can yield the same conclusion, they can also render divergent information. For instance, in a direct comparison of attitude and preference measurement strategies in the context of HIV testing procedures, Phillips and colleagues found that the attitude measurement strategy was more conducive to halo effects—a cognitive bias in which the perception of a particular object is influenced by previous value perceptions—and the strategies differed in their conclusions of how particular attributes of the test (e.g., price, location, counseling) were valued.97

### Other Decisionmaking Mechanisms

Behavioral economics. Behavioral economics developed as a field to modify standard economic theory by describing the behavioral bounds on rationality, willpower, and self-interest that constrain people’s economic decisions. Practitioners in the field integrate insights from psychology and cognitive science with economics with the hope of building more realistic models of human behavior that incorporate social, cognitive, and emotional factors.

It should be noted that behavioral economics is an active field with healthy debate on theoretical and methodological fronts, which fall outside the scope of this brief overview. However, the existence of such a debate is present in the fact that two of the three articles identified that used these methods, while focused on older adults’ preferences for preventive services, were methodological in nature.92,98

Herbert Simon coined the term “bounded rationality” to describe human limits to information processing and problem solving.99 Very simply, there is only so much time and so much brain power a person can employ toward decision processes. When the complexity of a problem breaches the bounds on rationality, or when conserving cognitive resources, people use heuristics. Heuristics are the common sense, experience-based methods, often called “rules of thumb,” that are used in problem solving and learning.

Heuristics have generally been regarded as a second-best way to process information and something to be avoided if greater information processing capacity becomes available. However, Gigerenzer and Brighton provide a counterview to the “Homo economicus” view of standard economic theory with their “Homo heuristicus,” which views “human nature as based on an adaptive toolbox of heuristics rather than on traits, attitudes, preferences, and similar internal explanations.”100 They detail decisional environments in which different “less is more” heuristic models, such as “take the best” (ignoring cues), tallying (ignoring weights), or ignoring dependencies, outperform complex models in prediction. Complex mathematical models may better describe the observed data (i.e., provide a better fit), but people make decisions in order to make choices about future health behaviors, and predictive models for decision processes may be more germane to the purpose.

Framing is another theme in behavioral economics. In this case, framing refers to the mental and emotional filters people develop from personal experience, anecdotes, cognitive biases, and other mental processes, and apply to situations to formulate understanding and responses.

The work by Arana and colleagues101 provides one example where both heuristics and framing were applied to understand the decision processes with which people valued health care programs for older people in the Canary Islands. They theorized that valuation involves the interplay between two paradigms: valuation by calculation and valuation by feelings. They found in a survey of 550 adults that the use of simplifying heuristics increased when the emotional intensity state of the participant was high. Their findings also support the notion that use of heuristics increases as decisional complexity increases.101

Socioemotional selectivity theory. Socioemotional selectivity theory, developed by Carstensen, suggests that the reduced life expectancy due to aging is a constraint that induces older adults to shift priorities from future-oriented information gathering goals to present-oriented emotion regulatory goals.102 These age-related shifts influence cognitive processing and lead to a “positivity effect,” a disproportionate emphasis on positive information in older adults’ attention and memory, which supports a state of well-being. Socioemotional selectivity theory has been tested within the context of health care decisions and has demonstrated age differences in decision processes. Older adults reviewed a greater proportion of positive choice criteria, were more positive in their recollections, and showed more positive emotional responses when making choices for themselves or another person of similar age than younger adults.103 Older adults demonstrated a shift to information-processing goals when making a health care decision for a young person. This perspective of the younger person was made at an emotional cost; in these situations the older adults reported a decline in positive emotions. Younger adult performance was not influenced by the age of the person for whom they were making a decision. They reviewed equal proportions of positive and negative material and experienced a decline in positive emotions, regardless of who they were choosing for.

The shift from future-oriented goals to present-oriented emotion regulatory goals could have important implications for preventive services and related shared decisionmaking processes. For example, the noted age factor in personal risk perception could perhaps be explained by socioemotional selectivity theory. It is also interesting to speculate how the findings of Lewis and colleagues might be interpreted using the theoretical underpinnings of socioemotional selectivity theory. Perhaps some of the noted inconsistencies in the reported statements might resolve under such scrutiny.

Habits. Factors other than benefits and harms can influence one’s intention to perform and the actual performance of a preventive behavior. This point is highlighted in many health psychology models and theories and is supported by empirical literature. (See the section on health psychology models). It appears that habit and early experience may influence older adults’ engagement in preventive health behaviors. For instance, factors influencing older adults’ participation in physical activity include parental modeling of physical activity into older age and establishment of physical activity habits early in life.35 Similarly, older women who recently had been screened reported that habit strongly influenced their decision to receive mammography screening.36

### Response Shift

Quality of life is an important outcome for older adults to assess within the context of preventive services. Some researchers suggest that measurement of quality of life is problematic because the assessment tools assume that patients have the same perspective of their disease and a static evaluation for their assessment of quality of life across time. That is, the patient’s internal standard of measurement does not change. Response shift is defined as a psychological phenomenon, a shift in one’s internal standard of measurement or how one values different health states, resulting from coping with a health condition.104

One study examined the response shift phenomenon in an older population. Razmjou et al used a “then-test” study design, which asks participants to complete a second set of quality of life instruments from the perspective of how they would have perceived themselves to be before their surgery, in a study of 236 patients receiving total knee replacement surgery.105 They found that the magnitude of response shift increased over time, from 6 months to 1 year post-operation, for the Short Form (36-item) Health Survey physical and mental component scores. Controlling for response shift uncovered a statistically significant change in mental health improvement.