# Introduction

## Overview

Prevention implies a future orientation. By engaging in preventive actions, individuals attempt to affect the likelihood of developing a health problem, delaying the development of a health problem, or reducing the severity of the health problem when it develops. An investment in preventive care today is expected to change a person’s future health trajectory.

At first glance, how expected trajectories impact how various preventive actions are viewed by older adults may seem relatively straightforward. Older persons have shorter life expectancies and hence may view the likelihood of benefit differently from younger people. The differences in perceived possible benefits between the age groups would logically lead to differences in how the age groups value preventive services. Organizations like the U.S. Preventive Services Task Force (USPSTF), charged with making recommendations about preventive services, would likely want to consider the values older people place on various preventive activities as part of the process of formulating recommendations.

Setting out to understand how older people value preventive services raises a number of questions regarding how age should be viewed and considered in clinical context. While a full discourse on life course theory and development or the discipline of gerontology is not possible here, a select set of issues is quite germane to the topic and deserves brief consideration as we examine these questions.

One question is how we determine age. Typically, age is assessed in terms of chronological years since birth; however, gerontologists measure age in terms of the force of mortality, the likelihood of dying. The gerontological definition of age gives great weight to factors such as illness, health status, and physical and cognitive function. An example of the importance of the difference between the definitions can be found in research by Gerstorf and colleagues,1 who found that decline in life satisfaction in old age is more predictive of death than chronological age itself.

When we talk about older people’s attitudes about prevention, the chronological and gerontological definitions of age take on special salience. In fact, shorter expected life spans, increased comorbidities, and competing causes of death can be present in a variety of populations and may affect their preferences for preventive services in ways similar to the older adult. So chronological age may not be the best indicator for differences in attitudes about and preferences for preventive care.

Another question is how aging shapes beliefs about preventive services. Understanding the role of aging requires separating intertwined themes: intergenerational differences from intragenerational differences, and the influence of historical forces. Some differences in beliefs about preventive services may occur because people of one generation hold different social values than those of the following generation, perhaps, in part, influenced by their experiences growing up (e.g., the Great Depression). Alternatively, people in a given cohort may change their values as they age, perhaps as a function of their life experiences or their changing physical state. Cross-sectional comparisons of people at a single point in time cannot separate these effects.

Generational differences in aging also bring up the issue of the age span encompassed in the term “older adult.” Given that the age range within this segment of the population covers 30 years and ages 65 and older, the term does not accurately reflect the heterogeneity of the older adult population. Neugarten first coined the term “young-old,” the age group 55 to 75 years, to differentiate from the “old-old” those older adults who are younger, generally healthier, relatively free from traditional work and family responsibilities, and socially and politically active. So, the developmental spectrum of aging has enormous variation, and individuals may not place such emphasis on decreasing life expectancy until their later years of aging.

Yet another question lies in the role of differences between people at the individual level in shaping beliefs about preventive services. An aphorism familiar in geriatrics is that age is a useful predictor for groups but very poor for predicting individual outcomes.2 Hence, one might expect considerable variation in attitudes and opinions among older persons.

Just as gerontological and chronological age definitions distinguish clinical and lay perspectives of age, there are factors that differentiate clinical and lay perspectives of preventive services at the individual level as well. Clinicians characterize a preventive service by whether it avoids disease, identifies disease at early stages, or reduces the negative impact of an established disease. Patients may characterize preventive services using different qualities. For example, preventive services can differ by the patient’s anticipated effort and/or burden. Some preventive actions require considerable discomfort (e.g., colonoscopy); others are simple and relatively painless (e.g., immunizations); still others require sustained behavior change (e.g., diet). Other factors such as time, money, cultural beliefs, and pain can also influence an individual’s attitudes about and preferences for a preventive behavior.

This project was requested by the USPSTF because clinical preventive services are increasing in importance as the U.S. population ages. However, there are challenges in evaluating the evidence for preventive services in older adults and in applying the evidence to developing recommendations specific to older adults; perceived benefits and harms may differ from the general population due to decreasing life expectancy, increasing comorbidities, and competing causes of death in older adults. A specific challenge is determining when the net balance of perceived benefits and harms turns negative; that is, when do the harms begin to outweigh the benefits? One important consideration is how patient values affect the determination of benefits and harms of clinical preventive services.

Uncertainty is a critical issue facing patients and providers in deciding a course of action for prevention. There is uncertainty regarding the potential benefits and harms an older person may receive from any particular preventive service. There is also uncertainty regarding the place of a particular preventive service, or the array of preventive services, within the context of other health concerns older persons may face. Such uncertainty may arise from the physiology of aging, the presence of a single chronic illness or multiple conditions, or the risk for mortality. The presence of uncertainty amplifies the importance of understanding values and preferences, because those values and preferences may end up mattering more, potentially driving the choices in directions different from what would have transpired in the case of certainty.

To the extent that there is uncertainty regarding medical outcomes and variability in how people value different outcomes, there is a growing need for decisionmaking processes that are more attentive to the needs and values of the patient. Recent decades have witnessed a decided shift in the philosophy of care away from a model of professional dominance to one of patient-centeredness. 3 A hallmark of this approach is the concept of shared decisionmaking. Shared decisionmaking is viewed as vital when no particular course of action presents itself as a prevailing option.4

The enthusiasm for shared decisionmaking is worth closer examination. Although studies have shown that patients often make very different clinical decisions when given full exposure to the risks and benefits of alternative treatments for a given disease, it is not altogether clear just how much older patients want to be the locus of decisionmaking, or how well some can process complex information surrounding choices.

The aim of this review is to provide to the USPSTF a compendium of general information that can be used as a resource when the Task Force is deliberating recommendations on preventive care for older persons and the decision to engage or not engage in a preventive behavior.

## Key Questions

The following key questions are the basis for this review.

KQ 1 How do older adults value the potential benefits of primary and secondary clinical preventive services, including reductions in morbidity and mortality, improvements in quality of life, maintenance of independence, and functional ability? Does cognitive ability or functional limitation affect how older adults value the potential benefits?
KQ 2 What attitudes do older adults have about potential harms of clinical preventive services?
KQ 3 What value do older adults place on the receipt of clinical preventive services?
KQ 4 How do older adults understand the balance of risks and benefits from clinical preventive services?
KQ 5 How should clinicians engage in shared decisionmaking related to clinical preventive services in older adults?

## Conceptual Model

We approached the key questions through the rubric of shared decisionmaking, rather than through any particular psychological or behavioral model. Figure 1 provides a conceptual model that illustrates the flow of the key questions. The model acknowledges the overarching contextual factors that contribute to the development of individual preferences and attitudes, such as experience, individual attributes, information, and environmental factors. Essentially, the older adult has values, preferences, and attitudes toward preventive services and the outcomes and harms these preventive services may provide. The older adult, through cognitive processes, then develops a net balance of benefits and harms, in which a negative benefit is possible if the benefits are outweighed by the harms. These same values, preferences, and harms impact the desire for, and process of, shared decisionmaking with providers.

Figure 1 Conceptual Model

Figure 1 provides a conceptual model that illustrates the flow of the key questions. The model acknowledges the overarching contextual factors that contribute to the development of individual preferences and attitudes, such as experience, individual attributes, information, and environmental factors. Essentially, the older adult has values, preferences, and attitudes toward preventive services and the outcomes and harms these preventive services may provide. The older adult, through cognitive processes, then develops a net balance of benefits and harms, in which a negative benefit is possible if the benefits are outweighed by the harms. These same values, preferences, and harms impact the desire for, and process of, shared decisionmaking with providers.

While at first the conceptual model would seem to neatly fit into a strictly rational cognitive model of decisionmaking, it should be noted that decisions are not made in a vacuum, and contextual factors can impact the decision process at any time point. Likewise, nonrational processes, such as affective responses, social cues, and habits, may also come to bear in decisionmaking. Older adults will also have attitudes about the uncertainties themselves that are inherent in the decisionmaking process.

## Scope of the Review

It is important to note that the focus of this review is on the perceptions, values, preferences, and attitudes of older adults about prevention. This review does not address the evidence for the effectiveness of the preventive services. The population of interest is community-dwelling adults ages 65 years and older. The review does not examine issues around advanced directives or end of life care.

### Clinical Preventive Services of Interest

No preventive service was specifically excluded from the review. The USPSTF recommendations for screening and prevention in older people provided the basis for the report focus. These include counseling for tobacco use, healthy diet and exercise, aspirin therapy for people at increased risk for coronary heart disease, lipid management and hypertension management for at-risk patients, ultrasonography for abdominal aortic aneurysm, and screening programs for mammography, colorectal cancer, diabetes, and osteoporosis. The topics addressed cover a wide range of activities. Some involve single actions; others require sustained patterns of behavior.

While attending to the USPSTF’s concerns for prevention for older adults, we also did not specifically exclude any particular primary or secondary prevention service. We included as services of interest preventive services recommended by the American Geriatric Society, including screening for depression, fall risk, obesity, alcohol abuse, skin cancer, hearing and vision impairment, elevated serum c-reactive protein in persons with coronary artery disease risk factors, cognitive impairment, glaucoma, abnormal thyroid stimulating hormone levels in women, and daily multivitamin use.31

### Concepts/Topics of Interest

The variables of interest are an individual’s attitudes, values, and preferences for outcomes related to preventive care. Preferences in health services imply a summary evaluation of the desirability of an object and are analogous to the concepts of “utility” in economics and “attitude” in psychology. Preferences themselves are also usually relative, in that one prefers something over something else. How older individuals establish preferences for health outcomes for potential utilization of clinical preventive services is influenced by their personal health priorities and lifestyle goals, their beliefs regarding their risk for developing a particular health condition, and the mental models they hold for both the condition in question and their personal definition of “successful aging.” Though each individual assigns personal meaning to the notion of successful aging, definitions are multifaceted and encompass features such as good physical, psychological, social, and functional health and life satisfaction (see Chapter 4 for further discussion). Therefore, we included improved health states as a potential benefit, risk for unnecessary treatment as a potential harm, the psychological benefit of receiving an “all clear” signal after screening, and the cost of anxiety as potential outcomes of interest. We did not focus on preferences for the actual services, such as whether patients prefer colonoscopy or fecal occult blood tests for colon cancer screening.

Primary and secondary prevention differ on a number of dimensions, such as purpose and how the preventive services are engaged in over time. These differences could have implications for the value associated with the behaviors in these categories. Accordingly, we distinguish between primary and secondary preventive behaviors in the discussion of each key question.

Primary prevention is defined as prevention aimed at avoiding developing a disease. The use of drug therapy to control identified risk factors for a disease in order to prevent the disease from occurring, such as hypertension or lipid management drug therapy to prevent cardiovascular disease, is also classified as primary prevention for the purposes of this report. Secondary prevention is defined as the early detection of a disease before signs or symptoms are evident.

## Organization of the Report

We follow the introduction with a brief section on the methods used to locate and evaluate relevant literature. Results of the literature searches are broken into two chapters. Chapter 2 covers the first four key questions and the literature regarding values and preferences for perceived benefits, harms, and preventive services. Chapter 3 covers the last key question and the literature regarding shared decisionmaking. Each of these chapters begins with the empirical literature available to directly answer the key questions, and follows with a discussion of related theories and issues. These discussions are intended to help expand the reader’s conceptual understanding of the topic and provide a possible starting place for a conceptual framework. The discussion is not meant to be, and indeed cannot be, exhaustive. Our goal is to stimulate curiosity about the larger context of values and decisionmaking, introduce important concepts, and raise questions regarding the limitations of some commonly held views.

## Methods

### Search Process

Our search process varied from a traditional systematic literature review process, as literature databases are not well indexed for “soft” topics such as values and preferences. We also noted during exploratory literature searches a paucity of studies specifically designed to address the key questions. We therefore augmented traditional search practices with multiple, iterative searches of the literature as material was reviewed and possible new search courses were suggested.

We included both electronic and manual searches. Electronic searches were conducted in the standard health and health behavior databases of MEDLINE, the Cumulative Index to Nursing and Allied Health Literature, PsychINFO, and the Cochrane Database of Systematic Reviews. We also searched EconLit for relevant behavioral economic literature on preferences and decisionmaking. Supplemental hand searches were conducted from article references and grey literature searches were independently carried out via the Internet.

Traditional search strings that rely on MeSH terms are neither sensitive nor specific for the topic of interest. For example, one related systematic review with highly focused, testable key questions had a documented hit ratio of approximately 1 out of 20,000 articles. Rather, we used key words which reflected the psychosocial and behavioral economic categories that best captured the topic content, including such terms as “preferences” or “lay understanding.” We also used search terms that captured qualitative research techniques, such as “focus group” or “interview,” to check for literature that described held beliefs, values, and preferences. We explored the literature through MeSH terms, such as “health behaviors,” “attitude to health,” and “patient acceptance of health care.” Key question 5 required search terms that captured the patient/provider relationship and processes involved in shared decisionmaking, such as “choice behavior,” “patient/provider relationship,” and “shared decisionmaking.” The literature was focused with MeSH terms that identified primary and secondary prevention (“primary prevention,” “preventive medicine,” “mass screening,” “geriatric assessment,” “preventive health service”) and limited to “English language,” “human,” and “ages 65 and older.” We were specifically instructed not to examine literature on younger groups with the intent of extrapolating the findings to older persons.

Traditional inclusion/exclusion criteria used in a linear deductive screening method were not appropriate for this project. We instead ran multiple iterations of literature screening, abstracting, and new searches using new potential key words derived from the literature to make use of both inductive and deductive reasoning. We also identified longitudinal studies on aging and national panel surveys that would allow for examining differences in attitudes and preferences based on age, and searched the literature for any related articles. Articles were also contributed from personal files of the authors, members of the Technical Expert Panel, and other experts in the field who were invited to identify relevant literature. Articles were not excluded based on country or setting. The retained literature was transferred to an EndNote library, where it was maintained and screened for duplication. Literature searches were conducted from inception of the database to between mid-October 2009 and March 2010.

### Article Assessment and Applicability

Wide ranges of study designs that used either quantitative or qualitative methods were included in the core literature because relevant randomized control trials and quasi-experimental studies were minimally available. Initial screening was based on a title and abstract review of the article. Further screening examined the research design, methodology, and the study population. Patient population inclusion criteria were community-dwelling adults aged 65 years and older. If there was no evidence that the mean age distribution was sufficiently over 65 years, the article was generally excluded. However, this eligibility criterion was used more loosely as a guideline rather than a strict decision rule, due to the nature of the report. A select few articles were passed to the full team for discussion if the report included an interesting finding or perspective. Researchers separately reviewed and rated the literature.

Literature examining the topic of self-care that focused on disease self-management was excluded. The topic of adherence to treatment or disease management programs among older adults was also excluded. Finally, the topic of care seeking was excluded due to the reactive rather than preventive nature of the research.

Researchers independently abstracted the literature for information regarding relevant study objectives, design, population, quality, and outcomes. The research team members met biweekly to review and revise the extraction and presentation of included articles in detailed evidence tables. Tables were organized by systematically comparable features.

Each study was rated for quality based on the research design, methodology, and the age of the study population as it applied to the key questions. At least two reviewers assessed the quality of all included studies.32,33 However, given the nature of the literature available to address how prevention is valued by older people, traditional measures of study quality proved difficult to apply. As such, no studies were excluded based on quality measures.

Articles with a high degree of applicability included those that met the age requirement and addressed decisional analysis concepts and factors influencing the decisionmaking process as a whole. Articles with a mean age distribution over 65 years that included younger age groups were also included, but applicability to older patient populations, particularly the oldest old patient, is unknown. We were unable to locate empirical literature to guide an understanding of what “adequate representation” of older persons would be to judge the applicability of the prevention literature.