# References

1 Cruickshanks KJ, Wiley TL, Tweed TS, et al. Prevalence of hearing loss in older adults in Beaver Dam, Wisconsin. The Epidemiology of Hearing Loss Study. Am J Epidemiol. 1998;148(9):879-886. [pmid: 9801018].
2 Dalton DS, Cruickshanks KJ, Klein BE, Klein R, Wiley TL, Nondahl DM. The impact of hearing loss on quality of life in older adults. Gerontologist. 2003;43(5):661-668. [pmid: 14570962].
3 Gates GA, Cooper JC Jr, Kannel WB, Miller NJ. Hearing in the elderly: the Framingham cohort, 1983–1985, part I: basic audiometric test results. Ear Hear. 1990;11(4):247-256. [pmid: 2210098].
4 Reuben DB, Walsh K, Moore AA, Damesyn M, Greendale GA. Hearing loss in community-dwelling older persons: national prevalence data and identification using simple questions. J Am Geriatr Soc. 1998;46(8):1008-1011. [pmid: 9706892].
5 Wallhagen MI, Strawbridge WJ, Cohen RD, Kaplan GA. An increasing prevalence of hearing impairment and associated risk factors over three decades of the Alameda County Study. Am J Public Health. 1997;87(3):440-442. [pmid: 9096550].
6 U.S. Preventive Services Task Force. Screening for hearing impairment in older adults, Guide to Clinical Preventive Services. 2nd. Washington, DC. Department of Health and Human Services. 1996:393-405.
7 Yueh B, Shapiro N, MacLean CH, Shekelle PG. Screening and management of adult hearing loss in primary care: scientific review. JAMA. 2003;289(15):1976-1985. [pmid: 12697801].
8 Bagai A, Thavendiranathan P, Detsky A. Does this patient have hearing impairment?. JAMA. 2006;295(4):416-428. [pmid: 16434632].
9 Ventry IM, Weinstein BE. Identification of elderly people with hearing problems. ASHA. 1983;25(7):37-42. [pmid: 6626295].
10 Clark JG. Uses and abuses of hearing loss classification. ASHA. 1984;23:493-500. [pmid: 7052898].
11 Goldstein D. Hearing impairment, hearing aids and audiology. ASHA. 1984;26:24-35. [pmid: 6487402].
12 Gates GA, Mills JH. Presbycusis. Lancet. 2005;366(9491):1111-1120. [pmid: 16182900].
13 Mulrow CD, Aguilar C, Endicott JE, et al. Quality-of-life changes and hearing impairment: a randomized trial. Ann Intern Med. 1990;113(3):188-194. [pmid: 2197909].
14 Weinstein BE, Ventry IM. Hearing impairment and social isolation in the elderly. J Speech Hear Res. 1982;25(4):593-599. [pmid: 7162161].
15 Carabellese C, Appollonio I, Rozzini R, et al. Sensory impairment and quality of life in a community elderly population. J Am Geriatr Soc. 1993;41(4):401-407. [pmid: 8463527].
16 Mulrow CD, Lichtenstein MJ. Screening for hearing impairment in the elderly: rationale and strategy. J Gen Int Med. 1991;6(3):249-258.
17 McMahon CM, Kifley A, Rochtchina E, Newall P, Mitchell P. The contribution of family history to hearing loss in an older population. Ear Hear. 2008;29(4):578-584. [pmid: 18469720].
18 Brant LJ, Gordon-Salant S, Pearson JD, et al. Risk factors related to age-associated hearing loss in the speech frequencies. J Am Acad Audiol. 1996;7(3):152-160. [pmid: 8780987].
19 Cruickshanks KJ, Klein R, Klein BE, Wiley TL, Nondahl DM, Tweed TS. Cigarette smoking and hearing loss: the epidemiology of hearing loss study. JAMA. 1998;279(21):1715-1719. [pmid: 9624024].
20 Cruickshanks KJ, Tweed TS, Wiley TL, et al. The 5-year incidence and progression of hearing loss: the epidemiology of hearing loss study. Arch Otolaryngol Head Neck Surg. 2003;129(10):1041-1046. [pmid: 14568784].
21 Agrawal Y, Platz EA, Niparko JK. Prevalence of hearing loss and differences by demographic characteristics among US adults: data from the National Health and Nutrition Examination Survey, 1999–2004. Arch Intern Med. 2008;168(14):1522-1530. [pmid: 18663164].
22 McBride WS, Mulrow CD, Aguilar C, Tuley MR. Methods for screening for hearing loss in older adults. Am J Med Sci. 1994;307(1):40-42. [pmid: 8291505].
23 Cook JA, Hawkins DB. Hearing loss and hearing aid treatment options. Mayo Clin Proc. 2006;81(2):234-237. [pmid: 16471079].
24 Gussekloo J, de Bont LE, von Faber M, et al. Auditory rehabilitation of older people from the general population—the Leiden 85-plus study. Br J Gen Pract. 2003;53(492):536-540. [pmid: 14694666].
25 Popelka MM, Cruickshanks KJ, Wiley TL, Tweed TS, Klein BE, Klein R. Low prevalence of hearing aid use among older adults with hearing loss: the Epidemiology of Hearing Loss Study. J Am Geriatr Soc. 1998;46(9):1075-1078. [pmid: 9736098].
26 Bogardus ST Jr, Yueh B, Shekelle PG. Screening and management of adult hearing loss in primary care: clinical applications. JAMA. 2003;289(15):1986-1990. [pmid: 12697802].
27 Danhauer JL, Celani KE, Johnson CE. Use of a hearing and balance screening survey with local primary care physicians. Am J Audiol. 2008;17(1):3-13. [pmid: 18519575].
28 Cohen SM, Labadie RF, Haynes DS. Primary care approach to hearing loss: the hidden disability. Ear Nose Throat J. 2005;84(1):26-31. [pmid: 15742769].
29 Johnson CE, Danhauer JL, Koch LL, Celani KE, Lopez IP, Williams VA. Hearing and balance screening and referrals for Medicare patients: a national survey of primary care physicians. J Am Acad Audiol. 2008;19(2):171-190. [pmid: 18669130].
30 American Speech-Language-Hearing Association. Hearing Screening and Testing. Rockville, MD. American Speech-Language-Hearing Association. 2011. Accessed at http://www.asha.org/public/hearing/Hearing-Testing/ on. 8. February. 2011.
31 American Academy of Family Physicians. Recommendations for Clinical Preventive Services: Hearing Difficulties. Leawood, KS. American Academy of Family Physicians. 1996. Accessed at http://www.aafp.org/online/en/home/clinical/exam/f-j.html on. 8. February. 2011.
32 American Academy of Audiology. Hearing Impairment in Aged People: Report of the Task Force on Hearing Impairment in Aged People. Reston, VA. American Academy of Audiology. 2011. Accessed at http://www.audiology.org/resources/documentlibrary/Pages/HearingImpairmentinAgedPeople.aspx on. 8. February. 2011.
33 Canadian Task Force on Preventive Health Care. Prevention of Hearing Impairment and Disability in the Elderly. Ottawa, ON. Canadian Task Force on Preventive Health Care. 1994. Accessed at http://www.canadiantaskforce.ca/_archive/index.html on. 8. February. 2011.
34 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
35 Leeflang MM, Deeks JJ, Gatsonis C, Bossuyt PM. Cochrane Diagnostic Test Accuracy Working Group. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149:889-897. [pmid: 19075208].
36 Yueh B, Collins MP, Souza PE, et al. Long-term effectiveness of screening for hearing loss: the Screening for Auditory Impairment—Which Hearing Assessment Test (SAI-WHAT) randomized trial. J Am Geriatr Soc. 2010;58:427-434. [pmid: 20398111].
37 Yueh B, Collins M, Souza P, Heagerty P, Loovis C, Hedrick S. Long-term effectiveness in a randomized trial of hearing loss screening. AAS Bulletin. 2005;30:31-32.
38 Yueh B, Collins MP, Souza PE, et al. Screening for Auditory Impairment—Which Hearing Assessment Test (SAI-WHAT): RCT design and baseline characteristics. Contemp Clin Trials. 2007;28(3):303-315. [pmid: 17030153].
39 Boatman DF, Miglioretti DL, Eberwein C, Alidoost M, Reich SG. How accurate are bedside hearing tests?. Neurology. 2007;68(16):1311-1314. [pmid: 17438223].
40 Eekhof JA, de Bock GH, de Laat JA, Dap R, Schaapveld K, Springer MP. The whispered voice: the best test for screening for hearing impairment in general practice?. Br J Gen Pract. 1996;46(409):473-474. [pmid: 8949327].
41 Macphee GJ, Crowther JA, McAlpine CH. A simple screening test for hearing impairment in elderly patients. Age Ageing. 1988;17(5):347-351. [pmid: 3068972].
42 Swan IR, Browning GG. The whispered voice as a screening test for hearing impairment. J R Coll Gen Pract. 1985;35(273):197. [pmid: 3989786].
43 Clark K, Sowers M, Wallace RB, Anderson C. The accuracy of self-reported hearing loss in women aged 60–85 years. Am J Epidemiol. 1991;134(7):704-708. [pmid: 1951276].
44 Nondahl DM, Cruickshanks KJ, Wiley TL, Tweed TS, Klein R, Klein BE. Accuracy of self-reported hearing loss. Audiology. 1998;37(5):295-301. [pmid: 9776206].
45 Sindhusake D, Mitchell P, Smith W, et al. Validation of self-reported hearing loss: the Blue Mountains Hearing Study. Int J Epidemiol. 2001;30(6):1371-1378. [pmid: 11821349].
46 Lichtenstein MJ, Bess FH, Logan SA. Validation of screening tools for identifying hearing-impaired elderly in primary care. JAMA. 1988;259(19):2875-2878. [pmid: 3285039].
47 Gates GA, Murphy M, Rees TS, Fraher A. Screening for handicapping hearing loss in the elderly. J Fam Pract. 2003;52(1):56-62. [pmid: 12540314].
48 Bienvenue GR, Michael PL, Chaffinch JC, Zeigler J. The AudioScope: a clinical tool for otoscopic and audiometric examination. Ear Hear. 1985;6(5):251-254. [pmid: 4054439].
49 Ciurlia-Guy E, Cashman M, Lewsen B. Identifying hearing loss and hearing handicap among chronic care elderly people. Gerontologist. 1993;33(5):644-649. [pmid: 8225009].
50 Frank T, Petersen DR. Accuracy of a 40 dB HL Audioscope and audiometer screening for adults. Ear Hear. 1987;8(3):180-183. [pmid: 3609515].
51 Koike KJ, Hurst MK, Wetmore SJ. Correlation between the American Academy of Otolaryngology-Head and Neck Surgery five-minute hearing test and standard audiologic data. Otolaryngol Head Neck Surg. 1994;111(5):625-632. [pmid: 7970802].
52 Rawool V, Keihl J. Perception of hearing status, communication, and hearing aids among socially active older individuals. J Otolaryngol. 2008;37(1):27-42.
53 Sever JC Jr, Harry DA, Rittenhouse TS. Using a self-assessment questionnaire to identify probable hearing loss among older adults. Percept Mot Skills. 1989;69(2):511-514. [pmid: 2813000].
54 Torre P, Moyer CJ, Haro NR. The accuracy of self-reported hearing loss in older Latino-American adults. Int J Audiol. 2006;45(10):559-562. [pmid: 17062497].
55 Voeks SK, Gallagher CM, Langer EH, Drinka PJ. Self-reported hearing difficulty and audiometric thresholds in nursing home residents. J Fam Pract. 1993;36(1):54-58. [pmid: 8419504].
56 Weinstein BE. Validity of a screening protocol for identifying elderly people with hearing problems. ASHA. 1986;28(5):41-45. [pmid: 3718608].
57 Yueh B, Souza PE, McDowell JA, et al. Randomized trial of amplification strategies. Arch Otolaryngol Head Neck Surg. 2001;127(10):1197-1204. [pmid: 11587599].
58 Jerger J, Chmiel R, Florin E, Pirozzolo F, Wilson N. Comparison of conventional amplification and an assistive listening device in elderly persons. Ear Hear. 1996;17(6):490-504. [pmid: 8979037].
59 Tolson D, Swan I, Knussen C. Hearing disability: a source of distress for older people and carers. Br J Nurs. 2002;11(15):1021-1025. [pmid: 12181509].
60 Ventry IM, Weinstein BE. The hearing handicap inventory for the elderly: a new tool. Ear Hear. 1982;3(3):128-134. [pmid: 7095321].
61 Mulrow CD, Tuley MR, Aguilar C. Sustained benefits of hearing aids. J Speech Hear Res. 1992;35(6):1402-1405. [pmid: 1494282].
62 Tuley MR, Mulrow CD, Aguilar C, Velez R. A critical reevaluation of the Quantified Denver Scale of Communication Function. Ear Hear. 1990;11(1):56-61. [pmid: 2307305].
63 Cox RM, Alexander GC. The abbreviated profile of hearing aid benefit. Ear Hear. 1995;16(2):176-186. [pmid: 7789669].
64 Kohan D, Sorin A, Marra S, Gottlieb M, Hoffman R. Surgical management of complications after hearing aid fitting. Laryngoscope. 2004;114(2):317-322. [pmid: 14755211].
65 Sood A, Taylor JS. Allergic contact dermatitis from hearing aid materials. Dermatitis. 2004;15(1):48-50. [pmid: 15573649].
66 Lear JT, Sandhu G, English JS. Hearing aid dermatitis: a study in 20 consecutive patients. Contact Dermatitis. 1998;38(4):212. [pmid: 9565294].
67 Macrae JH. Prediction of deterioration in hearing due to hearing aid use. J Speech Hear Res. 1991;34(3):661-670. [pmid: 2072691].
68 Browning GG, Swan IR, Chew KK. Clinical role of informal tests of hearing. J Laryngol Otol. 1989;103(1):7-11. [pmid: 2646384].
69 Wiley TL, Cruickshanks KJ, Nondahl DM, Tweed TS. Self-reported hearing handicap and audiometric measures in older adults. J Am Acad Audiol. 2000;11(2):67-75. [pmid: 10685672].
70 Abyad A. Screening for hearing loss in the elderly. Geriatrics Today. 2004;7(2):43-45.
71 Wu HY, Chin JJ, Tong HM. Screening for hearing impairment in a cohort of elderly patients attending a hospital geriatric medicine service. Singapore Med J. 2004;45(2):79-84. [pmid: 14985847].
72 Leong ST, Laortanakul P. Monitoring and assessment of daily exposure of roadside workers to traffic noise levels in an Asian city: a case study of Bangkok streets. Environ Monit Assess. 2003;85(1):69-85. [pmid: 12807257].
73 Garstecki DC, Erler SF. Hearing loss, control, and demographic factors influencing hearing aid use among older adults. J Speech Lang Hear Res. 1998;41(3):527-537. [pmid: 9638919].
74 Davis A, Smith P, Ferguson M, Stephens D, Gianopoulos I. Acceptability, benefit and costs of early screening for hearing disability: a study of potential screening tests and models. Health Technol Assess. 2007;11(42):1-294.
75 Collins MP, Souza PE, Liu CF, Heagerty PJ, Amtmann D, Yueh B. Hearing aid effectiveness after aural rehabilitation–individual versus group (HEARING) trial: RCT design and baseline characteristics. BMC Health Serv Res. 2009;9:233. [pmid: 20003515].