# Discussions

## Summary of Review Findings

Results of this evidence synthesis organized by KQ are summarized in Table 7

Table 7 Summary of Evidence

Number of studies, Overall quality rating | Limitations | Consistency | Primary care applicability | Summary of findings
KQ 1. Does screening for hearing loss in asymptomatic adults ages 50 years and older lead to improved health outcomes?
1 RCT Overall quality: Fair | One large (n=2305), fair-quality trial of screening versus no screening in a VA setting in patients with a high prevalence of perceived hearing loss. High loss to follow-up. | N/A (1 study) | Low-moderate | One trial found that screening with HHIE-S, AudioScope, or both was associated with greater hearing aid use at 1 year compared with no screening. Effects of screening on hearing aid use appeared to be limited to patients with perceived hearing loss at baseline. Screening was not associated with any differences in hearing-related quality of life compared with no screening. Because 3/4 of patients enrolled in the trial reported perceived hearing loss and all patients were eligible to receive free hearing aids, results are likely to be most generalizable to high-prevalence settings in which the cost of hearing aids is not a barrier.
KQ 2. How accurate are the methods for hearing loss screening in older adults?
20 studies total 4 Clinical test 8 Single question 9 Questionnaires 6 AudioScope Overall quality: Good | Most studies conducted in specialty or other high-prevalence settings. Differences between studies in how hearing loss was defined and in screening cutoffs used. | Consistent | Moderate | For detection of >25 or >30 dB hearing loss, four studies (one good-quality) found that the whispered voice test at 2 feet was associated with a median PLR of 5.1 (range, 2.3 to 7.4) and median NLR of 0.03 (range, 0.007 to 0.73). For detection of >25 dB hearing loss, six studies (four good-quality) found that a single question screening was associated with a median PLR of 3.0 (range, 2.4 to 3.8) and median NLR of 0.40 (range, 0.33 to 0.82), and four good-quality studies found that the HHIE-S (based on a cutoff score of 8) was associated with a median PLR of 3.5 (range, 2.4 to 11) and median NLR of 0.52 (range, 0.43 to 0.70). For detection of >40 dB hearing loss, three studies (two good-quality) found that the AudioScope (based on ability to hear tones between 500 and 4000 Hz at 40 dB) was associated with a median PLR of 3.4 (range, 1.7 to 4.9) and median NLR of 0.05 (range, 0.03 to 0.08).
KQ 3. How efficacious is the treatment of screening-detected hearing loss in improving health outcomes?
4 RCTs Overall quality: Fair | Only one good-quality trial of hearing aids versus no hearing aids, conducted in a VA setting in patients eligible for free hearing aids. | Consistent | Low-moderate | One good-quality RCT found that immediate hearing aid use was associated with moderate improvements in hearing-specific quality of life and communication difficulties compared with wait-list control in veterans with hearing loss >40 dB who are eligible for free hearing aids. A smaller, fair-quality RCT found no clear difference between an assistive listening device and no treatment in veterans ineligible for free hearing aids. Another fair-quality RCT found no difference between a hearing aid, an assistive listening device, or both compared with no amplification in a subgroup of patients not using hearing aids at enrollment with mild baseline hearing loss and hearing-related handicap. A fourth RCT of hearing aids versus no hearing aids reported outcomes very poorly.
KQ 4. What are the adverse effects of screening for hearing loss in adults ages 50 years and older?
No studies | No studies | N/A | N/A | No RCTs or controlled observational studies were found. Harms of hearing loss screening are unlikely to be greater than small or minimal due to the non-invasive nature of screening, confirmatory testing, and treatments.
KQ 5. What are the adverse effects of treatment of screening-detected hearing loss in adults ages 50 years and older?
No studies | No studies | N/A | N/A | No RCTs or controlled observational studies were found. Hearing aids are unlikely to be associated with serious harms, though there are reports of dermatitis, otitis externa, cerumen impaction, and other complications associated with their use.

Abbreviations: HHIE-S = Hearing Handicap Inventory for the Elderly-Screening; KQ = key question; N/A = not applicable; NLR = negative likelihood ratio; PLR = positive likelihood ratio; RCT = randomized controlled trial; VA = U.S. Department of Veteran Affairs.

SAI-WHAT is the only study that compared screening with no screening.36 Although hearing aid use was higher after 1 year with screening, there was no difference in the likelihood of experiencing a clinically important improvement in hearing-related function. Interpretation of SAI-WHAT is critically dependent on whether hearing aid use is an acceptable surrogate marker for hearing-related quality of life and functional outcomes. Hearing aid use at 1 year was less than 10 percent in all arms of SAI-WHAT, and the trial was not powered to assess improvements in hearing-related function. Nonetheless, over one third of patients (screened or unscreened) in SAI-WHAT experienced a clinically significant improvement in hearing-related function, suggesting that factors other than hearing aid use may affect functional outcomes. SAI-WHAT also restricted enrollment to veterans eligible for free hearing aids, three quarters of whom reported perceived hearing loss. Therefore, results are likely to be most applicable to populations with a high prevalence of perceived hearing loss, in settings where treatment cost is not a barrier.

There is good evidence from 20 studies of diagnostic accuracy that common screening tests for hearing loss are useful for identifying patients at higher risk for hearing loss. One challenge in interpreting studies of diagnostic accuracy is that studies used different thresholds and criteria to define hearing loss. The clinical relevance of detection of mild (25 to 40 dB) hearing loss as it pertains to effectiveness of screening is also uncertain, as the only trial showing benefits of hearing aids enrolled patients with screening-detected >40 dB hearing loss.13 Relatively simple tests, such as the whispered voice at 2 feet and a single question regarding perceived hearing loss, appear to be nearly as accurate compared with a more detailed hearing loss questionnaire or a handheld audiometric device for detecting hearing loss. A negative screening result based on a handheld audiometric device may be particularly useful for ruling out >40 dB hearing loss. Choices regarding which screening test to use may also depend in part on factors other than diagnostic accuracy, such as cost or convenience. For the whisper test, an important consideration is the need for clinicians to administer the test in a standardized and consistent fashion (such as the method described in published studies of diagnostic accuracy).39 Although the finger rub and watch tick tests may be easier to standardize, more studies are needed to clarify their diagnostic accuracy, as both were only evaluated in one study.39

Our conclusions regarding diagnostic accuracy are generally in accord with another recently published systematic review.8 That systematic review estimated stronger likelihood ratios for the whispered voice test, largely because it was conducted before the publication of a recent, good-quality study39 that reported substantially weaker estimates. The other review also pooled likelihood ratio estimates, included studies2, 68, 69 that analyzed the same populations reported in other studies,42, 44 included studies less applicable to U.S. primary care settings (e.g., studies of nursing home patients in Lebanon or Singapore),70, 71 and did not include studies that we deemed relevant.47, 52 For the whispered voice test, the other review calculated a pooled PLR of 6.1 (95% CI, 4.5 to 8.4) and NLR of 0.03 (95% CI, 0 to 0.24); for the single question screening, a pooled PLR of 2.5 (95% CI, 1.7 to 3.6) and NLR of 0.13 (95% CI, 0.09 to 0.19); for the HHIE-S (with a cutoff score >8), a pooled PLR of 3.8 (95% CI, 3.0 to 4.8) and NLR of 0.38 (95% CI, 0.29 to 0.51); and for the AudioScope, a pooled PLR of 2.4 (95% CI, 1.4 to 4.1) and NLR of 0.07 (95% CI, 0.03 to 0.17).8

Evidence on the efficacy of treatments for screening-detected hearing loss is limited. One good-quality RCT found that hearing aids resulted in near normalization of hearing-related quality of life and function in a subgroup of patients identified by screening, based on >40 dB hearing loss using a handheld audiometric device.13, 61 Because this trial was conducted in a VA center and almost exclusively enrolled white males, its generalizability to other settings may be limited. Two fair-quality RCTs found no clear differences in hearing-related quality of life or function between amplification and no treatment in patients with milder baseline hearing loss.57, 58

We did not find direct evidence on harms of screening or treatments with hearing aids. In community-based and primary care populations, rates of false-positive results from screening for >25 dB hearing loss ranged from 5 to 41 percent,43-47 depending on the screening test and population evaluated. However, harms of screening are likely to be minimal because screening is non-invasive, the reference standard (audiometric testing) is also non-invasive, and treatment with hearing aids is not known to be associated with serious adverse events. No study has validated the hypothesis that hearing aid use might lead to further hearing deterioration in those with severe to profound hearing loss because of the increased amplification required (the intensity level of sound rises by a factor of 10 for each additional decibel of amplification).67

## Contextual Issues

Several contextual issues could help inform the interpretation of the findings of this evidence review.

### Does Adherence to Hearing Aid Use Improve Health Outcomes in Screened Asymptomatic Adults Who are Prescribed Hearing Aids?

Older adults with hearing loss may not adhere to hearing aid use for cosmetic or psychosocial reasons, because of difficulty using the hearing aids, discomfort, cost, or perceived lack of benefit. In large population-based cohort studies, among the approximately one-third of older adults with hearing loss who had ever used hearing aids, 20 to 30 percent were no longer using them.1, 3 Despite the high rate of non-use or non-adherence to hearing aids, evidence showing that increased adherence improves health outcomes is limited. In one randomized trial, more hours per day of hearing aid use was positively correlated with greater improvements in HHIE (but not QDS) scores.13

### Are there Characteristics that can Predict Adherence to Hearing Aid Use Among Screened Populations?

Several observational studies have attempted to identify factors that predict adherence to hearing aid use. The large (n=1629) Beaver Dam population-based cohort study probably provides the best evidence.25 It found that among older adults (84 percent ages 60–92 years) who had ever had a hearing aid, factors associated with adherence were older age (age vs. age plus 5 years: adjusted OR, 1.2 [95% CI, 1.1 to 1.3]), more severe hearing loss (moderate loss vs. mild loss: adjusted OR, 5.0 [95% CI, 3.0 to 8.6]), better education (≥16 years of education vs. <12 years of education: adjusted OR, 3.2 [95% CI, 1.7 to 6.1]), lower word recognition scores (<80 vs. ≥90 percent: adjusted OR, 2.7 [95% CI, 1.6 to 4.4]), worse HHIE scores (>26 vs. 0: adjusted OR, 7.8 [95% CI, 3.1 to 19]), and self-reported hearing loss (presence vs. absence of self-reported loss: adjusted OR, 4.9 [95% CI, 2.0 to 12]). A smaller (n=131) observational study found non-statistically significant trends toward greater adherence among college-educated women with a higher income (>$40,000 per year) compared with women without a college education and/or lower income,73 though these factors did not predict adherence in men. A long-term retrospective cohort study found that among 116 participants who received hearing aids, 43 percent were still using their hearing aids 12 years later.74 Presence of hearing loss in the better ear (dB vs. dB plus 10: OR, 2.4 [95% CI, 1.4 to 3.8]) and presence of moderately severe tinnitus (presence vs. absence of moderately severe tinnitus: OR, 4.6 [95% CI, 1.6 to 13]) predicted adherence.

### Are there Treatments or Other Behavioral Interventions in Addition to Hearing Aid Use that Improve Health Outcomes in Adults with Hearing Loss?

We identified no studies on the effectiveness of behavioral interventions in addition to or instead of hearing aids to help patients cope with or manage hearing loss.

## Limitations

Our evidence review has some potential limitations. First, evidence was very limited for benefits and harms of screening and treatments for hearing loss, making it difficult to reach strong conclusions. Second, we excluded non-English language studies, which could introduce language bias, though we identified no relevant non-English language studies in literature searches or when searching reference lists. Third, a number of studies evaluated diagnostic accuracy of screening tests or programs in high-prevalence populations recruited from specialty settings, which could limit the generalizability to primary care settings. Finally, we did not attempt to construct outcomes tables due to the lack of sufficient direct or indirect evidence to reliably estimate benefits and harms.

## Emerging Issues

We found no ongoing trials of screening for hearing loss or trials of hearing aids versus no treatment in searches of [underlined: www.clinicaltrials.gov] or the Computer Retrieval of Information on Scientific Projects database of federally funded research. One trial on effectiveness of group versus individual fitting of hearing aids and group versus individualized follow-up has completed recruitment and reported baseline characteristics of participants, but results are not yet available.75

## Future Research

Further research is needed to understand the potential benefits of screening and treatment for hearing loss in older individuals. Additional research is needed on the effectiveness of screening in typical primary care settings, the optimal age at which to start screening, and the severity of hearing loss that is likely to benefit from hearing aids, in order to help define optimal screening test thresholds and methods. In addition, RCTs to test the efficacy of hearing aids (including more effective or usable designs) or other interventions in improving health, function, and quality of life outcomes should be carried out in patients with screening-detected hearing loss who are representative of those seen in typical primary care settings. Particular efforts should be made to enroll patients with comorbid clinical conditions such as depression or cognitive dysfunction that may be associated with or exacerbated by hearing loss.13 Because effectiveness of any hearing screening strategy will depend on how likely those who might benefit from hearing aids are to actually use them, research is needed on effective methods for enhancing follow-up rates and uptake of recommended treatment following screening.

## Conclusions

Additional research is needed to understand effects on health outcomes of screening adults ages 50 years and older for hearing loss compared with no screening, and to confirm benefits of treatment under conditions likely to be encountered in most primary care settings.