# Results

## Key Question 1 Does Screening for Hearing Loss in Asymptomatic Adults Ages 50 Years and Older Lead to Improved Health Outcomes?

### Summary

One trial found that screening with the HHIE-S, the AudioScope, or both was associated with greater hearing aid use at 1 year compared with no screening.36 Effects of screening on hearing aid use appeared to be limited to patients with perceived hearing loss at baseline. Screening was not associated with any differences in hearing-related quality of life compared with no screening. Because three quarters of patients enrolled in the trial reported perceived hearing loss at baseline and all patients were eligible to receive free hearing aids, results are likely to be most generalizable to high-prevalence settings in which the cost of hearing aids is not a barrier.

### Evidence

We identified one randomized trial of screening for hearing loss (Table 1, Appendix B1 and Appendix B2).36 Aspects of this trial were also described in a preliminary abstract37 and in an article describing its study design, baseline characteristics, and rates of positive screening results.38 We rated the Screening for Auditory Impairment—Which Hearing Assessment Test (SAI-WHAT) trial as fair quality primarily because of high loss to follow-up and unclear blinding status of outcomes assessors.36 The trial compared three different screening strategies (the AudioScope, based on inability to hear a 40 dB tone at 2000 Hz in either ear; the HHIE-S, based on a score ≥10; or the AudioScope plus the HHIE-S) versus usual care without screening in 2305 predominantly (94 percent) male patients ages 50 years and older (mean age, 61 years) at a Department of Veteran Affairs (VA) Medical Center. Some study design factors could limit the applicability of the SAI-WHAT trial to screening in other primary care settings. Specifically, all participants in the trial were eligible to receive free VA-issued hearing aids. In addition, about three quarters of patients reported perceived hearing loss at enrollment (based on the question, “Do you think you have hearing loss?”).

Table 1 Randomized Controlled Trials of Screening and Treatment

Study, year | Country & Setting | Population | Main outcomes | Quality score
Screening
Yueh et al, 2010^36^ | US VA primary care clinics | Mean age: 61 years Sex: 94% male Mean baseline hearing loss: NR | [underlined: Screening with AudioScope vs. HHIE-S questionnaire vs. both vs. no screening, results at 1 year] Hearing aid use: 6.3% vs. 4.1% vs. 7.4% vs. 3.3% (p=0.003) ≥6-point improvement on the Inner Effectiveness of Aural Rehabilitation Scale: 40% vs. 36% vs. 40% vs. 36% (p=0.39) | Fair
Treatment
Jerger et al, 1996^58^ | US Setting not reported | Mean age: 74 years Sex: 63% male Mean pure-tone threshold: 37 dB^*^ Mean baseline HHIE-S score: 30 | [underlined: Hearing aid vs. assistive listening device vs. both vs. no amplification, mean score at 6 weeks] HHIE-S: 25 vs. 27 vs. 26 vs. 28 (p>0.05 for any intervention vs. no amplification) Speech perception in noise: 53% vs. 75% vs. 71% vs. 42% (p<0.05 for any intervention vs. no amplification) Brief Symptom Inventory, Activity Scale, Life Satisfaction in the Elderly Scale, Affect Balance Scale: no differences between interventions (data NR) | Fair
Mulrow et al, 1990^13^ | US VA primary care clinic | Mean age: 72 years Sex: 99% male Race: 97% white Mean pure-tone threshold, better ear: 52 dB^*^ Mean baseline HHIE-S score: 50 | [underlined: Immediate hearing aid vs. wait list, mean score at 4 months (mean difference in change from baseline)] HHIE-S: 15 vs. 51 (34 [95% CI, 27 to 41]; p<0.001) Quantified Denver Scale: 36 vs. 62 (24 [95% CI, 17 to 31]; p<0.001) Short Portable Mental Status Questionnaire: 0.29 vs. 0.28 (0.28 [95% CI, 0.08 to 0.48]; p=0.008) Geriatric Depression Scale: 2.6 vs. 3.8 (0.80 [95% CI, 0.09 to 1.5]; p=0.03) Self Evaluation of Life Function: 92 vs. 97 (1.9 [95% CI, -1.6 to 5.4]; p=0.27) | Good
Tolson et al, 2002^59^ | UK General practice clinic attendees | Mean age: 77 years Sex: 23% male Other baseline characteristics: NR | [underlined: Hearing aid vs. no hearing aid, results at 6 months] Data for Mini Mental State Examination, Geriatric Depression Scale, Malaise Inventory (caregiver), Family Relationship Index, and 14-item caregiver's assessment of hearing difficulties NR; authors state “depression scores were unchanged at 6-month follow-up” in the intervention group | Poor
Yueh et al, 2001^57^ | US VA audiology clinic | Mean age: 68 years Sex: 100% male Race: NR Mean pure-tone threshold, right ear: 33 dB Mean pure-tone threshold, left ear: 32 dB Mean baseline HHIE-S score: 28 vs. 35 (assistive listening device vs. no treatment); 50 vs. 36 (programmable vs. standard hearing aid) | [underlined: Assistive listening device vs. no treatment, mean change from baseline at 3 months] HHIE-S: 4.4 vs. 2.2 Abbreviated Profile of Hearing Aid Benefit: 6.4 vs. 2.7 Revised Quantified Denver Scale: 0.03 vs. -0.05 Proportion reporting less social isolation: 0/15 (0%) vs. 0/15 (0%) [underlined: Programmable hearing aid vs. standard hearing aid, mean change from baseline at 3 months] HHIE-S: 31 vs. 17 (p<0.05) Abbreviated Profile of Hearing Aid Benefit: 16 vs. 7.7 Revised Quantified Denver Scale: 0.84 vs. 0.70 Proportion reporting less social isolation: 10/16 (62%) vs 2/14 (14%) | Fair

* Average of 1000, 2000, and 4000 Hz hearing levels.

Abbreviations: CI = confidence interval; HHIE-S = Hearing Handicap Inventory for the Elderly-Screening; NR = not reported; UK = United Kingdom; US = United States; VA = Veterans Administration.

Rates of positive screening results were 19 percent in the AudioScope arm, 59 percent in the HHIE-S arm, and 64 percent in the combined arm. Hearing aid use at 1 year, the primary outcome, was 6.3 percent in the AudioScope arm, 4.1 percent in the HHIE-S arm, 7.4 percent in the combined arm, and 3.3 percent in the control arm (p=0.03). In a post-hoc stratified analysis, hearing aid use was greater among patients with perceived hearing loss (5.7 to 9.6 percent in screened arms vs. 4.4 percent in control arm), but among those without perceived hearing loss, hearing aid use was minimal regardless of screening status (0 to 1.6 percent).

There was no difference in the proportion of patients that experienced a minimum clinically important difference (≥6 points of improvement on a 0 to 100 scale) on the Inner Effectiveness of Aural Rehabilitation scale (a measure of hearing-related function), a secondary outcome of the trial, at 1 year (36 to 40 percent in the screened arms vs. 36 percent in the control arm; p=0.39). In post-hoc analyses, there were also no differences in the proportion that experienced improvement in hearing-related function when patients were stratified according to whether they had perceived hearing loss at baseline, except in a subgroup that was also ages 65 years and older (54 percent in the AudioScope arm, 34 percent in the HHIE-S arm, 40 percent in the combined arm, and 34 percent in the control arm).

## Key Question 2 How Accurate are the Methods for Screening for Hearing Loss in Older Adults?

### Summary

Twenty studies evaluated the diagnostic accuracy of clinical tests, a single question, a questionnaire, or a handheld audiometric device for identification of hearing loss in older adults. For detection of >25 or >30 dB hearing loss, four studies (one good-quality) found that the whispered voice test at 2 feet was associated with a median positive likelihood ratio (PLR) of 5.1 (range, 2.3 to 7.4) and median negative likelihood ratio (NLR) of 0.03 (range, 0.007 to 0.73).39-42 For detection of >25 dB hearing loss, six studies (four good-quality) found that a single question was associated with a median PLR of 3.0 (range, 2.4 to 3.8) and median NLR of 0.40 (range, 0.33 to 0.82),39, 43-45 and four good-quality studies22, 44-46 found that the HHIE-S (based on a cutoff score of 8) was associated with a median PLR of 3.5 (range, 2.4 to 11) and median NLR of 0.52 (range, 0.43 to 0.70). Likelihood ratio estimates were similar for detection of >40 dB hearing loss. For detection of >40 dB hearing loss, three studies (two good-quality) found that the AudioScope (based on ability to hear tones between 500 and 4000 Hz at 40 dB) was associated with a median PLR of 3.4 (range, 1.7 to 4.9) and median NLR of 0.05 (range, 0.03 to 0.08).22, 40, 46

In direct comparisons, one good-quality study found that the watch tick and finger rub tests were associated with similar NLRs but substantially stronger PLRs compared with the whispered voice test or a single screening question.39 Three studies showed a consistent trade-off between lower sensitivity and higher specificity for the HHIE-S compared with a single screening question, resulting in somewhat stronger PLRs and weaker NLRs.39, 44, 45, 47 Two studies found that the AudioScope was associated with stronger NLRs compared with the HHIE-S, with relatively small differences in PLR estimates.22, 46

### Evidence

Twenty studies evaluated the diagnostic accuracy of various screening tests against a reference standard (usually pure-tone audiometry) for identification of hearing loss in older adults.9, 22, 39-56 Four studies evaluated clinical tests (Table 2, Appendix B3),39-42 eight evaluated a single question (Table 3, Appendix B4),39, 43-45, 47, 52, 54, 55 nine evaluated a hearing questionnaire (Table 4,Appendix B5),9, 22, 44-47, 51, 53, 56 and six evaluated a handheld audiometric device (Table 5,Appendix B6).22, 40, 46, 48-50 Four studies were population-based43-45, 47 and four22, 46, 53, 56 recruited patients from primary care or community-based settings. The remainder recruited patients from specialty (usually an audiology or otolaryngology clinic) or other high-prevalence settings, or evaluated older adults dwelling in nursing homes.49, 55

Table 2 Whispered Voice, Watch Tick, and Finger Rub Clinical Tests

Study, Year | Screening test, Definition of a positive screening exam | Definition of a case | Sensitivity (range) | Specificity (range) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Diagnostic odds ratio (95% CI) | Quality score
Boatman et al, 2007^39^ | Whispered voice at 2 feet Inability to repeat two or more words from two 3-word combinations | >25 dB hearing loss at 500, 1000, and 2000 Hz | 0.40 (0.32-0.49) | 0.82 (0.72-0.90) | 2.3 (1.3-3.8) | 0.73 (0.61-0.87) | 3.1 (1.5-6.6) | Good
Eekhof et al, 1996^40^ | Whispered voice at 2 feet Inability to repeat two or more combinations correctly | >30 dB hearing loss in either ear (frequency NR) | 0.90 (0.81-0.96) | 0.80 (0.67-0.90) | 4.6 (2.6-8.1) | 0.12 (0.06-0.24) | 39 (12-130) | Fair
Macphee et al, 1988^41^ | Whispered voice at 2 feet Inability to repeat one triplet set of numbers correctly or 50% of four sets of triplet numbers | >30 dB hearing loss at 500, 1000, and 2000 Hz | 1.0 (0.95-1.0) | 0.83 (0.70-0.93) | 5.7 (3.1-11) | 0.008 (0.0005-0.13) | 730 (41-12,950) | Fair
Swan et al, 1985^42^ | Whispered voice at 2 feet Unable to repeat at least three out of six letters or numerals correctly | >30 dB hearing loss at 500, 1000, and 2000 Hz | 1.0 (0.96-1.0) | 0.87 (0.79-0.93) | 7.4 (4.7-12) | 0.007 (0.0005-0.10) | 1140 (70-19,240) | Fair
| | Total | 0.95 (0.40-1.0) | 0.82 (0.80-0.87) | 5.1 (2.3-7.4) | 0.03 (0.007-0.73) | -- | --
Macphee et al, 1988^41^ | Whispered voice at 6 inches Inability to repeat one triplet set of numbers correctly or 50% of four sets of triplet numbers | >30 dB hearing loss at 500, 1000, and 2000 Hz | 0.74 (0.62-0.83) | 1.0 (0.93-1.0) | 72 (4.6-1140) | 0.27 (0.19-0.39) | 270 (16-4540) | Fair
Macphee et al, 1988^41^ | Conversation voice at 2 feet Inability to repeat one triplet set of numbers correctly or 50% of four sets of triplet numbers | >30 dB hearing loss at 500, 1000, and 2000 Hz | 0.47 (0.36-0.59) | 1.0 (0.93-1.0) | 46 (2.9-740) | 0.53 (0.43-0.66) | 87 (5.2-1470) | Fair
Boatman et al, 2007^39^ | Watch tick at 6 inches No response to two or more of six presentations of watch tick | >25 dB hearing loss at 500, 1000, and 2000 Hz | 0.44 (0.35-0.53) | 1.0 (0.95-1.0) | 70 (4.4-1120) | 0.57 (0.49-0.66) | 120 (7.5-2040) | Good
Boatman et al, 2007^39^ | Finger rub at 6 inches No response to two or more of six finger rubs | >25 dB hearing loss at 500, 1000, and 2000 Hz | 0.27 (0.19-0.35) | 0.98 (0.91-1.0) | 10 (2.6-43) | 0.75 (0.68-0.84) | 14 (3.4-120) | Good

Abbreviations: CI = confidence interval; NR = not reported.

Table 3 Single Screening Question

Study, Year | Screening question | Definition of a case | Sensitivity (range) | Specificity (range) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Diagnostic odds ratio (95% CI) | Quality score
Community-dwelling older adults
Boatman et al, 2007^39^ | Do you think you have difficulty hearing? | >25 dB hearing loss at 500, 1000, 2000, or 4000 Hz in either ear | 0.27 (0.16-0.41) | 0.89 (0.78-0.96) | 2.5 (1.0-5.9) | 0.82 (0.68-0.99) | 3.0 (0.96-10) | Good
Clark et al, 1991^43^ | Would you say that you have any difficulty hearing? | ≥25 dB hearing loss at 1000 and 2000 Hz in better ear | 0.66 (0.55-0.75)^*^ | 0.80 (0.74-0.86)^*^ | 3.3 (2.4-4.6)^*^ | 0.43 (0.32-0.58)^*^ | 7.7 (4.2-14)^*^ | Good
Clark et al, 1991^43^ | Would you say that you have any difficulty hearing? | ≥25 dB hearing loss at 1000, 2000, 3000, and 4000 Hz in better ear | 0.56 (0.47-0.65) | 0.82 (0.75-0.88) | 3.1 (2.1-4.5) | 0.53 (0.43-0.67) | 5.8 (3.2-10) | Good
Nondahl et al, 1998^44^; Wiley et al, 2000^69^ | Do you feel you have hearing loss? | >25 dB hearing loss at 500, 1000, 2000, and 4000 Hz in either ear | 0.67 (0.64-0.70) | 0.80 (0.77-0.83) | 3.4 (2.8-4.0) | 0.41 (0.38-0.45) | 8.1 (6.4-10) | Good
Rawool et al, 2008^52^ | Do you think you have hearing loss? | ≥25 dB hearing loss at 500, 1000, 2000, 3000, and 4000 Hz in better ear | 0.68 (0.43-0.87) | 0.81 (0.48-0.98) | 3.8 (1.0-13.7) | 0.39 (0.19-0.79) | 9.8 (1.3-110) | Fair
Sindhusake et al, 2001^45^ | Do you feel you have hearing loss? | >25 dB hearing loss at 500-4000 Hz | 0.78 (0.75-0.81) | 0.67 (0.64-0.70) | 2.4 (2.2-2.6) | 0.33 (0.29-0.38) | 7.2 (5.8-8.9) | Good
Torre et al, 2006^54^ | Do you feel you have hearing loss? (English and Spanish) | ≥25 dB hearing loss at 500, 1000, 2000, and 4000 Hz in worse ear | 0.76 (0.59-0.88) | 0.73 (0.50-0.89) | 2.8 (1.4-5.6) | 0.33 (0.18-0.62) | 8.3 (2.2-33) | Fair
| | Total | 0.67 (0.27-0.78) | 0.80 (0.67-0.89) | 3.0 (2.4-3.8) | 0.40 (0.33-0.82) | -- | --
Clark et al, 1991^43^ | Would you say that you have any difficulty hearing? | >40 dB hearing loss at 1000 and 2000 Hz in worse ear | 0.81 (0.67-0.91) | 0.74 (0.68-0.80) | 3.1 (2.4-4.1) | 0.26 (0.14-0.47) | 12 (5.3-30) | Good
Gates et al, 2003^47^ | Do you have a hearing problem now? | >40 dB hearing loss at 1000 or 2000 Hz in both ears or >40 dB hearing loss at 1000 and 2000 Hz in one ear | 0.71 (0.63-0.78) | 0.72 (0.67-0.76) | 2.5 (2.1-3.0) | 0.41 (0.31-0.53) | 6.2 (4.0-9.6) | Good
Sindhusake et al, 2001^45^ | Do you feel you have hearing loss? | >40 dB hearing loss at 500-4000 Hz | 0.93 (0.89-0.96) | 0.56 (0.54-0.58) | 2.1 (2.0-2.3) | 0.13 (0.08-0.20) | 17 (10-28) | Good
| | Total | 0.81 (0.71-0.93) | 0.72 (0.56-0.74) | 2.5 (2.1-3.1) | 0.26 (0.13-0.41) | -- | --
Sindhusake et al, 2001^45^ | Do you feel you have hearing loss? | >60 dB hearing loss at 500-4000 Hz | 1.0 (0.92-1.0) | 0.50 (0.48-0.52) | 2.0 (1.9-2.1) | 0.02 (0.001-0.34) | 91 (5.6-1480) | Good
Nursing home-dwelling older adults
Voeks et al, 1993^55^ | Do you have trouble hearing? | >25 dB hearing loss at 500, 1000, 2000, and 4000 Hz in better ear | 0.69 (0.60-0.78) | 0.51 (0.40-0.61) | 1.4 (1.1-1.8) | 0.61 (0.43-0.87) | 2.3 (1.2-4.3) | Fair

* Not included in the total estimate in order to avoid double counting a sample.

Table 4 Screening Questionnaires

Study, Year | Screening test, Definition of a positive screening exam | Definition of a case | Sensitivity (range) | Specificity (range) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Diagnostic odds ratio (95% CI) | Quality score
Lichtenstein et al, 1988^46^ | HHIE-S Score >8 | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 0.66 (0.54-0.77) | 0.79 (0.70-0.86) | 3.2 (2.1-4.7) | 0.43 (0.30-0.60) | 7.4 (3.6-16) | Good
McBride et al, 1994^22^ | HHIE-S Score >8 | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 0.58 (0.45-0.70) | 0.76 (0.69-0.84) | 2.4 (1.6-3.5) | 0.55^*^ | 4.4^*^ | Good
Sever et al, 1989^53^ | HHIE-S Score >8 | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 0.71 (0.48-0.89) | NR | NC | NC | ND | Fair
Lichtenstein et al, 1988^46^ | HHIE-S Score >8 | [underlined: HFPTA]: ≥25 dB hearing loss at 1000, 2000, and 4000 Hz in better ear | 0.53 (0.43-0.63)^†^ | 0.84 (0.74-0.91)^†^ | 3.3 (1.9-5.8)^†^ | 0.56 (0.44-0.70)^†^ | 6.0 (2.8-14) | Good
McBride et al, 1994^22^ | HHIE-S Score >8 | [underlined: HFPTA]: ≥25 dB hearing loss at 1000, 2000, and 4000 Hz in better ear | 0.48 (0.39-0.58)^†^ | 0.86 (0.79-0.94)^†^ | 3.6 (2.0-6.6)^†^ | 0.60^*,†^ | 5.7^*^ | Good
Nondahl et al, 1998^44^; Wiley et al, 2000^69^ | HHIE-S Score >8 | >25 dB hearing loss at 500, 1000, 2000, and 4000 Hz in either ear | 0.32 (0.29-0.35) | 0.97 (0.95-0.98) | 10.7 (6.8-17) | 0.70 (0.67-0.73) | 15 (9.4-26) | Good
Sindhusake et al, 2001^45^ | HHIE-S Score >8 | >25 dB hearing loss at 500, 1000, 2000, and 4000 Hz | 0.58 (0.54-0.62) | 0.85 (0.83-0.87) | 3.9 (3.3-4.5) | 0.49 (0.45-0.54) | 7.8 (6.2-10) | Good
| | Total | 0.58 (0.32-0.66) | 0.82 (0.76-0.97) | 3.5 (2.4-11) | 0.52 (0.43-0.70) | -- | --
Weinstein, 1986^56^ | HHIE-S Score >8 | Audiologist recommendation for evaluation | 0.74^*^ | 0.68^*^ | 2.3^*^ | 0.38^*^ | 6.1^*^ | Fair
Gates et al, 2003^47^ | HHIE-S Score >8 | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears or 1000 and 2000 Hz in one ear | 0.36 (0.28-0.44) | 0.92 (0.89-0.94) | 4.5 (3.0-6.7) | 0.70 (0.61-0.79) | 6.5 (3.8-11) | Good
Lichtenstein et al, 1988^46^ | HHIE-S Score >8 | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears or 1000 and 2000 Hz in one ear | 0.72 (0.58-0.83) | 0.77 (0.68-0.84) | 3.1 (2.2-4.4) | 0.37 (0.24-0.57) | 8.4 (3.8-19) | Good
McBride et al, 1994^22^ | HHIE-S Score >8 | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears or 1000 and 2000 Hz in one ear | 0.63 (0.49-0.76) | 0.75 (0.68-0.82) | 2.5 (1.8-3.6) | 0.49^*^ | 5.1^*^ | Good
Sever et al, 1989^53^ | HHIE-S Score >8 | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears or 1000 and 2000 Hz in one ear | 0.81 (0.54-0.96) | NR | NC | NC | ND | Fair
Sindhusake et al, 2001^45^ | HHIE-S Score >8 | >40 dB hearing loss at 500, 1000, 2000, and 4000 Hz | 0.80 (0.74-0.85) | 0.76 (0.74-0.78) | 3.3 (3.0-3.7) | 0.26 (0.20-0.34) | 13 (8.9-18) | Good
Ventry & Wein-stein, 1983^9^ | HHIE-S Score >8 | >40 dB hearing loss at 1000 or 2000 Hz in both ears | 0.72 (0.56-0.85) | 0.66 (0.52-0.77) | 2.1 (1.4-3.1) | 0.43 (0.26-0.71) | 4.9 (1.9-13) | Fair
| | Total | 0.72 (0.36-0.81) | 0.76 (0.66-0.92) | 3.1 (2.1-4.5) | 0.43 (0.26-0.70) | -- | --
McBride et al, 1994^22^ | HHIE-S Score >24 | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 0.36 (0.23-0.48) | 0.87 (0.81-0.93) | 2.8 (1.6-5.0) | 0.74^*^ | 3.8^*^ | Good
McBride et al, 1994^22^ | HHIE-S Score >24 | [underlined: HFPTA]: ≥25 dB hearing loss at 1000, 2000, and 4000 Hz in better ear | 0.29 (0.20-0.37) | 0.93 (0.88-0.99) | 4.3 (1.7-10) | 0.76^*^ | 5.4^*^ | Good
| | Total | 0.32 (0.29-0.36) | 0.90 (0.87-0.93) | 3.5 (2.8-4.3) | 0.75 (0.74-0.76) | -- | --
Lichtenstein et al, 1988^46^ | HHIE-S Score >24 | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears or 1000 and 2000 Hz in one ear | 0.25 (0.14-0.38) | 0.98 (0.93-1.0) | 10.2 (3.0-34.0) | 0.77 (0.66-0.90) | 13 (3.3-75) | Good
McBride et al, 1994^22^ | HHIE-S Score >24 | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears or 1000 and 2000 Hz in one ear | 0.42 (0.28-0.56) | 0.88 (0.82-0.93) | 3.4 (1.9-5.9) | 0.66^*^ | 5.3^*^ | Good
| | Total | 0.32 (0.25-0.42) | 0.93 (0.88-0.98) | 5.9 (3.4-10.2) | 0.71 (0.66-0.77) | -- | --
Sindhusake et al, 2001^45^ | HHIE-S Score >8 | >60 dB hearing loss at 500, 1000, 2000, and 4000 Hz | 1.0 (0.90-1.0) | 0.70 (0.68-0.72) | 3.3 (3.0-3.6) | 0.02 (0.001-0.31) | 165 (10-2700) | Good
Weinstein, 1986^56^ | HHIE-S Score >10 | Audiologist recommendation for evaluation | 0.65^*^ | 0.83^*^ | 3.8^*^ | 0.42^*^ | 9.0^*^ | Fair
Koike et al, 1994^51^ | 5-Minute Hearing Test Various cutoffs | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 10: 0.90^*^ 15: 0.80^*^ 25: 0.90^*^ 30: 0.74^*^ 35: 0.51^*^ 40: 0.26^*^ | 10: 0.20^*^ 15: 0.55^*^ 25: 0.54^*^ 30: 0.72^*^ 35: 0.87^*^ 40: 0.97^*^ | 10: 1.1^*^ 15: 1.8^*^ 25: 2.0^*^ 30: 2.6^*^ 35: 4.0^*^ 40: 9.9^*^ | 10: 0.47^*^ 15: 0.36^*^ 25: 0.18^*^ 30: 0.36^*^ 35: 0.56^*^ 40: 0.76^*^ | 10: 2.3^*^ 15: 5.0^*^ 25: 11^*^ 30: 7.2^*^ 35: 7.1^*^ 40: 13^*^ | Fair

* Confidence interval not calculable.

† Not included in total estimates in order to avoid double counting a sample.

Abbreviations: HFPTA = High Frequency Pure-Tone Average; HHIE-S = Hearing Handicap Inventory for the Elderly-Screening; NC = not calcuable; ND = not dichotomized; NR = not reported; SFPTA = Speech Frequency Pure-Tone Average; V&W = Ventry and Weinstein criteria.

Table 5 Handheld Audiometric Device

Study, Year | Definition of a positive screening exam | Definition of a case | Sensitivity (range) | Specificity (range) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Diagnostic odds ratio (95% CI) | Quality score
Community-dwelling older adults
Eekhof et al, 1996^40^ | Failure to hear 40 dB at 500, 1000, 2000, or 4000 Hz using AudioScope | >40 dB hearing loss | 1.0 (0.91-1.0) | 0.42 (0.31-0.54) | 1.7 (1.4-2.1) | 0.03 (0.002-0.45) | 61 (3.6-102) | Fair
Lichtenstein et al, 1988^46^ | Failure to hear 40 dB at 500, 1000, 2000, or 4000 Hz using AudioScope | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears or 1000 and 2000 Hz in one ear | 0.94 (0.84-0.99) | 0.72 (0.63-0.80) | 3.4 (2.5-4.5) | 0.08 (0.03-0.24) | 43 (12-220) | Good
McBride et al, 1994^22^ | Failure to hear 40 dB at 2000 Hz in better ear using AudioScope | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears or 1000 and 2000 Hz in one ear | 0.96 (0.90-1.00) | 0.80 (0.74-0.87) | 4.9 (3.4-6.8) | 0.05^*^ | 98^*^ | Good
| | Total | 0.96 (0.94-1.0) | 0.72 (0.42-0.89) | 3.4 (1.7-4.9) | 0.05 (0.03-0.08) | -- | --
McBride et al, 1994^22^ | Failure to hear 40 dB at 2000 Hz in better ear using AudioScope | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 0.64 (0.52-0.77) | 0.89 (0.83-0.94) | 5.8 (3.4-9.8) | 0.40^*^ | 14^*^ | Good
McBride et al, 1994^22^ | Failure to hear 40 dB at 2000 Hz in better ear using AudioScope | [underlined: HFPTA]: ≥25 dB hearing loss at 1000, 2000, and 4000 Hz in better ear | 0.71 (0.63-0.80)^†^ | 0.91 (0.84-0.97)^†^ | 7.5 (3.7-15)^†^ | 0.32^*,†^ | 23^*^ | Good
Bienvenue et al, 1985^48^ | Failure to hear 25 dB at 500, 1000, 2000, or 4000 Hz using AudioScope | ≥30 dB hearing loss at 500, 1000, 2000, and 4000 Hz | 0.93^*^ | 0.70^*^ | 3.1^*^ | 0.10^*^ | 31^*^ | Fair
Frank and Petersen, 1987^50^ | Failure to hear 40 dB at 500, 1000, 2000, 4000 Hz | ≥45 dB hearing loss at 500, 1000, 2000, and 4000 Hz | [underlined: Age] 50-59: 0.90^*^ 60-69: 0.89 70-79: 0.85 80-89: 0.86 90-96: 0.86 | [underlined: Age] 50-59: 0.94^*^ 60-69: 0.90 70-79: 0.90 80-89: 0.89 90-96: 0.90 | [underlined: Age] 50-59: 16^*^ 60-69: 9.2^*^ 70-79: 8.7^*^ 80-89: 8.1^*^ 90-96: 9.1^*^ | [underlined: Age] 50-59: 0.11^*^ 60-69: 0.12^*^ 70-79: 0.17^*^ 80-89: 0.16^*^ 90-96: 0.15^*^ | [underlined: Age] 50-59:140^*^ 60-69: 77^*^ 70-79: 51^*^ 80-89: 51^*^ 90-96: 61^*^ | Fair
Chronic care facility-dwelling older adults
Ciurlia-Guy et al, 1993^49^ | Failure to hear 40 dB at 1000 or 2000 Hz in either ear | >40 dB hearing loss at 1000 or 2000 Hz in either ear | 0.98 (0.91-1.0) | 0.21 (0.08-0.41) | 1.3 (1.0-1.5) | 0.08 (0.01-0.61) | 16 (1.8-76) | Fair

* Confidence interval not calculable.

† Not included in total estimates in order to avoid double counting a sample.

Abbreviations: HFPTA = High Frequency Pure-Tone Average; SFPTA = Speech Frequency Pure-Tone Average; V&W = Ventry and Weinstein criteria.

We rated seven studies as good quality22, 39, 43-47 and the remainder as fair quality (Appendix B7). The most common methodological shortcomings were failure to describe enrollment of a representative spectrum of patients (nine studies met this criterion), failure to report interpretation of the reference standard blinded to results of the screening test (five studies met this criterion), and failure to describe enrollment of a random or consecutive series of patients (11 studies met this criterion). All studies except for one used pure-tone audiometry as the reference standard for hearing loss, though four studies used a portable (bedside) audiometer instead of standard audiometry.49, 52, 54, 55 The exception was one study that performed an audiometric examination but used an audiologist as its reference standard.56

Table 6 summarizes the main results on diagnostic accuracy. Results for each screening test are described in more detail below.

Table 6 Diagnostic Accuracy of Screening Tests for Hearing Loss

Screening test | Number of studies, References | Positive likelihood ratio | Negative likelihood ratio
>25 or >30 dB hearing loss
Whispered voice test | Four39-42 | Median: 5.1 Range: 2.3-7.4 | Median: 0.03 Range: 0.007-0.73
Finger rub test | One39 | 10 (95% CI, 2.6-43) | 0.75 (95% CI, 0.68-0.84)
Watch tick test | One39 | 70 (95% CI, 4.4-1120) | 0.57 (95% CI, 0.49-0.66)
Single-question screening | Six39, 43-45, 52, 54 | Median: 3.0 Range: 2.4-3.8 | Median: 0.40 Range: 0.33-0.82
Screening questionnaire (Hearing Handicap in the Elderly-Screening^*^) | Four22, 44-46 | Median: 3.5 Range: 2.4-11 | Median: 0.52 Range: 0.43-0.70
Handheld audiometric devices | Two22, 48 | 3.1 (95% CI not calculable) 5.8 (95% CI, 3.4-9.8) | 0.10 (95% CI not calcuable) 0.40 (95% CI not calculable)
>40 dB hearing loss
Single-question screening | Three43, 45, 47 | Median: 2.5 Range: 2.1-3.1 | Median: 0.26 Range: 0.13-0.41
Screening questionnaire (Hearing Handicap in the Elderly-Screening^*^) | Five9, 22, 45-47 | Median: 3.1 Range: 2.1-4.5 | Median: 0.43 Range: 0.26-0.70
Handheld audiometric devices | Three22, 40, 46 | Median: 3.4 Range: 1.7-4.9 | Median: 0.05 Range: 0.03-0.08

* Based on cutoff score of >8

Abbreviation: CI = confidence interval.

Whispered voice, finger rub, and watch tick tests. One good-quality39 and three fair-quality40-42 studies evaluated the diagnostic accuracy of a whispered voice at 2 feet for identification of >25 or >30 dB hearing loss (Table 2, Appendix B3). Likelihood ratio estimates varied, with a median PLR of 5.1 (range, 2.3 to 7.4) and median NLR of 0.03 (range, 0.007 to 0.73). The good-quality study reported the weakest likelihood ratios.39 Based on a sensitivity of 0.40 (range, 0.32 to 0.49) and specificity of 0.82 (range, 0.72 to 0.90), the PLR was 2.3 (95% CI, 1.3 to 3.8) and the NLR was 0.73 (95% CI, 0.61 to 0.87). In the three fair-quality studies, sensitivity was higher (range, 0.90 to 1.0), with similar specificity (range, 0.80 to 0.87), resulting in stronger likelihood ratios (PLR range, 4.6 to 7.4; NLR range, 0.007 to 0.12).40-42 One fair-quality study found that inability to hear a whispered voice at 6 inches (PLR, 72 [95% CI, 4.6 to 1140]) or a conversation at 2 feet (PLR, 46 [95% CI, 2.9 to 740]) was more useful than inability to hear a whispered voice at 2 feet (PLR, 5.7 [95% CI, 3.1 to 11]), but estimates were imprecise and the confidence intervals overlapped.41 On the other hand, normal results on the first two tests were less useful than the whispered voice test at 2 feet for identifying those without hearing loss (NLR, 0.27 [95% CI, 0.19 to 0.39] and 0.53 [95% CI, 0.43 to 0.66], respectively, vs. 0.008 [95% CI, 0.0005 to 0.13]), primarily due to lower sensitivities.

The one good-quality study also evaluated the accuracy of the finger rub and watch tick tests at 6 inches for detecting >25 dB hearing loss (Table 2,Appendix B3).39 Compared with the whispered voice test, inability to hear a finger rub or watch tick was more useful for identifying hearing loss (PLR, 10 [95% CI, 2.6 to 43] and 70 [95% CI, 4.4 to 1120], respectively), with normal results similarly useful for identifying individuals without hearing loss (NLR, 0.75 [95% CI, 0.68 to 0.84] and 0.57 [95% CI, 0.46 to 0.66], respectively), based on similar sensitivities (0.27 [95% CI, 0.19 to 0.35] and 0.44 [95% CI, 0.35 to 0.53], respectively) and higher specificities (0.98 [95% CI, 0.91 to 1.0] and 1.0 [95% CI, 0.95 to 1.0], respectively).

Single-question screening. Five good-quality39, 43-45, 47 and three fair-quality52, 54, 55 studies evaluated the diagnostic accuracy of a single question regarding perceived hearing difficulties (e.g., “Do you have difficulty with your hearing?”) for detection of hearing loss (Table 3,Appendix B4). For detection of >25 dB hearing loss, six studies reported a median sensitivity of 0.67 (range, 0.27 to 0.78) and median specificity of 0.80 (range, 0.67 to 0.89).39, 43-45, 52, 54 A positive response to a single question increased the likelihood of hearing loss (median PLR, 3.0 [range, 2.4 to 3.8]), though the usefulness of a negative response was variable (median NLR, 0.40 [range, 0.33 to 0.82]). For detection of >40 dB hearing loss, three good-quality studies reported a median sensitivity of 0.81 (range, 0.71 to 0.93) and median specificity of 0.72 (range, 0.56 to 0.74), resulting in a median PLR of 2.5 (range, 2.1 to 3.1) and median NLR of 0.26 (range, 0.13 to 0.41).43, 45, 47 One fair-quality study of nursing home residents reported a weaker PLR (1.4 [95% CI, 1.1 to 1.8]) and similar NLR (0.61 [95% CI, 0.43 to 0.87]) compared with the other studies, which evaluated community-dwelling older adults.55

Screening questionnaires. Five good-quality22, 44-47 and three fair-quality9, 53, 56 studies evaluated the diagnostic accuracy of the HHIE-S screening questionnaire, and one fair-quality study evaluated the diagnostic accuracy of the 5-Minute Hearing Test51 (Table 4,Appendix B5).

For detection of >25 dB hearing loss, four good-quality studies reported a median sensitivity for the HHIE-S (based on a cutoff score >8) of 0.58 (range, 0.32 to 0.66) and median specificity of 0.82 (range, 0.76 to 0.97), resulting in a median PLR of 3.5 (range, 2.4 to 11) and NLR of 0.52 (range, 0.43 to 0.70).22, 44-46 One fair-quality study reported a somewhat lower PLR and similar NLR (2.3 and 0.38, respectively), but the reference standard was an audiologist recommendation for evaluation, rather than strictly results of pure-tone audiometry.56 Studies on the accuracy of HHIE-S cutoff scores >8 for identification of >40 dB hearing loss reported slightly better sensitivity and slightly worse specificity compared with identification of >25 dB hearing loss, resulting in similar likelihood ratios (Table 4).9, 22, 45-47 Changing the HHIE-S threshold from >8 to >24 increased the PLR for identification of >40 dB hearing loss (based on Ventry and Weinstein criteria) from 3.1 to 10 and increased the NLR from 0.37 to 0.77 in one good-quality study (due to decreased sensitivity but higher specificity),46 but had little effect on likelihood ratio estimates for either >25 dB or >40 dB hearing loss in another good-quality study.22

One fair-quality study evaluated the accuracy of the 5-Minute Hearing Test for identification of >25 dB hearing loss at various cutoff scores.51 Sensitivity ranged from 0.90 at a cutoff score of 10 to 0.26 at a cutoff score of 40, with specificities of 0.20 and 0.97, respectively, resulting in PLRs of 1.1 to 9.9 and NLRs of 0.47 to 0.76, depending on the cutoff score evaluated.

Handheld audiometric devices. Two good-quality22, 46 and four fair-quality40, 48-50 studies evaluated the diagnostic accuracy of the AudioScope handheld audiometric device for identification of hearing loss (Table 5,Appendix B6). The frequencies and intensities of the tones tested with the AudioScope varied across studies. For detection of >25 dB hearing loss, one good-quality study found that the AudioScope (based on ability to hear a 2000 Hz tone at 40 dB) was associated with a sensitivity of 0.64 (95% CI, 0.52 to 0.77) based on SFPTA criteria and 0.71 (95% CI, 0.63 to 0.80) based on HFPTA criteria, with specificities of 0.89 (95% CI, 0.83 to 0.94) and 0.91 (0.84 to 0.97), respectively.22 Corresponding PLRs were 5.8 (95% CI, 3.4 to 9.8) and 7.5 (95% CI, 3.7 to 15), and NLRs were 0.40 and 0.32 (CIs not calculable).22 For detection of >30 dB hearing loss, a fair-quality study found that the AudioScope (based on ability to hear 500, 1000, 2000, and 4000 Hz at 25 dB) was associated with a sensitivity of 0.93, specificity of 0.70, PLR of 3.1, and NLR of 0.10 (CIs not calculable).48 For detection of >40 dB hearing loss, three studies of community-dwelling older adults found that the AudioScope (based on ability to hear tones between 500 and 4000 Hz at 40 dB) was associated with a median sensitivity of 0.96 (range, 0.94 to 1.0), median specificity of 0.72 (range, 0.42 to 0.80), median PLR of 3.4 (range, 1.7 to 4.9), and median NLR of 0.05 (range, 0.03 to 0.08).22, 40, 46 A fair-quality study of older adult nursing home residents reported a very high sensitivity (0.98 [95% CI, 0.91 to 1.0]) but very low specificity (0.21 [95% CI, 0.08 to 0.41]) for identification of >40 dB hearing loss using the AudioScope (based on failure to hear 1000 or 2000 Hz in both ears), resulting in a much weaker PLR (1.3 [95% CI, 1.0 to 1.5]) but similar NLR (0.08 [95% CI, 0.01 to 0.61]) compared with results from the studies of community-dwelling older adults.49

Direct comparisons of different types of screening tests. Six good-quality studies directly compared the diagnostic accuracy of different screening tests for hearing loss in older adults.22, 39, 44-47 One study found that the whispered voice test and single question screening were associated with similar PLRs (2.3 [95% CI, 1.3 to 3.8] and 2.5 [95% CI, 1.0 to 5.9], respectively) and NLRs (0.73 [95% CI, 0.61 to 0.87] and 0.82 [95% CI, 0.68 to 0.99], respectively), but the watch tick and finger rub tests were associated with substantially stronger PLRs (70 [range, 4.4 to 1120] and 10 [range, 2.6 to 43], respectively) and comparable NLRs (0.57 [95% CI, 0.49 to 0.66] and 0.75 [95% CI, 0.68 to 0.84], respectively).39 Three studies showed a consistent trade-off between lower sensitivity and higher specificity for the HHIE-S compared with a single screening question, resulting in somewhat stronger PLRs and weaker NLRs.39, 44, 45, 47 Two studies found that normal results on the AudioScope were generally associated with stronger NLRs (0.05 and 0.24) compared with the HHIE-S (0.37 and 0.76), with relatively small differences in PLR estimates, though likelihood ratio estimates varied depending on the HHIE-S cutoff score evaluated and the criteria used to define hearing loss.22, 46

## Key Question 3 How Efficacious is the Treatment of Screening-Detected Hearing Loss in Improving Health Outcomes?

### Summary

Four RCTs evaluated benefits of amplification compared with no amplification for treatment of screening-detected hearing loss. One good-quality RCT found that immediate hearing aids were associated with near normalization of hearing-specific quality of life and communication difficulties in veterans with primarily screening-detected moderate to severe hearing loss, compared with essentially no changes in these outcomes in wait-list controls.13 A smaller, fair-quality RCT found no clear difference between an assistive listening device and no treatment in veterans ineligible for free hearing aids with less severe hearing loss.57 Another fair-quality RCT found no difference between a hearing aid, an assistive listening device, or both compared with no amplification in a subgroup of patients not using hearing aids at enrollment with mild baseline hearing loss and hearing-related handicap. A fourth RCT of hearing aids versus no hearing aids reported outcomes very poorly.

### Evidence

We identified four RCTs on treatment for hearing loss in older adults (Table 1, Appendix B1 and Appendix B2).13, 57-59 Two trials13, 57 evaluated older male veterans and two58, 59 evaluated community-dwelling older adults. Numerous measures were used to assess both hearing-related and general quality of life and function (Appendix C).

One trial was rated good quality,13 two were rated fair quality,57, 58 and one was rated poor quality59 (Appendix B2). Shortcomings of the fair-quality trials included potentially important baseline differences between groups and failure to describe intention-to-treat analysis,57 and failure to describe randomization or allocation concealment methods or loss to follow-up.58 The poor-quality trial did not describe allocation concealment, use of intention-to-treat analysis, or loss to follow-up, and reported outcomes incompletely.59 All of the trials had characteristics which could limit generalizability to screening in typical primary care settings, including recruitment of mostly white male veterans,13, 57 restriction to patients eligible for free hearing aids,57 inclusion of patients referred for suspected hearing problems,13 and inclusion of patients already using hearing aids.58

The good-quality RCT (n=194) randomly assigned veterans (mean age, 72 years) to immediate hearing aids or wait-list control for 4 months.13 About two thirds of patients were recruited from a primary care setting based on a positive AudioScope screening for >40 dB hearing loss. The others were referred into the trial due to suspected hearing problems. The mean pure-tone threshold was 52 dB and similar among screening-detected and referred patients. The mean baseline HHIE score was about 50 (standard deviation [SD], 28), indicating severe (HHIE score >42) effects on hearing-related quality of life and function.60 Hearing-related quality of life outcomes were measured using the HHIE and the Quantified Denver Scale of Communication Function (QDS). General quality of life was assessed with the Geriatric Depression Scale (GDS), a 0 to 15 scale, the Short Portable Mental Status Questionnaire (SPMSQ), a 0 to 10 scale, and the Self-Evaluation of Life Function (SELF), a 54 to 216 scale.

At 4 months there was no change from baseline in HHIE or QDS scores in the control group, but the hearing aid group HHIE score improved from a mean of 49 at baseline to 15 at 4 months, and the QDS score improved from 59 to 36. The mean between-group difference in change from baseline was 34 (95% CI, 27 to 41) on the HHIE and 24 (95% CI, 17 to 31) on the QDS. Results were similar in the subgroup of screening-detected patients. Greater improvements in HHIE scores were associated with increased hearing aid use (p=0.05), but not with changes in QDS scores. Statistically significant but small (<1 point) effects on GDS and SPMSQ scores were also observed in the hearing aid group compared with the control group. However, the potential for improvement may have been limited because the baseline scores indicated only mild baseline depression or cognitive dysfunction. In both groups, there were no significant differences from baseline in SELF scores. A follow-up study found that improvements in HHIE and QDS scores were sustained in the hearing aid group through 12 months, even though the proportion of patients that reported 4 hours or more of daily hearing aid use decreased from 90 to 76 percent between 4 and 12 months.61

A second, fair-quality trial (n=64) enrolled veterans (mean age, 68 years) with less severe (mean pure-tone threshold, 32 dB) hearing loss.57 Patients eligible for free VA-issued hearing aids (n=30) were randomly assigned to a standard non-directional or programmable directional digital hearing aid. Patients ineligible for free hearing aids (n=30) were randomly assigned to an assistive listening device (an instrument used to pick up and amplify targeted sounds while reducing background noise) or no treatment. Although this design resulted in essentially two separate randomized trials, the investigators analyzed results as a single, four-armed randomized trial. A revised (shortened) version of the QDS (Revised Quantified Denver Scale of Communication Function [RQDS]), a 1 to 5 scale,62 the HHIE, and the Abbreviated Profile of Hearing Aid Benefit (APHAB), a 0-to-100 scale questionnaire designed to assess self-reported communication ability,63 were used to assess hearing-specific quality of life. Baseline differences across the intervention groups in APHAB scores were statistically significant (range, 38 to 52; p=0.04). For baseline HHIE scores, differences across groups were not statistically significant, but ranged from moderate to severe and were likely to be clinically significant (range, 28 to 50).

At 3-month follow-up, there were trivial improvements from baseline on HHIE scores in the assistive listening device and no treatment groups (mean change of 4.4 and 2.2 points, respectively), but both types of hearing aids were associated with clinically significant improvements (mean change of 17 and 31 points in the standard and programmable hearing aid groups, respectively). Changes in APHAB scores were small in the assistive listening device and no treatment groups (mean change of 6.4 and 2.7 points, respectively), with no change in RQDS scores. Improvements in the APHAB score were larger in both hearing aid groups (mean change of 7.7 and 16 for standard and programmable hearing aids, respectively). Although both hearing aid groups experienced greater improvements in hearing-related outcomes compared with the no treatment and assistive listening device groups, there were baseline differences between groups. In addition, statistical significance was only reported for differences across all four groups, but such results are subject to additional confounding because patients were separately randomly assigned based on eligibility for free hearing aids.

In another fair-quality crossover trial (n=80), a subgroup of patients not using hearing aids at enrollment (mean pure-tone threshold hearing loss, 37 dB; mean HHIE score, 30) found no clear differences between hearing aids, an assistive listening device, or both compared with no amplification on HHIE scores and other measures of function or quality of life.58 Improvements in HHIE scores for all four intervention groups were small and not clinically significant, ranging from 2.2 points in the no amplification group to 5.2 points in the hearing aid only group. A poor-quality trial (n=133) found that older adults randomly assigned to hearing aids did not experience improvement in GDS scores at 6 months, and did not report results in those randomly assigned to no hearing aids.59

## Key Question 4 What are the Adverse Effects of Screening for Hearing Loss in Adults Ages 50 Years and Older?

### Summary

We identified no studies on harms associated with screening for hearing loss in older adults. Harms are unlikely to be greater than minimal because screening and confirmatory testing are non-invasive and treatment with hearing aids is not associated with significant harms.

### Evidence

No randomized trials or controlled observational studies evaluated harms associated with screening for hearing loss in older adults. Because screening and confirmatory testing are non-invasive and hearing aid treatment is not known to be associated with major harms, it is unlikely that adverse effects of screening for hearing loss would be greater than minimal. It is possible that screening could be associated with anxiety, labeling, or other psychosocial effects, but no studies are available to estimate these outcomes.

## Key Question 5 What are the Adverse Effects of Treatment of Screening-Detected Hearing Loss in Adults Ages 50 Years and Older?

### Summary

No randomized trials of hearing aids evaluated harms, and we identified no relevant controlled observational studies. However, serious harms appear to be rare.

### Evidence

Hearing aids are non-invasive and generally believed to be safe, although potential harms include dermatitis, accidental retention of molds, cerumen impaction, otitis externa, or associated middle ear problems,64-66 as well as psychosocial effects. Harms were not reported in any trials of hearing aids, and we identified no controlled observational studies on adverse effects associated with hearing aid use. Although it has been postulated that the amplification from hearing aids might lead to further deterioration in hearing, particularly in those with severe hearing loss because they require marked amplification, no study has addressed this issue.67