# Methods

Using the methods of the USPSTF that are fully described in Appendix A and with the input of members of the USPSTF, we developed an analytic framework (Figure 1) and key questions (KQs) to guide our literature search and review. We defined the target population as persons ages 50 years and older who did not have diagnosed hearing loss and were evaluated in primary care settings, including patients both with and without perceived hearing loss. For the purposes of this review, both groups are referred to as “asymptomatic,” so long as they have not sought evaluation for a perceived hearing problem. The target condition for this review was chronic sensorineural hearing loss, the most common type of hearing loss in older adults. We excluded conductive hearing loss, congenital hearing loss, and sudden hearing loss or hearing loss due to recent occupational or other exposure, as these were considered to be outside the scope of hearing screening in primary care. For treatments, we focused on hearing aids. Outcomes of interest were hearing-related function, quality of life, and adverse events related to screening or treatment (such as anxiety, labeling, or other psychosocial effects, and false-positive results).

Figure 1 Analytic Framework and Key Questions

* In primary care applicable settings.

** Such as emotional and social function, communication, and cognitive function. Does not include outcomes related to hearing aid performance and efficacy, such as speech intelligibility and quality of the listening experience.

Key Questions

KQ 1 Does screening for hearing loss in asymptomatic adults ages 50 years and older lead to improved health outcomes?
KQ 2 How accurate are the methods for hearing loss screening in older adults?
KQ 3 How efficacious is the treatment of screening-detected hearing loss in improving health outcomes?
KQ 4 What are the adverse effects of screening for hearing loss in adults ages 50 years and older?
KQ 5 What are the adverse effects of treatment of screening-detected hearing loss in adults ages 50 years and older?

Contextual Questions

1. Does adherence to hearing aid use improve health outcomes in screened asymptomatic adults who are prescribed hearing aids?
2. Are there characteristics that can predict adherence to hearing aid use among screened populations?
3. Are there treatments or other behavioral interventions in addition to hearing aid use that improve health outcomes in adults with hearing loss?

Figure 1 is an analytic framework that depicts the events that older adults experience while undergoing screening for hearing loss. The framework includes five headings: Screening, Formal Audiometric Evaluation, Treatment (Amplification), Health Outcomes, and Adverse Effects. The patient population undergoing screening is asymptomatic adults ages 50 years and older who are seen in primary care applicable settings. The intervention is audiometric evaluation, including the whispered voice, finger rub, and watch tick clinical tests; a single screening question, such as “Do you have difficulty with your hearing?”; a more detailed questionnaire, such as the Hearing Handicap Inventory for the Elderly-Screening Version; or a handheld audiometric device, such as the AudioScope. Treatment for hearing loss is signal amplification, including hearing aids and assistive listening devices. The health outcomes include health-related quality of life, such as emotional and social function, communication, and cognitive function. It does not include outcomes related to hearing aid performance and efficicay, such as speech intelligibility or quality of the listening experience. Potential harms of screening for hearing loss include anxiety, labeling, or other psychosocial effects. Potential harms of treatment include dermatitis, accidental retention of molds, cerumen impaction, otitis externa, or associated middle ear problems, as well as psychosocial effects.

The KQs used to guide this evidence synthesis were:

1. Does screening for hearing loss in asymptomatic adults ages 50 years and older lead to improved health outcomes?
2. How accurate are the methods for hearing loss screening in older adults, including questionnaires, clinical techniques, and handheld audiometric devices?
3. How efficacious is the treatment of screening-detected hearing loss, namely amplification, in improving health outcomes?
4. What are the adverse effects of screening for hearing loss in adults ages 50 years and older?
5. What are the adverse effects of treatment of screening-detected hearing loss in adults ages 50 years and older?

## Search Strategies

We searched Ovid MEDLINE from 1950 to July 2010 and the Cochrane Database of Systematic Reviews and the Cochrane Central Register of Controlled Trials through the second quarter of 2010 to identify relevant articles (Appendix A1). We identified additional studies from citations in relevant articles and experts in hearing screening and treatment.

## Study Selection

We selected studies pertaining to screening, diagnosis, and treatment of hearing loss based on predefined inclusion and exclusion criteria for each KQ (Appendix A2). Two reviewers evaluated each study at the title/abstract and full-text article stages to determine eligibility for inclusion. The flow of studies from initial identification of titles and abstracts to final inclusion or exclusion is diagrammed in Appendix A3. We also included studies of hearing screening in specialty settings, but evaluated their applicability to primary care settings. The target sample was persons ages 50 years and older who did not have diagnosed hearing loss and were evaluated in primary care settings, including those with and without self-perceived hearing problems. The target condition for this review was chronic sensorineural hearing loss, the most common type of hearing loss in older adults.1 Although hearing problems can occur despite normal tonal perception,3 hearing loss is generally defined based on pure-tone audiometric testing because the primary treatment is signal amplification. For screening tests, we focused on clinical tests (e.g., detection of a whispered voice, finger rub, or watch tick), a single question (e.g., “Do you have difficulty with your hearing?”), questionnaires (e.g., HHIE-S)9, 22 and handheld audiometric devices (e.g., the AudioScope). The purpose of all screening tests was to identify individuals at higher risk for hearing loss who should be referred for formal audiometry. We excluded the Rinne and Weber tests because their main purpose is to distinguish conductive from sensorineural hearing loss, not to screen patients for hearing loss. For treatments, we focused on hearing aids and assistive listening devices (instruments with an off-ear microphone to pick up and amplify targeted sounds). Outcomes of interest were hearing-related function, quality of life, and adverse events related to screening or treatment. We used randomized controlled trials (RCTs) and controlled observational studies to assess the effectiveness and harms of screening and treatment. For diagnostic accuracy, we included studies that compared a screening test with a reference standard.

We excluded congenital hearing loss, sudden hearing loss, and hearing loss due to recent occupational or other exposure. We also excluded conductive hearing loss because it is uncommon in older adults.1 We restricted our review to published studies available in the English language. Studies that were excluded after review of the full-text article and reasons for exclusion are listed in Appendix A4

## Data Abstraction and Quality Rating

We abstracted details about the patient population, study design, data analysis, follow-up, and results. One author abstracted data and another author verified the abstracted data for accuracy. Two authors independently rated the internal validity of each study as “good,” “fair,” or “poor” using predefined criteria developed by the USPSTF (Appendix A5).34, 35 We also evaluated the applicability of studies to primary care screening, based on whether patients were recruited from primary care or community settings, the prevalence and severity of hearing loss, the proportion of patients with perceived hearing loss, and factors related to access to hearing aids (e.g., free hearing aids provided to eligible veterans). Discrepancies in quality ratings were resolved by discussion and consensus.

For diagnostic accuracy studies, we used the diagti procedure in Stata (Stata Version 10, StataCorp, College Station, TX) to calculate sensitivities, specificities, and likelihood ratios. We used the cci procedure to calculate diagnostic odds ratios with exact confidence intervals.

## Data Synthesis

We assessed the overall strength of the body of evidence for each KQ (“good,” “fair,” or “poor”), or part of a KQ, using methods developed by the USPSTF, based on the number, quality and size of studies, consistency of results between studies, and directness of evidence.34 We did not quantitatively pool results of studies on diagnostic accuracy of screening tests for hearing loss due to differences across studies in populations evaluated, definitions of hearing loss, specific screening tests evaluated, and screening cutoffs applied. Instead, we created descriptive statistics with the median sensitivity, specificity, and likelihood ratios for detecting hearing loss of >25 and >40 dB, along with associated ranges. The total range rather than the interquartile range was chosen because several findings were reported in few studies, and because the summary range highlights the greater uncertainty we have in the estimates. For studies that reported diagnostic accuracy based on more than one definition of hearing loss, we estimated median values based on the Ventry and Weinstein criteria (for >40 dB hearing loss), the SFPTA criteria (for >25 dB hearing loss), or another definition most like the ones used by other relevant studies. There were too few randomized trials of treatments for hearing loss to perform meta-analysis.

## External Review

We distributed a draft of the report for review by four external experts not affiliated with the USPSTF (Appendix A6), and revised the report based on their comments.