# Measures of Quality of Life or Function

Hearing-Related Quality of Life or Function13, 57

Test | Description
Abbreviated Profile of Hearing Aid Benefit (APHAB) | 24-item questionnaire Measures self-rated communication function Score 0-100; 4 subscales
Hearing Handicap Inventory for the Elderly-Screening Version (HHIE-S) | 25-item questionnaire Measures emotional/ social impact of hearing loss Score 0-100
Quantified Denver Scale of Communication Function (QDS) | 25-item questionnaire Measures self-reported communication function Score 0-100; 4 subscales
Revised Quantified Denver Scale of Communication Function (RQDS) | 5-item questionnaire Measures self-rated communication function Score 1-5

General Quality of Life or Function

Test | Description
Geriatric Depression Scale (GDS) | 30-item questionnaire Measures self-perceived depression in the elderly Score 0-30
Self-Evaluation of Life Function (SELF) | 54-item questionnaire Measures self-reported physical, emotional, and social function Score 54-216
Short Portable Mental Status Questionnaire (SPMSQ) | 10-item questionnaire Measures function related to psychiatric issues Score 0-10