# Appendix B - Evidence and Quality Tables

Appendix B1 Randomized Controlled Trials of Screening and Treatment Evidence Table

Study, Year | Purpose of study | Study design | Inclusion criteria | Exclusion criteria | # Screened/ eligible/enrolled | Subject age, Sex, Diagnosis | Country & Setting | Sponsor | Measures | Intervention Type | Results | Duration of follow-up | Loss to follow-up | Adverse events & withdrawals | Quality Score
Screening
Yueh et al, 2010^36^ | To evaluate effect of hearing screening on long-term hearing outcomes in a population of older veterans | Unblinded randomized trial | Outpatients seeking general medical care from VA Puget Sound Health Care System (Seattle and Tacoma) between Jan 2002 and Dec 2003; age ≥50 yrs; eligible to receive audiology services (must have 10-100% disability rating for any medical condition or any disability rating for a hearing-related condition) | Previous use of hearing aid; hearing evaluation in prior 6 months; unable to complete questionnaire; unwilling to follow-up by mail 1 year after screening | NR/NR/2314 2305 after post-randomization exclusions | Mean age: 61 yrs Sex: 94% male Mean baseline hearing loss: NR | US VA primary care clinic | VHA | Screening Tone-emitting otoscope; HHIE-S; and both otoscope and HHIE-S Hearing-related function Effectiveness of Aural Rehabilitation Scale; single-question test (Do you think you have a hearing problem?) Primary outcome measure Single-question test (Do you use your hearing aids?) | 4 screening arms: Otoscope only (n=463) Questionnaire only (n=462) Otoscope and questionnaire (n=460) No screening (n=929) | Screening w/AudioScope vs. HHIE-S vs. both vs. no screening, results at 1 year Hearing aid use: 29/462 (6.3%) vs. 19/461 (4.1%) vs. 34/459 (7.4%) vs. 30/923 (3.3%); p=0.003 >6 point improvement on the Inner Effectiveness of Aural Rehabilitation scale: 146/361 (40%) vs. 125/346 (36%) vs. 141/355 (40%) vs. 252/700 (36%); p=0.39 Screening was not associated with any statistically significant differences in hearing-related quality of life compared with no screening (reported in text; no data) | 1 year | High overall loss to follow-up (23.1%) | NR | Fair
Treatment
Jerger et al, 1996^58^ | To assess impact of personal amplification systems on quality of life in elderly persons and compare conventional hearing aids with assistive listening devices | Cross-over | Age >60 yrs; hearing loss >15 dB in both ears; normal middle ear status; average score ≤3 on self-report physical health scale; score ≥24 on Mini Mental State Exam; no history of neurologic or psychiatric disorder | NR | NR/NR/180 | Mean age: 74.3 yrs (range, 60-96 yrs) Sex: 63% male Mean pre-tone threshold: 37 dB Mean baseline HHIE-S score: 30 (New users only) | US Setting NR | National Institute on Aging | HHIE-S; Speech Perception in Noise Test; Brief Symptom Inventory: Social Activity Scale, Life Satisfaction in the Elderly Scale, Affect Balance Scale | n=80 for each intervention (cross-over) Hearing aid vs. assistive listening device vs. both vs. none | Hearing aid vs. assistive listening device vs. both vs. none, mean scores at 6 weeks HHIE-S: 25 vs. 27 vs. 26 vs. 28 (p>0.05) Speech Perception in Noise: 53% vs. 75% vs. 71% vs. 42% (p<0.05) Brief Symptom Inventory: no differences between interventions (data NR) | 6 weeks | NR | NR | Fair
Mulrow et al, 1990^13^ | To assess whether hearing aids improve quality of life in elderly persons with hearing loss | Unblinded RCT | Age >64 yrs; attending general medicine clinic between June 1987 and June 1988 | Already using a hearing aid; severe comorbidity including terminal cancer, hepatic encephalopathy, and end-stage pulmonary disease; requiring home oxygen therapy; residence >100 miles from clinic | 771/587/194^*^ | Mean age: 72 yrs Sex: 99% male Race:97% white Mean pure-tone threshold, better ear: 52 dB^†^ Mean baseline HHIE-S score: 50 | US VA primary care clinic | Robert Wood Johnson Foundation; Milbank Scholar Program; ACP Teaching and Research Scholar Award | HHIE-S; Quantified Denver Scale;Short Portable Mental Status Questionnaire; Geriatric Depression Scale; Self Evaluation of Life Function | Immediate hearing aid use (n=95) vs. wait list (n=99) | Immediate hearing aid use vs. wait list, mean scores at 4 months (mean difference in change from baseline) HHIE-S: 15 vs. 51 (34 [95% CI, 27 to 41]; p<0.001) Quantified Denver Scale: 36 vs. 62 (24 [95% CI, 17 to 31]; p<0.001) Short Portable Mental Status Questionnaire: 0.29 vs. 0.28 (0.28 [95% CI, 0.08 to 0.48]; p=0.008) Geriatric Depression Scale: 2.6 vs. 3.8 (0.80 [95% CI, 0.09 to 1.5]; p=0.03) Self Evaluation of Life Function: 92 vs. 97 (1.9 [95% CI, -1.6 to 5.4]; p=0.27) | 4 months | At 4 months: 6/194 (3%) | NR | Good
Tolson et al, 2002^59^ | To determine if hearing aid use makes a difference in mood, perception of wellbeing in patients and caregivers, caregiver stress, and familial relationships | Unblinded RCT | NR | NR | 356/NR/133 | Mean age: 76.6 yrs Sex: 23% male Other baseline characteristics: NR | UK General practice clinic | NR | Mini Mental Status Examination; Geriatric Depression Scale, Malaise Inventory (caregiver); Family Relationship Index; 14-item caregiver's assessment of hearing difficulties | Hearing aid (n=63) vs. no hearing aid (n=70) | NR; authors state “depression scores were unchanged at the 6-month follow-up” in the intervention group | 6 months | NR | NR | Poor
Yueh et al, 2001^57^ | To compare the effectiveness of a non-programmable hearing aid with a programmable hearing aid | Unblinded RCT | Age >50 yrs; seeking diagnostic or hearing aid evaluation | Asymmetric or conductive hearing loss; loss other than mild to moderately severe; upsloping hearing loss of ≥5 dB per octave between 500 and 3000 Hz; poor word recognition scores; atypical cause of sensorineural hearing loss; prior hearing aid use; poor cognitive function; poor manual dexterity | NR/NR/64 | Mean age: 68.5 yrs Sex: 100% male Race: NR Mean pure-tone threshold, right ear: 33 dB Mean pure-tone threshold, left ear: 32 dB Mean baseline HHIE-S score: 28 vs. 35 (assistive listening device vs. no treatment); 50 vs. 36 (programmable vs. standard hearing aid) | US VA audiology clinic | Career Development Award; VA | HHIE-S;Abbreviated Profile of Hearing Aid Benefit; Revised Quantified Denver Scale; social isolation | Programmable hearing aid (n=16) vs. standard (non-programmable) hearing aid (n=14) and assistive listening device (n=15) vs. no treatment (n=15) | Assistive listening device vs. no treatment, mean scores at 3 months HHIE-S: 4.4 vs. 2.2 Abbreviated Profile of Hearing Aid Benefit: 6.4 vs. 2.7 Revised Quantified Denver Scale: 0.03 vs. -0.05 Proportion reporting less social isolation: 0/15 (0%) vs. 0/15 (0%) Programmable hearing aid vs. standard hearing aid, results at 3 months HHIE-S: 31 vs. 17 (p<0.05) Abbreviated Profile of Hearing Aid Benefit: 16 vs. 7.7 Revised Quantified Denver Scale: 0.84 vs. 0.70 Proportion reporting less social isolation: 10/16 (62%) vs. 2/14 (14%) | 3 months | 4/64 (6%) | NR | Fair

* Includes 72 subjects referred from other clinics.

† Average at 1000, 2000, and 4000 Hz.

‡ p=0.05.

Abbreviations: # = number; ACP = American College of Physicians; CI = confidence interval; HHIE-S = Hearing Handicap Inventory In the Elderly-Screening; NR = not reported; RCT = randomized controlled trial; UK = United Kingdom; US = United States; VA = Department of Veterans Affairs; VHA = Veterans Health Administration.

Appendix B2 Quality Ratings for Trials of Screening and Treatment

Study, Year | Random assignment | Allocation concealed | Groups similar at baseline | Eligibility criteria specified | Patient blinding | Provider blinding | Outcome assessor or data analyst blinding | Intention-to-treat analysis | Reporting of attrition, contamination | Differential loss to follow-up, overall high loss to follow-up, or incomplete follow-up | Funding source | External validity | Quality score
Screening
Yueh et al, 2010^36^ | Described as randomized, method NR | Yes | Yes | Yes | N/A | N/A | Cannot tell | Yes | Yes | High overall loss to follow-up | Veterans Health Administration | Mean age: 61 years (SD, 9) Sex: 94% male Race: 75% white Mean hearing loss: NR | Fair
Treatment
Jerger et al, 1996^58^ | Described as randomized, method NR | Cannot tell | Cannot tell | Yes | N/A | N/A | Cannot tell | Yes | No | Cannot tell | National Institute on Aging | Mean age: 74.3 years (range, 60-96) Sex: 63% male Mean pure-tone threshold: 37 dB^**^ | Fair
Mulrow et al, 1990^13^ | Described as randomized, method NR | Yes | Yes | Yes | N/A | N/A | Cannot tell | Yes | Yes | No | Robert Wood Johnson Foundation; Milbank Scholar Program; ACP Teaching and Research Scholar Award | Mean age: 72 years (SD, 6) Sex: 99% male Race: 97% white Mean pure-tone threshold, better ear: 52 dB (SD, 8)^*^ | Good
Tolson et al, 2002^59^ | Yes | Cannot tell | Yes | No | N/A | N/A | Cannot tell | Cannot tell | No | Cannot tell | Not reported | Mean age: 76.6 years Sex: 77% female Other baseline characteristics: NR | Poor
Yueh et al, 2001^57^ | Described as randomized, method NR | Yes | No | Yes | N/A | N/A | Cannot tell | Cannot tell | No | No | Career Development Award, Department of Veterans Affairs | Mean age: 68.5 years (range, 50-86) Sex: 100% male Race: NR Mean pure-tone threshold, right ear: 32.8 dB (SD, 5.6) Mean pure-tone threshold, left ear: 32.3 (SD, 5.7) | Fair

* Average of 1000, 2000, and 4000 Hz hearing levels.

** New users group only.

Abbreviations: ACP = American College of Physicians; N/A = not applicable; NR = not reported; SD = standard deviation.

Appendix B3 Whispered Voice, Watch Tick, and Finger Rub Clinical Tests Evidence Table

Study, Year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N | Proportion with hearing loss | Definition of a positive screening exam | Definition of a case | Subjects | Proportion un-examinable by screening test | Analysis of screening failures | Proportion who underwent reference standard | Sensitivity (range) | Specificity (range) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value | Negative predictive value | Diagnostic odds ratio | Quality score
Boatman et al, 2007^39^ | Whispered voice at 2 feet | Pure-tone audiometry | Cross-sectional | Movement disorders clinic (patients or family) | Neurologist | 50-88 years | 107 (214 ears) | Hearing loss >25 dB: 63% (135/214) | Inability to repeat 2 or more words from two 3-word combinations | >25 dB hearing loss at 500 Hz | Age: 66 years Sex: 51% female | Appears to be none | NA | 100% (214/214 ears) | 0.40 (0.32-0.49) | 0.82 (0.72-0.90) | 2.3 (1.3-3.8) | 0.73 (0.61-0.87) | 0.79 (0.68-0.88) | 0.45 (0.36-0.53) | 3.1 (1.5-6.6) | Good
Boatman et al, 2007^39^ | Watch tick at 6 inches | | | | | | | | No response to 2 or more of 6 presentations of watch tick | >25 dB hearing loss at 1000 Hz | Age: 66 years Sex: 51% female | Appears to be none | NA | 100% (214/214 ears) | 0.44 (0.35-0.53) | 1.0 (0.95-1.0) | 70 (4.4-1120) | 0.57 (0.49-0.66) | 1.0 (0.94-1.0) | 0.51 (0.43-0.59) | 120 (7.5-2040) | Good
Boatman et al, 2007^39^ | Finger rub at 6 inches | | | | | | | | No response to 2 or more of 6 finger rubs | >25 dB hearing loss at 2000 Hz | Age: 66 years Sex: 51% female | Appears to be none | NA | 100% (214/214 ears) | 0.27 (0.19-0.35) | 0.98 (0.91-1.0) | 10 (2.6-43) | 0.75 (0.68-0.84) | 0.95 (0.82-0.99) | 0.44 (0.36-0.51) | 14 (3.4-120) | Good
Eekhof et al,1996^40^ | Whispered voice at 2 feet | Pure-tone audiometry | Cross-sectional | Otolaryngology clinic | NR | ≥55 years (mean age NR) | 62 (124 ears) | Hearing loss >30 dB: 59% (73/124) Hearing loss >40 dB: 33% (41/124) | Inability to repeat 2 or more combinations correctly | >30 dB hearing loss in either ear (frequency NR) | Age: ≥55 years (mean NR) Sex: NR | Appears to be none | NA | 100% (124/124 ears) | 0.90 (0.81-0.96) | 0.80 (0.67-0.90) | 4.6 (2.6-8.1) | 0.12 (0.06-0.24) | 0.87 (0.77-0.94) | 0.85 (0.72-0.94) | 39 (12-130) | Fair
Macphee et al,1988^41^ | Whispered voice at 2 feet | Pure-tone audiometry | Cross-sectional | Acute rehabilitation wards | Geriatrician and otolaryngologist | Mean age 81 years (range, 66 to 96) | 62 (124 ears) | Hearing loss >30dB: 61% (38/62) | Inability to repeat 1 triplet set of numbers correctly or 50% of 4 sets of triplet numbers | >30 dB hearing loss at 500 Hz | Mean age: 81 years Sex: 69% female | Appears to be none | NA | 100% (124/124 ears) | 1.0 (0.95-1.0) | 0.83 (0.70-0.93) | 5.7 (3.1-10.6) | 0.008 (0.0005-0.13) | 0.91 (0.82-0.96) | 1.0 (0.91-1.0) | 730 (41-12,950) | Fair
Macphee et al,1988^41^ | Whispered voice at 6 inches | | | | | | | | Inability to repeat 1 triplet set of numbers correctly or 50% of 4 sets of triplet numbers | >30 dB hearing loss at 1000 Hz | Mean age: 81 years Sex: 69% female | Appears to be none | NA | 100% (124/124 ears) | 0.74 (0.62-0.83) | 1.0 (0.93-1.0) | 72 (4.6-1140) | 0.27 (0.19-0.39) | 1.0 (0.94-1.0) | 0.71 (0.58-0.81) | 270 (16-4540) | Fair
Macphee et al,1988^41^ | Conversation voice at 2 feet | | | | | | | | Inability to repeat 1 triplet set of numbers correctly or 50% of 4 sets of triplet numbers | >30 dB hearing loss at 2000 Hz | Mean age: 81 years Sex: 69% female | Appears to be none | NA | 100% (124/124 ears) | 0.47 (0.36-0.59) | 1.0 (0.93-1.0) | 46 (2.9-740) | 0.53 (0.43-0.66) | 1.0 (0.90-1.0) | 0.55 (0.44-0.65) | 87 (5.2-1470) | Fair
Swan et al, 1985^42^ | Whispered voice at 2 feet | Pure-tone audiometry | Cross-sectional | Audiology clinic | NR | Mean age 57 years | 101 (202 ears) | Hearing loss >30 dB: 43% (87/202) | Unable to repeat at least 3 out of 6 letters or numerals correctly | >30 dB hearing loss at 500, 1000, and 2000 Hz | Mean age: 57 years Sex: NR | Appears to be none | NA | 100% (202/202 ears) | 1.0 (0.96-1.0) | 0.87 (0.79-0.93) | 7.4 (4.7-12) | 0.007 (0.0005-0.10) | 0.85 (0.77-0.92) | 1.0 (0.96-1.0) | 1140 (70-19,240) | Fair

Abbreviations: CI = confidence interval; N = number of enrollees; NA = not applicable; NR = not reported.

Appendix B4 Single Screening Question Evidence Table

Study, Year | Screening question | Reference standard | Type of study | Setting | Screener | Age of enrollees | N | Proportion with hearing loss | Subjects | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard | Definition of a case | Sensitivity | Specificity | Positive likelihood ratio | Negative likelihood ratio | Positive predictive value | Negative predictive value | Diagnostic odds ratio | Quality score
Community-Dwelling Older Adults
Boatman et al, 2007^39^ | Do you think you have difficulty hearing? | Pure-tone audiometry | Cross-sectional | Patients and family from movement disorders clinic | Neurologist Reference test: audiologist | 50-88 years | 107 | Hearing loss >25 dB: 24% | Ages 50-64: 37% Ages 65-74: 49% Ages >74: 14% Sex: 49% male | NR | None | 100% | >25 dB hearing loss at 500, 1000, 2000, or 4000 Hz in either ear | 0.27 (0.16-0.41) | 0.89 (0.78-0.96) | 2.5 (1.0-5.9) | 0.82 (0.68-0.99) | 0.70 (0.46-0.88) | 0.56 (0.45-0.67) | 3.0 (0.96-10) | Good
Clark et al, 1991^43^ | Would you say that you have any difficulty hearing? | Pure-tone audiometry | Cross-sectional | Population from an osteoporosis study | NR Reference test: audiologist | 60-85 years | 267 | Hearing loss >40 dB: 18% Hearing loss >25 dB: 45% | Age: NR Sex: 100% female | NR | None | 99% (267/290) | ≥25 dB hearing loss at 1000 and 2000 Hz in better ear | 0.66 (0.55-0.75) | 0.80 (0.74-0.86) | 3.3 (2.4-4.6) | 0.43 (0.32-0.58) | 0.63 (0.52-0.73) | 0.82 (0.76-0.88) | 7.7 (4.2-14) | Good
Clark et al, 1991^43^ | Would you say that you have any difficulty hearing? | Pure-tone audiometry | Cross-sectional | Population from an osteoporosis study | NR Reference test: audiologist | 60-85 years | 267 | Hearing loss >40 dB: 18% Hearing loss >25 dB: 45% | Age: NR Sex: 100% female | NR | None | 99% (267/290) | ≥25 dB hearing loss at 1000, 2000, 3000, and 4000 Hz in better ear | 0.56 (0.47-0.65) | 0.82 (0.75-0.88) | 3.1 (2.1-4.5) | 0.53 (0.43-0.67) | 0.71 (0.61-0.80) | 0.70 (0.63-0.77) | 5.8 (3.2-10) | Good
Clark et al, 1991^43^ | Would you say that you have any difficulty hearing? | Pure-tone audiometry | Cross-sectional | Population from an osteoporosis study | NR Reference test: audiologist | 60-85 years | 267 | Hearing loss >40 dB: 18% Hearing loss >25 dB: 45% | Age: NR Sex: 100% female | NR | None | 99% (267/290) | >40 dB hearing loss at 1000 and 2000 Hz in worse ear | 0.81 (0.67-0.91) | 0.74 (0.68-0.80) | 3.1 (2.4-4.1) | 0.26 (0.14-0.47) | 0.40 (0.30-0.51) | 0.95 (0.90-0.98) | 12 (5.3-30) | Good
Gates et al, 2003^47^ | Do you have a hearing problem now? | Pure-tone audiometry | Cross-sectional | Subset of Framingham cohort | Self-administered questionnaire with audiologist review | >70 years | 546 | Hearing loss >40 dB (V&W): 27% | Mean age: 78.3 (±4.1) Sex: 36% male | 7% (due to time, fatigue, malaise) | None | 93% (672/723) | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears or >40 dB hearing loss at 1000 and 2000 Hz in one ear | 0.71 (0.63-0.78) | 0.72 (0.67-0.76) | 2.5 (2.1-3.0) | 0.41 (0.31-0.53) | 0.48 (0.41-0.55) | 0.87 (0.83-0.90) | 6.2 (4.0-9.6) | Good
Nondahl et al, 1998^44^; Wiley et al, 2000^69^ | Do you feel you have hearing loss? | Pure-tone audiometry | Cross-sectional | Subset of Beaver Dam Eye Study | NR | 48-92 years | 3342 | Hearing loss >25 dB: 32% | Age: 65.8 years Sex: 42.3% male | 6.0% did not respond or answered "I don't know" | None | 89% (3342/3753); 1701 were ages 65-92 years | >25 dB hearing loss at 500, 1000, 2000, and 4000 Hz in either ear | 0.67 (0.64-0.70) | 0.80 (0.77-0.83) | 3.4 (2.8-4.0) | 0.41 (0.38-0.45) | 0.86 (0.84-0.88) | 0.57 (0.53-0.60) | 8.1 (6.4-10) | Good
Rawool et al, 2008^52^ | Do you think you have hearing loss? | Pure-tone audiometry (portable audiometer) | Cross-sectional | Volunteer active community dwelling | Researcher | ≥65 years | 30 | Hearing loss >25 dB: 63% | Age: 77.5 years Sex: 26.7% male | NR | None | 100% | ≥25 dB hearing loss at 500, 1000, 2000, 3000, and 4000 Hz in better ear | 0.68 (0.43-0.87) | 0.81 (0.48-0.98) | 3.8 (1.0-13.7) | 0.39 (0.19-0.79) | 0.87 (0.60-0.98) | 0.60 (0.32-0.84) | 9.8 (1.3-110) | Fair
Sindhusake et al, 2001^45^ | Do you feel you have hearing loss? | Pure-tone audiometry | Cross-sectional | Subset of Blue Mountain Eye Study | NR Reference test: audiologist | 55-99 years | 1931 | Hearing loss >25 dB: 39% | Age 55-64: 29.8% Age 65-74: 41.1% Age 75-84: 24% Age ≥85: 5.1% Sex: 42.6% male | 3.6% did not answer or answered "don't know" | None | 96% (1931/2015) | >25 dB hearing loss at 500-4000 Hz | 0.78 (0.75-0.81) | 0.67 (0.64-0.70) | 2.4 (2.2-2.6) | 0.33 (0.29-0.38) | 0.61 (0.58-0.64) | 0.82 (0.80-0.85) | 7.2 (5.8-8.9) | Good
Sindhusake et al, 2001^45^ | Do you feel you have hearing loss? | Pure-tone audiometry | Cross-sectional | Subset of Blue Mountain Eye Study | NR Reference test: audiologist | 55-99 years | 1931 | Hearing loss >40 dB: 14% | Age 55-64: 29.8% Age 65-74: 41.1% Age 75-84: 24% Age ≥85: 5.1% Sex: 42.6% male | 3.6% did not answer or answered "don't know" | | | >40 dB hearing loss at 500-4000 Hz | 0.93 (0.89-0.96) | 0.56 (0.54-0.58) | 2.1 (2.0-2.3) | 0.13 (0.08-0.20) | 0.25 (0.23-0.28) | 0.98 (0.97-0.99) | 17 (10-28)
Sindhusake et al, 2001^45^ | Do you feel you have hearing loss? | Pure-tone audiometry | Cross-sectional | Subset of Blue Mountain Eye Study | NR Reference test: audiologist | 55-99 years | 1931 | Hearing loss >60 dB: 2% | Age 55-64: 29.8% Age 65-74: 41.1% Age 75-84: 24% Age ≥85: 5.1% Sex: 42.6% male | 3.6% did not answer or answered "don't know" | | | >60 dB hearing loss at 500-4000 Hz | 1.0 (0.92-1.0) | 0.50 (0.48-0.52) | 2.0 (1.9-2.1) | 0.02 (0.001-0.34) | 0.05 (0.03-0.06) | 1.0 (1.0-1.0) | 91 (5.6-1480)
Torre et al, 2006^54^ | Do you feel you have hearing loss? English and Spanish) | Pure-tone audiometry (portable audiometer) | Cross-sectional | Referred from physicians or medical staff | NR | 42-88 years | 59 | Hearing loss >25 dB: 63% | Mean age: 62.3 years Sex: 45.8% male | None | NA | 100% (32/32) all were ages 60 and older | ≥25 dB hearing loss at 500, 1000, 2000, and 4000 Hz in worse ear | 0.76 (0.59-0.88) | 0.73 (0.50-0.89) | 2.8 (1.4-5.6) | 0.33 (0.18-0.62) | 0.82 (0.66-0.93) | 0.64 (0.43-0.82) | 8.3 (2.2-33) | Fair
Nursing Home-Dwelling Older Adults
Voeks et al, 1993^55^ | Do you have trouble hearing? | Pure-tone audiometry (portable audiometer) | Cross-sectional | New admissions to nursing home | NR | NR | 198 | Hearing loss >25 dB: 54% | Mean age: 72.4 years (±11.4) Sex: 80% male | 17% (41/239) did not have reliable audiometric responses | >50% of those with unreliable results gave verbal indication of some hearing dysfunction | 84% (198/239) | >25 dB hearing loss at 500, 1000, 2000, and 4000 Hz in better ear | 0.69 (0.60-0.78) | 0.51 (0.40-0.61) | 1.4 (1.1-1.8) | 0.61 (0.43-0.87) | 0.62 (0.53-0.71) | 0.58 (0.47-0.69) | 2.3 (1.2-4.3) | Fair

Abbreviations: N = number of enrollees; NR = not reported; V&W = Ventry & Weinstein criteria.

Appendix B5 Hearing Questionnaires Evidence Table

Study, Year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N | Proportion with hearing loss | Definition of a positive screening exam | Subjects | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference test | Definition of a case | Sensitivity | Specificity | Positive likelihood ratio | Negative likelihood ratio | Positive predictive value | Negative predictive value | Diagnostic odds ratio | Quality score
Community-Dwelling
Gates et al, 2003^47^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Subset of Framingham cohort | Self-administered questionnaire with audiologist review | >70 years | 546 | Hearing loss >40 dB (V&W criteria): 27% | Score >8 on HHIE-S | Mean age: 78.3 yrs (±4.1) Sex: 36% male | 7% (51/723) due to time, fatigue, malaise | None | 100% (672/672) | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears; or 1000 and 2000 Hz in one ear | 0.36 (0.28-0.44) | 0.92 (0.89-0.94) | 4.5 (3.0-6.7) | 0.70 (0.61-0.79) | 0.62 (0.51-0.73) | 0.80 (0.76-0.83) | 6.5 (3.8-11) | Good
Lichtenstein et al, 1988^46^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Internal medicine clinic | Self-administered HHIE-S Reference test: unknown | >65 years | 178 | Hearing loss >40 dB (V&W criteria): 30% | Score >8 on HHIE-S | Age: 74.2 yrs ±6.4 Sex: 37.1% male Race: 77.5% white | 13% (36/284) | None | 100% (178/178) | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears; or 1000 and 2000 Hz in one ear | 0.72 (0.58-0.83) | 0.77 (0.68-0.84) | 3.1 (2.2-4.4) | 0.37 (0.24-0.57) | 0.57 (0.44-0.69) | 0.87 (0.79-0.92) | 8.4 (3.8-19) | Good
Lichtenstein et al, 1988^46^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Internal medicine clinic | Self-administered HHIE-S Reference test: unknown | >65 years | 178 | Hearing loss >40 dB (V&W criteria): 30% | Score >24 on HHIE-S | Age: 74.2 yrs ±6.4 Sex: 37.1% male Race: 77.5% white | 13% (36/284) | None | 100% (178/178) | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears; or 1000 and 2000 Hz in one ear | 0.25 (0.14-0.38) | 0.98 (0.93-1.0) | 10.2 (3.0-34.0) | 0.77 (0.66-0.90) | 0.81 (0.54-0.96) | 0.75 (0.68-0.82) | 13 (3.3-75) | Good
Lichtenstein et al, 1988^46^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Internal medicine clinic | Self-administered HHIE-S Reference test: unknown | >65 years | 178 | Hearing loss >25 dB (SFPTA criteria): 38% | Score >8 on HHIE-S | Age: 74.2 yrs ±6.4 Sex: 37.1% male Race: 77.5% white | 13% (36/284) | None | 100% (178/178) | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 0.66 (0.54-0.77) | 0.79 (0.70-0.86) | 3.2 (2.1-4.7) | 0.43 (0.30-0.60) | 0.66 (0.54-0.77) | 0.79 (0.70-0.86) | 7.4 (3.6-16) | Good
Lichtenstein et al, 1988^46^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Internal medicine clinic | Self-administered HHIE-S Reference test: unknown | >65 years | 178 | Hearing loss >25 dB (HFPTA criteria): 58% | Score >8 on HHIE-S | Age: 74.2 yrs ±6.4 Sex: 37.1% male Race: 77.5% white | 13% (36/284) | None | 100% (178/178) | [underlined: HFPTA]: ≥25 dB hearing loss at 1000, 2000, and 4000 Hz in better ear | 0.53 (0.43-0.63) | 0.84 (0.74-0.91) | 3.3 (1.9-5.8) | 0.56 (0.44-0.70) | 0.82 (0.71-0.90) | 0.57 (0.47-0.66) | 6.0 (2.8-14) | Good
McBride et al, 1994^22^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Community health clinic; VA Medical Center | Trained researcher | >60 years | 185 | Not reported | Score >8 on HHIE-S; Score >24 on HHIE-S | Mean age: 70 yrs (±5.0) Sex: 69% male SES: 8 mean yrs of school | 6.1% (13/212) | Not applicable | 100% | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 0.58 (0.45-0.70) | 0.76 (0.69-0.84) | 2.4 (1.6-3.5)^*^ | 0.55^*^ | Not calculable | Not calculable | 4.4^*^ | Good
McBride et al, 1994^22^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Community health clinic; VA Medical Center | Trained researcher | >60 years | 185 | Not reported | Score >8 on HHIE-S; Score >24 on HHIE-S | Mean age: 70 yrs (±5.0) Sex: 69% male SES: 8 mean yrs of school | 6.1% (13/212) | Not applicable | 100% | [underlined: HFPTA]: ≥25 dB hearing loss at 1000, 2000, and 4000 Hz in better ear | 0.48 (0.39-0.58) | 0.86 (0.79-0.94) | 3.6 (2.0-6.6)^*^ | 0.60^*^ | Not calculable | Not calculable | 5.7^*^ | Good
McBride et al, 1994^22^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Community health clinic; VA Medical Center | Trained researcher | >60 years | 185 | Not reported | Score >8 on HHIE-S; Score >24 on HHIE-S | Mean age: 70 yrs (±5.0) Sex: 69% male SES: 8 mean yrs of school | 6.1% (13/212) | Not applicable | 100% | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears; or 1000 and 2000 Hz in one ear | 0.63 (0.49-0.76) | 0.75 (0.68-0.82) | 2.5 (1.8-3.6)^*^ | 0.49^*^ | Not calculable | Not calculable | 5.1^*^ | Good
McBride et al, 1994^22^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Community health clinic; VA Medical Center | Trained researcher | >60 years | 185 | Not reported | Score >8 on HHIE-S; Score >24 on HHIE-S | Mean age: 70 yrs (±5.0) Sex: 69% male SES: 8 mean yrs of school | 6.1% (13/212) | Not applicable | 100% | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 0.36 (0.23-0.48) | 0.87 (0.81-0.93) | 2.8 (1.6-5.0)^*^ | 0.74^*^ | Not calculable | Not calculable | 3.8^*^ | Good
McBride et al, 1994^22^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Community health clinic; VA Medical Center | Trained researcher | >60 years | 185 | Not reported | Score >8 on HHIE-S; Score >24 on HHIE-S | Mean age: 70 yrs (±5.0) Sex: 69% male SES: 8 mean yrs of school | 6.1% (13/212) | Not applicable | 100% | [underlined: HFPTA]: ≥25 dB hearing loss at 1000, 2000, and 4000 Hz in better ear | 0.29 (0.20-0.37) | 0.93 (0.88-0.99) | 4.3 (1.7-10)^*^ | 0.76^*^ | Not calculable | Not calculable | 5.4^*^ | Good
McBride et al, 1994^22^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Community health clinic; VA Medical Center | Trained researcher | >60 years | 185 | Not reported | Score >8 on HHIE-S; Score >24 on HHIE-S | Mean age: 70 yrs (±5.0) Sex: 69% male SES: 8 mean yrs of school | 6.1% (13/212) | Not applicable | 100% | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears; or 1000 and 2000 Hz in one ear | 0.42 (0.28-0.56) | 0.88 (0.82-0.93) | 3.4 (1.9-5.9)^*^ | 0.66^*^ | Not calculable | Not calculable | 5.3^*^ | Good
Nondahl et al, 1998^44^ Wiley et al, 2000^69^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Subset of Beaver Dam Eye Study | Unknown | 48-92 years | 3471 | Hearing loss >25 dB: 32% | Score >8 on HHIE-S | Age: 65.8 years Sex: 42.3% male | 2.4% did not complete all questions and were excluded | None | 100% (1725/1725 for ages 65-92 yrs) | >25 dB hearing loss at 500, 1000, 2000, and 4000 Hz in either ear | 0.32 (0.29-0.35) | 0.97 (0.95-0.98) | 10.7 (6.8-17.1) | 0.70 (0.67-0.73) | 0.95 (0.93-0.97) | 0.44 (0.41-0.46) | 15 (9.4-26) | Good
Sever et al, 1989^53^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Audiology clinic | Unknown | 60-84 years | 59 | Hearing loss >25 dB (SFPTA criteria): 36% Hearing loss >40 dB (V&W criteria): 27% | Score 0-8, 10-24, or 26-40 on HHIE-S | Age: Not reported Sex: Not reported | Not reported | None | 100% | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 0.71 (0.48-0.89) for HHIE-S score >8 | Not reported | Not calculable | Not calculable | HHIE-S 0-8: 0.43^*^ HHIE-S 10-24: 1.81^*^ HHIE-S 26-40: 3.02^*^ | Not dichotomized | Not dichotomized | Fair
Sever et al, 1989^53^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Audiology clinic | Unknown | 60-84 years | 59 | Hearing loss >25 dB (SFPTA criteria): 36% Hearing loss >40 dB (V&W criteria): 27% | Score 0-8, 10-24, or 26-40 on HHIE-S | Age: Not reported Sex: Not reported | Not reported | None | 100% | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears; or 1000 and 2000 Hz in one ear | 0.81 (0.54-0.96) for HHIE-S score >8 | Not reported | Not calculable | Not calculable | HHIE-S 0-8: 0.29^*^ HHIE-S 10-24: 1.80^*^ HHIE-S 26-40: 5.37^*^ | Not dichotomized | Not dichotomized | Fair
Sindhusake et al, 2001^45^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Subset of Blue Mountain Eye Study | Screening test: unknown Reference test: audiologist | 55-99 years | 1807 | Hearing loss >25 dB: 39% Hearing loss >40 dB: 13% Hearing loss >60 dB: 2% | Score >8 on HHIE-S | Age 55-64: 29.8% Age 65-74: 41.1% Age 75-84: 24.0% Age ≥85: 5.1% Sex: 42.6% male | 9.8% did not complete all questions and were excluded | None | 100% (1807/1807) | >25 dB hearing loss at 500, 1000, 2000, and 4000 Hz | 0.58 (0.54-0.62) | 0.85 (0.83-0.87) | 3.9 (3.3-4.5) | 0.49 (0.45-0.54) | 0.71 (0.67-0.75) | 0.76 (0.74-0.78) | 7.8 (6.2-10) | Good
Sindhusake et al, 2001^45^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Subset of Blue Mountain Eye Study | Screening test: unknown Reference test: audiologist | 55-99 years | 1807 | Hearing loss >25 dB: 39% Hearing loss >40 dB: 13% Hearing loss >60 dB: 2% | Score >8 on HHIE-S | Age 55-64: 29.8% Age 65-74: 41.1% Age 75-84: 24.0% Age ≥85: 5.1% Sex: 42.6% male | 9.8% did not complete all questions and were excluded | None | 100% (1807/1807) | >40 dB hearing loss at 500, 1000, 2000, and 4000 Hz | 0.80 (0.74-0.85) | 0.76 (0.74-0.78) | 3.3 (3.0-3.7) | 0.26 (0.20-0.34) | 0.33 (0.29-0.37) | 0.96 (0.95-0.97) | 13 (8.9-18) | Good
Sindhusake et al, 2001^45^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Subset of Blue Mountain Eye Study | Screening test: unknown Reference test: audiologist | 55-99 years | 1807 | Hearing loss >25 dB: 39% Hearing loss >40 dB: 13% Hearing loss >60 dB: 2% | Score >8 on HHIE-S | Age 55-64: 29.8% Age 65-74: 41.1% Age 75-84: 24.0% Age ≥85: 5.1% Sex: 42.6% male | 9.8% did not complete all questions and were excluded | None | 100% (1807/1807) | >60 dB hearing loss at 500, 1000, 2000, and 4000 Hz | 1.0 (0.90-1.0) | 0.70 (0.68-0.72) | 3.3 (3.0-3.6) | 0.02 (0.001-0.31) | 0.06 (0.04-0.08) | 1.0 (1.0-1.0) | 165 (10-2700) | Good
Ventry & Wein-stein, 1983^9^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Community volunteers | Unknown | ≥65 years | 104 | Hearing loss >40 dB: 51% | Score >8 on HHIE-S | Age: Not reported Sex: Not reported | Not reported | None | 100% | >40 dB hearing loss at 1000 or 2000 Hz in both ears | 0.72 (0.56-0.85) | 0.66 (0.52-0.77) | 2.1 (1.4-3.1) | 0.43 (0.26-0.71) | 0.60 (0.45-0.73) | 0.77 (0.63-0.88) | 4.9 (1.9-13) | Fair
Weinstein, 1986^56^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Senior citizen centers | Unknown | 62-91 years | 106 | Not reported | Score >8 on HHIE-S; Score >10 on HHIE-S | Age: 76 yrs (±6.9) Sex: 42.3% male | Not reported | None | 100% | Audiologist recommendation for evaluation | 0.74^*^ | 0.68^*^ | 2.3^*^ | 0.38^*^ | Not calculable | Not calculable | 6.1^*^ | Fair
Weinstein, 1986^56^ | HHIE-S | Pure-tone thresholds | Cross-sectional | Senior citizen centers | Unknown | 62-91 years | 106 | Not reported | Score >8 on HHIE-S; Score >10 on HHIE-S | Age: 76 yrs (±6.9) Sex: 42.3% male | Not reported | None | 100% | Audiologist recommendation for evaluation | 0.65^*^ | 0.83^*^ | 3.8^*^ | 0.42^*^ | Not calculable | Not calculable | 9.0^*^ | Fair
Koike et al, 1994^51^ | FMHT | Pure-tone thresholds | Cross-sectional | Audiology clinic | Unknown | >55 years | 70 | Not reported | Various cutoff scores on the FMHT | Age: 69.1 yrs (±8.39) Sex: 56% male | Not reported | None | 100% | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 10: 0.90^*^ 15: 0.80^*^ 25: 0.90^*^ 30: 0.74^*^ 35: 0.51^*^ 40: 0.26^*^ | 10: 0.20^*^ 15: 0.55^*^ 25: 0.54^*^ 30: 0.72^*^ 35: 0.87^*^ 40: 0.97^*^ | 10: 1.1^*^ 15: 1.8^*^ 25: 2.0^*^ 30: 2.6^*^ 35: 4.0^*^ 40: 9.9^*^ | 10: 0.47^*^ 15: 0.36^*^ 25: 0.18^*^ 30: 0.36^*^ 35: 0.56^*^ 40: 0.76^*^ | Not calculable | Not calculable | 10: 2.3^*^ 15: 5.0^*^ 25: 11^*^ 30: 7.2^*^ 35: 7.1^*^ 40: 13^*^ | Fair

* Confidence interval not calculable.

Abbreviations: FMHT = Five-Minute Hearing Test; HFPTA = High Frequency Pure-Tone Average; HHIE-S = Hearing Handicap Inventory for the Elderly-Screening; SES = socioeconomic status; SFPTA = Speech Frequency Pure-Tone Average; V&W = Ventry & Weinstein criteria.

Appendix B6 Handheld Audiometric Devices Evidence Table

Study, Year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N | Proportion with hearing loss | Definition of a positive screening exam | Subjects | Recruitment sources | Proportion un-examinable by screening test | Analysis of screening failures | Proportion screened who under-went reference standard | Definition of a case | Sensitivity | Specificity | Positive likelihood ratio | Negative likelihood ratio | Positive predictive value | Negative predictive value | Diagnostic odds ratio | Quality score
Community-Dwelling
Bienvenue et al, 1985^48^ | AudioScope | Pure-tone audiometry | Cross-sectional | Speech and hearing clinics | NR | 51-81 yrs | 30 | NR | Failure to hear 25 dB at 500, 1000, 2000, and 4000 Hz | Age: 51-81 yrs Sex: NR | Speech and hearing clinics | Appears to be none | NA | 100% | ≥30 dB hearing loss at 500, 1000, 2000,and 4000 Hz | 0.93^*^ | 0.7^*^ | 3.1^*^ | 0.10^*^ | Not calculable | Not calculable | 31^*^ | Fair
Eekhof et al, 1996^40^ | AudioScope | Pure-tone audiometry | Cross-sectional | Otolaryngology clinic | NR | ≥55 yrs | 62 (124 ears) | Hearing loss >30 dB: 59% (73/124) Hearing loss >40 dB: 33% (41/124) | Failure to hear 40 dB at 500, 1000, 2000, and 4000 Hz using AudioScope | Age: ≥55 yrs Sex: NR | Outpatient ENT clinic | Appears to be none | NA | 100% | >40 dB hearing loss | 1.0 (0.91-1.0) | 0.42 (0.31-0.54) | 1.7 (1.4-2.1) | 0.03 (0.002-0.45) | 0.46 (0.35-0.57) | 1.0 (0.90-1.0) | 61 (3.6-102)
Frank and Petersen, 1987^50^ | AudioScope | Pure-tone audiometry | Cross-sectional | Speech and hearing clinic; Rehab center | AudioScope: audiologist or speech pathologist; Reference test: audiologist | 50-96 yrs | 405 (688 ears) | NR | Failure to hear 40 dB at 500, 1000, 2000, and 4000 Hz | Age: 50-96 yrs Sex: NR | Speech and hearing clinics; rehab center; senior citizen groups | 10% ears were not able to be screened | NA; rate of screening failure increased with age | 100% | ≥45 dB hearing loss at 500, 1000, 2000, and 4000 Hz | Age 50-59: 0.90^*^ 60-69: 0.89 70-79: 0.85 80-89: 0.86 90-96: 0.86 | Age 50-59: 0.94^*^ 60-69: 0.90 70-79: 0.90 80-89: 0.89 90-96: 0.90 | Age 50-59: 16^*^ 60-69: 9.2^*^ 70-79: 8.7^*^ 80-89: 8.1^*^ 90-96: 9.1^*^ | Age 50-59: 0.11^*^ 60-69: 0.12^*^ 70-79: 0.17^*^ 80-89: 0.16^*^ 90-96: 0.15^*^ | Not calculable | Not calculable | Age 50-59: 140^*^ 60-69: 77^*^ 70-79: 51^*^ 80-89: 51^*^ 90-96: 61^*^ | Fair
Lichtenstein et al, 1988^46^ | AudioScope | Pure-tone audiometry | Cross-sectional | Internal medicine clinic | AudioScope: internist; Reference test: NR | >65 yrs | 178 | Hearing loss >40 dB: 30% at 40 dB | Failure to hear 40 dB at 500, 1000, 2000, or 4000 Hz | Age: 74.2 yrs Sex: 37.1% male Race: 77.5% white | 6 internal medicine clinics | (25+7+16)/284 17% (due to stroke, dementia, or severe illness) | Not screened due to severe health conditions | 100% | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears; or 1000 and 2000 Hz in 1 ear | 0.94 (0.84-0.99) | 0.72 (0.63-0.80) | 3.4 (2.5-4.5) | 0.08 (0.03-0.24) | 0.59 (0.48-0.69) | 0.97 (0.91-0.99) | 43 (12-220) | Good
McBride et al, 1994^22^ | AudioScope | Pure-tone audiometry | Cross-sectional | Community health clinic; VA Medical Center | Trained researcher | >60 yrs | 185 | NR | Failure to hear 40 dB at 2000 Hz in better ear | Mean age: 70 yrs (±5.0) Sex: 69% male SES: 8 mean yrs of school | Community health clinic; VA Medical Center | 6.1% (13/212) | NA | 100% | [underlined: SFPTA]: ≥25 dB hearing loss at 500, 1000, and 2000 Hz in better ear | 0.64 (0.52-0 .77) | 0.89 (0.83-0.94) | 5.8 (3.4-9.8) | 0.40^*^ | Not calculable | Not calculable | 14^*^ | Good
McBride et al, 1994^22^ | AudioScope | Pure-tone audiometry | Cross-sectional | Community health clinic; VA Medical Center | Trained researcher | >60 yrs | 185 | NR | Failure to hear 40 dB at 2000 Hz in better ear | Mean age: 70 yrs (±5.0) Sex: 69% male SES: 8 mean yrs of school | Community health clinic; VA Medical Center | 6.1% (13/212) | NA | 100% | [underlined: HFPTA]: ≥25 dB hearing loss at 1000, 2000 and 4000 Hz in better ear | 0.71 (0.63-0.80) | 0.91 (0.84-0.97) | 7.5 (3.7-15) | 0.32^*^ | Not calculable | Not calculable | 23^*^ | Good
McBride et al, 1994^22^ | AudioScope | Pure-tone audiometry | Cross-sectional | Community health clinic; VA Medical Center | Trained researcher | >60 yrs | 185 | NR | Failure to hear 40 dB at 2000 Hz in better ear | Mean age: 70 yrs (±5.0) Sex: 69% male SES: 8 mean yrs of school | Community health clinic; VA Medical Center | 6.1% (13/212) | NA | 100% | [underlined: V&W]: >40 dB hearing loss at 1000 or 2000 Hz in both ears; or 1000 and 2000 Hz in 1 ear | 0.96 (0.90-1.00) | 0.80 (0.74-0.87) | 4.9 (3.4-6.8) | 0.05^*^ | Not calculable | Not calculable | 98^*^ | Good
Chronic Care Facility-Dwelling Older Adults
Ciurlia-Guy et al, 1993^49^ | AudioScope | Pure-tone audiometry | Cross-sectional | VA chronic care facilities | AudioScope: research assistant; Reference test: audiologist | 60-99 yrs | 99 | Hearing loss >40 dB: 69% | Failure to hear 40 dB at 1000 or 2000 Hz in either ear | Age: 79 yrs (±9.98) Sex: 88% male | VA chronic care facility | 3.8% (4/104) didn’t complete AudioScopescreening | None | 100% of those included | >40 dB hearing loss at 1000 or 2000 Hz in either ear | 0.98 (0.91-1.0) | 0.21 (0.08-0.41) | 1.3 (1.0-1.5) | 0.08 (0.01-0.61) | 0.73 (0.62-0.82) | 0.86 (0.42-1.0) | 16 (1.8-76) | Fair

* Confidence interval not calculable.

Abbreviations: HFPTA = Hearing Frequency Pure-Tone Average; NA = not applicable; NR = not reported; SES = socioeconomic status; SFPTA = Speech Frequency Pure-Tone Average; V&W = Ventry & Weinstein criteria.

Appendix B7 Quality Ratings of Diagnostic Test Studies

Study, year | Representative spectrum | Random or consecutive sample | Screening test adequately described | Screening cutoffs predefined | Credible reference standard | Reference standard applied to all patients or a random subset | Same reference standard applied to all patients | Reference standard and screening examination interpreted independently | High rate of uninterpretable results or non-compliance with screening | Analysis includes patients with uninterpretable results or non-compliance | Quality score
Bienvenue et al, 1985^48^ | No | Cannot tell | Yes | Yes | Yes | Yes | Yes | Cannot tell | No | Not applicable | Fair
Boatman et al, 2007^39^ | High prevalence | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Not applicable | Good
Ciurlia-Guy et al, 1993^49^ | High prevalence | Yes | Yes | Yes | Yes, portable audiometer | No (5/104) | Yes | Yes | No | No | Fair
Clark et al, 1991^43^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Cannot tell | No | No | Good
Eekhof et al, 1996^40^ | High prevalence | Yes | Yes | Yes | Yes | Yes | Yes | Cannot tell | No | Not applicable | Fair
Frank and Petersen, 1987^50^ | Yes | Cannot tell | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Fair
Gates et al, 2003^47^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | Good
Koike et al, 1994^51^ | No | Cannot tell | Yes | No | Yes | Yes | Yes | Cannot tell | Cannot tell | Cannot tell | Fair
Lichtenstein et al, 1988^46^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Cannot tell | No | No | Good
Macphee et al,1988^41^ | High prevalence | Cannot tell | Yes | Yes | Yes | Yes | Yes | Yes | No | Not applicable | Fair
McBride et al, 1994^22^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Cannot tell | No | NA | Good
Nondahl et al, 1998^44^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Cannot tell | No | No | Good
Rawool et al, 2008^52^ | High prevalence | No | Yes | Yes | Yes, portable audiometer | Yes | Yes | Cannot tell | Cannot tell | Cannot tell | Fair
Sever et al,1989^53^ | Yes | Cannot tell | Yes | Yes | Yes | Yes | Yes | Cannot tell | Cannot tell | Cannot tell | Fair
Sindhusake et al, 2001^45^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Cannot tell | Yes | No | Good
Swan et al,1985^42^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Cannot tell | No | Not applicable | Fair
Torre et al, 2006^54^ | High prevalence (63%) | No | Yes | Yes | Yes, portable audiometer | Yes | Yes | Cannot tell | No | Not applicable | Fair
Ventry and Weinstein, 1983^9^ | Cannot tell | Cannot tell | Yes | Yes | Yes | Yes | Yes | Cannot tell | Cannot tell | Cannot tell | Fair
Voeks et al, 1993^55^ | High prevelance (54%) | Yes | Yes | Yes | Yes, portable audiometer | Yes | Yes | Cannot tell | Yes | Yes | Fair
Weinstein, 1986^56^ | Yes | No | Yes | No | No | Yes | Yes | Yes | Cannot tell | Cannot tell | Fair