# Expert Reviewers of the Draft Report

Karen J. Cruickshanks, PhD

Professor, University of Wisconsin-Madison School of Medicine and Public Health, Ophthalmology and Visual Sciences and Population Health Sciences

Linda Kinsinger, MD, MPH

Chief Consultant, Preventive Medicine, Veterans Health Administration, National Center for Health Promotion and Disease Prevention

Paul Shekelle, MD, PhD

Director, Southern California Evidence-Based Practice Center, RAND Corporation; Professor of Medicine, University of California, Los Angeles School of Medicine; Staff physician, Veterans Affairs Medical Center

Daniel A. Sklare, PhD

Research Training Officer, National Institute on Deafness and Other Communication Disorders, National Institutes of Health, Division of Scientific Programs