# Excluded Studies

## Wrong Population

Ahn JH, Lee HS, Kim YJ, et al. Comparing pure-tone audiometry and auditory steady state response for the measurement of hearing loss. Otolaryngol Head Neck Surg. 2007;136(6):966-971. [pmid: 17547989].
Andelin LC, Alessi CA, Aronow HU. Reliability of screening for sensory impairment in depressed versus nondepressed older adults. J Am Geriatr Soc. 1995;43(6):684-687. [pmid: 7775731].
Barbara M, Bandiera G, Serra B, et al. Digital hearing aids for high-frequency sensorineural hearing loss: preliminary experience with the RetroX device. Acta Otolaryngol. 2005;125(7):693-696. [pmid: 16012028].
Bille M, Jensen AM, Kjaerbol E, et al. Clinical study of a digital vs an analogue hearing aid. Scand Audiol. 1999;28(2):127-135. [pmid: 10384900].
Bosman AJ, Hol MK, Snik AF, et al. Bone-anchored hearing aids in unilateral inner ear deafness. Acta Otolaryngol. 2003;123(2):258-260. [pmid: 12701753].
Chao TK, Chen TH. Distortion product otoacoustic emissions as a prognostic factor for idiopathic sudden sensorineural hearing loss. Audiol Neurootol. 2006;11(5):331-338. [pmid: 16983184].
Cienkowski KM, McHugh MS, McHugo GJ, et al. A computer method for assessing satisfaction with hearing aids. Int J Audiol. 2006;45(7):393-399. [pmid: 16938797].
Cohen SM, Labadie RF, Dietrich MS, et al. Quality of life in hearing-impaired adults: the role of cochlear implants and hearing aids. Otolaryngol Head Neck Surg. 2004;131(4):413-422. [pmid: 15467610].
Cohen SM, Turley R. Coprevalence and impact of dysphonia and hearing loss in the elderly. Laryngoscope. 2009;119(9):1870-1873. [pmid: 19572385].
De Silva ML, McLaughlin MT, Rodrigues EJ, et al. A mini-mental status examination for the hearing impaired. Age Ageing. 2008;37(5):593-595. [pmid: 18687874].
Del Bo L, Ambrosetti U. Hearing aids for the treatment of tinnitus. Prog Brain Res. 2007;166:341-345. [pmid: 17956798].
Dias de Freitas C, Costa M. Hearing aid fitting process in users fitted in a federal public institution, part II: self-assessment questionnaire results. Braz J Otorhinolaryngol. 2007;73(5):660-670. [pmid: 18094808].
Fellinger J, Holzinger D, Gerich J, et al. Mental distress and quality of life in the hard of hearing. Acta Psychiatr Scand. 2007;115(3):243-245. [pmid: 17302625].
Folmer RL, Carroll JR. Long-term effectiveness of ear-level devices for tinnitus. Otolaryngol Head Neck Surg. 2006;134(1):132-137. [pmid: 16399193].
Freyaldenhoven MC, Nabelek AK, Tampas JW. Relationship between acceptable noise level and the abbreviated profile of hearing aid benefit. J Speech Lang Hear Res. 2008;51(1):136-146. [pmid: 18230861].
Gilhome Herbst KR, Meredith R, Stephens SD. Implications of hearing impairment for elderly people in London and in Wales. Acta Otolaryngol Suppl. 1990(476):209-214. [pmid: 2087965].
Gordon-Salant S, Lantz J, Fitzgibbons P. Age effects on measures of hearing disability. Ear Hear. 1994;15(3):262-265. [pmid: 8076724].
Hill SL 3rd, Marcus A, Digges EN, et al. Assessment of patient satisfaction with various configurations of digital CROS and BiCROS hearing aids. Ear Nose Throat J. 2006;85(7):427-430. [pmid: 16909811].
Hol MK, Snik AF, Mylanus EA, et al. Long-term results of bone-anchored hearing aid recipients who had previously used air-conduction hearing aids. Arch Otolaryngol Head Neck Surg. 2005;131(4):321-325. [pmid: 15837900].
Jespersen CT, Groth J, Kiessling J, et al. The occlusion effect in unilateral versus bilateral hearing aids. J Am Acad Audiol. 2006;17(10):763-773. [pmid: 17153723].
Jupiter T, Palagonia CL. The Hearing Handicap Inventory for the Elderly screening version adapted for use with elderly Chinese American individuals. Am J Audiol. 2001;10(2):99-103. [pmid: 11808726].
Karlsmose B, Lauritzen T, Engberg M, et al. A randomised controlled trial of screening for adult hearing loss during preventive health checks. Br J Gen Pract. 2001;51(466):351-355. [pmid: 11360697].
Lopez-Vazquez M, Orozco JA, Jimenez G, et al. Spanish hearing impairment inventory for the elderly. Int J Audiol. 2002;41(4):221-230. [pmid: 12154812].
Mendel LL. Objective and subjective hearing aid assessment outcomes. Am J Audiol. 2007;16(2):118-129. [pmid: 18056880].
Metselaar M, Maat B, Krijnen P, Verschuure H, Dreschler WA, Feenstra L. Self-reported disability and handicap after hearing-aid fitting and benefit of hearing aids: comparison of fitting procedures, degree of hearing loss, experience with hearing aids and uni- and bilateral fittings. Eur Arch Otorhinolaryngol. 2009;266(6):907-917. [pmid: 19005632].
Okamoto M, Nakanishi N, Tatara K. Self-reported hearing difficulty and hearing impairment in Japanese people living in a community. Int J Audiol. 2004;43(1):54-59. [pmid: 14974628].
Palmer CV, Bentler R, Mueller HG. Amplification with digital noise reduction and the perception of annoying and aversive sounds. Trends Amplif. 2006;10(2):95-104. [pmid: 16959733].
Saunders GH, Forsline A. The Performance-Perceptual Test (PPT) and its relationship to aided reported handicap and hearing aid satisfaction. Ear Hear. 2006;27(3):229-242. [pmid: 16672792].
Smith MF, Nathan RG, Wayner DS, et al. Comparative validity of two hearing loss screening questionnaires. J Fam Pract. 1992;35(4):411-416. [pmid: 1402729].
Surr RK, Kolb JA, Cord MT, et al. Tinnitus Handicap Inventory (THI) as a hearing aid outcome measure. J Am Acad Audiol. 1999;10(9):489-495. [pmid: 10522622].
Uhlmann RF, Rees TS, Psaty BM, et al. Validity and reliability of auditory screening tests in demented and non-demented older adults. J Gen Intern Med. 1989;4(2):90-96. [pmid: 2651606].

## Wrong Intervention

Andersson G. Decreased use of hearing aids following training in hearing tactics. Percept Mot Skills. 1998;87(2):703-706. [pmid: 9842626].
Andersson G, Green M, Melin L. Behavioural hearing tactics: a controlled trial of a short treatment programme. Behav Res Ther. 1997;35(6):523-530. [pmid: 9159976].
Andersson G, Melin L, Scott B, et al. Behavioral counselling for subjects with acquired hearing loss: a new approach to hearing tactics. Scand Audiol. 1994;23(4):249-256. [pmid: 7878376].
Badran K, Bunstone D, Arya AK, et al. Patient satisfaction with the bone-anchored hearing aid: a 14-year experience. Otol Neurotol. 2006;27(5):659-666. [pmid: 16868513].
Blackmore KJ, Kernohan MD, Davison T, et al. Bone-anchored hearing aid modified with directional microphone: do patients benefit? J Laryngol Otol. 2007;121(9):822-825.
Calviti KC, Pereira LD. Sensitivity, specificity and predictive values of hearing loss to different audiometric mean values. Braz J Otorhinolaryngol. 2009;75(6):794-800. [pmid: 20209277].
Chaiklin JB. A descending LOT-Bekesy screening test for functional hearing loss. J Speech Hear Disord. 1990;55(1):67-74. [pmid: 2299841].
Chang HP, Ho CY, Chou P. The factors associated with a self-perceived hearing handicap in elderly people with hearing impairment—results from a community-based study. Ear Hear. 2009;30(5):576-583. [pmid: 19633566].
Chisolm TH, Noe CM, McArdle R, et al. Evidence for the use of hearing assistive technology by adults: the role of the FM system. Trends Amplif. 2007;11(2):73-89. [pmid: 17494874].
Collins MP, Souza PE, Liu CF, Heagerty PJ, Amtmann D, Yueh B. Hearing Aid Effectiveness After Aural Rehabilitation-Individual Versus Group (HEARING) trial: RCT design and baseline characteristics. BMC Health Serv Res. 2009;9:233. [pmid: 20003515].
Culling JF, Zhao F, Stephens D. The viability of speech-in-noise audiometric screening using domestic audio equipment. Int J Audiol. 2005;44(12):691-700. [pmid: 16450920].
Doshi J, Karagama Y, Buckley D, et al. Observational study of bone-anchored hearing aid infection rates using different post-operative dressings. J Laryngol Otol. 2006;120(10):842-844. [pmid: 16709268].
Ellison JC, Keefe DH. Audiometric predictions using stimulus-frequency otoacoustic emissions and middle ear measurements. Ear Hear. 2005;26(5):487-503. [pmid: 16230898].
Ho AT, Hildreth AJ, Lindsey L. Computer-assisted audiometry versus manual audiometry. Otol Neurotol. 2009;30(7):876-883. [pmid: 20179426].
House JW, Kutz JW Jr. Bone-anchored hearing aids: Incidence and management of postoperative complications. Otol Neurotol. 2007;28(2):213-217. [pmid: 17255890].
Johnson CE, Danhauer JL, Reith AC, et al. A systematic review of the nonacoustic benefits of bone-anchored hearing aids. Ear Hear. 2006;27(6):703-713. [pmid: 17086080].
Lesner SA. Candidacy and management of assistive listening devices: special needs of the elderly. Int J Audiol. 2003;42(Suppl 2):S68-S76. [pmid: 12918612].
Luntz M, Yehudai N, Shpak T. Hearing progress and fluctuations in bimodal-binaural hearing users (unilateral cochlear implants and contralateral hearing aid). Acta Otolaryngol. 2007;127(10):1045-1050. [pmid: 17851963].
Wazen JJ, Spitzer J, Ghossaini SN, et al. Results of the bone-anchored hearing aid in unilateral hearing loss. Laryngoscope. 2001;111(6):955-958. [pmid: 11404603].

## Wrong Outcome

Ahmad N, Etheridge C, Farrington M, et al. Prospective study of the microbiological flora of hearing aid moulds and the efficacy of current cleaning techniques. J Laryngol Otol. 2007;121(2):110-113. [pmid: 17040598].
Allen NH, Burns A, Newton V, et al. The effects of improving hearing in dementia. Age Ageing. 2003;32(2):189-193. [pmid: 12615563].
Barton GR, Bankart J, Davis AC, et al. Comparing utility scores before and after hearing-aid provision: results according to the EQ-5D, HUI3 and SF-6D. Appl Health Econ Health Policy. 2004;3(2):103-105. [pmid: 15702947].
Bentler R, Palmer C, Mueller HG. Evaluation of a second-order directional microphone hearing aid, I: speech perception outcomes. J Am Acad Audiol. 2006;17(3):179-189. [pmid: 16646278].
Blamey PJ, Fiket HJ, Steele BR. Improving speech intelligibility in background noise with an adaptive directional microphone. J Am Acad Audiol. 2006;17(7):519-530. [pmid: 16927516].
Brooks DN, Hallam RS, Mellor PA. The effects on significant others of providing a hearing aid to the hearing-impaired partner. Br J Audiol. 2001;35(3):165-171. [pmid: 11548043].
Burk MH, Humes LE, Amos NE, et al. Effect of training on word-recognition performance in noise for young normal-hearing and older hearing-impaired listeners. Ear Hear. 2006;27(3):263-278. [pmid: 16672795].
Chang WH, Tseng HC, Chao TK, et al. Measurement of hearing aid outcome in the elderly: comparison between young and old elderly. Otolaryngol Head Neck Surg. 2008;138(6):730-734. [pmid: 18503844].
Chisolm TH, Abrams HB, McArdle R. Short- and long-term outcomes of adult audiological rehabilitation. Ear Hear. 2004;25(5):464-477. [pmid: 15599193].
Cilento BW, Norton SJ, Gates GA. The effects of aging and hearing loss on distortion product otoacoustic emissions. Otolaryngol Head Neck Surg. 2003;129(4):382-389. [pmid: 14574293].
Compton-Conley CL, Neuman AC, Killion MC, et al. Performance of directional microphones for hearing aids: real-world versus simulation. J Am Acad Audiol. 2004;15(6):440-455. [pmid: 15341225].
Cord MT, Leek MR, Walden BE. Speech recognition ability in noise and its relationship to perceived hearing aid benefit. J Am Acad Audiol. 2000;11(9):475-483. [pmid: 11057731].
Danhauer JL, Celani KE, Johnson CE. Use of a hearing and balance screening survey with local primary care physicians. Am J Audiol. 2008;17(1):3-13. [pmid: 18519575].
Davies JE, John DG, Stephens SD. Intermediate hearing tests as predictors of hearing aid acceptance. Clin Otolaryngol. 1991;16(1):76-83. [pmid: 2032364].
Davis A, Stephens D, Rayment A, et al. Hearing impairments in middle age: the Acceptability, Benefit and Cost of Detection (ABCD). Br J Audiol. 1992;26(1):1-14. [pmid: 1586844].
DeStefano AL, Gates GA, Heard-Costa N, et al. Genomewide linkage analysis to presbycusis in the Framingham Heart Study. Arch Otolaryngol Head Neck Surg. 2003;129(3):285-289. [pmid: 12622536].
Dhar S, Humes LE, Calandruccio L, et al. Predictability of speech-in-noise performance from real ear measures of directional hearing aids. Ear Hear. 2004;25(2):147-158. [pmid: 15064660].
Durvasula VS, Patel H, Mahendran S, et al. Bone anchored hearing aids: a second fixture reduces auditory deprivation in Cambridge. Eur Arch Otorhinolaryngol. 2007;264(9):991-994. [pmid: 17415580].
Eekhof J, De Bock G, Schaapveld K, et al. Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. 2000;17(4):329-333. [pmid: 10934182].
Gianopoulos I, Stephens D. Opting for two hearing aids: a predictor of long-term use among adult patients fitted after screening. Int J Audiol. 2002;41(8):518-526. [pmid: 12477172].
Gopinath B, McMahon CM, Rochtchina E, Mitchell P. Dizziness and vertigo in an older population: the Blue Mountains prospective cross-sectional study. Clin Otolaryngol. 2009;34(6):552-556. [pmid: 20070765].
Haskell GB, Noffsinger D, Larson VD, et al. Subjective measures of hearing aid benefit in the NIDCD/VA clinical trial. Ear Hear. 2002;23(4):301-307. [pmid: 12195172].
Horwitz AR, Ahlstrom JB, Dubno JR. Factors affecting the benefits of high-frequency amplification. J Speech Lang Hear Res. 2008;51(3):798-813. [pmid: 18506052].
Hough DA, Matthews P, Hough JV. Bone conduction implants for amplification: comparison of results. Ear Nose Throat J. 1997;76(12):857. [pmid: 9431774].
Humes LE, Wilson DL. An examination of changes in hearing-aid performance and benefit in the elderly over a 3-year period of hearing-aid use. J Speech Lang Hear Res. 2003;46(1):137-145. [pmid: 12647894].
Hurley RM. Onset of auditory deprivation. J Am Acad Audiol. 1999;10(10):529-534. [pmid: 10613349].
Jauhiainen T. Progression of sensorineural hearing impairment in aided and unaided ears. Scand Audiol Suppl. 2001;(52):28-31. [pmid: 11318475].
Johnson CE, Danhauer JL, Koch LL, et al. Hearing and balance screening and referrals for Medicare patients: a national survey of primary care physicians. J Am Acad Audiol. 2008;19(2):171-190. [pmid: 18669130].
Jupiter T. Screening for hearing loss in the elderly using distortion product otoacoustic emissions, pure tones, and a self-assessment tool. Am J Audiol. 2009;18(2):99-107. [pmid: 19474453].
Koopman J, Davey E, Thomas N, et al. How should hearing screening tests be offered?. Int J Audiol. 2008;47(5):230-237. [pmid: 18465407].
Kramer SE, Allessie GH, Dondorp AW, et al. A home education program for older adults with hearing impairment and their significant others: a randomized trial evaluating short- and long-term effects. Int J Audiol. 2005;44(5):255-264. [pmid: 16028788].
Lapsley Miller JA, Marshall L, Heller LM. A longitudinal study of changes in evoked otoacoustic emissions and pure-tone thresholds as measured in a hearing conservation program. Int J Audiol. 2004;43(6):307-322. [pmid: 15457813].
Larson VD, Williams DW, Henderson WG, et al. A multi-center, double blind clinical trial comparing benefit from three commonly used hearing aid circuits. Ear Hear. 2002;23(4):269-276. [pmid: 12195168].
Larson VD, Williams DW, Henderson WG, et al. NIDCD/VA Hearing Aid Clinical Trial Group. Efficacy of 3 commonly used hearing aid circuits: a crossover trial. JAMA. 2000;284(14):1806-1813. [pmid: 11025833].
Lee LW, Geddes ER. Perception of microphone noise in hearing instruments. J Acoust Soc Am. 1998;104(6):3364-3367. [pmid: 9857504].
Lunner T, Sundewall-Thoren E. Interactions between cognition, compression, and listening conditions: effects on speech-in-noise performance in a two-channel hearing aid. J Am Acad Audiol. 2007;18(7):604-617. [pmid: 18236647].
Magnusson L, Karlsson M, Ringdahl A, et al. Comparison of calculated, measured and self-assessed intelligibility of speech in noise for hearing-aid users. Scand Audiol. 2001;30(3):160-171. [pmid: 11683454].
Manwaring N, Jones MM, Wang JJ, et al. Mitochondrial DNA haplogroups and age-related hearing loss. Arch Otolaryngol Head Neck Surg. 2007;133(9):929-933. [pmid: 17875861].
McMahon CM, Kifley A, Rochtchina E, et al. The contribution of family history to hearing loss in an older population. Ear Hear. 2008;29(4):578-584. [pmid: 18469720].
Meister H, Lausberg I, Kiessling J, et al. Identifying the needs of elderly, hearing-impaired persons: the importance and utility of hearing aid attributes. Eur Arch Otorhinolaryngol. 2002;259(10):531-534. [pmid: 12434187].
Moore AA, Siu A, Partridge JM, et al. A randomized trial of office-based screening for common problems in older persons. Am J Med. 1997;102(4):371-378. [pmid: 9217619].
Moore BC, Stone MA, Alcantara JI. Comparison of the electroacoustic characteristics of five hearing aids. Br J Audiol. 2001;35(5):307-325. [pmid: 11824533].
Munro KJ, Patel RK. Are clinical measurements of uncomfortable loudness levels a valid indicator of real-world auditory discomfort?. Br J Audiol. 1998;32(5):287-293. [pmid: 9845026].
Noble W, Gatehouse S. Effects of bilateral versus unilateral hearing aid fitting on abilities measured by the Speech, Spatial, and Qualities of Hearing Scale (SSQ). Int J Audiol. 2006;45(3):172-181. [pmid: 16579492].
Schow RL, Smedley TC, Longhurst TM. Self-assessment and impairment in adult/elderly hearing screening—recent data and new perspectives. Ear Hear. 1990;11(5 Suppl):17S-27S. [pmid: 2269411].
Smits C, Kapteyn TS, Houtgast T. Development and validation of an automatic speech-in-noise screening test by telephone. Int J Audiol. 2004;43(1):15-28. [pmid: 14974624].
Souza PE, Boike KT, Witherell K, et al. Prediction of speech recognition from audibility in older listeners with hearing loss: effects of age, amplification, and background noise. J Am Acad Audiol. 2007;18(1):54-65. [pmid: 17252958].
Souza PE, Yueh B, Sarubbi M, et al. Fitting hearing aids with the Articulation Index: impact on hearing aid effectiveness. J Rehabil Res Dev. 2000;37(4):473-481. [pmid: 11028703].
Takahashi G, Martinez CD, Beamer S, et al. Subjective measures of hearing aid benefit and satisfaction in the NIDCD/VA follow-up study. J Am Acad Audiol. 2007;18(4):323-349. [pmid: 17580727].
Torres-Russotto D, Landau WM, Harding GW, et al. Calibrated Finger Rub Auditory Screening Test (CALFRAST). Neurology. 2009;72(18):1595-1600. [pmid: 19414727].
Vestergaard MD. Self-report outcome in new hearing-aid users: longitudinal trends and relationships between subjective measures of benefit and satisfaction. Int J Audiol. 2006;45(7):382-392. [pmid: 16938796].
Wu HY, Chin JJ, Tong HMH. Screening for hearing impairment in a cohort of elderly patients attending a hospital geriatric medicine service. Singapore Med J. 2004;45(2):79-84. [pmid: 14985847].

## Wrong Study Design or Publication Type

Abrams HB, Hnath-Chisolm T, Guerreiro SM, et al. The effects of intervention strategy on self-perception of hearing handicap. Ear Hear. 1992;13(5):371-377. [pmid: 1487096].
Appollonio I, Carabellese C, Frattola L, et al. Effects of sensory aids on the quality of life and mortality of elderly people: a multivariate analysis. Age Ageing. 1996;25(2):89-96. [pmid: 8670534].
Appollonio I, Carabellese C, Magni E, et al. Sensory impairments and mortality in an elderly community population: a six-year follow-up study. Age Ageing. 1995;24(1):30-36. [pmid: 7762459].
Bagai A, Thavendiranathan P, Detsky A. Does this patient have hearing impairment?. JAMA. 2006;295(4):416-428. [pmid: 16434632].
Blanchet C, Pommie C, Mondain M, et al. Pure-tone threshold description of an elderly French screened population. Otol Neurotol. 2008;29(4):432-440. [pmid: 18520580].
Bratt GW, Rosenfeld MA, Williams DW. NIDCD/VA hearing aid clinical trial and follow-up: background. J Am Acad Audiol. 2007;18(4):274-281. [pmid: 17580723].
Brickley GJ, Cleaver VC, Bailey S. An evaluation of a group follow-up scheme for new NHS hearing aid users. Br J Audiol. 1996;30(5):307-312. [pmid: 8922695].
Bromwich MA, Parsa V, Lanthier N, et al. Active noise reduction audiometry: a prospective analysis of a new approach to noise management in audiometric testing. Laryngoscope. 2008;118(1):104-109. [pmid: 18043495].
Brooks DN. Some factors influencing choice of type of hearing aid in the UK: behind-the-ear or in-the-ear. Br J Audiol. 1994;28(2):91-98. [pmid: 7841893].
Brooks DN, Hallam RS. Attitudes to hearing difficulty and hearing aids and the outcome of audiological rehabilitation. Br J Audiol. 1998;32(4):217-226. [pmid: 9923983].
Browning GG, Swan IR, Chew KK. Clinical role of informal tests of hearing. J Laryngol Otol. 1989;103(1):7-11. [pmid: 2646384].
Bunnag C, Prasansuk S, Nakorn AN, et al. Ear diseases and hearing in the Thai elderly population, part I: a comparative study of the accuracy of diagnosis and treatment by general practitioners vs ENT specialists. J Med Assoc Thai. 2002;85(5):521-531. [pmid: 12188380].
Cacciatore F, Napoli C, Abete P, et al. Quality of life determinants and hearing function in an elderly population: Osservatorio Geriatrico Campano Study Group. Gerontology. 1999;45(6):323-328. [pmid: 10559650].
Cherry R, Rubinstein A. The long-term effect of early telephone intervention on hearing aid success. Scand Audiol. 1995;24(4):243-246. [pmid: 8750753].
Cook JA, Hawkins DB. Hearing loss and hearing aid treatment options. Mayo Clin Proc. 2006;81(2):234-237. [pmid: 16471079].
Cook JA, Hawkins DB. Outcome measurement for patients receiving hearing aid services. Laryngoscope. 2007;117(4):610-613. [pmid: 17415130].
Coren S, Hakstian AR. The development and cross-validation of a self-report inventory to assess pure-tone threshold hearing sensitivity. J Speech Hear Res. 1992;35(4):921-928. [pmid: 1405547].
Cox RM, Alexander GC, Gray GA. Personality, hearing problems, and amplification characteristics: contributions to self-report hearing aid outcomes. Ear Hear. 2007;28(2):141-162. [pmid: 17496667].
Davis A. Population study of the ability to benefit from amplification and the provision of a hearing aid in 55–74-year-old first-time hearing aid users. Int J Audiol. 2003;42(Suppl 2):S39-S52.
Dobie RA. The burdens of age-related and occupational noise-induced hearing loss in the United States. Ear Hear. 2008;29(4):565-577. [pmid: 18469718].
Erber NP. Use of hearing aids by older people: influence of non-auditory factors (vision, manual dexterity). Int J Audiol. 2003;42(Suppl 2):S21-S25.
Hands S. Hearing loss in over-65s: is routine questionnaire screening worthwhile?. J Laryngol Otol. 2000;114(9):661-666. [pmid: 11091826].
Henrichsen J, Noring E, Christensen B, et al. In-the-ear hearing aids: the use and benefit in the elderly hearing-impaired. Scand Audiol. 1988;17(4):209-212. [pmid: 3232021].
Hickson L. Rehabilitation approaches to promote successful unilateral and bilateral fittings and avoid inappropriate prescription. Int J Audiol. 2006;45(Suppl 1):S72-S77. [pmid: 16938778].
Hickson L, Worrall L. Beyond hearing aid fitting: improving communication for older adults. Int J Audiol Suppl. 2003;42(Suppl 2):S84-S91.
Hildesheimer M, Muchnik C. Cooperation of hearing-impaired elderly subjects for participation in a hearing screening program. Audiology. 1992;31(4):222-227. [pmid: 1444933].
Holcomb SS, Punch JL. Multimedia hearing handicap inventory: reliability and clinical utility. Am J Audiol. 2006;15(1):3-13. [pmid: 16803787].
Humes LE. Factors underlying the speech-recognition performance of elderly hearing-aid wearers. J Acoust Soc Am. 2002;112(3 Pt 1):1112-1132. [pmid: 12243159].
Humes LE. The contributions of audibility and cognitive factors to the benefit provided by amplified speech to older adults. J Am Acad Audiol. 2007;18(7):590-603. [pmid: 18236646].
Humes LE, Garner CB, Wilson DL, et al. Hearing-aid outcome measured following one month of hearing aid use by the elderly. J Speech Lang Hear Res. 2001;44(3):469-486. [pmid: 11407554].
Humes LE, Halling D, Coughlin M. Reliability and stability of various hearing-aid outcome measures in a group of elderly hearing-aid wearers. J Speech Hear Res. 1996;39(5):923-935. [pmid: 8898247].
Humes LE, Wilson DL. A comparison of single-channel linear amplification and two-channel wide-dynamic-range-compression amplification by means of an independent-group design. Am J Audiol. 2004;13(1):39-53. [pmid: 15248803].
Humes LE, Wilson DL, Barlow NN, et al. Changes in hearing-aid benefit following 1 or 2 years of hearing-aid use by older adults. J Speech Lang Hear Res. 2002;45(4):772-782. [pmid: 12199406].
Ivory PJ, Hendricks BL, Van Vliet D, Beyer CM, Abrams HB. Short-term hearing aid benefit in a large group. Trends Amplif. 2009;13(4):260-280. [pmid: 20150189].
Iwai H, Baba S, Omae M, et al. Maintenance of systemic immune functions prevents accelerated presbycusis. Brain Res. 2008;1208:8-16. [pmid: 18381209].
Jerram JC, Purdy SC. Technology, expectations, and adjustment to hearing loss: predictors of hearing aid outcome. J Am Acad Audiol. 2001;12(2):64-79. [pmid: 11261460].
Joore MA, Brunenberg DE, Chenault MN, et al. Societal effects of hearing aid fitting among the moderately hearing impaired. Int J Audiol. 2003;42(3):152-160. [pmid: 12705780].
Joore M, Brunenberg D, Zank H, et al. Development of a questionnaire to measure hearing-related health state preferences framed in an overall health perspective. Int J Technol Assess Health Care. 2002;18(3):528-539. [pmid: 12391946].
Joore MA, Potjewijd J, Timmerman AA, et al. Response shift in the measurement of quality of life in hearing impaired adults after hearing aid fitting. Qual Life Res. 2002;11(4):299-307. [pmid: 12086115].
Kaneko K, Shoji K, Kojima H, et al. Nonlinear digital hearing aid with near-instantaneous amplitude compression. Eur Arch Otorhinolaryngol. 2001;258(10):523-528. [pmid: 11829189].
Kricos PB. Audiologic management of older adults with hearing loss and compromised cognitive/psychoacoustic auditory processing capabilities. Trends Amplif. 2006;10(1):1-28. [pmid: 16528428].
Kricos PB. Hearing assistive technology considerations for older individuals with dual sensory loss. Trends Amplif. 2007;11(4):273-279. [pmid: 18080391].
Lamden KH, St Leger AS, Raveglia J. Hearing aids: value for money and health gain. J Public Health Med. 1995;17(4):445-449. [pmid: 8639344].
Laplante-Levesque A, Pichora-Fuller MK, Gagne JP. Providing an internet-based audiological counseling programme to new hearing aid users: a qualitative study. Int J Audiol. 2006;45(12):697-706. [pmid: 17132558].
Lewis MS, Valente M, Horn JE, et al. The effect of hearing aids and frequency modulation technology on results from the communication profile for the hearing impaired. J Am Acad Audiol. 2005;16(4):250-261. [pmid: 16050335].
Martin M. International technical standards: whose problem is it?. Int J Audiol. 2002;41:371-373. [pmid: 12353610].
McBride C, Mulrow CD, Tuley MR. Screening tests for hearing loss in the elderly. Clin Res. 1990;38(2):707A.
McLeod B, Upfold L, Broadbent C. An investigation of the applicability of the inventory, satisfaction with amplification in daily life, at 2 weeks post hearing aid fitting. Ear Hear. 2001;22(4):342-347. [pmid: 11527040].
McPherson B, Wong ET. Effectiveness of an affordable hearing aid with elderly persons. Disabil Rehabil. 2005;27(11):601-609. [pmid: 16019870].
Metz MJ, Nilsson MJ. The Words-In-Noise (WIN) test with multitalker babble and speech-spectrum noise maskers. J Am Acad Audiol. 2007;18(8):718. [pmid: 18326157].
Munro KJ, Lutman ME. Self-reported outcome in new hearing aid users over a 24-week post-fitting period. Int J Audiol. 2004;43(10):555-562. [pmid: 15724519].
Nabelek AK. Acceptable noise level: a clinical measure for predicting hearing aid outcome. J Am Acad Audiol. 2006;17(9):624-625. [pmid: 17039764].
Newman CW, Jacobson GP, Hug GA, et al. Practical method for quantifying hearing aid benefit in older adults. J Am Acad Audiol. 1991;2(2):70-75. [pmid: 1768876].
Noffsinger D, Haskell GB, Larson VD, et al. Quality rating test of hearing aid benefit in the NIDCD/VA clinical trial. Ear Hear. 2002;23(4):291-300. [pmid: 12195171].
Ohlemiller KK. Age-related hearing loss: the status of Schuknecht’s typology. Curr Opin Otolaryngol Head Neck Surg. 2004;12(5):439-443. [pmid: 15377958].
Palmer CV, Adams SW, Bourgeois M, et al. Reduction in caregiver-identified problem behaviors in patients with Alzheimer disease post-hearing-aid fitting. J Speech Lang Hear Res. 1999;42(2):312-328. [pmid: 10229449].
Parving A, Philip B. Use and benefit of hearing aids in the tenth decade—and beyond. Audiology. 1991;30(2):61-69. [pmid: 1877899].
Philibert B, Collet L, Vesson JF, et al. Auditory rehabilitation effects on speech lateralization in hearing-impaired listeners. Acta Otolaryngol. 2003;123(2):172-175. [pmid: 12701735].
Saunders GH, Forsline A, Fausti SA. The performance-perceptual test and its relationship to unaided reported handicap. Ear Hear. 2004;25(2):117-126. [pmid: 15064656].
Saunders GH, Jutai JW. Hearing specific and generic measures of the psychosocial impact of hearing aids. J Am Acad Audiol. 2004;15(3):238-248. [pmid: 15119464].
Schum DJ. Responses of elderly hearing aid users on the hearing aid performance inventory. J Am Acad Audiol. 1992;3(5):308-314. [pmid: 1421466].
Schum DJ. Perceived hearing aid benefit in relation to perceived needs. J Am Acad Audiol. 1999;10(1):40-45. [pmid: 9921724].
Someya S, Yamasoba T, Weindruch R, et al. Caloric restriction suppresses apoptotic cell death in the mammalian cochlea and leads to prevention of presbycusis. Neurobiol Aging. 2007;28(10):1613-1622. [pmid: 16890326].
Sood A, Taylor JS. Allergic contact dermatitis from hearing aid materials. Dermatitis. 2004;15(1):48-50. [pmid: 15573649].
Taylor KS. Self-perceived and audiometric evaluations of hearing aid benefit in the elderly. Ear Hear. 1993;14(6):390-394. [pmid: 8307242].
Tesch-Romer C. Psychological effects of hearing aid use in older adults. J Gerontol B Psychol Sci Soc Sci. 1997;52(3):127-138.
van Hooren SA, Anteunis LJ, Valentijn SA, et al. Does cognitive function in older adults with hearing impairment improve by hearing aid use?. Int J Audiol. 2005;44(5):265-271. [pmid: 16028789].
Vikram KB, Naseeruddin K. Combined tuning fork tests in hearing loss: explorative clinical study of the patterns. J Otolaryngol. 2004;33(4):227-234. [pmid: 15903203].
Ward JA, Lord SR, Williams P, et al. Hearing impairment and hearing aid use in women over 65 years of age: cross-sectional study of women in a large urban community. Med J Aust. 1993;159(6):382-384. [pmid: 8377688].
Wazen JJ, Caruso M, Tjellstrom A. Long-term results with the titanium bone-anchored hearing aid: the U.S. experience. Am J Otol. 1998;19(6):737-741. [pmid: 9831146].
Weinstein BE. Age-related hearing loss: how to screen for it, and when to intervene. Geriatrics. 1994;49(8):40-45. [pmid: 8039728].
Weinstein BE. The quantification of hearing aid benefit in the elderly: the role of self-assessment measures. Acta Otolaryngol Suppl. 1990;476:257-261. [pmid: 2087973].
Yamasoba T, Someya S, Yamada C, et al. Role of mitochondrial dysfunction and mitochondrial DNA mutations in age-related hearing loss. Hear Res. 2007;226(1-2):185-193. [pmid: 16870370].

## Diagnostic Test Accuracy Not Reported

Matthews LJ, Lee FS, Mills JH, et al. Audiometric and subjective assessment of hearing handicap. Arch Otolaryngol Head Neck Surg. 1990;116(11):1325-1330. [pmid: 2242265].
Pugh KC, Crandell CC. Hearing loss, hearing handicap, and functional health status between African American and Caucasian American seniors. J Am Acad Audiol. 2002;13(9):493-502. [pmid: 12416934].