# Literature Flow Diagram

* Abstracts were identified through the Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, Ovid MEDLINE, and other sources, including reference lists and suggestions by experts.

† Some articles are included for more than one Key Question.

Abbreviation: RCT = randomized controlled trial.

Appendix A3 is a flow chart that summarizes the search and selection of articles. There were 3,343 abstracts identified by searching MEDLINE and Cochrane databases (including the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews) and other sources (such as reference lists and suggestions by experts). Of these, 3,140 abstracts were excluded after review. The full text of the remaining 203 articles were assessed for eligibility by key question. Of the 203 articles reviewed, 177 were excluded for the following reasons: wrong population (31); wrong intervention (19); wrong outcome (52); wrong study design or publication type (73); or diagnostic test accuracy not reported (2). Of the remaining 26 articles, 1 randomized controlled trial was deemed eligible for inclusion for key question 1 (screening and outcomes). For key question 2 (accuracy of screening), 20 studies were deemed eligible for inclusion, including 4 studies of clinical tests, 8 studies of single-question screening, 9 studies of questionnaires, and 6 studies of AudioScope devices. For key question 3 (efficacy of treatment), 4 randomized controlled trials (representing 5 articles) were deemed eligible for inclusion. For key question 4 (adverse effects of screening), no studies were deemed eligible for inclusion. For key question 5 (adverse effects of treatment), no studies were deemed eligible for inclusion. Some articles were included for more than one key question.