# Inclusion and Exclusion Criteria

## All Key Questions

Ages/population:

[underlined: Include]: Adults ages 50 years or older without diagnosed hearing loss; comorbid conditions of depression and cognitive dysfunction. Also include nursing home populations

[underlined: Exclude]: Adults younger than age 50 years; previously diagnosed hearing loss; current hearing aid users (within the last 6 months)

Disease:

[underlined: Include]: Sensorineural hearing loss, presbycusis

[underlined: Exclude]: Conductive hearing loss, congenital hearing loss, sudden hearing loss, hearing loss due to recent noise or occupational exposure

Languages:

[underlined: Include]: Full text published in English

Settings:

[underlined: Include]: Studies performed in settings generalizable to primary care

[underlined: Exclude]: Countries with populations not similar to the United States

## Key Question 1 (Screening and Outcomes)

Interventions/diagnostic tests:

[underlined: Include]: Screening tests used, available, or feasible in primary care settings, including whispered voice, finger rub, watch tick, single question regarding perceived hearing loss, hearing loss questionnaire, and portable audiometer

[underlined: Exclude]: Screening tests not used or available in primary care settings (e.g., audiometric testing), Rinne and Weber tests (used to distinguish sensorineural from conductive hearing loss, not to screen persons for hearing loss)

Outcomes:

[underlined: Include]: Hearing-related quality of life and function (e.g., emotional and social function, communication, and cognitive function)

[underlined: Exclude]: Outcomes related to hearing aid performance and efficacy (e.g., speech intelligibility and quality of the listening experience)

Study designs:

[underlined: Include]: Randomized controlled trials and controlled observational studies

## Key Question 2 (Accuracy of Screening Methods and Testing)

Interventions/diagnostic tests:

[underlined: Include]: See Key Question 1

[underlined: Exclude]: Audiometric testing, except as reference standard

Outcomes:

[underlined: Include]: Sensitivity, specificity, positive and negative predictive values, positive and negative likelihood ratios, diagnostic odds ratios

Study designs:

[underlined: Include]: Cross-sectional or cohort studies of primary care, community-based, or specialty settings

[underlined: Exclude]: Case control studies (e.g., 50 selected patients with hearing loss vs. 50 selected patients without hearing loss)

## Key Question 3 (Effectiveness of Amplification Treatment)

Interventions/treatments:

[underlined: Include]: Amplification with hearing aids or assistive listening devices

[underlined: Exclude]: Nutritional pharmaceuticals, hearing rehabilitation

Outcomes:

[underlined: Include]: Health-related quality of life (e.g., emotional and social function, communication, and cognitive function)

[underlined: Exclude]: Outcomes related to hearing aid performance and efficacy (e.g., speech intelligibility and quality of the listening experience)

Study designs:

[underlined: Include]: Randomized controlled trials and controlled observational studies

## Key Question 4 (Harms of Screening) and 5 (Harms of Treatment)

Interventions/diagnostic tests:

See Key Question 1

Outcomes:

[underlined: Include]: False-positives, labeling, anxiety, any other significant harms

Study designs:

[underlined: Include]: Randomized controlled trials and controlled observational studies