# Literature Search Strategies

## Overall

Database: Cochrane Database of Systematic Reviews

1. (hearing and adult$).mp. [mp=title, short title, abstract, full text, keywords, caption text]
2. 1 not (neonat$ or pregnan$ or infant or child or pediatri$).mp. [mp=title, short title, abstract, full text, keywords, caption text]
3. limit 2 to full systematic reviews

## Key Question 1 Screening and Outcomes

Databases: Ovid MEDLINE; Cochrane Central Register of Controlled Trials

1. Hearing Disorders/
2. Hearing Loss/
3. Hearing Loss, Mixed Conductive-Sensorineural/
4. Hearing Loss, Sensorineural/
5. PRESBYCUSIS/
6. or/1-5
7. mass screening/
8. screen$.mp.
9. 7 or 8
10. 6 and 9
11. (clinical trial or controlled clinical trial or multicenter study or randomized controlled trial).pt.
12. Comparative Study/
13. Follow-Up Studies/
14. (prospectiv$ or retrospectiv$ or baseline or cohort or consecutive$ or compar$).tw.
15. 10 and (or/11-14)
16. limit 15 to ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)")

## Key Question 2 Accuracy of Screening

Databases: Ovid MEDLINE; Cochrane Central Register of Controlled Trials

1. Hearing Disorders/
2. Hearing Loss/
3. Hearing Loss, Mixed Conductive-Sensorineural/
4. Hearing Loss, Sensorineural/
5. PRESBYCUSIS/
6. presbyacusis.mp.
7. or/1-6
8. Mass Screening/
9. screen$.ti,ab,hw.
10. 8 or 9
11. 7 and 10
12. Hearing Tests/
13. Audiometry/ or Audiometry, Pure-Tone/
14. 12 or 13
15. "Sensitivity and Specificity"/
16. "Predictive Value of Tests"/
17. ROC Curve/
18. accuracy.ti,ab.
19. specificit$.ti,ab.
20. predictive value.ti,ab.
21. or/15-20
22. (11 or 14) and 21
23. audioscop$.ti,ab.
24. hhie$.mp. or hearing handicap inventory.ti,ab. [mp=title, original title, abstract, name of substance word, subject heading word]
25. 23 or 24
26. 22 or 25
27. limit 26 to humans
28. limit 27 to ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)")

## Key Question 3 Overall Treatment

Databases: Ovid MEDLINE; Cochrane Central Register of Controlled Trials

1. Hearing Aids/
2. hearing aid$.ti,ab.
3. 1 or 2
4. treatment outcome/
5. Treatment Failure/
6. health outcome$.ti,ab.
7. "Outcome Assessment (Health Care)"/
8. functional status.ti,ab.
9. Health Status/
10. Health Status Indicators/
11. health status.ti,ab.
12. "Quality of Life"/
13. quality of life.ti,ab.
14. qol.ti,ab.
15. depression/
16. Depressive Disorder/
17. Mood Disorders/
18. depression.ti,ab.
19. Social Isolation/
20. Loneliness/
21. Social Alienation/
22. social$ isolat$.ti,ab.
23. Communication/
24. (improv$ adj4 communicat$).ti,ab.
25. Cognition/
26. cognitive function$.ti,ab.
27. or/4-26
28. 3 and 27
29. limit 28 to ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)")

## Key Question 4 Adverse Effects of Screening

Database: Ovid MEDLINE

1. Hearing Disorders/
2. Hearing Loss/
3. Hearing Loss, Mixed Conductive-Sensorineural/
4. Hearing Loss, Sensorineural/
5. Presbycusis/
6. presbyacusis.mp.
7. age related hearing loss.mp.
8. Hearing Loss, Noise-Induced/
9. or/1-8
10. Mass Screening/
11. screen$.ti,ab.
12. 10 or 11
13. 9 and 12
14. ((advers$ adj3 effect$) or harm$ or contraindicat$).mp.
15. ae.fs.
16. exp Diagnostic Errors/
17. (overtest$ or overdiagnos$ or over-test$ or over-diagnos$).mp.
18. (false$ adj2 (result$ or positiv$ or negativ$)).mp.
19. (observer$ adj3 bias$).mp.
20. (diagnos$ adj3 (error$ or mistak$ or incorrect$)).mp.
21. or/14-20
22. 13 and 21
23. limit 22 to ("middle aged (45 plus years)" or "all aged (65 and over)" or "aged (80 and over)")

## Key Question 5 Adverse Effects of Treatment

Database: Ovid MEDLINE

1. Hearing Aids/ or hearing aid$.mp.
2. Cochlear Implants/
3. 1 not 2
4. Hearing Loss/th [Therapy]
5. 3 or 4
6. adverse effect$.mp.
7. (ae or co).fs.
8. (safety or harm$).mp.
9. or/6-8
10. 5 and 9
11. limit 10 to ("middle age (45 to 64 years)" or "all aged (65 and over)")

## Keyword Searches

### Tuning Fork

Databases: Cochrane Central Register of Controlled Trials; Cochrane Database of Systematic Reviews

1. (whisper$ adj5 (test$ or screen$ or measur$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. (tuning adj3 fork$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]

### Tuning Fork

Database: Ovid MEDLINE

1. (whisper$ adj5 (test$ or screen$ or measur$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
2. (tuning adj3 fork$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3. exp Hearing/
4. exp Hearing Disorders/
5. exp Hearing Tests/
6. or/3-5
7. 2 and 6
8. 1 and 7

### Whisper Test

Databases: Cochrane Central Register of Controlled Trials; Cochrane Database of Systematic Reviews

1. (whisper$ adj5 (test$ or screen$ or measur$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. (tuning adj3 fork$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]

### Whisper Test

Database: Ovid MEDLINE

1. (whisper$ adj5 (test$ or screen$ or measur$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
2. (tuning adj3 fork$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3. exp Hearing/
4. exp Hearing Disorders/
5. exp Hearing Tests/
6. or/3-5
7. 2 and 6
8. 1 and 7