# References

1 Helfand M, Pyle Krages K. (2003). Counseling to Prevent Skin Cancer: A Summary of the Evidence, AHRQ Pub No 03-521B.
2 US Preventive Services Task Force. (2008). US Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF.
3 Wolff T, Tal E, Miller T. (2009). Screening for skin cancer: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med.
4 American Cancer Society. (2008). Skin Cancer Facts.
5 National Cancer Institute. (2008). Table XVI-2: melanoma of the skin (invasive) age-adjusted SEER incidence rates by year, race, and sex. Ries LA, Melbert D, Krapcho M, et al., editors. SEER Cancer Statistics Review 1975–2005.
6 Jemal A, Siegel R, Ward E, et al. (2008). Cancer statistics, 2008. CA Cancer J Clin.
7 Berwick M, Wiggins C. (2006). The current epidemiology of cutaneous malignant melanoma. Front Biosci.
8 Linos E, Swetter SM, Cockburn MG, Colditz GA, Clarke CA. (2009). Increasing burden of melanoma in the United States. J Invest Dermatol.
9 Purdue MP, Freeman LE, Anderson WF, Tucker MA. (2008). Recent trends in incidence of cutaneous melanoma among US Caucasian young adults. J Invest Dermatol.
10 National Cancer Institute. (2010). SEER Stat Fact Sheet: Melanoma of the Skin.
11 Helfand M, Gorman AK, Mahon S, Chan BK, Swanson N. (2001). Actinic Keratoses.
12 Housman TS, Feldman SR, Williford PM, et al. (2003). Skin cancer is among the most costly of all cancers to treat for the Medicare population. J Am Acad Dermatol.
13 Markovic SN, Erickson LA, Rao RD, et al. (2007). Malignant melanoma in the 21st century, part 1: epidemiology, risk factors, screening, prevention, and diagnosis. Mayo Clin Proc.
14 Titus-Ernstoff L, Perry AE, Spencer SK, Gibson JJ, Cole BF, Ernstoff MS. (2005). Pigmentary characteristics and moles in relation to melanoma risk. Int J Cancer.
15 Gandini S, Sera F, Cattaruzza MS, et al. (2005). Meta-analysis of risk factors for cutaneous melanoma, III: family history, actinic damage and phenotypic factors. Eur J Cancer.
16 International Agency for Research on Cancer. (1992). Solar and Ultraviolet Radiation.
17 Gandini S, Sera F, Cattaruzza MS, et al. (2005). Meta-analysis of risk factors for cutaneous melanoma, II: sun exposure. Eur J Cancer.
18 Dennis LK, VanBeek MJ, Beane Freeman LE, Smith BJ, Dawson DV, Coughlin JA. (2008). Sunburns and risk for cutaneous melanoma: does age matter? A comprehensive meta-analysis. Ann Epidemiol.
19 Marks R, Rennie G, Selwood TS. (1988). Malignant transformation of solar keratoses to squamous cell carcinoma. Lancet.
20 Mittelbronn MA, Mullins DL, Ramos-Caro FA, Flowers FP. (1998). Frequency of pre-existing actinic keratosis in cutaneous squamous cell carcinoma. Int J Dermatol.
21 Dinehart SM, Nelson-Adesokan P, Cockerell C, Russell S, Brown R. (1997). Metastatic cutaneous squamous cell carcinoma derived from actinic keratosis. Cancer.
22 Gandini S, Sera F, Cattaruzza MS, et al. (2005). Meta-analysis of risk factors for cutaneous melanoma, I: common and atypical naevi. Eur J Cancer.
23 Bauer J, Garbe C. (2003). Acquired melanocytic nevi as risk factor for melanoma development: a comprehensive review of epidemiological data. Pigment Cell Res.
24 Saraiya M, Glanz K, Briss PA, et al. (2004). Interventions to prevent skin cancer by reducing exposure to ultraviolet radiation: a systematic review. Am J Prev Med.
25 Balk SJ, O’Connor KG, Saraiya M. (2004). Counseling parents and children on sun protection: a national survey of pediatricians. Pediatrics.
26 Gritz ER, Tripp MK, de Moor CA, Eicher SA, Mueller NH, Spedale JH. (2003). Skin cancer prevention counseling and clinical practices of pediatricians. Pediatr Dermatol.
27 Hornung RL, Hansen LA, Sharp LK, Poorsattar SP, Lipsky MS. (2007). Skin cancer prevention in the primary care setting: assessment using a standardized patient. Pediatr Dermatol.
28 Geller AC, Colditz G, Oliveria S, et al. (2002). Use of sunscreen, sunburning rates, and tanning bed use among more than 10,000 US children and adolescents. Pediatrics.
29 Coups EJ, Manne SL, Heckman CJ. (2008). Multiple skin cancer risk behaviors in the U.S. population. Am J Prev Med.
30 (2006). The association of use of sunbeds with cutaneous malignant melanoma and other skin cancers: a systematic review. Int J Cancer.
31 Dennis LK, Beane Freeman LE, VanBeek MJ. (2003). Sunscreen use and the risk for melanoma: a quantitative review. Ann Intern Med.
32 Elwood JM, Jopson J. (1997). Melanoma and sun exposure: an overview of published studies. Int J Cancer.
33 English DR, Armstrong BK, Kricker A, Winter MG, Heenan PJ, Randell PL. (1998). Demographic characteristics, pigmentary and cutaneous risk factors for squamous cell carcinoma of the skin: a case-control study. Int J Cancer.
34 Gallagher RP, Spinelli JJ, Lee TK. (2005). Tanning beds, sunlamps, and risk for cutaneous malignant melanoma. Cancer Epidemiol Biomarkers Prev.
35 Gorham ED, Mohr SB, Garland CF, Chaplin G, Garland FC. (2007). Do sunscreens increase risk for melanoma in populations residing at higher latitudes?. Ann Epidemiol.
36 Kricker A, Armstrong BK, English DR, Heenan PJ. (1995). A dose-response curve for sun exposure and basal cell carcinoma. Int J Cancer.
37 Nelemans PJ, Rampen FH, Ruiter DJ, Verbeek AL. (1995). An addition to the controversy on sunlight exposure and melanoma risk: a meta-analytical approach. J Clin Epidemiol.
38 Oliveria SA, Saraiya M, Geller AC, Heneghan MK, Jorgensen C. (2006). Sun exposure and risk for melanoma. Arch Dis Child.
39 Rosso S, Zanetti R, Pippione M, Sancho-Garnier H. (1998). Parallel risk assessment of melanoma and basal cell carcinoma: skin characteristics and sun exposure. Melanoma Res.
40 Westerdahl J, Olsson H, Masback A, et al. (1994). Use of sunbeds or sunlamps and malignant melanoma in southern Sweden. Am J Epidemiol.
41 Westerdahl J, Olsson H, Masback A, Ingvar C, Jonsson N. (1995). Is the use of sunscreens a risk factor for malignant melanoma?. Melanoma Res.
42 Westerdahl J, Ingvar C, Masback A, Jonsson N, Olsson H. (2000). Risk for cutaneous malignant melanoma in relation to use of sunbeds: further evidence for UV-A carcinogenicity. Br J Cancer.
43 Bastuji-Garin S, Diepgen TL. (2002). Cutaneous malignant melanoma, sun exposure, and sunscreen use: epidemiological evidence. Br J Dermatol.
44 Koepsell T, Weiss N. (2003). Epidemiologic Methods: Studying the Occurence of Illness.
45 Crane LA, Deas A, Mokrohisky ST, et al. (2006). A randomized intervention study of sun protection promotion in well-child care. Prev Med.
46 Glazebrook C, Garrud P, Avery A, Coupland C, Williams H. (2006). Impact of a multimedia intervention “Skinsafe” on patients’ knowledge and protective behaviors. Prev Med.
47 Dietrich AJ, Olson AL, Sox CH, et al. (1998). A community-based randomized trial encouraging sun protection for children. Pediatrics.
48 Olson AL, Gaffney C, Starr P, Gibson JJ, Cole BF, Dietrich AJ. (2007). SunSafe in the middle school years: a community-wide intervention to change early-adolescent sun protection. Pediatrics.
49 Hillhouse J, Turrisi R, Stapleton J, Robinson J. (2008). A randomized controlled trial of an appearance-focused intervention to prevent skin cancer. Cancer.
50 Geller AC, Emmons KM, Brooks DR, et al. (2006). A randomized trial to improve early detection and prevention practices among siblings of melanoma patients. Cancer.
51 Prochaska JO, Velicer WF, Redding C, et al. (2005). Stage-based expert systems to guide a population of primary care patients to quit smoking, eat healthier, prevent skin cancer, and receive regular mammograms. Prev Med.
52 Prochaska JO, Velicer WF, Rossi JS, et al. (2004). Multiple risk expert systems interventions: impact of simultaneous stage-matched expert system interventions for smoking, high-fat diet, and sun exposure in a population of parents. Health Psychol.
53 Mahler HI, Kulik JA, Gerrard M, Gibbons FX. (2007). Long-term effects of appearance-based interventions on sun protection behaviors. Health Psychol.
54 Norman GJ, Adams MA, Calfas KJ, et al. (2007). A randomized trial of a multicomponent intervention for adolescent sun protection behaviors. Arch Pediatr Adolesc Med.
55 Patrick K, Calfas KJ, Norman GJ, et al. (2006). Randomized controlled trial of a primary care and home-based intervention for physical activity and nutrition behaviors: PACE+ for adolescents. Arch Pediatr Adolesc Med.
56 Rosenberg DE, Norman GJ, Sallis JF, Calfas KJ, Patrick K. (2007). Covariation of adolescent physical activity and dietary behaviors over 12 months. J Adolesc Health.
57 Green A, Williams G, Neale R, et al. (1999). Daily sunscreen application and betacarotene supplementation in prevention of basal-cell and squamous-cell carcinomas of the skin: a randomised controlled trial. Lancet.
58 Green A, Battistutta D, Hart V, et al. (1994). The Nambour Skin Cancer and Actinic Eye Disease Prevention Trial: design and baseline characteristics of participants. Control Clin Trials.
59 Pandeya N, Purdie DM, Green A, Williams G. (2005). Repeated occurrence of basal cell carcinoma of the skin and multifailure survival analysis: follow-up data from the Nambour Skin Cancer Prevention Trial. Am J Epidemiol.
60 van der Pols JC, Williams GM, Pandeya N, Logan V, Green AC. (2006). Prolonged prevention of squamous cell carcinoma of the skin by regular sunscreen use. Cancer Epidemiol Biomarkers Prev.
61 Neale RE, Davis M, Pandeya N, Whiteman DC, Green AC. (2007). Basal cell carcinoma on the trunk is associated with excessive sun exposure. J Am Acad Dermatol.
62 Kricker A, Armstrong BK, English DR, Heenan PJ. (1991). Pigmentary and cutaneous risk factors for non-melanocytic skin cancer—a case-control study. Int J Cancer.
63 English DR, Armstrong BK, Kricker A, Winter MG, Heenan PJ, Randell PL. (1998). Case-control study of sun exposure and squamous cell carcinoma of the skin. Int J Cancer.
64 Rosso S, Joris F, Zanetti R. (1999). Risk for basal and squamous cell carcinomas of the skin in Sion, Switzerland: a case-control study. Tumori.
65 Green A, Battistutta D, Hart V, Leslie D, Weedon D. (1996). Skin cancer in a subtropical Australian population: incidence and lack of association with occupation. The Nambour Study Group. Am J Epidemiol.
66 Gallagher RP, Hill GB, Bajdik CD, et al. (1995). Sunlight exposure, pigmentation factors, and risk for nonmelanocytic skin cancer, II: squamous cell carcinoma. Arch Dermatol.
67 Grodstein F, Speizer FE, Hunter DJ. (1995). A prospective study of incident squamous cell carcinoma of the skin in the Nurses’ Health Study. J Natl Cancer Inst.
68 Hunter DJ, Colditz GA, Stampfer MJ, Rosner B, Willett WC, Speizer FE. (1990). Risk factors for basal cell carcinoma in a prospective cohort of women. Ann Epidemiol.
69 van Dam RM, Huang Z, Rimm EB, et al. (1999). Risk factors for basal cell carcinoma of the skin in men: results from the health professionals follow-up study. Am J Epidemiol.
70 Gallagher RP, Hill GB, Bajdik CD, et al. (1995). Sunlight exposure, pigmentary factors, and risk for nonmelanocytic skin cancer, I: basal cell carcinoma. Arch Dermatol.
71 Han J, Colditz GA, Hunter DJ. (2006). Risk factors for skin cancers: a nested case-control study within the Nurses’ Health Study. Int J Epidemiol.
72 White E, Kirkpatrick CS, Lee JA. (1994). Case-control study of malignant melanoma in Washington state, I: constitutional factors and sun exposure. Am J Epidemiol.
73 Berwick M, Begg CB, Fine JA, Roush GC, Barnhill RL. (1996). Screening for cutaneous melanoma by skin self-examination. J Natl Cancer Inst.
74 Shors AR, Solomon C, McTiernan A, White E. (2001). Melanoma risk in relation to height, weight, and exercise (United States). Cancer Causes Control.
75 Gallagher RP, Elwood JM, Hill GB. (1986). Risk factors for cutaneous malignant melanoma: the Western Canada Melanoma Study. Recent Results Cancer Res.
76 Tabenkin H, Tamir A, Sperber AD, Shapira M, Shvartzman P. (1999). A case-control study of malignant melanoma in Israeli kibbutzim. Isr Med Assoc J.
77 Green AC, O’Rourke MG. (1985). Cutaneous malignant melanoma in association with other skin cancers. J Natl Cancer Inst.
78 Garbe C, Kruger S, Stadler R, Guggenmoos-Holzmann I, Orfanos CE. (1989). Markers and relative risk in a German population for developing malignant melanoma. Int J Dermatol.
79 Fargnoli MC, Piccolo D, Altobelli E, Formicone F, Chimenti S, Peris K. (2004). Constitutional and environmental risk factors for cutaneous melanoma in an Italian population: a case-control study. Melanoma Res.
80 Holly EA, Aston DA, Cress RD, Ahn DK, Kristiansen JJ. (1995). Cutaneous melanoma in women, I: exposure to sunlight, ability to tan, and other risk factors related to ultraviolet light. Am J Epidemiol.
81 Le Marchand L, Saltzman BS, Hankin JH, et al. (2006). Sun exposure, diet, and melanoma in Hawaii Caucasians. Am J Epidemiol.
82 Veierod MB, Weiderpass E, Thorn M, et al. (2003). A prospective study of pigmentation, sun exposure, and risk for cutaneous malignant melanoma in women. J Natl Cancer Inst.
83 Osterlind A, Tucker MA, Stone BJ, Jensen OM. (1988). The Danish case-control study of cutaneous malignant melanoma, II: importance of UV-light exposure. Int J Cancer.
84 Zanetti R, Franceschi S, Rosso S, Colonna S, Bidoli E. (1992). Cutaneous melanoma and sunburns in childhood in a southern European population. Eur J Cancer.
85 Westerdahl J, Ingvar C, Masback A, Olsson H. Sunscreen use and malignant melanoma. Int J Cancer.
86 Westerdahl J, Olsson H, Ingvar C. (1994). At what age do sunburn episodes play a crucial role for the development of malignant melanoma?. Eur J Cancer.
87 Weinstock MA, Colditz GA, Willett WC, et al. (1991). Melanoma and the sun: the effect of swimsuits and a “healthy” tan on the risk for nonfamilial malignant melanoma in women. Am J Epidemiol.
88 Karagas MR, Stannard VA, Mott LA, Slattery MJ, Spencer SK, Weinstock MA. (2002). Use of tanning devices and risk for basal cell and squamous cell skin cancers. J Natl Cancer Inst.
89 Chen YT, Dubrow R, Zheng T, Barnhill RL, Fine J, Berwick M. (1998). Sunlamp use and the risk for cutaneous malignant melanoma: a population-based case-control study in Connecticut, USA. Int J Epidemiol.
90 Walter SD, King WD, Marrett LD. (1999). Association of cutaneous malignant melanoma with intermittent exposure to ultraviolet radiation: results of a case-control study in Ontario, Canada. Int J Epidemiol.
91 Bataille V, Boniol M, De Vries E, et al. (2005). A multicentre epidemiological study on sunbed use and cutaneous melanoma in Europe. Eur J Cancer.
92 Clough-Gorr KM, Titus-Ernstoff L, Perry AE, Spencer SK, Ernstoff MS. (2008). Exposure to sunlamps, tanning beds, and melanoma risk. Cancer Causes Control.
93 Cho E, Rosner BA, Feskanich D, Colditz GA. (2005). Risk factors and individual probabilities of melanoma for whites. J Clin Oncol.
94 Milne E, Simpson JA, Johnston R, Giles CB, English DR. (2007). Time spent outdoors at midday and children’s body mass index. Am J Public Health.
95 Autier P, Dore JF, Negrier S, et al. (1999). Sunscreen use and duration of sun exposure: a double-blind, randomized trial. J Natl Cancer Inst.
96 Autier P, Dore JF, Reis AC, et al. (2000). Sunscreen use and intentional exposure to ultraviolet A and B radiation: a double blind randomized trial using personal dosimeters. Br J Cancer.
97 Dupuy A, Dunant A, Grob JJ. (2005). Randomized controlled trial testing the impact of high-protection sunscreens on sun-exposure behavior. Arch Dermatol.
98 Marks R, Foley PA, Jolley D, Knight KR, Harrison J, Thompson SC. (1995). The effect of regular sunscreen use on vitamin D levels in an Australian population: results of a randomized controlled trial. Arch Dermatol.
99 Brot C, Vestergaard P, Kolthoff N, Gram J, Hermann AP, Sorensen OH. (2001). Vitamin D status and its adequacy in healthy Danish perimenopausal women: relationships to dietary intake, sun exposure and serum parathyroid hormone. Br J Nutr.
100 John EM, Schwartz GG, Dreon DM, Koo J. (1999). Vitamin D and breast cancer risk: the NHANES I epidemiologic follow-up study, 1971–1975 to 1992. National Health and Nutrition Examination Survey. Cancer Epidemiol Biomarkers Prev.
101 Kampman E, Slattery ML, Caan B, Potter JD. (2000). Calcium, vitamin D, sunshine exposure, dairy products and colon cancer risk (United States). Cancer Causes Control.
102 Hughes AM, Armstrong BK, Vajdic CM, et al. (2004). Pigmentary characteristics, sun sensitivity and non-Hodgkin lymphoma. Int J Cancer.
103 Hughes AM, Armstrong BK, Vajdic CM, et al. (2004). Sun exposure may protect against non-Hodgkin lymphoma: a case-control study. Int J Cancer.
104 Smedby KE, Hjalgrim H, Melbye M, et al. (2005). Ultraviolet radiation exposure and risk for malignant lymphomas. J Natl Cancer Inst.
105 John EM, Schwartz GG, Koo J, Van Den BD, Ingles SA. (2005). Sun exposure, vitamin D receptor gene polymorphisms, and risk for advanced prostate cancer. Cancer Res.
106 Hartge P, Lim U, Freedman DM, et al. (2006). Ultraviolet radiation, dietary vitamin D, and risk for non-Hodgkin lymphoma (United States). Cancer Causes Control.
107 John EM, Schwartz GG, Koo J, Wang W, Ingles SA. (2007). Sun exposure, vitamin D receptor gene polymorphisms, and breast cancer risk in a multiethnic population. Am J Epidemiol.
108 Green A, Williams G, Neale R, Battistutta D. (1999). Betacarotene and sunscreen use. Lancet.
109 Gallagher RP, Rivers JK, Lee TK, Bajdik CD, McLean DI, Coldman AJ. (2000). Broad-spectrum sunscreen use and the development of new nevi in white children: a randomized controlled trial. JAMA.
110 Bauer J, Büttner P, Wiecker TS, Luther H, Garbe C. (2005). Interventional study in 1,232 young German children to prevent the development of melanocytic nevi failed to change sun exposure and sun protective behavior. Int J Cancer.
111 Turrisi R, Stapleton J, Mallett K, Hillhouse J. (2006). Methods in skin cancer prevention: using a question-driven approach to guide the choice of assessment approaches.[comment]. Arch Dermatol.
112 International Agency for Research on Cancer. (2008). Vitamin D and Cancer.
113 Task Force on Community Preventive Services. (2004). Recommendations to prevent skin cancer by reducing exposure to ultraviolet radiation. Am J Prev Med.
114 Saraiya M, Glanz K, Briss P, et al. (2003). Preventing skin cancer: findings of the Task Force on Community Preventive Services on reducing exposure to ultraviolet light. MMWR Recomm Rep.
115 Whiteman DC, Stickley M, Watt P, Hughes MC, Davis MB, Green AC. (2006). Anatomic site, sun exposure, and risk for cutaneous melanoma. J Clin Oncol.
116 Kricker A, Armstrong BK, English DR, Heenan PJ. (1995). Does intermittent sun exposure cause basal cell carcinoma? A case-control study in Western Australia. Int J Cancer.
117 Glanz K, Yaroch AL, Dancel M, et al. (2008). Measures of sun exposure and sun protection practices for behavioral and epidemiologic research. Arch Dermatol.
118 Lazovich D, Stryker JE, Mayer JA, et al. (2008). Measuring nonsolar tanning behavior: indoor and sunless tanning. Arch Dermatol.
119 Saraiya M, Hall HI, Thompson T, et al. (2004). Skin cancer screening among US adults from 1992, 1998, and 2000 National Health Interview Surveys. Prev Med.
120 Huncharek M, Kupelnick B. (2002). Use of topical sunscreens and the risk for malignant melanoma: a meta-analysis of 9067 patients from 11 case-control studies. Am J Public Health.
121 Gefeller O, Pfahlberg A. (2002). Sunscreen use and melanoma: a case of evidence-based prevention?. Photodermatol Photoimmunol Photomed.
122 Grant WB. (2007). A meta-analysis of second cancers after a diagnosis of nonmelanoma skin cancer: additional evidence that solar ultraviolet-B irradiance reduces the risk for internal cancers. J Steroid Biochem Mol Biol.
123 Autier P, Boniol M, Dore JF. (2007). Sunscreen use and increased duration of intentional sun exposure: still a burning issue. Int J Cancer.
124 De Haes P, Garmyn M, Verstuyf A, et al. (2005). 1,25-dihydroxyvitamin D3 and analogues protect primary human keratinocytes against UVB-induced DNA damage. J Photochem Photobiol B.
125 Dietrich AJ, Olson AL, Sox CH, Tosteson TD, Grant-Petersson J. (2000). Persistent increase in children’s sun protection in a randomized controlled community trial. Prev Med.
126 Grant-Petersson J, Dietrich AJ, Sox CH, Winchell CW, Stevens MM. (1999). Promoting sun protection in elementary schools and child care settings: the SunSafe Project. J Sch Health.
127 Vlajinac HD, Adanja BJ, Lazar ZF, et al. (2000). Risk factors for basal cell carcinoma. Acta Oncol.
128 Bajdik CD, Gallagher RP, Astrakianakis G, Hill GB, Fincham S, McLean DI. (1996). Non-solar ultraviolet radiation and the risk for basal and squamous cell skin cancer. Br J Cancer.
129 Osterlind A, Tucker MA, Hou-Jensen K, Stone BJ, Engholm G, Jensen OM. (1988). The Danish case-control study of cutaneous malignant melanoma, I: importance of host factors. Int J Cancer.
130 Lea CS, Scotto JA, Buffler PA, Fine J, Barnhill RL, Berwick M. (2007). Ambient UVB and melanoma risk in the United States: a case-control analysis. Ann Epidemiol.
131 Chen YT, Dubrow R, Holford TR, et al. (1996). Malignant melanoma risk factors by anatomic site: a case-control study and polychotomous logistic regression analysis. Int J Cancer.
132 Walter SD, Marrett LD, From L, Hertzman C, Shannon HS, Roy P. (1990). The association of cutaneous malignant melanoma with the use of sunbeds and sunlamps. Am J Epidemiol.
133 Green A, Bain C, McLennan R, Siskind V. (1986). Gallagher RP, editor. Risk factors for cutaneous melanoma in Queensland.
134 Solomon CC, White E, Kristal AR, Vaughan T. (2004). Melanoma and lifetime UV radiation. Cancer Causes Control.
135 Elwood JM, Gallagher RP, Hill GB, Pearson JC. (1985). Cutaneous melanoma in relation to intermittent and constant sun exposure—the Western Canada Melanoma Study. Int J Cancer.
136 Elwood JM, Gallagher RP, Hill GB, Spinelli JJ, Pearson JC, Threlfall W. (1984). Pigmentation and skin reaction to sun as risk factors for cutaneous melanoma: Western Canada Melanoma Study. Br Med J.
137 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med.
138 National Institute for Health and Clinical Excellence. (2006). The Guidelines Manual.
139 Wells GA, Shea B, O’Connell D, Peterson J, Welch V, Losos M, Tugwell P. (2008). The Newcastle-Ottawa Scale (NOS) for Assessing the Quality of Non randomised Studies in Meta-Analyses.
140 Green A, Siskind V, Bain C, Alexander J. (1985). Sunburn and malignant melanoma. Br J Cancer.
141 Green A. (1984). Sun exposure and the risk for melanoma. Australas J Dermatol.
142 Rosso S, Sera F, Segnan N, Zanetti R. (2008). Sun exposure prior to diagnosis is associated with improved survival in melanoma patients: results from a long-term follow-up study of Italian patients. Eur J Cancer.