# 3 Results

## Key Question 1 Is There Direct Evidence That Counseling Patients in Sun-Protective Behaviors Reduces Intermediate Outcomes or Skin Cancer?

We found no trials directly examining whether behavioral counseling interventions can reduce skin cancer or intermediate outcomes (e.g., sunburns, nevi, and actinic keratoses). One trial, by Crane and colleagues, included both self-reported behavioral outcomes and number of nevi on skin examination as outcome measures. As only 38 percent of participants were examined, this study was excluded for poor quality for this KQ.45 Another trial, by Glazebrook and colleagues, included self-reported sunburn in the composite sun-protective behavior score, but was not reported separately.46 Both these trials are included in KQ 2.

## Key Question 2 Do Primary Care Relevant Counseling Interventions Change Sun-Protective Behaviors?

We found eight unique trials examining primary care relevant counseling interventions to increase sun-protective behaviors (Table 2). Given the limited number of trials, especially in adolescents and children, we discuss two additional trials that were multimodal community-based interventions to prevent skin cancer and included primary care counseling as one component (Table 2).47,48 One of these two trials was included in the previous review. 47 Only one trial explicitly targeted decreased use or avoidance of indoor tanning.49

Table 2 Effectiveness of Primary Care Feasible Counseling to Increase Sun-Protective Behaviors

Trial, Design, Quality | Setting, Population, Characteristics | Intervention | Efficacy
Adults
Glazebrook 2006^46^ Cluster RCT by practice Fair | PC practices in UK N: 589 Age: mean 38 yrs Male: 20% Risk: 100% with high risk characteristic, not specified | IG: “Skinsafe program”: single 10- to 15-min session using a self- directed computer workstation in the practice CG: Usual care, details not given | Mean score on Sun Protection Behavior Scale at 6 months Pre-, post- (complete case analysis), post- (missing values imputed) IG: 4.60 (SD, 1.82), 5.70 (SD, 1.51), 5.36 (SD, 1.72) CG: 4.66 (SD, 1.55), 5.30 (SD, 1.57), 5.06 (SD, 1.59) Complete case analysis: p=0.007 Missing values imputed: p=0.004 Mean difference between IG and CG p value Complete case analysis: 0.33 (95% CI, 0.09–0.57) Missing values at follow-up replaced by baseline values: 0.30 (95% CI, 0.10–0.51)
Geller 2006^50^ Cluster RCT by sibling relationship Fair | Home-based, patients recruited from dermatologists in US N: 494 Age: 58% 18–50 yrs Male: 47% Risk: 85% fair skin type, 100% white | IG: Four 10- to 15-min telephone sessions with health educator and computer-generated tailored materials CG: Usual care | % tanned by end of last summer at 12 months IG: 25.7 CG: 35.6 Adjusted OR, 0.72 (95% CI, 0.47–1.09) % routinely use sunscreen with SPF 15+ at 12 months IG: 67.4 CG: 66.1 Adjusted OR, 0.96 (95% CI, 0.67–1.38)
Prochaska 2005^51^ RCT Fair | Home-based, patients recruited from PC practices in US N: 5407, subset of 3834 at risk for sun exposure Age: mean 45 yrs Male: 30% Risk: sun sensitivity NR, 96.7% white | IG: Four telephone sessions of unknown duration and written survey assessments with computer- generated tailored materials CG: Assessment only | Mean score on Sun Avoidance Subscale of Sun Protection Behavior Scale at baseline, 12 months, and 24 months IG: 12.7 (SD, 3.6), 13.5 (SD, 3.5), 13.7 (SD, 3.5) CG: 12.4 (SD, 3.7), 12.9 (SD, 3.6), 12.9 (SD, 3.6) p<0.005 Mean score on Sunscreen Use Subscale of Sun Protection Behavior Scale at baseline, 12 months, and 24 months IG: 8.6 (SD, 3.9), 9.8 (SD, 3.8), 10.0 (SD, 3.9) CG: 8.5 (SD, 3.9), 8.9 (SD, 3.9), 9.2 (SD, 3.9) p<0.0001
Prochaska 2004^124^ RCT Fair | Home-based, patients recruited from schools in US N: 2460, subset of 1802 at risk for sun exposure Age: mean 42 yrs Male: 25% Risk: Sun sensitivity NR, 92% white | IG: Four telephone sessions of unknown duration and written survey assessments with computer- generated tailored materials CG: Assessment only | Mean score on Sun Avoidance Subscale of Sun Protection Behavior Scale at baseline, 12 months, and 24 months IG: 12.65 (SD, 3.86), 13.71 (SD, 3.52), 13.99 (SD, 3.39) CG: 12.60 (SD, 3.90), 13.22 (SD, 3.64), 13.35 (SD, 3.73) p>0.05 Mean score on Sunscreen Use Subscale of Sun Protection Behavior Scale at baseline, 12 months, and 24 months IG: 8.32 (SD, 4.00), 9.96 (SD, 3.87), 10.21 (SD, 3.94) CG: 8.16 (SD, 3.99), 9.29 (SD, 3.98), 9.18 (SD, 3.82) p<0.05
Young adults
Hillhouse 2008^49^ RCT Fair | Universities (2) in US N: 430 Age: mean 19 yrs Male: 0% Risk: Self-reported intention to indoor tan, approximately 1/3 fair skin | IG: Professionally produced booklet with appearance-focused intervention to reduce indoor tanning CG: Assessment only, details not given | Indoor tanning in past 3 months Mean at baseline, 6 months IG: 4.67 (SE, 0.60), 6.80 (SE, 0.93) CG: 4.48 (SE, 0.55), 10.90 (SE, 0.93) p<0.001
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | Skin color using skin reflectance spectrophotometry at 12 months (b* higher is more tan; L* higher is lighter; L* scale results in figure, exact numbers NR)
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | | Video (n=38) | | No video (n=46) | p
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | Higher exposure site, b* scale | 0.82 (0.28) | | 0.90 (0.25) | NS
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | Lower exposure site, b* scale | 0.32 (0.28) | | 0.39 (0.25) | NS
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | Higher exposure site, L* scale | ~ 1.6 (NR) | | ~ −0.6 (NR) | sig
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | Lower exposure site, L* scale | ~ 2.3 (NR) | | ~ 0.9 (NR) | sig
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | Sun exposure z-score, adjusted for baseline
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | Intentional exposure | −0.12(0.16) | | 0.10 (0.14) | NS
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | Incidental exposure | −0.23 (0.16) | | 0.28 (0.15) | sig
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | Sun Protection Behavior Scale z-score, adjusted for baseline
Mahler 2007^53^ RCT Fair | University in US N: 133 Age: mean 20 yrs Male: 20% Risk: Sun sensitivity NR, 45% white | IG: Appearance- focused intervention with UV facial photo, 11-min videotape with photoaging information, or both CG: Assessment only, details not given | Sun protection index | −0.02 (0.10) | | −0.07 (0.09) | NS
Adolescents
Norman 2007^54^ Patrick 2006^55^ Rosenberg 2007^56^ RCT Fair | PC practices in US N: 819 Age: mean 13 yrs Male: 46% Risk: 25% high sun sensitvity, 58.4% white | IG: Two 20-min interactive computer sessions with computer- generated tailored materials, four follow-up telephone sessions of unknown duration, and 2–3 min counseling by primary care providers CG: Attention control on physical activity and diet intervention, except no brief counseling by primary care providers | Sun Protection Behavior Scale score at 6, 12, and 24 months Adjusted sample means: IG with statistically significant increase in sun protection scores compared with CG, with trajectory of scores flattening (but still statistically significant) between 12 and 24 months (results in figure, exact numbers NR) Sun protection behaviors at 24 months (results in figure, exact numbers NR)
Norman 2007^54^ Patrick 2006^55^ Rosenberg 2007^56^ RCT Fair | PC practices in US N: 819 Age: mean 13 yrs Male: 46% Risk: 25% high sun sensitvity, 58.4% white | | % response “often” or “always” | IG | CG | p
Norman 2007^54^ Patrick 2006^55^ Rosenberg 2007^56^ RCT Fair | PC practices in US N: 819 Age: mean 13 yrs Male: 46% Risk: 25% high sun sensitvity, 58.4% white
Norman 2007^54^ Patrick 2006^55^ Rosenberg 2007^56^ RCT Fair | PC practices in US N: 819 Age: mean 13 yrs Male: 46% Risk: 25% high sun sensitvity, 58.4% white | | Wear a shirt? | ~84 | ~85 | NS
Norman 2007^54^ Patrick 2006^55^ Rosenberg 2007^56^ RCT Fair | PC practices in US N: 819 Age: mean 13 yrs Male: 46% Risk: 25% high sun sensitvity, 58.4% white | | Stay in shade? | ~44 | ~45 | NS
Norman 2007^54^ Patrick 2006^55^ Rosenberg 2007^56^ RCT Fair | PC practices in US N: 819 Age: mean 13 yrs Male: 46% Risk: 25% high sun sensitvity, 58.4% white | | Avoid sun exposure midday? | ~40 | ~30 | p<0.05
Norman 2007^54^ Patrick 2006^55^ Rosenberg 2007^56^ RCT Fair | PC practices in US N: 819 Age: mean 13 yrs Male: 46% Risk: 25% high sun sensitvity, 58.4% white | | Limit sun exposure midday? | ~38 | ~31 | p<0.05
Norman 2007^54^ Patrick 2006^55^ Rosenberg 2007^56^ RCT Fair | PC practices in US N: 819 Age: mean 13 yrs Male: 46% Risk: 25% high sun sensitvity, 58.4% white | | Use sunscreen? | ~55 | ~48 | p<0.05
Norman 2007^54^ Patrick 2006^55^ Rosenberg 2007^56^ RCT Fair | PC practices in US N: 819 Age: mean 13 yrs Male: 46% Risk: 25% high sun sensitvity, 58.4% white | | Use sunscreen on face? | ~62 | ~48 | p<0.05
Norman 2007^54^ Patrick 2006^55^ Rosenberg 2007^56^ RCT Fair | PC practices in US N: 819 Age: mean 13 yrs Male: 46% Risk: 25% high sun sensitvity, 58.4% white | | Use sunscreen on all sun exposed areas? | ~56 | ~40 | p<0.05
Olson 2007^48^ Cluster RCT by school | Geographically distinct towns in US N: 797 Age: 98% in 6th grade Male: 43% Risk: 28% usually or always burn; 94% white | IG: Multimodal education with individual counseling during well visits (PC practices), classroom curriculum and group activities (schools), announcements and team policies (athletic and recreational facilities), posted information (community venues) CG: No intervention | Body surface area covered (by direct observation and interview) Adjusted mean percentage* at baseline and 24 months IG: 71.8 (SE, 1.6), 66.1 (SE, 1.5) CG: 73.7 (SE, 1.4), 56.8 (SE, 2.3) p<0.01 ^*^Adjusted for sex, skin reaction to sun, UV level, year of observation, and temperature % any sunscreen use at baseline, 12 months, and 24 months IG: 58.0, 47.0, 47.0 CG: 65.8, 59.6, 13.8 p <0.05, p<0.01, p<0.001
Children and their parents
Crane 2006^45^ Cluster RCT by practice Fair | PC practices in US N: 728 Age: 30% of parents aged 20–29 yrs, 59% aged 30–39 yrs Male (parents): 100% Risk: 40% of parents with painful burn, no to light tan; 76% parents white | IG: Assessment and counseling by PC providers at 4 well-child visits and written information for parents CG: Usual care | Sun protection behaviors at 12, 24, and 36 months % response “frequently” or “always” Clothing use? IG: 51.0, 38.4, 24.2; p=0.22 CG: 43.8, 32.4, 25.5 Midday sun avoidance? IG: 70.6, 63.2, 64.2; p=0.14 CG: 64.9, 62.0, 59.0 Limit time in sun? IG: 48.9, 38.1, 32.1; p=0.97 CG: 47.5, 35.4, 34.3 Shade use? IG: 90.0, 79.2, 72.6; p=0.03 CG: 87.3, 71.9, 65.2 Hat use? IG: 61.9, 61.9, 57.3; p=0.08 CG: 60.8, 56.1, 47.4 Sunglasses use? IG: 5.2, 24.2, 39.4; p=0.22 CG: 8.3, 22.3, 29.9 Sunscreen use? IG: 90.0, 92.4, 94.2; p=0.46 CG: 87.9, 92.2, 93.1 Sun protection practice score at 12, 24, and 36 months IG: 18.55, 18.52, 18.18; p=0.04 CG: 18.40, 18.05, 17.71
Dietrich 1998^47^ Dietrich 2000^125^ Grant-Petersson 1999^126^ Cluster RCT by town Fair | Geographically distinct towns in US N: 865 Age: 38% aged <5 yrs Male: 52% Risk: 54% burn easily, implied 99% white | IG: Multimodal education with individual counseling during well child and illness visits (PC practices), classroom curriculum (schools and day care centers), posted information and sunscreen (beach areas) CG: No intervention | Sun-protective behaviors at baseline and 12 months* Any protective clothing (by observation) IG: 0.30, 0.24 CG: 0.26, 0.18 Difference of change (IG-CG): 0.02; p=0.78 Protection by shade (by observation) IG: 0.14, 0.14 CG: 0.18, 0.24 Difference of change (IG-CG): −0.06; p=0.38 Sunscreen used on ≥ 1 body area (self report) IG: 0.57, 0.75 CG: 0.65, 0.66 Difference of change (IG-CG): 0.17; p=0.011 Protection on ≥1 body area by sunscreen, clothes, and/or shade (self report) IG: 0.78, 0.87 CG: 0.85, 0.80 Difference of change (IG-CG): 0.13; p=0.029 Protection on all 3 body areas by any means (self report) IG: 0.53, 0.74 CG: 0.66, 0.72 Difference of change (IG-CG): 0.15; p=0.18 ^*^All values corrected by age, sex, ease with which child burns, and weather conditions at time of interview

RCT=randomized controlled trial; N=number; IG=intervention group; CG=control group; UK=United Kingdom; US=United States; PC=primary care; CI=confidence interval; SD=standard deviation; SE=standard error; OR=odds ratio; NR=not reported; UV=ultraviolet; SPF=sun protection factor; NS=not significant; sig=significant

### Adults

Summary of findings. We found four fair-quality randomized controlled trials (RCTs) evaluating primary care conducted or relevant behavioral counseling interventions to prevent skin cancer in adults.46,50–52 Three trials were conducted in the United States,50–52 and one trial was conducted in the United Kingdom.46 The counseling interventions conducted in the United States were coupled with in-office computer support using the transtheoretical model to generate printed stage-based, tailored feedback.50–52 Two of these counseling interventions with computer support targeted multiple behaviors in addition to sun protection and were called “Expert System” interventions.51,52 The trial conducted in the United Kingdom used a self-directed computer station in a primary care practice to deliver the counseling intervention.46

Overall, three of the four trials (n=6,225) showed that primary care relevant counseling combined with computer support can modestly impact self-reported sun-protective behaviors, as measured by composite behavior scores.46,51,52 Populations studied included predominantly middle-aged white men and women. One trial (n=589) included only persons with high-risk skin characteristics,46 and the other trials did not report the participants’ sun sensitivity or skin type. Interventions ranged from a single low-intensity intervention (approximately one 15-minute session) to multiple (three or four) in-person counseling or, phone sessions followed by tailored written feedback.

These trials, however, have a few important limitations. The trial by Glazebrook and colleagues had only a 6-month followup. In addition, all three trials had small but statistically significant differences in followup between the intervention and control groups. Most importantly, these three trials all showed a difference in composite scores measuring self-reported sun protection behaviors. The differences in these scores, though statistically significant, were small, and it is unclear if these small differences would translate into clinically meaningful behavior change to prevent skin cancer. In addition, the true feasibility and cost of implementing the in-office computer support to generate individual tailored feedback in primary care is not clear.

One trial conducted among siblings of patients with melanoma (n=494) failed to show any statistically significant changes in sun-protective behaviors at 12 months in those receiving individual telephone counseling (four 15-minute sessions) conducted by a health educator with computer support and tailored printed materials, compared with those receiving usual care.50 This trial used different outcome measures than the other trials (i.e., percent tanned by the end of last summer, routine use of sunscreen with SPF 15 or higher). It is unclear if the nonsignificant findings are a result of trial design issues (e.g., choice of study population, number of participants, choice of outcome measures) or due to lack of efficacy of the intervention itself. Additionally, this trial had low followup at 12 months (approximately 64 percent).

Additional study details. One fair-quality trial randomly assigned 10 primary care practices in Nottinghamshire, United Kingdom, to have a computer workstation that delivered a brief 10-to 15-minute self-directed counseling session, called the “Skinsafe” program.46 This Skinsafe intervention, based on the health belief model, was organized into eight sections, designed to be completed in a single session, to inform users about the dangers of excessive sun exposure, sun-protective behaviors, skin characteristics that are at risk for developing skin cancer, early signs of melanoma, how to reduce risk for melanoma, and how to check skin for suspicious lesions. Across the 10 sites, 589 persons with “high-risk” skin characteristics (mean age, 38 years; mostly women) were either given a prescription for the Skinsafe program or received usual care. Persons at the five primary care practices in the intervention group had statistically significantly higher sun-protection behavior scores at 6-month followup (mean difference, 0.33 [95% CI, 0.09–0.57]).

Two fair-quality trials by Prochaska and colleagues randomly assigned adults at risk for sun exposure, as defined by their stage of change in the transtheoretical model, to receive telephone-based counseling and written survey assessments with tailored, mailed feedback using computerized support (the Expert System intervention).51,52 The Expert System intervention, based on the transtheoretical model, is designed to use computerized support to deliver stage-based, tailored communications to inform persons about how to reduce sun exposure by limiting sun exposure to 15 minutes a day or always using SPF 15 or higher sunscreen. While the duration of the phone or written assessments were not described, they were administered at 0, 6, 12, and 24 months, followed by a three-to five-page tailored, mailed feedback at 0, 6, and 12 months. In the 2005 trial, adults from 79 different nonhospital-based primary care practices (n=5,407) who were age 45 years on average, about 30 percent male, and overwhelmingly white were randomly assigned to receive the Expert System intervention or assessment only.51 Among the subset of individuals (n=3,834) who were at risk for sun exposure (defined as being in the precontemplation, contemplation, or preparation stage of change), those in the intervention group had a very small, but statistically significant, increase in sun avoidance and sunscreen use behaviors at 12 and 24 months, as measured by a four-item Sun Protection Scale. In the 2004 trial, the participants (n=2,460), while similar in age, sex, and race distribution to the 2005 trial, were recruited through schools (parents of children in the ninth grade).52 Among the subset of parents (n=1,802) at risk for sun exposure, those in the intervention group had a very small, but statistically significant, difference in sunscreen use at 12 and 24 months using the same four-item Sun Protection Scale, but not sun avoidance.

The final trial in adults was a fair-quality cluster RCT among siblings of melanoma patients identified through dermatologists at teaching hospitals in the Boston area.50 These siblings (n=494) were approximately 47 percent male and 100 percent white, and 85 percent had “fair” skin. Siblings were randomly assigned to receive either usual care or four sessions of telephone-based counseling by a health educator with computer-generated tailored materials at 0, 1, 3, and 5 months. At 6-and 12-month followup, there were no statistically significant differences between the intervention and control groups in tanning behavior (as measured by percent tanned by the end of last summer) or in routine sunscreen use.

### Young Adults

Summary of findings. We found two fair-quality RCTs evaluating primary care relevant behavioral counseling interventions to prevent skin cancer in young adults in college.49,53 Both of these trials used “appearance-based” behavioral interventions that emphasized the photoaging effects of UV exposure and cultural norms regarding tanning and appearing tan instead of a primarily “health-based” message about skin cancer prevention. In one RCT, young university women who self-reported an intention to tan indoors (n=430) received either a professionally produced booklet with an appearance-focused approach aimed at reducing indoor tanning or were assigned to a control group of assessment only. This intervention appeared to statistically significantly reduce the normative increases in indoor tanning during the 3 months of heaviest use, by over 35 percent at 6-month followup.49 In another RCT (n=133), mostly female college students were randomly assigned to view a brief video with or without a UV facial photo or to a control group of assessment only. At 12 months, the persons who viewed the video had a “moderate” decrease in objectively measured skin pigmentation.53 The change in pigmentation was judged “moderate” based on the authors’ report of the Cohen d statistic.

Both these trials, however, have a few important limitations. The trial by Hillhouse and colleagues had only a 6-month followup and was conducted among young women who self-identified with the intention to indoor tan. The trial by Mahler and colleagues had a fairly small number of participants randomly assigned to four different intervention groups, in a two-by-two factorial design. Followup was only 63 percent for the results reported, and results were not reported with a true control group. It appears that the UV facial photo, however, did not have an intervention effect, and the authors of the paper state that none of the primary analyses indicated any significant interaction between the video and UV photo interventions. Finally, participants in the Mahler study received course credit for their participation in the trial.

Additional study details. One fair-quality RCT conducted in two U.S. universities randomly assigned young women (n=430) to receive either a professionally produced booklet with an appearance-focused message aimed at reducing indoor tanning or assessment only.49 This booklet had five sections addressing the history of tanning and the context for tanning norms, analysis of tanning and image norms, effects of UV radiation on skin, effects of indoor tanning, and indoor tanning guidelines. Women were age 19 years on average and selected based on a self-reported intention to tan indoors. Approximately one third of the participants had fair or medium skin type. At 6 months, with over 90 percent followup, women in the intervention group had statistically significantly less than normative increases in indoor tanning during the 3 months of heaviest use, by over 35 percent (6.8 events vs. 10.9 events over past 3 months; p<0.001).

One fair-quality trial RCT in a Southern California university randomly assigned participants (n=133) in a two-by-two factorial design to receive either a brief video session, a UV facial photo, both, or assessment only.53 The interventions included an 11-minute videotaped slideshow on photoaging of the skin due to UV exposure and effective practices for reducing photoaging, a UV facial photograph using a modified instant camera, and a natural-light instant photograph. Participants were about 80 percent female, 45 percent white, and had a mean age of 20 years. This trial evaluated both self-reported behaviors and objectively measured skin pigmentation using skin reflectance spectrophotometry. At 12 months, the trial had 80 percent followup for self-reported behavior outcomes and 70 percent followup for spectrophotometry readings, but only 63 percent had followup at both 5 and 12 months and were therefore included in the final results. Results were reported for the video groups versus no video groups. Since the UV facial photo is not necessarily primary care feasible and the photo intervention did not appear to have a significant effect on self-reported or objectively measured outcomes, it is not discussed further (see Appendix B Table 1 for details). At 12 months, those persons who received the video session had lighter pigmentation as measured by one of two skin reflectance measures. This change was statistically significant, and based on the reported Cohen d statistic, was considered “moderate.” There did not appear to be any statistically significant difference between the groups in the self-reported eight-item composite measure of sun-protective behaviors.

### Children and Adolescents

Summary of findings. We found only two fair-quality RCTs evaluating primary care relevant behavioral counseling interventions to prevent skin cancer in children and adolescents.45,54 Participants in both these trials were predominantly white. In one trial (n=819), young adolescents who were randomly assigned to brief counseling by their primary care providers coupled with an Expert System intervention had both higher self-reported composite sun protection scores and greater likelihood of avoiding or limiting midday sun exposure or using sunscreen on the face or sun-exposed areas at 24 months. The other cluster RCT was conducted in a large managed-care organization in which parents of newborns (n=728) received either usual care or sun protection counseling integrated into four sequential well-child care visits, at the discretion of the primary care provider.45 Patients randomly assigned to receive the intervention had small but statistically significant higher self-reported composite sun protection scores at 36 months compared with those in control practices. However, the clinical significance of these higher scores is unclear, given the very small numerical differences and the lack of statistically significant differences in each of the seven sun-protection questions (with the exception of “shade use”) that contributed to the composite score.

Because we found only two trials in children and adolescents, we discuss two additional fair-quality trials in adolescents and children that primarily examined community-based interventions to prevent skin cancer but included a counseling component conducted in primary care.47,48 One of these trials was included in the prior report.47 Both of these trials show that multimodal community-based interventions to promote sun-protective behaviors in predominantly white neighborhoods and delivered through primary care practices, schools and/or day care centers, recreational facilities, and other community venues can improve directly observed and self-reported sun-protective behaviors in grade school and middle school children over 2 years of followup. Although these two trials were well-conducted community-level interventions, both trials followed the communities’, rather than the individuals’, behaviors, so the children and adolescents observed at baseline were not the same individuals at followup. Additionally, given the design of the intervention, it is impossible to determine the relative effect of each component, such as counseling in primary care.

Additional study details. The only fair-quality trial in adolescents was conducted in children aged 11 to 15 years attending one of six San Diego primary care clinics.54 Participants (n=819) were age 13 years on average, 47 percent male, and 58 percent white, with 25 percent reporting high sun sensitivity (based on ability to tan, skin and hair color). Patients were randomly assigned to receive either a “Sun Smart” or physical activity and diet intervention, both using an Expert System intervention. The interventions consisted of brief counseling by primary care providers, interactive computer sessions, telephone assessments at 3, 6, 15, and 18 months, printed tailored feedback, mailed information, and sunscreen samples. The control group was matched in intensity, but did not receive the 2- to 3-minute primary care counseling. At 24 months, adolescents receiving sun protection counseling appeared to be approximately 5 to 10 percent (exact numbers not reported) more likely to report “always” or “often” avoiding midday sun exposure, limiting midday sun exposure, using sunscreen on face, and using sunscreen on sun-exposed areas. However, there were no significant differences between the two groups in self-report of wearing a shirt or staying in the shade.

The only fair-quality trial in younger children was conducted in parents and infants attending one of 14 primary care clinics part of a large managed-care organization in Colorado.45 The majority of parents (n=728) were aged 30 to 39 years, nearly all were female, and about 76 percent were white, with the majority (75 percent) self-reporting fair to medium white skin. Parents and infants were randomly assigned to receive sun protection promotion at four consecutive well-child visits (at ages 2, 6, 18, and 36 months) or to usual care visits. The intervention included counseling at the discretion of the provider and packets of information, as well as a sun hat, sunglasses, and sunscreen samples. Although the intervention group had a small but statistically significant improvement in the seven-item Sun Protection Practice score at 36 months, these behavior changes were not significant when looked at individually (e.g., clothing use, midday sun avoidance, limiting time in sun, hat use, sunglasses use, sunscreen use). The measure “use of shade” was statistically significantly increased by 7 percent among the intervention group at 24 months (p=0.04), but was no longer statistically significant at the end of the trial (p=0.06).

Two fair-quality cluster RCTs evaluated a multi component community-based intervention, “SunSafe,” which included some counseling in primary care.47,48 The SunSafe intervention included training primary care clinicians to incorporate sun protection messages into well visits, as well as providing patient education materials to supplement sun-protection curriculum delivered through schools, recreational areas/facilities, and other community venues. One trial targeted adolescents entering sixth through eighth grade at beaches and swimming pools in geographically distinct towns in New Hampshire and Vermont.48 Cross-sections of the adolescent population were assessed at baseline (n=797) and at 1 (n=637) and 2 years (n=493). Participants at baseline and followup did not represent a single cohort. Participants at baseline were in sixth grade, approximately 45 percent male, and mostly white. As compared with adolescents in schools and communities without the SunSafe intervention, adolescents in the intervention communities were observed to have a greater percentage of body surface area protected at 24 months (66.1 vs. 56.8 percent; p<0.01) and more frequently reported sunscreen use (47.0 vs. 13.8 percent; p<0.001). The other trial targeted children aged 2 to 9 years and their caregivers visiting beaches in 10 geographically distinct towns in New Hampshire.47 Cross-sections of the communities were assessed at baseline (n=865) and 12 months (n=1,065). Participants were about one half male and overwhelmingly white. There was no statistically significant difference in observed sun-protective behaviors (use of sun-protective behaviors or protection by shade) between children in the intervention and control communities at 12 months. As compared with children in communities without the SunSafe intervention, those children in the intervention communities reported using sunscreen more frequently at 12 months (approximately 17 percent difference; p=0.011).

## Key Question 3 Do Primary Care Relevant Counseling Interventions Have Adverse Effects?

Of the 10 trials examining primary care relevant counseling interventions to prevent skin cancer, we found no evidence for a paradoxical decrease in sun-protective behaviors. In one trial, the skin cancer counseling intervention was an attention control intervention for a physical activity and diet counseling intervention.54–56 In this trial, adolescent girls and boys (n=395) with a mean age of 13 years received skin cancer counseling in a primary care practice. There was no clinically or statistically significant effect on self-reported measures of sedentary behaviors (mean hours per day), 7-day physical activity recall (moderate and vigorous activity, mean minutes per week), or number of days per week active (refer to Appendix B Table 1 for more details).

## Key Question 4 Is Sun Exposure, Indoor Tanning, or Sunscreen Use Associated With Skin Cancer Outcomes?

In total, we found 56 articles representing 32 unique fair-or good-quality studies that evaluated the association of sun exposure, indoor tanning, or sunscreen use with skin cancer, the majority of which were case-control studies. We did not find any studies meeting our inclusion criteria that examined the association between a decrease in an individual’s sun exposure (e.g., due to protective clothing or avoidance of midday sun exposure) and skin cancer outcomes. Therefore, in this KQ, we discuss the relationship between sun exposure and skin cancer outcomes. We found only one good-quality trial, the Nambour Skin Cancer Prevention Trial,57–61 which was reported in multiple publications and included in the prior report.1 We found seven fair-or good-quality cohort studies, one of which was a cohort derived from the Nambour Skin Cancer Prevention Trial. We included 25 fair- or good-quality population-based case-control studies, two of which were nested case-control studies. In this section, we discuss the results for each exposure (sun exposure, indoor tanning, and sunscreen use) separately. Sun exposure is discussed by type of exposure: “intermittent,” which includes predominantly measures of recreational sun exposure;“ chronic,” which includes occupational measures or weekday measures of sun exposure; or“ total,” which includes cumulative estimates of sun exposure. However, it is important to note that measures of sun exposure within these categories vary greatly between studies. In addition, when possible, we categorized exposures by timing: in childhood (generally before age 19 or 20 years), in the recent past (ranging from past 5 to 20 years), or over the entire lifetime. Given the considerable heterogeneity in study characteristics and measurement of exposure variables, we did not attempt a quantitative summary of results. The reported odds and risk ratios are to illustrate a general estimate of the magnitude of association (e.g., between the highest and lowest risk groups). However, odds and risk ratios should not be compared between studies, because they used very different measures of exposure and choice of reference groups. Individual study details, including quality assessment, are available in Tables 3–5 and Appendix C Table 1.

Table 3 Association Between Sun Exposure and Skin Cancer

Study reference, USPSTF quality rating | Design, Setting, Population | Total Sun Exposure (RR or OR)^*^ | Intermittent Sun Exposure (RR or OR [95% CI])^*^ | | | ChronicSun Exposure (RR or OR)^*^ | | | Adjustments reported
Squamous cell or basal cell carcinoma
Grodstein 1995^67^ Nurses’ Health Study Good | Cohort US (11 states) n=107,900 | NR | SCC, regular time outdoors in summer Yes (use sunscreen): reference Yes (no sunscreen): 0.9 (0.6–1.2) No: 0.7 (0.4–1.1) | | | NR | | | Age; smoking; region; natural hair color; reaction to sun; lifetime # of sunburns
Hunter 1990^68^ Nurses’ Health Study Fair | Analytic cohort US (11 states) n=73,366 | NR | BCC, regular time spent outdoors in summer (at least 8 hrs/wk) Yes (use sunscreen): reference Yes (no sunscreen): 0.70 (0.60–0.82) No: 0.73 (0.59–0.90) | | | NR | | | Age; time period; region; time spent outdoors in summer and sunscreen use; hair color; childhood tendency to burn; lifetime # of severe and painful sun- burns on face and arms
van Dam 1999^69^ Health Professionals Follow-up Study Fair | Cohort US (multistate) n=44,591 | NR | BCC, frequency outdoors in swimsuit as teenager in summer <1 time/wk: reference 1 time/wk: 1.30 (1.14–1.47) 2 times/wk: 1.34 (1.19–1.52) Several times/wk: 1.36 (1.22–1.52) Daily: 1.42 (1.24–1.63) | | | NR | | | Age; time period; hair color; eye color; skin reaction to sun; ancestry; BMI; region of residence
Green 1996^65^ Nambour Skin Cancer Study Fair | Cohort Queensland Australia N=2,095 | NR | Leisure exposure SCC Mainly indoors: reference Indoors/outdoors: 0.81 (0.37–1.80) Mainly outdoors: 1.29 (0.66–2.52) BCC Mainly indoors: reference Indoors/outdoors: 0.93 (0.63–1.37) Mainly outdoors: 0.85 (0.59–1.21) | | | Occupational exposure SCC Mainly indoors: reference Indoors/outdoors: 0.82 (0.47–1.43) Mainly outdoors: 1.37 (0.80–2.34) BCC Mainly indoors: reference Indoors/outdoors: 1.07 (0.79–1.46) Mainly outdoors: 1.25 (0.88–1.78) | | | Age; sex; skin color
Neale 2007^61^ Fair | Cohort from Nambour Skin Cancer Trial Queensland Australia N=1,517 | NR | Leisure exposure BCC (head, trunk respectively) Mainly indoors: reference Indoors/outdoors: 0.93 (0.64–1.35); 1.15 (0.62–2.12) Mainly outdoors: 0.99 (0.60–1.63); 0.84 (0.32–2.17) | | | Occupational exposure BCC (head, trunk respectively) Mainly indoors: reference Indoors/outdoors: 0.95 (0.60–1.49); 1.07 (0.60–1.93) Mainly outdoors: 0.86 (0.53–1.40); 1.12 (0.60–2.11) | | | Age; sex
Vlajinac 2000^127^ Fair | Case-control Yugoslavia Cases n=200 Controls n=399 | NR | BCC # of vacations at seaside before age 10 NS; OR not reported Average # wks per year spent at seaside 0: reference 1–6: NR 7+: 1.81 (1.24–2.64) | | | NR | | | NR
Han 2006^71^ Nurses’ Health Study Fair | Nested case- control US (11 states) SCC n=275 BCC n=283 Control n=804 | NR | Total lifetime sun exposure while wearing bathing suit (tertile) SCC Low: reference Intermediate: 1.28 (0.85–1.93) High: 2.15 (1.45–3.19) BCC Low: reference Intermediate: 1.71 (1.14–2.56) High: 2.05 (1.38–3.06) | | | NR | | | Age; constitutional susceptibility; family history of skin cancer; # of lifetime severe sunburns which blistered; sunlamp use or tanning salon attendance; geographic region
Rosso 1999^64^ Fair | Case-control Valais, Switzerland Cases n=146 Controls n=144 | SCC, total # lifetime hrs <5,000: reference −64,200: 1.78 (0.18–17.67) 64,200+:1.42 (0.53–3.85) BCC, total # lifetime hrs <5,000: reference −15,800: 1.09 (0.62–1.92) −64,200: 0.99 (0.35–2.79) 64,200+: 0.70 (0.20–2.39) | Lifetime hrs at beach on vacation SCC Never: reference 2,260+: 0.78 (0.26–2.40) BCC Never: reference <300: 1.46 (0.52–4.07) −1,140: 1.39 (0.72–2.66) −2,260: 0.92 (0.44–1.91) 2,260+: 1.20 (0.61–2.34) | | | Lifetime hrs of outdoor work SCC Never: reference −47,900: 1.84 (0.30–11.09) −77,200: 2.02 (0.60–6.78) 77,200+: 1.88 (0.30–11.70) BCC Never: reference −12,000: 0.98 (0.58–1.66) −47,900: 1.30 (0.69–2.46) −77,200: 0.78 (0.52–1.19) 77,200+: 0.90 (0.51–1.59) | | | Age; sex
Kricker 1991^62^ Kricker 1995^36^ Kricker 1995^116^ English 1998^63^ English 1998^33^ Fair | Case-control Western Australia n=248 (23 w/BCC + SCC) BCC n=226 SCC n=45 Control n=1,015 BCC control n=1,021 (6 w/SCC) SCC control n=1,064 (49 w/BCC) | BCC Total hrs (thousands) sun exposure 9am to 5pm, whole wk 0–40.5: reference 40.5–56.4: 0.99 (0.61–1.58) 56.4–81.6: 1.42 (0.86–2.35) 81.6+: 0.77 (0.43–1.40) Total hrs (thousands) sun exposure 9am to 5pm, whole wk, age ≥ 15 0–14.7: reference 14.8–27.7: 1.25 (0.79–1.97) 27.8–49.3: 1.17 (0.72–1.90) 49.4+: 0.86 (0.50–1.51) Total ambient sunlight in accumulated global radiance (mWh cm-2 X 105) 0–8.8: reference 8.8–10.1: 1.32 (0.69–2.55) 10.1–11.4: 1.72 (0.72–4.09) 11.4+: 2.18 (0.82–5.82) SCC Total ambient sunlight in accumulated global radiance (mWh cm-2 X 105) <8.8410: reference 8.8410–10.1399: 1.4 (0.51– 3.6) 10.1400–11.4509: 2.7 (0.84– 8.6) 11.4510+: 2.3 (0.62–8.3) | BCC Intermittent sun exposure, ages 15–19 0–40%: reference 41–58%: 1.49 (0.88–2.52) 59–99%: 1.82 (1.01–3.28) 100%: 3.86 (1.93–7.75) Lifetime hrs sun exposure on holiday 0–602: reference 602–2268: 1.65 (1.01–2.70) 2268–3794: 1.68 (1.00–2.80)3794+: 1.85 (1.09–3.13) Lifetime frequency of sunbathing None: reference 1–200: 1.57 (0.98–2.51) 201–700: 1.08 (0.68–1.72) 701–9000: 1.02 (0.63–1.64) SCC Total hrs sun exposure on nonworking days 0–4,999: reference 5,000–8,499: 2.0 (0.89–4.4) 8,500–13,999: 1.9 (0.86–4.2) 14,000+: 1.3 (0.57–2.9) Lifetime hrs sun exposure on holidays <600: reference 600–2,268: 0.89 (0.44–1.8) 2,269–3,793: 1.0 (0.51–2.1) 3,794+: 0.93 (0.44–1.9) | | | BCC NR SCC Total hrs sun exposure on working days 0–11,499: reference 11,500–19,999: 0.93 (0.42–2.1) 20,000–32,999: 1.7 (0.81–3.8) 33,000+: 1.3 (0.58–2.8) | | | Age; sex; ability to tan; total sun exposure (for recreational sun exposure)
Gallagher 1995^66^ Bajdik 1996^128^ Fair | Case-control Alberta, Canada Cases n=180 Controls n=406 | NR | SCC Mean recreational sun exposure per year, ages 0–19 <100/y WBE, <3.8 h/wk summer: reference 100–199/y WBE, 3.8–7.4 h/wk summer: 1.2 (0.6–2.5) 200–332/y WBE, 7.5–12.4 h/wk summer: 1.1 (0.5–2.6) 333+/y WBE, 12.5+ h/wk summer: 1.6 (0.6– 4.5) Mean recreational sun exposure per year, lifetime <75/y WBE, <2.8 h/wk summer: reference 75–149/y WBE, 2.8–5.5 h/wk summer: 0.6 (0.3–1.1) 150–224/y WBE, 5.6–8.4 h/wk summer: 0.8 (0.3–1.8) 225+/y WBE, 8.5+ h/wk summer: 0.3 (0.1– 0.9) BCC Mean recreational sun exposure per year, ages 0–19 <100/y WBE, <3.8 h/wk summer: reference 100–199/y WBE, 3.8–7.4 h/wk summer: 1.1 (0.6–2.0) 200–332/y WBE, 7.5–12.4 h/wk summer: 1.4 (0.7–3.0) 333+/y WBE, 12.5+ h/wk summer: 2.6 (1.1– 6.5) Mean recreational sun exposure per year, lifetime <75/y WBE, <2.8 h/wk summer: reference 75–149/y WBE, 2.8–5.5 h/wk summer: 0.9 (0.5–1.7) 150–224/y WBE, 5.6–8.4 h/wk summer: 0.6 (0.3–1.3) 225+/y WBE, 8.5+ h/wk summer: 0.4 (0.2– 1.0) | | | SCC NR BCC Mean lifetime occupational sun exposure per year <15/y WBE, <3.5 h/wk summer: reference 15–59/y WBE, 3.5–13.9 h/wk summer: 1.0 (0.6–1.8) 60–104/y WBE, 14.0–24.9 h/wk summer: 1.3 (0.8–2.3) 105+/y WBE, 25+ h/wk summer: 1.4 (0.8–2.4) | | | Mother’s ethnic origin; hair color; skin color
Melanoma
Veierod 2003^82^ Norwegian- Swedish Women’s Lifestyle and Health Cohort Study Fair | Cohort Norway & Sweden N=106,379 | NR | Annual wks on sunbathing vacation, ages 10–19 0: reference 1 wk/yr: 1.21 (0.80–1.83) 2–3 wks/yr: 1.09 (0.71–1.65) ≥4 wks/yr: 1.67 (1.01–2.74) Annual wks on sunbathing vacation, ages 10–39 0: reference ≥1 wk/yr: 1.56 (0.95–2.56) | | | NR | | | Age; region of residence; hair color
Weinstock 1991^87^ Nurses’ Health Study Fair | Nested case- control US (multistate) Cases n=130 Controls n=300 | NR | Annual frequency of swimsuit use outdoors, ages 15–20, by skin type [underlined: Sun resistant]^[underlined: ^*^]^ 0–10: reference 11–30: 0.6 (0.2–1.4) ≥31: 0.3 (0.1–0.8) [underlined: Sun sensitive]^[underlined: **]^ 0–10: reference 11–30: 1.2 (0.6–2.6) ≥31: 3.5 (1.3–9.3) ^*^ A priori sun sensitivity score <0.5 ^**^A priori sun sensitivity score ≥0.5 | | | NR | | | NR
Han 2006^71^ Nurses’ Health Study Fair | Nested case- control US (11 states) Melanoma n=200 Controls n=804 | | Total lifetime sun exposure while wearing a bathing suit (tertile) Low: reference Intermediate: 1.20 (0.73–1.97) High: 2.37 (1.51–3.73) | | | NR | | | Age; constitutional susceptibility; family history of skin cancer; # of lifetime severe sunburns which blistered; sunlamp use or tanning salon attendance; geographic region
White 1994^72^ Fair | Case-control Washington, US Cases n= 256 Controls n=273 | Avg yearly sun exposure (hrs), previous 10 yrs 0: reference 1–201: 1.16 (0.72–1.87) 202–499: 0.80 (0.45–1.42) 500–2,880: 0.88 (0.47–1.64) | NR | | | Lifetime occupational sun exposure None: reference <50%: 0.89 (0.60–1.32) ≥50%: 0.64 (0.33–1.23) | | | Age; sex; education
Osterlind 1988^83^ Osterlind 1988^129^ Fair | Case-control East Denmark Cases n= 474 Controls n=926 | NR | Sunbathing habits, adjusted for sex, nevi, freckles and hair color Never: reference At some time: 1.6 (1.1–2.4) 1–9 years: 1.9 (0.9–3.9) 10–24 years: 1.6 (1.1–2.5) 25–39 years: 1.7 (1.1–2.5) 40+ years: 1.9 (1.3–2.9) Vacations spent in sun, adjusted for history of sunbathing and sunburning Never: reference Sunny: 1.0 (0.8–1.3) Very sunny: 1.4 (1.0–2.1) | | | NR | | | Sex; nevi; freckles and hair color; history of sunbathing and sunburning
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | Total lifetime sun exposure, adjusted for skin self-exam; total nevi; family history; skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned Light: reference Moderate: 1.26 (0.69–2.29) Heavy: 2.20 (1.21–4.01) Very heavy: 2.63 (1.25–5.54) | Total recreational sun exposure index (by body site), adjusted for sex; age; skin color; # of nevi on arms; skin type | | | Total yrs in outdoor jobs (by body site) | | | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | Total recreational sun exposure index (by body site), adjusted for sex; age; skin color; # of nevi on arms; skin type | | | | Head/neck | Upper limb | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | Total recreational sun exposure index (by body site), adjusted for sex; age; skin color; # of nevi on arms; skin type | | | | | | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | Total recreational sun exposure index (by body site), adjusted for sex; age; skin color; # of nevi on arms; skin type | | | | Lower limb | Trunk | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | | | | | | | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | | Head/neck | Upper limb | 0 | reference | reference | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | | | | | | | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | | Lower limb | Trunk | | reference | reference | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | | | | | | | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | Level 1 | reference | reference | <5 | 0.8 (0.4–1.5) | 0.7 (0.4–1.4) | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | | reference | reference | | 0.7 (0.3–1.3) | 0.7 (0.5–1.1) | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | Level 2 | 1.5 (0.7–3.3) | 0.9 (0.4–1.8) | 5+ | 0.5 (0.2–1.1) | 0.6 (0.2–1.1) | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | | 1.0 (0.5–2.2) | 1.7 (1.0–2.9) | | 0.3 (0.1–0.9) | 0.9 (0.6–1.3) | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | Level 3 | 1.0 (0.7–2.1) | 1.0 (0.5–2.0) | | | | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | | 1.2 (0.6–2.7) | 1.4 (0.7–2.2) | | | | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | Level 4 | 2.6 (1.2–5.6) | 2.4 (1.2–4.8) | | | | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | | 2.7 (1.2–5.8) | 2.7 (1.6–4.5) | | | | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ Fair | Case-control Connecticut, US Cases n=650 Controls n=549 | | # vacations, age 0–15 0: reference 1–14: 1.1 (0.8–1.7) 15–90: 0.9 (0.5–1.4) | | | | | | Sex; age; skin self-exam; total nevi; family history skin cancer; skin type; eye color; hair color; freckles; ever severely sunburned
Walter 1999^90^ Walter 1990^132^ Fair | Case-control Ontario, Canada Cases n=583 Controls n=608 | NR | Beach vacation, past 5 yrs No: reference Yes: 1.04 (0.82–1.32) | | | NR | | | Age; sex; reaction to initial summer sun exposure
Green 1985^77^ Green 1986^133^ Fair | Case-control Queensland, Australia Cases n=183 (excludes lentigo maligna) Controls n=183 | Total lifetime # hrs of sun exposure, adjusted for age, nevi on arms, hair color, and sunburn propensity <2,000: reference 2,000–100,000: 3.2 (0.9– 12.4) >100,000: 5.3 (0.9–30.8) Total # hrs sun exposure, adjusted for age and nevi on arms [underlined: Lifetime] <2000: reference 2000-: 2.3 (1.0–5.1) 50,000-: 1.7 (0.4–7.8) [underlined: Ages 10–19 years] <500: reference 500-: 1.0 (0.5–2.0) 5000-: 4.4 (1.8–184.5) | Recreational hrs on beach, adjusted for nevi on arms and age [underlined: Lifetime] 0: reference 1-: 0.6 (0.2–1.4) 500-: 0.3 (0.1–0.8) 5000-: 1.3 (0.4–4.3) [underlined: Ages 10–19] 0: reference 1-: 1.1 (0.6–2.0) 500-: 0.8 (0.4–1.9) | | | NR | | | Age; nevi on the arms; hair color; and sunburn propensity
Shors 2001^74^ Soloman 2004^134^ Fair | Case-control Washington, US Cases n=386 Controls n=727 | Lifetime avg days spent >4 hrs in the sun 1stt quartile: reference 2nd quartile: 1.3 (0.86–1.9) 3rd quartile: 1.4 (0.92–2.0) 4th quartile: 1.4 (0.95–2.0) Lifetime overall UV exposure (includes time in sun, erythemal exposure) [underlined: Men] 1st quartile: reference 2nd quartile: 0.51 (0.23–0.80) 3rd quartile: 0.67 (0.31–1.03) 4th quartile: 1.24 (0.62-–.86) [underlined: Women] 1st quartile: reference 2nd quartile: 1.35 (0.64–2.05) 3rd quartile: 2.45 (1.23–3.68) 4th quartile: 1.99 (0.95–3.03) | NR | | | NR | | | Age; income; tendency to sunburn; #of sunburns ages 2–10
Garbe 1989^78^ Fair | Case-control Germany Cases n= 200 Controls n=200 | NR | NR | | | Occupational sun exposure None: reference Sometimes: 1.18 (0.56–2.48) Nearly every time: 11.62 (2.13–63.33) | | | NR
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study Fair | Case-control Western Canada Cases n= 595 Controls n=595 | Total hrs annual sun exposure <49: reference 50–99: 1.5 (0.8–2.7) 100–149: 1.5 (0.9–2.7) 150–199: 1.6 (0.9–2.9) 200–299: 1.0 (0.6–1.7) 300–399: 1.1 (0.6–1.9) 400–499: 1.6 (0.9–2.7) 500+: 1.2 (0.7–2.0) | Total hrs recreational exposure in summer <1: reference 1–19: 1.1 (0.7–1.6) 20–79: 1.7 (1.2–2.5) 80–159: 1.8 (1.2–2.7) 160+: 1.7 (1.1–2.7) Total hrs vacation in summer <1: reference 1–6: 0.9 (0.7–1.3) 7–19: 0.9 (0.6–1.4) 20–39: 1.9 (1.3–3.0) 40+: 1.5 (1.0–2.3) # sunny vacations per decade of life 0: reference <1: 1.1 (1.0–1.1) 1–3: 1.3 (1.1–1.5) 4+: 1.7 (1.2–2.3) | | | Occupational, hrs/summer season <1: reference 1–99: 1.8 (1.2–2.5) 100–199: 1.0 (0.7–1.5) 200–399: 0.9 (0.6–1.4) 400+ : 0.9 (0.6–1.5) | | | Hair color; skin color; freckling; ethnic origin
Fargnoli 2004^79^ Fair | Case-control Central Italy Cases n=100 Controls n=200 | NR | Hrs recreational sun exposure per year <60: reference 60–120: 0.761 (0.420–1.378) 120–240: 1.641 (0.799–3.370) >240: 5.010 (2.110–11.891) | | | Occupational sun exposure No: reference Yes: 2.57 (1.40–4.73) | | | Hair color; eye color; skin type
Holly 1995^80^ Fair | Case-control San Francisco, US Cases n=452 Controls n=930 | NR | Time spent outdoors on weekends, past 10 years None: reference <1/4 of time: 0.72 (0.35–1.4) 1/4 - 1/2 of time: 0.71 (0.37–1.4) 1/2 - 3/4 of time: 0.86 (0.42–1.8) ≥3/4 of time: 0.84 (0.37–1.9) Frequency of sunbathing in typical year, past 10 years Never: reference <Once/month: 0.75 (0.52–1.1) Once/month: 0.57 (0.36–0.89) 2–3 times/month: 0.67 (0.46–0.98) ≥Once/week: 0.79 (0.56–1.1) | | | Time spent outdoors on weekday, past 10 years None: reference <1/4 of time: 0.71 (0.49–1.0) 1/4 – 1/2 of time: 0.83 (0.53–1.3) ≥1/2 of time: 0.83 (0.46–1.5) | | | None
Tabenkin 1999^76^ Fair | Case-control Israel Cases n=168 Controls n=325 | # hrs sun exposure, ages 6–13 Statistically significant difference; OR not reported # hrs sun exposure, ages 14–18, 18–21, and >21 NS; OR not reported | NR | | | Occupational sun exposure age >21 No: 2.44 (1.01–5.91) Yes: reference | | | NR
Zanetti 1992^84^ Fair | Case-control Turin, Italy Cases n=260 Controls n=416 | NR | # weeks of sunny vacation in childhood 0: reference 1–59: 2.8 (1.6–4.6) ≥60: 1.7 (1.0–2.9) # sunny vacations in lifetime 0: reference 1–29: 0.9 (0.5–1.6) 30–59: 1.6 (0.9–2.8) 60–89: 1.6 (0.9–2.9) 90–119: 1.5 (0.8–2.7) ≥120: 2.3 (1.4–3.8) | | | NR | | | Age; sex
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ Fair | Case-control Sweden Cases n=400 Controls n=640 | NR | Frequent sunbathing during summer No: reference Yes: 1.2 (0.9–1.7) | | | NR | | | Exposure to sunbeds or sunlamps; history of sunburns; hair color; # of raised nevi; history of malignant melanoma in immediate family
Westerdahl 2000^85^ Fair | Case-control Sweden Cases n=558 Controls n=891 | NR | Frequency of sunbathing in summer, stratified by sunscreen use | | | NR | | | Sunburns age >19; skin phototype; hair color
Westerdahl 2000^85^ Fair | Case-control Sweden Cases n=558 Controls n=891 | NR | | Use of sunscreen | | NR | | | Sunburns age >19; skin phototype; hair color
Westerdahl 2000^85^ Fair | Case-control Sweden Cases n=558 Controls n=891 | NR | | | | NR | | | Sunburns age >19; skin phototype; hair color
Westerdahl 2000^85^ Fair | Case-control Sweden Cases n=558 Controls n=891 | NR | | Never | Ever | NR | | | Sunburns age >19; skin phototype; hair color
Westerdahl 2000^85^ Fair | Case-control Sweden Cases n=558 Controls n=891 | NR | | | | NR | | | Sunburns age >19; skin phototype; hair color
Westerdahl 2000^85^ Fair | Case-control Sweden Cases n=558 Controls n=891 | NR | <15 times | reference | 1.3 (0.8–2.2) | NR | | | Sunburns age >19; skin phototype; hair color
Westerdahl 2000^85^ Fair | Case-control Sweden Cases n=558 Controls n=891 | NR | ≥15 times | 0.9 (0.5–1.8) | 1.2 (0.7–2.0) | NR | | | Sunburns age >19; skin phototype; hair color
LeMarchand 2006^81^ Fair | Case-control Hawaii, US Cases n=278 Controls n=278 | NR | # hrs during summer in bathing suit, ages 8–10 [underlined: Men] 0: reference 1–32: 1.2 (0.6–2.3) 33–80: 0.9 (0.4–1.8) ≥80: 2.0 (0.9–4.4) [underlined: Women] 0: reference 1–20: 2.1 (0.8–5.4) 21–64: 1.4 (0.5–3.7) ≥65: 3.4 (1.2–9.1) # hrs during summer in bathing suit, past 5 yrs [underlined: Men] 0: reference 1–12: 1.4 (0.6–3.0) 13–24: 1.9 (0.8–4.4) ≥25: 2.5 (1.2–5.4) [underlined: Women] 0: reference 1–8: 2.1 (0.8–5.6) 9–20: 4.8 (1.7–13.4) ≥21: 3.3 (1.1–10.10) | | | Lifetime # f hours worked outdoors [underlined: Men] ≤438: reference 439–1,644: 1.0 (0.5–2.0) 1,645–3,360: 0.7 (0.4–1.5) ≥3,361: 1.3 (0.7–2.7) [underlined: Women] 0: reference 1–330: 1.3 (0.6–3.8) 331–864: 1.8 (0.8–4.2) ≥865: 1.2 (0.5–3.0) | | | Height; education; hair color; ability to tan; drinking status

* Adjusted unless otherwise stated.

US=United States; N=sample size; CI=confidence interval; SCC=squamous cell carcinoma; RR=relative risk; BCC=basal cell carcinoma; OR=odds ratio; WBE=whole body equivalent; NS=not significant; NR=not reported

Table 4 Association Between Indoor Tanning and Skin Cancer

Study, USPSTF quality | Design, Setting, Years | Population | Ever use (RR or OR [95% CI])^*^ | Frequency of use (RR or OR [95% CI])^*^ | Adjustments reported
Squamous cell or basal cell carcinoma
Han 2006^71^ Nurses’ Health Study Fair | Nested case-control US (11 states) 1989–1998/2000 | Cases SCC n=275 BCC n=283 Controls n=804 | SCC: 1.44 (0.93–2.24) BCC: 1.32 (0.87–2.03) | NR | Age; constitutional susceptibility; family history of skin cancer; # of lifetime severe sunburns which blistered; cumulative sun exposure while wearing a bathing suit; geographic region
Gallagher 1995^66^ Bajdik 1996^128^ Fair | Case-control Alberta, Canada 1983–1984 | Cases SCC n=180 BCC n=226 Controls SCC n=406 BCC n=406 | SCC: 1.4 (0.7–2.7) BCC: 1.2 (0.7–2.2) | NR | Age; ethnic origin; skin and hair color; lifetime occupational sun exposure
Rosso 1999^64^ Fair | Case-control Valais, Switzerland 1994–1996 | Cases n=146 Controls n=144 | SCC: Not calculated BCC: 1.24 (0.53–2.88) | NR | Age; sex
Karagas 2002^88^ Fair | Case-control New Hampshire and bordering regions 1993–1995 | Cases n=896 (BCC n=603, SCC n=293) Controls n=540 | SCC: 2.5 (1.7–3.8) BCC: 1.5 (1.1–2.1) | Age at first tanning device use [underlined: SCC:] <20: 3.6 (1.9–6.9) 20–35: 2.8 (1.4–5.5) [underlined: BCC:] <20: 1.8 (1.0–3.0) 20–35: 1.4 (0.8–2.3) | NR
Melanoma
Veierod 2003^82^ Norwegian-Swedish Women’s Lifestyle and Health Cohort Study Fair | Cohort Norway & Sweden 1992–1992 ~8 year follow-up | n=106,379 | Ages 10–19: 1.52 (0.56–4.12) | Frequent use (1+ per month), ages 10–39: 1.55 (1.04–2.32) | Age; region of residence; hair color; corresponding # of age-specific sunburns and weeks spent on annual summer vacations
Han 2006^71^ Nurses’ Health Study Fair | Nested case-control US (11 states) 1989–1998/2000 | Cases melanoma n=200 Controls n=804 | 2.06 (1.30–3.26) | NR | Age; constitutional susceptibility; family history of skin cancer; # of lifetime severe sunburns which blistered; cumulative sun exposure while wearing a bathing suit; geographic region
Osterlind 1988^83^ Osterlind 1988^129^ Fair | Case-control East Denmark 1982–1985 | Cases n=474 Controls n=926 | 0.7 (0.5–1.0) | NR | NR
Berwick 1996^73^ Chen 1998^89^ Fair | Case-control Connecticut, US 1987–1989 | Cases n=624 Controls n=512 | 1.13 (0.82–1.54) | Total lifetime # sunlamp uses <10 times: 1.25 (0.84–1.84) ≥10 times: 1.15 (0.60–2.20) Age at first use of sunlamp <25: 1.35 (0.88–2.08) 25–45: 1.02 (0.61–1.70) | Sex; age; cutaneous phenotype index; total recreational sun exposure index
Walter 1999^90^ Walter 1990^132^ Fair | Case-control Ontario, Canada 1984–1986 | Cases n=583 Controls n=608 | 1.54 (1.16–2.05) | See appendix for sex-stratified, age-adjusted only OR for; 1. total lifetime # minutes use, and; 2. age at first use | Sex; age; reaction to initial summer sun exposure; potential confounders
Bataille 2005^91^ Fair | Case-control Sweden, The Netherlands, UK, Belgium, France 1998–2001 | Cases n=597 Controls n=622 | 0.90 (0.71–1.14) Age <15: 1.82 (0.92–3.62) | Total lifetime # hours use <10: 0.95 (0.71–1.25) 10–30: 0.75 (0.50–1.11) 31–60: 0.75 (0.43–1.30) 61–100: 1.10 (0.55–2.24) >100: 1.19 (0.73–1.93) | Age; sex; skin phototype
Fargnoli 2004^79^ Fair | Case-control Central Italy 2000–2001 | Cases n=100 Controls n=200 | 0.63 (0.25–1.63) | NR | Hair color; eye color; skin type for pigmentation factors
Holly 1995^80^ Fair | Case-control San Francisco, US 1981–1986 | Cases n=452 Controls n=930 | 0.94 (0.74–1.2) | NR | None
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ Fair | Case-control Sweden 1988–1990 | Cases n=400 Controls n=640 | Age <30: 2.7 (0.7–9.8) | # times per year use [underlined: age <30 years] 1–10: 2.0 (0.5–8.0) >10: 7.7 (1.0–63.6) [underlined: age 30–60 years] 1–10: 1.0 (0.7–1.6) 10: 1.4 (0.7–2.7) | History of sunburns; blond/fair and red hair color; raised nevi; history of frequent sunbathing during summer
Westerdahl 2000^85^ Westerdahl 2000^42^ Fair | Case-control Sweden 1995–1997 | Cases n=571 Controls n=913 | Sometimes use: 1.1 (0.8–1.4) Regular use: 1.8 (1.2–2.7) | Total lifetime # uses 1–125: 2.8 (1.0–7.8) 126–250: 3.1 (1.3–7.1) >250: 1.5 (0.7–3.2) Age at first use ≤35: 2.3 (1.2–4.2) >35: 1.6 (0.9–2.9) | Hair color; # raised nevi; skin type; # of sunburns
Clough-Gorr 2008 92 Fair | Case-control New Hampshire, US 1995–1998 | Cases n=423 Controls n=678 | Sunlamp use: 1.39 (1.00–1.96) Tanning bed use: 1.14 (0.80–1.61) | Frequency of sunlamp use <6 times: 1.29 (0.84–1.99) 6+ times: 1.54 (0.93–2.57) Age at first sunlamp use ≤20: 1.23 (0.81–1.88) >20: 1.71 (1.00–2.92) Frequency of tanning bed use <10 times: 1.05 (0.67–1.64) 10+ times: 1.25 (0.79–1.98) Age at first tanning bed use ≤20: 1.78 (0.76–4.15) >20: 1.08 (0.75–1.55) | Age; sex; family history of melanoma; hair color; freckles; sun sensitivity; total sun exposure hours

* Adjusted unless otherwise stated.

US=United States; N=sample size; CI=confidence interval; SCC=squamous cell carcinoma; RR=relative risk; BCC=basal cell carcinoma; OR=odds ratio

Table 5 Association Between Sunscreen Use and Skin Cancer

Study, USPSTF quality | Design, Setting, Years | Population | Ever use (RR or OR [95% CI])^*^ | Frequency of use (RR or OR [95% CI])^*^ | Adjustments reported
Squamous cell or basal cell carcinoma
Green 1999^57^ Green 1994^58^ van der Pols 2006^60^ Nambour Skin Cancer Prevention Trial Good for 4-yr f/u Fair for 8-yr f/u | RCT Queensland, Australia 1992 Up to 8-yr follow-up | n=1,621 | Regular sunscreen use (vs. usual sunscreen use) [underlined: 1993–1996] SCC: 0.88 (0.50–1.56) BCC: 1.03 (0.73–1.46) [underlined: 1993–2004] SCC: 0.65 (0.45–0.94) BCC: 1.02 (0.78–1.35) | NR | NR
Grodstein 1995^67^ Nurses’ Health Study Good | Cohort US (11 states) 1982–1990 8-yr follow-up | n=107,900 | # of persons who spent regular time outdoors (never use) SCC: 0.9 (0.6–1.2) | NR | Age; smoking; region; natural hair color; reaction to sun; lifetime # of sunburns
Hunter 1990^68^ Nurses’ Health Study Fair | Analytic cohort US (11 states) 1982–1990 4-yr follow-up | n=73,366 | # of persons who spent regular time outdoors (never use) BCC: 0.70 (0.60–0.82) | NR | Age; time period; region; time spent outdoors in summer and sunscreen habit; hair color; childhood tendency to burn; lifetime # of severe and painful sunburns on face and arms
Kricker 1991^62^ Kricker 1995^36^ Kricker 1995^116^ Fair | Case-control Western Australia 1987 | BCC cases n=226 BCC Controls n=1,021 (6 cases of SCC) | NR | Use of SPF 10+ ≥half the time 1–9 years: 1.92 (1.17–3.13) 10+ years: 1.25 (0.82–1.90) | Age; sex; ability to tan; site
Rosso 1999^64^ Fair | Case-control Valais, Switzerland 1994–1996 | Cases n=146 Controls n=144 | Ever use SCC: 1.63 (0.41–6.53) BCC: 1.69 (1.14–2.05) | NR | Age; sex
Melanoma
Cho 2005^93^ Nurses’ Health Study I & II, Health Professionals Follow-up Study Fair | Analytic cohort US (multistate) 1986 for NHS 1992 for HPS Up to 14-yr follow-up | n=178,155 | NR | NR | NR
Fargnoli 2004^79^ Fair | Case-control Central Italy 2000–2001 | Cases n=100 Controls n=200 | Ever use: 0.63 (0.25–1.63) | NR | Hair color; eye color; skin type for pigmentation factors
Holly 1995^80^ Fair | Case-control San Francisco, CA 1981–1986 | Cases (calc) n=452 Controls n=930 | Sometimes use: 1.5 (1.1–2.2) Never use: 2.1 (1.5–3.0) | NR | History of sunburn ages ≤12 yrs; skin reaction after few days of sun exposure; hair color; # of large nevi; complexion; age; maternal ethnicity; history of skin cancer
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ Fair | Case-control Sweden 1988–1990 | Cases n=400 Controls n=640 | Sometimes use: 1.3 (0.9–1.9) Almost always use: 1.8 (1.1–2.8) | NR | History of sunburns; history of frequent sunbathing during summer; outdoor employment during summer; host factors (raised nevi, hair color, eye color, freckling)
Westerdahl 2000^85^ Westerdahl 2000^42^ Fair | Case-control Sweden 1995–1997 | Cases n=558 Controls n=891 | Sometimes use: 1.3 (0.9–1.9) Always initially, and sometimes use: 0.9 (0.6–1.5) Always use: 1.8 (1.1–2.9) | # yrs of regular sunscreen use 1–20: 4.3 (0.8–21.9) >20: 1.7 (0.5–5.6) | Hair color; history of sunburns; frequency of sunbathing during summer; duration of each sunbathing occasion

* Adjusted unless otherwise stated

US=United States; N=sample size; CI=confidence interval; SCC=squamous cell carcinoma; RR=relative risk; BCC=basal cell carcinoma; OR=odds ratio; NHS=Nurses’ Health Study; NPS=Professionals Follow-up Study; NR=not reported

### Sun Exposure

Summary of findings. Based on 11 primarily fair-quality cohort and case-control studies, increasing intermittent (or recreational) sun exposure in childhood and over one ’s lifetime is associated with an increased risk for both squamous cell and basal cell carcinoma (range OR, 1.27 to 3.86). The evidence is more consistent for intermittent sun exposure in childhood leading to an increased risk for squamous cell and basal cell carcinoma than in adulthood (range OR, 1.42 to 3.86). While there are fewer studies that examined the association of total (or cumulative) and chronic (or occupational) sun exposure, existing studies did not suggest a strong association between total or chronic sun exposure and squamous cell or basal cell carcinoma.

There were 18 fair-quality studies examining the association between sun exposure and melanoma. Based on mainly case-control studies, it appears that both total and chronic sun exposure are not strongly associated with melanoma. However, some evidence suggests that total sun exposure in childhood is associated with an increased risk for melanoma (range OR, 1.81 to 4.4), and occupational sun exposure may be associated with a decreased risk for melanoma. Case-control studies examining the risk for melanoma and intermittent sun exposure are inconsistent, but some studies suggest that increasing recreational sun exposure increases the risk for melanoma (range OR, 1.3 to 5.0). However, the evidence is more consistent for recreational sun exposure in childhood leading to an increased risk for melanoma than in adulthood (range OR, 1.7 to 3.5).

Measures of intermittent, chronic, and total sun exposure, delineation of levels of exposure, and reference groups for each measure varied largely between studies, making it difficult to make comparisons across studies. We did not quantitatively pool risk estimates.

Study details. A total of five fair-or good-quality cohort studies and six fair-or good-quality case-control studies examined the association between sun exposure and squamous cell or basal cell carcinoma, using different measures of total (or cumulative) sun exposure, intermittent (or recreational) sun exposure, and chronic (or occupational) sun exposure (Table 3).

None of the three case-control studies that examined total sun exposure showed a statistically significant association between total sun exposure and squamous cell or basal cell carcinoma,62–64 even after adjusting for skin phenotype.62,63 None of the two cohort studies (n=3, 612)61,65 or three case-control studies62,64,66 that examined chronic or occupational sun exposure showed a statistically significant association between occupational sun exposure and squamous cell or basal cell carcinoma. All but two of these studies adjusted for skin phenotype.61,64

The largest number of studies examined intermittent or recreational sun exposure and the risk for squamous cell or basal cell carcinoma (five cohort and six case-control studies)(Table 3). Of the cohort studies, the largest three were conducted in the United States (Nurses’ Health Study: n=107,900 for squamous cell carcinoma, n=73,366 for basal cell carcinoma; Health Professionals Study: n=44,591).67–69 These studies suggest that women who report not spending regular time outdoors in the summer are at decreased risk for squamous cell (RR, 0.7 [CI, 0.4–1.1]) and basal cell carcinoma (RR, 0.73 [CI, 0.59–0.90]),67,68 and men who had frequent sun exposure in the summer as a teenager are at increased risk for basal cell carcinoma (range RR, 1.30 to 1.42).69 In two smaller cohort studies from Australia (n=3,612), recreational sun exposure, measured as mainly indoors, indoors and outdoors, or mainly outdoors, was not significantly associated with risk for squamous cell or basal cell carcinoma.61,65 Five of the six case-control studies adjusted for skin phenotype.62,63,66,70,71 In these studies, increasing recreational sun exposure in childhood increased risk for basal cell carcinoma (range OR, 1.82 to 2.6),62,70 but the association between lifetime increase in recreational sun exposure and squamous cell or basal cell carcinoma was not as consistent.62,63,66,70,71 The largest case-control study, nested within the Nurses’ Health Study, suggests an increase in squamous cell (OR, 2.15 [CI, 1.45–3.19]) and basal cell carcinoma (OR, 2.05 [CI, 1.38–3.06]) with the highest categorization of life time recreational sun exposure.71 A smaller case-control study also suggests an increased risk for basal cell carcinoma with increasing recreational sun exposure;62 however, the other case-control studies do not.63,66,70 Only one study stratified results by skin type. This study showed an interaction between sun exposure and basal cell carcinoma, with a higher risk seen in those persons with a lesser ability to tan.62

One fair-quality cohort study and 17 fair-or good-quality case-control studies examined the association between sun exposure and melanoma, using different measures of total, intermittent, and chronic sun exposure. Six case-control studies included some measure of total sun exposure, either in childhood, in the recent past, or over the life time.72–77 These studies showed mixed results, with two studies finding a statistically significant association between total lifetime sun exposure and melanoma (range OR, 2.20 to 2.63).73,74 The other four studies did not find this association.72,75–77 One study that presented results stratified by skin type suggests that those who tan easily have a decreased risk for melanoma with increasing total lifetime sun exposure.72 All three studies that examined total sun exposure in childhood showed a statistically significant association between increasing sun exposure and melanoma(range OR, 1.81 to 4.4).74,76,77 Eight case-control studies included some measure of chronic or occupational sun exposure. 72,73,75,76,78–81 Two of these studies suggest that occupational sun exposure is associated with an increased risk for melanoma. Both of these studies, however, used crude measures of occupational sun exposure (yes/no, none/sometimes/often).78,79 The confidence intervals in one of these studies, though statistically significant, were extremely wide due to the very small number of cases.78 In contrast, five of the remaining six studies suggest that occupational sun exposure is inversely associated with melanoma risk.72,73,75,76,80

One fair-quality cohort study and 13 fair-quality case-control studies examined the association between intermittent or recreational sun exposure and melanoma. A large (n=106,379) fair-quality cohort study from Norway and Sweden showed no significant association between frequency of sunbathing vacations in childhood or as an adult and risk for melanoma.82 Of the eight case-control studies that examined lifetime recreational sun exposure,71,73,75,79,83–86 five studies showed that increasing recreational sun exposure was associated with melanoma risk (range OR, 1.3 to 5.0);71,73,75,79,84 all but one adjusted for skin phenotype.84 Only one of these studies presented results stratified by skin type, which suggested an interaction between a lesser ability to tan and an increased risk for melanoma.71 Of the three case-control studies that did not show a statistically significant association between lifetime recreational sun exposure and melanoma risk, two from Sweden used a crude dichotomous measure of recreational sun exposure, and one from Denmark lost statistical significance after adjusting for important confounders including skin phenotype. All three case-control studies that examined recreational sun exposure during childhood suggest that increasing sunbathing behavior in childhood is associated with an increased risk for melanoma (range OR, 1.7 to 3.5).81,84,87 Only one study presented results stratified by skin type, which suggested an interaction between a lesser ability to tan and an increased risk for melanoma. 87

### Indoor Tanning

Summary of findings. We found very few studies that examined the relationship between exposure to indoor tanning devices and risk for squamous cell and basal cell carcinoma, after adjusting for all important confounders. Results generally suggest no association. However, a slightly larger body of higher-quality evidence suggests that “regular” or “early” use of indoor tanning devices may increase the risk for developing melanoma(range OR, 1.55 to 2.3). Most of these studies used crude measures of indoor tanning exposure.

Study details. We found only five fair-quality case-control studies that examined the association between indoor tanning and the risk for squamous cell or basal cell carcinoma (Table 4).64,66,70,71,88 Two of these studies were conducted in Canada during the early 1980s. The remaining studies were conducted in the 1990s. Four of the five studies used only a crude dichotomous measure (ever/never) of indoor tanning, and none of these studies found a statistically significant association between ever and never use.64,66,70,71 Three of these studies adjusted for both skin phenotype and sun exposure.66,70,71 One fair-quality case-control study that was slightly larger and had a slightly higher proportion of exposed individuals showed a statistically significant association between indoor tanning and risk for squamous cell or basal cell carcinoma, with greater risk for those who reported early first use (before age 20 years).88 However, this study only adjusted for skin phenotype and did not adjust for sun exposure.

We found one fair-quality cohort study and 10 fair-quality case-control studies that examined the association between indoor tanning and melanoma.71,79,80,82,83,85,86,89–92 The cohort study, derived from the Norwegian-Swedish Women’s Lifestyle and Health Cohort Study, found that women who reported solarium use one time or more per month during ages 10 to 39 years had an increased risk for melanoma (RR, 1.55 [CI, 1.04–2.32]), after adjusting for important confounders including skin phenotype and intermittent sun exposure.82 Of the 10 case-control studies, three studies were conducted in the early to mid1980s.80,83,90 Only one of the 10 case-control studies conducted a separate analysis for sunlamps (used mostly pre-1980 and with higher UVB content) and tanning beds (used mostly post-1980 and with higher UVA content).92 Five of the 10 studies did not find any association between ever or never use of indoor tanning and melanoma.79,80,83,89,91 Only one of these studies adjusted for both skin phenotype and some measure of sun exposure.89 This study by Chen and colleagues also examined measures of total sunlamp use and age at first use, but did not find any statistically significant association between these measures and melanoma. Of the four studies that found a statistically significant association between indoor tanning exposure and melanoma, only two adjusted for both skin phenotype and some measure of sun exposure,71,85 while one adjusted for skin phenotype and number of sunburns85 and one adjusted for only skin phenotype. 90 These studies suggest that regular or higher frequency indoor tanning or use at a younger age may increase risk for melanoma. The one study that examined sunlamp and tanning bed exposure separately found a statistically significant trend (p=0.02) for frequent sunlamp use (≥6 times) and melanoma risk (OR, 1.54 [CI, 0.93–2.57]), but not for frequent tanning bed use (≥10 times) and melanoma risk (OR, 1.25 [CI, 0.79–1.98]).92 However, the study investigators stated that while no association with tanning bed use was found, sufficient lag time may not have elapsed to assess a potential effect, given the more recent use of tanning beds.

### Sunscreen Use

Summary of findings. Based on one trial, regular sunscreen use may prevent squamous cell carcinoma (RR, 0.65 [CI, 0.45–0.94]). It is unclear whether regular sunscreen use prevents basal cell carcinoma; case-control studies that suggest sunscreen use reduces the risk for basal cell carcinoma have major limitations. Based on five fair-quality studies, sunscreen use has no clear protective or harmful effect on the risk for melanoma. However, the case-control studies examining this risk have major limitations.

Study details. We found one RCT (n=1,621), examining whether regular sunscreen use can prevent squamous cell or basal cell carcinoma (Table 5).57–59 Based on this trial, individuals randomly assigned to regular sunscreen use had a decreased risk for squamous cell carcinoma after 8 years of followup (RR, 0.65 [CI, 0.45–0.94]). No statistically significant decrease in risk was seen for basal cell carcinoma. Although this was a good-quality RCT, at 8 years a substantial proportion of participants had only passive followup with pathology records. Two fair-quality cohort studies (n=181,266) derived from the Nurses’Health Study did not show a decrease in squamous cell or basal cell carcinoma risk with sunscreen use after adjusting for skin phenotype and sun exposure.67,68 However, both of these studies used only a crude dichotomous measure of sunscreen use. While two fair-quality case-control studies suggest a protective effect of sunscreen for basal cell carcinoma, both used crude measures of sunscreen use, and neither study adjusted for sun exposure. 62,64

We found one fair-quality cohort study and four fair-quality case-control studies that examined the association between sunscreen use and melanoma.79,80,85,86,93 One cohort study (n=178,155) and one case-control study found no significant association between a crude dichotomous measure of sunscreen use and risk for melanoma.79,93 Three case-control studies found a statistically significant association between sunscreen use and melanoma, but were inconsistent. One study found a protective effect for women who reported always using sunscreen compared with women who reported sometimes or never using sunscreen, after adjusting for skin phenotype and sunburn but not sun exposure.80 Two studies in Sweden found a statistically significant harmful effect of sunscreen, such that persons who reported always or almost always using sunscreen were at increased risk for melanoma, after adjusting for both skin phenotype and sun exposure.85,86

## Key Question 5 Are Sun-Protective Behaviors Associated With Adverse Effects?

We found 16 fair-or good -quality studies that directly examined the potential harms of sun-protective behaviors (Table 6).94–107 Of these, one fair-quality trial examined whether adherence to sun-protective behaviors in children reduces physical activity; 94 six fair-or good-quality trials examined whether sunscreen use leads to increased sun exposure;95–97,108–110 two fair-quality studies examined the effect of sun exposure or sunscreen on vitamin D levels;98,99 and seven fair- or good-quality studies examined the relationship between sun exposure and risk for breast cancer, colon cancer, prostate cancer, or lymphoma. We found no studies that examined the effect of sun-protective behaviors on mood (for individual study details, refer to Appendix C Table 3).

Table 6 Adverse Outcomes of Sun-Protective Behaviors

Study, Design, Quality | Setting (country), Population description | Study objective, Intervention or exposure | Measurement of adverse outcome
Decreased physical activity
Milne 2007^94^ Cluster CCT by school Fair | Australia N: 1615 children (33 schools) Age: 5–6 years at baseline Sex: NR Skin phenotype: NR | To determine if adherence to sun safety could have a detrimental effect on children’s body mass index IG (high-and moderate-intensity): specially designed sun protection curriculum administered over 4 consecutive years beginning at age 6; curriculum integrated into a range of subjects, including physical education; children in high-intensity intervention group were sent program materials over summer vacation and offered low-cost sun-protective swimwear CG: standard Western Australian health education curriculum | Difference in z score* 4 years IG high-intensity: −0.08 (95% CI, −0.22 to 0.06) IG moderate-intensity: 0.01 (95% CI, −0.12 to 0.14) CG: reference 6 years IG high-intensity: −0.11 (95% CI, −0.27 to 0.05) IG moderate-intensity: 0.05 (95% CI, −0.09 to 0.20) CG: reference * adjusted for sex, ethnicity, parent education, z score at baseline Relative difference in total time spent outdoors* 4 years IG high-intensity: 0.90 (95% CI, 0.78 to 1.05) IG moderate-intensity: 1.0 (95% CI, 0.87 to 1.15) CG: reference 6 years IG high-intensity: 0.98 (95% CI, 0.83 to 1.15) IG moderate-intensity: 0.94 (95% CI, 0.81 to 1.09) CG: reference * adjusted for sex, ethnicity, parent education, tendency to burn, total time spent outdoors at baseline
Increased sun exposure (with sunscreen use)
Autier 1999^95^ RCT Good | France and Switzerland N: 87 Age: 18–24 yrs Sex: 41% male Skin phenotype: 2% skin type I 33% skin type II 65% skin type III 0% skin type IV | To determine if sunscreen use encourages longer sun exposure duration IG1: SPF 10 sunscreen IG2: SPF 30 sunscreen | Mean sun exposure (hours) per participant 2 months IG1: 58.2 (95% CI, 52.0 to 64.4) IG2: 72.6 (95% CI, 63.5 to 81.7); p=0.011 2 months, daily sun exposure IG1: 4.0 (95% CI, 3.3 to 4.7) IG2: 4.6 (95% CI, 3.9 to 5.3); p ≤0.0001 2 months, daily outdoor activity IG1: 3.6 (95% CI, 2.9 to 4.3) IG2: 3.8 (95% CI, 3.0 to 4.6); p=0.62 2 months, daily sunbathing IG1: 2.6 (95% CI, 2.1 to 3.1) IG2: 3.1 (95% CI, 2.5 to 3.7); p=0.0013 # of sunburns or skin-reddening episodes IG1: 159 IG2: 159; p=0.99 # of sunburns IG1: 42 IG2: 34; p=0.90
Autier 2000^96^ RCT Good | France and Belgium N: 62 randomized, 58 analyzed Age: 18–24 years Sex: 26% male Skin phenotype: 5% skin type I 53% skin type II 41% skin type III 0% skin type IV | To determine if sunscreen use encourages longer sun exposure duration IG1: SPF 10 sunscreen IG2: SPF 30 sunscreen | Median time spent (hours) per day sunbathing IG1: 2.4 IG2: 3.0 % change: +25%; p=0.054 Median UVB exposure (joules/m^2^) per day IG1: 841 IG2: 984 % change: +17%; p=0.15 Median UVA exposure (kjoules/m^2^) per day IG1: 136 IG2: 125 % change: −8%; p=0.50
Dupuy 2005^97^ RCT Good | France N: 367 randomized, 359 analyzed Age: 39 years Sex: 18% male Skin phenotype: 35% fair complexion 15% neither fair nor dark 49% dark complexion | To determine if high-SPF sunscreen has an impact on sun-exposure behavior; to determine the impact of actual high-SPF protection and the impact of the impression of being well protected IG1: high protection label, SPF 40 sunscreen IG2: basic protection label, SPF 40 sunscreen CG: basic protection label, SPF 12 sunscreen | Mean total sun exposure (hours) per participant at 1 week IG1: 14.2 (SD, 7.6) IG2: 12.9 (SD,7.2) CG: 14.6 (SD,6.7) Label comparison (IG1 vs. IG2): p=0.13 SPF comparison (IG2 vs. CG): p=0.06 Proportion with sunburn at 1 week IG1: 0.15 IG2: 0.14 CG: 0.24 Label comparison (IG1 vs. IG2): p=0.80 SPF comparison (IG2 vs. CG): p=0.06 Label comparison (IG1 vs. IG2): OR, 0.91 (95% CI, 0.43 to 1.91) SPF comparison (IG2 vs. CG): OR, 1.96 (95% CI, 0.98 to 3.92)
Green 1999^57,108^ RCT Good | Australia N: 1621 Age: 49 years Sex: 44% male Skin phenotype: ~21% burn only ~68% burn/tan ~11% tan only | To investigate effectiveness of daily sunscreen application and dietary betacarotene supplement in reducing the incidence of basal cell and squamous cell carcinoma; secondary endpoint included sun exposure IG1: SPF 15 sunscreen plus betacarotene IG2: SPF 15 sunscreen and placebo tablet IG3: 30 mg betacarotene and placebo cream CG: Placebo cream and placebo tablet | Spent <50% of weekend outdoors in previous summer 4.5 years IG1 and IG2: 79.3% (549/692); p=NR IG3 and CG: 77.4% (535/691) Median ambient UV exposure from polysuphone badges (n=175) Over summer (range) IG1 and IG2: 2.8% (0–32.2); p=0.55 IG3 and CG: 3.5% (0–23.8) Over winter IG1 and IG2: 6.5% (0–36.2); p=0.36 IG3 and CG: 7.1% (1.0–35.8)
Gallagher 2002^109^ RCT Fair | Canada N: 458 Age: 51% 6–7 yrs, 49% 9–10 yrs Sex: NR Skin reflectance: ~33% dark ~33% medium ~33% light | To determine whether use of broad-spectrum, high-SPF sunscreen attenuates development of nevi in white children; secondary endpoint included sun exposure IG: SPF 30 sunscreen plus advice CG: no advice, no placebo | Median UV exposure from 1993 to 1996 Time spent outdoors IG: 357.0; p=NR CG: 361.5 Vacation sun exposure IG: 962.5; p=NR CG: 962.5 Total sunlight exposure for whole body, adjusted for clothing coverage IG: 1252.2; p=NR CG: 1214.3
Bauer 2005^110^ Cluster RCT Fair | Germany N: 1887 Age: 4.3 years Sex: 51% male Skin phenotype: 10.1% skin type I | To determine if children receiving education or education and sunscreen develop less incident nevi; secondary endpoint included sun exposure and sun protection habits IG1: education and SPF 25 sunscreen IG2: education only CG: control | Sun exposure in 2001 and changes between 1998 and 2001 Median time (weeks) on holiday in sunny climates IG1: 4 (IQR, 2 to 7.5); p=0.021 IG2: 6 (IQR, 2 to 8) CG: 5 (IQR, 2 to 8) Median difference in hours/day sun exposure during sunny holiday IG1: 0 (IQR, −1 to 1); p=0.061 IG2: 0 (IQR, −1 to 1) CG: 0 (IQR, −1 to 1) Mean difference in hours/day outdoors at home IG1: 0.15 (SD, 1.12); p=0.353 IG2: 0.14 (SD, 1.13) CG: 0.24 (SD, 1.09)
Vitamin D deficiency
Marks 1995^98^ RCT Fair | Australia N: 153 randomized, 113 analyzed Age: 52% ages <70 years Sex: 41% male Skin phenotype: 27% burn 50% burn/tan 23% tan | To determine if regular use of sunscreen may put individuals at risk for vitamin D deficiency IG: SPF 17 sunscreen; participants were given specific instructions on application of sunscreen and were given other sun-protective behavior instructions CG: placebo cream, participants were given same instructions | Mean change in vitamin D levels at 7 months 25-hydroxyvitamin D (nmol/L) IG: 11.8 (95% CI, 7.6 to 15.9); 21% change CG: 12.8 (95% CI, 8.4 to 17.1); 25% change p=0.75 1,25-hydroxyvitamin D (nmol/L) IG: 1.3 (95% CI, −2.3 to 4.9); 1% change CG: 10.8 (95% CI, 6.7 to 14.8); 14% change p=0.0009 Change in vitamin D levels at 7 months by age, sex, and skin type No statistically significant changes Also reported: “no person using sunscreen developed serum vitamin D levels below the reference range over the period of the study.”
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR | To assess prevalence of vitamin D deficiency in perimenopausal women; to estimate relative influences of sun exposure and vitamin D intake on 25-hydroxyvitamin D concentration All participants were interviewed by two physicians to determine sun exposure (never, occasionally, regularly) and sunbed use (no, yes) | Prevalence of low vitamin D status during winter and spring Mean 25-hydroxyvitamin D serum level (nmol/L)
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR | | | | Vitamin supplement
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR | | | | No | Yes
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR | | Never | | 36.5 | 45.3
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR | | Occasionally | | 41.5 | 49.3
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR | | Regularly | | 53.5 | 62.3
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR | | Percent of subgroup with low 25-hydroxyvitamin D status (≤25 nmol/L)
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR | | Never | | 32.8 | 12.9
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR | | Occasionally | | 17.6 | 10.7
Brot 2001^99^ Cohort, prospective Fair | Denmark N: 2016 Age: 45–58 years Sex: 0% male Skin phenotype: NR | | Regularly | | 9.8 | 2.8
Increased cancer risk (due to protective nature of vitamin D)
John 1999^100^ Cohort, retrospective Fair | US N: 5009 analyzed Age: 25–74 years Sex: 0% male Skin phenotype: NR | To examine possible protective role of vitamin D (dietary or sun exposure) on breast cancer risk In-person interviews; medical exams to determine usual sunlight exposure, sun-induced skin damage, residential sulight exposure, and dietary and supplemental vitamin D intake | Sun exposure and breast cancer risk Recreational sun exposure (# cases) Rare or never: 40 (age-adj RR, 1.0; mv-adj RR,1.0) Occasional: 55 (age-adj RR, 0.70 [95% CI, 0.46–1.06]; mv-adj RR, 0.65 [95% CI, 0.43–0.98]) Frequent: 60 (age-adj RR, 0.70 [95% CI, 0.47–1.05]; mv-adj RR, 0.66 [95% CI, 0.44–0.99]) p=0.12 (trend=0.08) Occupational sun exposure (# cases) Rare or never: 81 (age-adj RR, 1.0; mv-adj RR,1.0) Occasional: 44 (age-adj RR, 1.05 [95% CI, 0.73–1.51]; mv-adj RR, 1.06 [95% CI, 0.73–1.53]) Frequent: 29 (age-adj RR, 0.60 [95% CI, 0.39–0.91]; mv-adj RR, 0.64 [95% CI, 0.41–0.98]) p=0.03 (trend=0.07) Combined recreational and occupational sun exposure (# cases) Low: 32 (age-adj RR, 1.0; mv-adj RR, 1.0) Medium: 99 (age-adj RR, 0.67 [95% CI, 0.45–1.01]; mv-adj RR, 0.81 [95% CI, 0.56–1.17]) High: 23 (age-adj RR, 0.50 [95% CI, 0.29–0.86]; mv-adj RR, 0.67 [95% CI, 0.42–1.06]) p=0.01 (trend=0.06) Sun exposure and dietary vitamin D (# cases) Low sun + <200 IU: 71 (age-adj RR, 1.0; mv-adj RR, 1.0) Low sun + ≥200 IU: 18 (age-adj RR, 0.79 [95% CI, 0.57–1.11]; mv-adj RR, 0.75 [95% CI, 0.54–1.06]) High sun + <200 IU: 65 (age-adj RR, 0.78 [95% CI,0.46–1.31]; mv-adj RR, 0.77 [95% CI, 0.46–1.29] High sun + ≥200 IU: 22 (age-adj RR, 0.72 [95% CI, 0.45, 1.17]; mv-adj RR, 0.71 [95% CI, 0.44–1.14] p=0.11 (trend=0.08) Sunlight exposure by region of residence (low, medium, or high solar radiation) Combined recreational and occupational sun exposure (# cases)
John 1999^100^ Cohort, retrospective Fair | US N: 5009 analyzed Age: 25–74 years Sex: 0% male Skin phenotype: NR | | | Low Solar | | Medium Solar | | | High Solar
John 1999^100^ Cohort, retrospective Fair | US N: 5009 analyzed Age: 25–74 years Sex: 0% male Skin phenotype: NR
John 1999^100^ Cohort, retrospective Fair | US N: 5009 analyzed Age: 25–74 years Sex: 0% male Skin phenotype: NR | | Low: | 15 (RR,1.0) | | 9 (RR,1.0) | | | 8 (RR,1.0)
John 1999^100^ Cohort, retrospective Fair | US N: 5009 analyzed Age: 25–74 years Sex: 0% male Skin phenotype: NR | | Med: | 44 (RR,0.53 [0.29–0.97]) | | 34 (RR,0.83 [0.39–1.76]) | | | 19 (RR,0.54 [0.23–1.25])
John 1999^100^ Cohort, retrospective Fair | US N: 5009 analyzed Age: 25–74 years Sex: 0% male Skin phenotype: NR | | High: | 9 (RR,0.40 [0.17–0.94]) | | 10 (RR,0.77 [0.31–1.93]) | | | 4 (RR,0.35 [0.10–1.20])
John 1999^100^ Cohort, retrospective Fair | US N: 5009 analyzed Age: 25–74 years Sex: 0% male Skin phenotype: NR | | Multivariate-adjusted RR: adjusted for age, education, age at menarche, age at menopause, BMI, alcohol consumption, physical activity, and calcium
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR | To evaluate sources of inconsistency in the association between calcium and vitamin D (dietary or sun exposure) and colon cancer risk In-person interviews asking participants to recall behaviors 2 years before date of selection to determine dietary intake, supplement use, and sun exposure | Association between sun exposure (per quintile) and colon cancer
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR | | | Men | | | Women
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR | | | Quintile | # Cases | OR [95% CI] | Quintile | # Cases | OR [95% CI]
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR | | Low | 236 | 260 | 1.0 [N/A] | 196 | 239 | 1.0 [N/A]
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR | | 2 | 224 | 264 | 1.0 [0.8–1.3] | 198 | 203 | 1.3 [1.0–1.7]
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR | | 3 | 230 | 252 | 1.1 [0.8–1.4] | 155 | 231 | 0.9 [0.7–1.2]
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR | | 4 | 211 | 273 | 0.9 [0.7–1.2] | 171 | 216 | 1.1 [0.8–1.5]
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR | | High | 185 | 235 | 0.9 [0.7–1.1] | 160 | 216 | 1.0 [0.8–1.4]
Kampman 2000^101^ Case-control Fair | US N: 1983 cases, 2400 controls Age: 65 years Sex: 54% male Skin phenotype: NR | | Multivariate-adjusted OR: adjusted for age, BMI, family history, aspirin or nonsteroidal anti-inflammatory drug use, energy intake, physical activity, fiber, and calcium
Hughes 2004^103^ Hughes 2004^102^ Case-control Fair | Australia N: 704 cases, 694 controls Age: 73% <50 years Sex: 54% male Skin phenotype: 27% cases, 29% controls have ability to deeply tan 44% cases, 42% controls have ability to moderately tan 21% cases, 42% controls have ability to mildly tan 8% cases, 6% controls have no ability to tan | To determine if high levels of sun exposure are associated with increased risk for nonHodgkin lymphoma Brief paper questionnaire and telephone interview to determine sun exposure; three measures of ambient solar irradiance were assigned to each residential location for each subject using latitude/longitude coordinates; socioeconomic status assessed using census data | Sun exposure (years) and nonHodgkin lymphoma risk (per quartile) During the past decade Lowest: OR, 1.0 25–50%: OR, 0.72 (95% CI, 0.53–0.98) 50–75%: OR, 0.66 (95% CI, 0.48–0.91) Highest: OR, 0.65 (95% CI, 0.46–0.91) p=0.01 Lifetime occupational sun exposure Lowest: OR, 1.0 25–50%: OR, 1.03 (95% CI, 0.76–1.40) 50–75%: OR, 1.04 (95% CI, 0.76–1.43) Highest: OR, 1.21 (95% CI, 0.87–1.69) p=0.30 Vacation sun exposure (years) and nonHodgkin lymphoma risk During the past decade Lowest: OR, 1.0 25–50%: OR, 0.98 (95% CI, 0.72–1.32) 50–75%: OR, 0.82 (95% CI, 0.60–1.12) Highest: OR, 0.60 (95% CI, 0.43–0.85) p=0.003 Multivariate-adjusted OR: adjusted for age, sex, state, ethnicity, skin color, and ability to tan
Smedby 2005^104^ Case-control Fair | Denmark and Sweden N: 3740 cases, 3187 controls Age: median 59 years Sex: 56% male Skin phenotype: 17% cases, 15% controls skin type I 20% cases, 25% controls skin type II 28% cases, 31% controls skin type III 32% cases, 29% controls skin type IV | To determine if UV exposure (sun and sunbeds) is associated with increased lymphoma risk Telephone interview to determine host factors and exposure (sun and sunbed/lamps), as well as self-reported skin cancer | Sun exposure and lymphoma risk
Smedby 2005^104^ Case-control Fair | | | | | # controls | nonHodgkin lymphoma (OR [95% CI]) | | Hodgkin lymphoma (OR [95% CI])
Smedby 2005^104^ Case-control Fair
Smedby 2005^104^ Case-control Fair | | | Sunbathing in past 5–10 years
Smedby 2005^104^ Case-control Fair | | | Never | | 799 | 946 (1.0 [N/A]) | | 122 (1.0 [N/A])
Smedby 2005^104^ Case-control Fair | | | ≤Once/wk | | 1013 | 938 (0.9 [0.7–1.0]) | | 236 (0.8 [0.6–1.0])
Smedby 2005^104^ Case-control Fair | | | 2 to 3 times/wk | | 666 | 555 (0.8 [0.7–0.9]) | | 141 (0.7 [0.5–1.0])
Smedby 2005^104^ Case-control Fair | | | ≥4 times/wk | | 666 | 581 (0.7 [0.6–0.9]) | | 118 (0.7 [0.5–1.0])
Smedby 2005^104^ Case-control Fair | | | p<0.001 (trend=0.06)
Smedby 2005^104^ Case-control Fair | | | Sunbathing at age 20 years
Smedby 2005^104^ Case-control Fair | | | Never | | 434 | 568 (1.0 [N/A]) | | 49 (1.0 [N/A])
Smedby 2005^104^ Case-control Fair | | | ≤Once/wk | | 931 | 918 (0.8 [0.7–0.9]) | | 84 (0.8 [0.5–1.2])
Smedby 2005^104^ Case-control Fair | | | 2 to 3 times/wk | | 674 | 635 (0.7 [0.6–0.9]) | | 50 (0.6 [0.4–1.0])
Smedby 2005^104^ Case-control Fair | | | ≥4 times/wk | | 653 | 642 (0.7 [0.6–0.9]) | | 73 (0.9 [0.6–1.4])
Smedby 2005^104^ Case-control Fair | | | p=0.001 (trend=0.84)
Smedby 2005^104^ Case-control Fair | | | Sun vacations abroad
Smedby 2005^104^ Case-control Fair | | | Never | | 830 | 910 (1.0 [N/A]) | | 146 (1.0 [N/A])
Smedby 2005^104^ Case-control Fair | | | 1 to 5 times | | 1002 | 1000 (1.0 [0.9–1.1]) | | 234 (0.8 [0.6–1.0])
Smedby 2005^104^ Case-control Fair | | | 6 to 20 times | | 919 | 822 (0.9 [0.8–1.0]) | | 177 (0.7 [0.5–0.9])
Smedby 2005^104^ Case-control Fair | | | >20 times | | 410 | 305 (0.7 [0.6–0.8]) | | 60 (0.8 [0.6–1.2])
Smedby 2005^104^ Case-control Fair | | | p<0.001 (trend=0.06)
Smedby 2005^104^ Case-control Fair | | | Sunbed/sunlamp use
Smedby 2005^104^ Case-control Fair | | | Never | | 1254 | 1317 (1.0 [N/A]) | | 203 (1.0 [N/A])
Smedby 2005^104^ Case-control Fair | | | <10 times | | 742 | 790 (1.0 [0.9–1.2]) | | 134 (0.8 [0.6–1.0])
Smedby 2005^104^ Case-control Fair | | | 10 to 49 times | | 765 | 643 (0.9 [0.8–1.0]) | | 161 (0.7 [0.5–0.9])
Smedby 2005^104^ Case-control Fair | | | ≥50 times | | 377 | 270 (0.8 [0.7–1.0]) | | 116 (0.7 [0.5–0.9])
Smedby 2005^104^ Case-control Fair | | | p=0.01 (trend=0.004)
Smedby 2005^104^ Case-control Fair | | | History of sun burn and lymphoma risk
Smedby 2005^104^ Case-control Fair | | | Sunburn in past 5–10 years
Smedby 2005^104^ Case-control Fair | | | Never | | 2001 | 2121 (1.0 [N/A]) | | 308 (1.0 [N/A])
Smedby 2005^104^ Case-control Fair | | | <1/year | | 702 | 590 (0.9 [0.8–1.0]) | | 186 (0.8 [0.6–1.0])
Smedby 2005^104^ Case-control Fair | | | 1/year | | 319 | 224 (0.8 [0.6–0.9]) | | 78 (0.7 [0.5–0.9])
Smedby 2005^104^ Case-control Fair | | | ≥2/year | | 134 | 96 (0.8 [0.6–1.1]) | | 34 (0.7 [0.4–1.0])
Smedby 2005^104^ Case-control Fair | | | p=0.003 (trend=0.006)
Smedby 2005^104^ Case-control Fair | | | Sunburn at age 20 years
Smedby 2005^104^ Case-control Fair | | | Never | | 1077 | 1208 (1.0 [N/A]) | | 108 (1.0 [N/A])
Smedby 2005^104^ Case-control Fair | | | <1/year | | 804 | 929 (1.0 [0.9–1.2]) | | 79 (0.9 [0.7–1.3])
Smedby 2005^104^ Case-control Fair | | | 1/year | | 485 | 420 (0.8 [0.7–0.9]) | | 38 (0.8 [0.5–1.1])
Smedby 2005^104^ Case-control Fair | | | ≥2/year | | 305 | 211 (0.6 [0.5–0.8]) | | 27 (0.8 [0.5–1.3])
Smedby 2005^104^ Case-control Fair | | | p<0.001 (trend=0.14)
Smedby 2005^104^ Case-control Fair | | | Sunburn in childhood
Smedby 2005^104^ Case-control Fair | | | Never | | 1570 | 1747 (1.0 [N/A]) | | 283 (1.0 [N/A])
Smedby 2005^104^ Case-control Fair | | | <1/year | | 546 | 461 (0.8 [0.7–1.0]) | | 156 (0.9 [0.7–1.2])
Smedby 2005^104^ Case-control Fair | | | 1/year | | 358 | 284 (0.8 [0.6–0.9]) | | 79 (0.9 [0.7–1.3])
Smedby 2005^104^ Case-control Fair | | | ≥2/year | | 219 | 172 (0.7 [0.6–0.9]) | | 39 (0.7 [0.5–1.1])
Smedby 2005^104^ Case-control Fair | | | p<0.001 (trend=0.14)
Smedby 2005^104^ Case-control Fair | | | Multivariate-adjusted OR: adjusted for age, sex, country, and skin type
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | To determine if sun exposure is associated with increased risk for advanced prostate cancer In-person interviews and structured questionnaires; exam including skin pigmentation measurement with portable reflectometer and DNA sample (blood or mouthwash); and solar radiation level by state of residence, as assessed by National Weather Service stations | Sun exposure and risk for advanced prostate cancer
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | | | # cases | # controls | age-adj OR (95% CI) | | mv-adj OR (95% CI)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | Lifetime outdoor activities (hours/week)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | <2.7 | | 85 | 91 | 1.0 (N/A) | | 1.0 (N/A)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 2.7–5.6 | | 99 | 91 | 1.16 (0.77–1.75) | | 1.15 (0.76–1.73)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 5.7–10.4 | | 92 | 91 | 1.08 (0.72–1.64) | | 1.09 (0.72–1.65)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 10.5–19.8 | | 94 | 91 | 1.11 (0.73–1.67) | | 1.10 (0.73–1.67)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | ≥19.9 | | 80 | 91 | 0.94 (0.62–1.44) | | 0.95 (0.62–1.45)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | p=0.8
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | Lifetime outdoor jobs (hours/week)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 0 | | 123 | 120 | 1.0 (N/A) | | 1.0 (N/A)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | <1.4 | | 84 | 84 | 0.99 (0.67–1.47) | | 0.96 (0.65–1.43)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 1.4–5.6 | | 100 | 83 | 1.19 (0.81–1.75) | | 1.20 (0.81–1.77)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 5.7–14.7 | | 81 | 84 | 0.94 (0.63–1.40) | | 0.95 (0.64–1.41)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | ≥14.8 | | 62 | 84 | 0.73 (0.48–1.10) | | 0.73 (0.48–1.11)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | p=0.3
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | Facultative pigmentation
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | Light | | 100 | 90 | 1.0 (N/A) | | 1.0 (N/A)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 2 | | 107 | 90 | 1.08 (0.73–1.61) | | 1.08 (0.73–1.62)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 3 | | 86 | 91 | 0.85 (0.56–.28) | | 0.83 (0.55–1.26)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 4 | | 86 | 91 | 0.85 (0.56–1.28) | | 0.83 (0.55–1.26)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | Dark | | 68 | 90 | 0.68 (0.44–1.03) | | 0.66 (0.43–1.01)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | p=0.03
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | Sun exposure index
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | Low | | 106 | 89 | 1.0 (N/A) | | 1.0 (N/A)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 2 | | 93 | 90 | 0.85 (0.57–1.28) | | 0.87 (0.58–1.30)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 3 | | 89 | 92 | 0.81 (0.54–1.21) | | 0.80 (0.53–1.20)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | 4 | | 103 | 91 | 0.94 (0.63–1.40) | | 0.95 (0.64–1.42)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | High | | 56 | 90 | 0.52 (0.33–0.80) | | 0.51 (0.33–0.80)
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | p=0.02
John 2005^105^ Case-control Fair | US N: 450 cases, 455 controls Age: median 65 years Sex: 100% male Skin phenotype: NR | | Multivariate-adjusted OR: adjusted for age, family history of prostate cancer, +/− month of pigmentation measurements
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | To determine if UV exposure is associated with risk for nonHodgkin lymphoma In-person interviews plus mailed questionnaire to determine demographic, diet, and sun exposure history; measurements of solar radiation obtained from Robertson-Berger meters, located in many states | Sun exposure and risk for nonHodgkin lymphoma
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | | # cases | # controls | OR (95% CI)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | Exposure to midday sun (hours) in last 10 years
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <7 | 216 | 159 | 1.0 (N/A)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <14 | 145 | 126 | 0.85 (0.62–1.18)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <28 | 131 | 123 | 0.75 (0.54–1.05)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | ≥28 | 59 | 51 | 0.73 (0.46–1.15)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | p=0.07
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | Exposure to midday sun (hours) during teen years
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <7 | 62 | 46 | 1.0 (N/A)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <14 | 89 | 68 | 0.97 (0.59–1.61)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <28 | 185 | 155 | 0.81 (0.52–1.27)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | ≥28 | 211 | 187 | 0.75 (0.48–1.18)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | p=0.12
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | Exposure to midday sun (hours) during 20s
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <7 | 143 | 107 | 1.0 (N/A)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <14 | 143 | 124 | 0.86 (0.60–1.22)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <28 | 156 | 132 | 0.83 (0.58–1.18)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | ≥28 | 105 | 94 | 0.75 (0.50–1.11)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | p=0.15
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | Exposure to midday sun during 30s
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <7 | 183 | 137 | 1.0 (N/A)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <14 | 135 | 135 | 0.75 (0.54–1.04)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <28 | 145 | 112 | 0.95 (0.68–1.33)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | ≥28 | 68 | 66 | 0.78 (0.50–1.19)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | p=0.44
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | Sunlamp or sunbed use
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | Never | 401 | 338 | 1.0 (N/A)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | <5 times | 32 | 33 | 0.78 (0.46–1.32)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | 5–9 times | 32 | 25 | 0.90 (0.52–1.58)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | ≥10 times | 84 | 66 | 0.90 (0.61–1.30)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | p=0.49
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | History of blistering sunburns
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | Never | 224 | 177 | 1.0 (N/A)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | Once | 117 | 103 | 0.87 (0.62–1.23)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | 2–4 times | 114 | 84 | 1.02 (0.72–1.46)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | ≥5 times | 92 | 96 | 0.68 (0.47–0.97)
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | p=0.10
Hartge 2006^106^ Case-control Fair | US N: 551 cases,462 controls Age: 35% <55 years Sex: 53% male Skin phenotype: 5% cases, 4% controls dark 56% cases, 55% controls medium 39% cases, 41% controls light | | Multivariate-adjusted OR: NR
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | To determine if sun exposure is associated with increased risk for breast cancer In-person interviews and structured questionnaires, plus exam including measurement of skin pigmentation with portable reflectometer and DNA sample (blood or mouthwash) | Sun exposure and risk for advanced breast cancer
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | | Light pigment | | | Medium pigment | | | Dark pigment
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | | cases | controls | OR (95%CI) | cases | controls | OR (95%CI) | cases | controls | OR (95%CI)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Lifetime outdoor activities (hours/week by quartile)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Low | 37 | 153 | 1.0 (N/A) | 43 | 180 | 1.0 (N/A) | 49 | 174 | 1.0 (N/A)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 2 | 41 | 167 | 0.97 (0.58–1.62) | 47 | 154 | 1.17 (0.72–1.91) | 52 | 180 | 1.01 (0.65–1.59)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 3 | 59 | 188 | 1.29 (0.80–2.09) | 55 | 169 | 1.23 (0.76–1.97) | 61 | 165 | 1.31 (0.84–2.03)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | High | 37 | 180 | 0.86 (0.51–1.45) | 36 | 175 | 0.77 (0.46–1.29) | 50 | 153 | 1.14 (0.72–1.81)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | p | | 0.90 | | | 0.82 | | | 0.36
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Facultative pigmentation
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Light | 55 | 171 | 1.0 (N/A) | 48 | 171 | 1.0 (N/A) | 53 | 169 | 1.0 (N/A)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 2 | 48 | 183 | 0.73 (0.45–1.17) | 54 | 161 | 1.22 (0.76–1.98) | 48 | 169 | 0.89 (0.52–1.55)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 3 | 35 | 167 | 0.56 (0.33–0.94) | 38 | 180 | 0.86 (0.51–1.46) | 56 | 169 | 1.00 (0.56–1.81)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Dark | 37 | 173 | 0.54 (0.32–0.94) | 41 | 171 | 1.07 (0.62–1.85) | 57 | 174 | 1.00 (0.55–1.81)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | p | | 0.02 | | | 0.88 | | | 0.81
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Sun exposure index
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Low | 56 | 174 | 1.0 (N/A) | 47 | 172 | 1.0 (N/A) | 50 | 171 | 1.0 (N/A)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 2 | 47 | 174 | 0.78 (0.49–1.26) | 55 | 173 | 1.29 (0.80–2.08) | 52 | 170 | 1.15 (0.73–1.82)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 3 | 37 | 171 | 0.62 (0.37–1.04) | 35 | 167 | 0.90 (0.53–1.55) | 59 | 168 | 1.39 (0.89–2.17)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | High | 35 | 175 | 0.53 (0.31–0.91) | 44 | 171 | 1.26 (0.74–2.15) | 53 | 172 | 1.28 (0.81–2.05)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | p | | 0.01 | | | 0.68 | | | 0.20
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Sun exposure and risk for localized breast cancer
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Lifetime outdoor activities (hours/week by quartile)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Low | 85 | 153 | 1.0 (n/a) | 97 | 180 | 1.0 (n/a) | 101 | 174 | 1.0 (n/a)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 2 | 91 | 167 | 0.95 (0.65–1.40) | 70 | 154 | 0.79 (0.53–1.17) | 89 | 180 | 0.80 (0.56–1.15)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 3 | 103 | 188 | 0.89 (0.61–1.29) | 129 | 169 | 1.35 (0.94–1.93) | 96 | 165 | 0.94 (0.66–1.35)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | High | 107 | 180 | 1.05 (0.72–1.54) | 92 | 175 | 1.02 (0.70–1.50) | 64 | 153 | 0.70 (0.47–1.04)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | p | | 0.85 | | | 0.20 | | | 0.18
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Facultative pigmentation
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Light | 95 | 171 | 1.0 (N/A) | 101 | 171 | 1.0 (N/A) | 73 | 169 | 1.0 (N/A)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 2 | 109 | 183 | 1.18 (0.82–1.71) | 118 | 161 | 1.34 (0.93–1.94) | 87 | 169 | 1.22 (0.76–1.97)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 3 | 97 | 167 | 1.10 (0.75–1.61) | 90 | 180 | 1.04 (0.70–1.54) | 88 | 169 | 1.20 (0.71–2.01)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Dark | 89 | 173 | 1.11 (0.74–1.67) | 81 | 177 | 1.12 (0.73–1.71) | 102 | 174 | 1.40 (0.83–2.33)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | p | | 0.72 | | | 0.80 | | | 0.24
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Sun exposure index
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Low | 104 | 174 | 1.0 (N/A) | 108 | 172 | 1.0 (N/A) | 75 | 171 | 1.0 (N/A)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 2 | 103 | 174 | 1.09 (0.76–1.58) | 107 | 173 | 1.12 (0.78–1.62) | 99 | 170 | 1.43 (0.97–2.10)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | 3 | 87 | 171 | 0.96 (0.65–1.41) | 90 | 167 | 1.01 (0.68–1.49) | 87 | 168 | 1.30 (0.88–1.93)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | High | 96 | 175 | 1.10 (0.74–1.63) | 84 | 171 | 1.06 (0.71–1.60) | 89 | 172 | 1.11 (0.74–1.67)
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | p | | 0.81 | | | 0.86 | | | 0.74
John 2007^107^ Case-control Good | US N: 1786 cases, 2127 controls Age: 40% ages 50–64 years Sex: 0% male Skin phenotype: NR | | Multivariate-adjusted OR: adjusted for age, race/ethnicity, education, family history of breast cancer, personal history of breast disease, age at menarche, # full-term pregnancies, breastfeeding, BMI, height, physical activity, and alcohol consumption

CCT=controlled clinical trial; RCT=randomized controlled trial; IG=intervention group; CG=control group; BMI=body mass index; UK=United Kingdom; US=United States; SPF=sun protection factor; PC=primary care;calc=calculated; NR=not reported; CI=confidence interval; OR=odds ratio; RR=relative risk; mv=multivariate; adj=adjusted; #=number; N/A=not applicable; nmol=nanomole; L=liter; IU=international unit

### Reduced Physical Activity

Limited trial evidence suggests that there is no increased risk for sedentary behaviors or increase in body mass index (BMI) in children who reduced their amount of midday sun exposure. Based on one fair-quality cluster nonrandomized trial (n=1, 615) in Australia, grade school children who received a 4-year sun protection curriculum beginning at age 6 years had the same mean BMI at 4-and 6-year followup as children receiving a standard health education curriculum.94 In addition, there was no difference in self-reported total time spent outdoors between the children in the intervention and control schools. Although the counseling intervention in this trial was not primary care relevant, this study does show that children who practice sun-protective behavior as a result of school-based education do not decrease the total time spent outdoors or show an increase in BMI. This trial’s findings are consistent with those observed in the sun protection counseling arm of the trial by Norman and colleagues, which found no difference in self-reported measures of sedentary behavior or physical activity in adolescents before and 12 months after counseling.54

### Increased Sun Exposure

Two good-quality trials suggest that use of higher SPF (SPF 30) sunscreen increases intentional sun exposure, although not risk for sunburn, in young adult sunbathers. However, based on two other trials in adults and two fair-quality trials in children, sunscreen use in general does not appear to increase sun exposure. We found two small but good-quality double-blind RCTs (n=149) conducted in Europe that examined whether sunscreen use encourages longer sun exposure in healthy student volunteers on vacation.95,96 In these trials, persons randomly assigned to higher SPF sunscreen (SPF 30) had increased self-reported sun exposure from sunbathing (approximately 19 to 25 percent) compared with those using SPF 10 sunscreen. However, there was no significant difference in sunburns between the two groups, and the greatest differences in total number of sunbathing hours was in those who did not have sunburns. Another similarly designed fair-quality RCT (n=367) conducted in France was designed to determine whether higher SPF sunscreens have an impact on sun exposure behavior and to determine the impact of actual versus perceived SPF protection.97 Adults in this trial were randomly assigned into one of three arms: SPF 12 sunscreen labeled as “basic protection,” SPF 40 sunscreen labeled as “basic protection,” or SPF 40 sunscreen labeled as “high protection.” Adults blinded to SPF who received SPF 40 sunscreen did not have increased sun exposure from sunbathing, but did have an increase in sunburns compared with those who received SPF 12 sunscreen (14 percent vs. 24 percent, respectively; p=0.06). However, this is complicated by the fact that persons who received SPF 12 sunscreen labeled as “basic protection” used three times as much sunscreen on average compared with those who received SPF 40 sunscreen. In addition, there was no difference in self-reported sun bathing or sunburns between the adults who received SPF 40 sunscreen labeled as “basic” or “high” protection. Allocation concealment may have been threatened in this trial, and in addition, patients in this trial, compared with the other two trials by Autier and colleagues, were older (mean age, 39 years) and generally spent fewer hours sunbathing (13 to 14 hours/week vs. approximately 2.5 to 3 hours/day). The largest trial (n=1,621), the Nambour Skin Cancer Prevention Trial, randomly assigned persons (mean age, 49 years)to receive SPF 15 sunscreen or placebo sunscreen and did not find any difference at 4.5 years in self-reported time spent outdoors or ambient UV exposure, as measured by polysulphone badges worn by a random subset of participants (n=175).57,108 Two fair-quality trials in grade school and nursery school children (n=2,345) did not find any difference at 3 years in self-reported time spent outdoors or time spent on sunny vacations between those students who received high SPF sunscreen or no sunscreen.109,110

### Vitamin D Deficiency

Due to the inclusion criteria for this review, we only found two studies examining sun-protective behaviors and possible harms of vitamin D deficiency (see the Discussion section for additional information). In one fair-quality trial, sunscreen use did not significantly decrease vitamin D levels or cause vitamin D deficiency.98 In a fair-quality cohort study, vitamin D levels were greatly influenced by sun exposure, and women living at high latitudes who avoided direct sun exposure were at increased risk for vitamin D deficiency during the winter and spring months.99 A placebo-controlled RCT in Australia investigated whether regular sunscreen use in adults put individuals at risk for vitamin D deficiency.98 Participants (n=153) were randomly assigned to SPF 17 sunscreen or placebo cream over the summer. At 7 months there was no statistically significant change in 25-hydroxyvitamin D3 levels between the two groups. More importantly, no one in the sunscreen group developed vitamin D deficiency. A cohort study nested within a multi center RCT in Denmark (Danish Osteoporosis Prevention Study) assessed the prevalence of vitamin D deficiency in perimenopausal women and the relative influences of sun exposure and vitamin D intake on measured levels of 25-hydroxyvitamin D3.^99^ Healthy Danish women (n=2,016) were interviewed to determine their sun exposure and sunbed use and were given diet records to determine their vitamin D intake. Overall, only 7 percent of the population had vitamin D deficiency (3 percent during the summer through autumn and 11 percent during the winter through spring). However, those avoiding direct sunshine and not taking vitamin D supplements were at increased risk for vitamin D deficiency compared with those who had occasional or regular sun exposure (32.8 percent vs. 17.6 percent and 9.8 percent, respectively). Although the data are not reported, the authors state that “most of the women with low serum 25-hydroxyvitamin D3 values were only deficient for part of the year.” According to the study authors, no cutaneous vitamin D production occurs from October to April at Denmark’s latitude, thus the maintenance of vitamin D is dependent on vitamin D intake and stores built up during the previous summer.

### Increased Cancer Risk

Sun exposure, through the production of vitamin D, may be protective against some types of cancer. Based on a sparse body of fair-or good-quality cohort and case-control studies, it appears that sun exposure in lighter pigmented persons may be inversely related to risk for advanced breast and prostate cancer after adjusting for well-established risk factors, and that intermittent sun exposure may be inversely related to risk for nonHodgkin lymphoma. None of these studies adjusted for vitamin D intake or measured vitamin D status. We did not identify any studies examining the association between reduction in sun exposure and risk for developing cancer other than skin cancer.

Breast cancer. Two observational studies, one fair-quality retrospective cohort study and one good-quality case-control study, examined the possible protective role of sun exposure in relation to breast cancer.100,107 The analytic cohort was derived from the NHANES I Epidemiologic Follow-up Study, and included women ages 25 to 74 years with adequate followup and available dietary and dermatologic data.100 There was a nonstatistically significant trend of decreasing risk for breast cancer in relation to increasing levels of combined recreational and occupational sun exposure (p=0.06), after adjusting for age, education, age at menarche, age at menopause, BMI, frequency of alcohol consumption, and physical activity. This trend was most prominent within a stratified analysis across region of residence, although statistical significance of these trends was not reported. However, adjustment for dietary vitamin D intake appeared to attenuate this trend (p=0.08). While none of the analyses adjusted for skin type, the analytic cohort was restricted to white women. In a large, well-done case-control study by the same group of investigators, the associations between sun exposure, vitamin D receptor gene polymorphism, and breast cancer risk were examined in a multiethnic population in California. 107 Using either measures of observed skin pigmentation or a sun exposure index, increasing sun exposure was statistically significantly associated with a decreased risk for advanced breast cancer. In persons with the lightest skin type (by tertile), the highest sun exposure groups (by quartile) had an adjusted relative risk reduction of 0.53 (CI, 0.31–0.91) based on a sun exposure index(p=0.01). The analysis adjusted for age, race, education, family history of breast cancer, personal history of benign breast disease, number of full-term pregnancies, breastfeeding, height, alcohol consumption, BMI, menopausal status, and history of hormone therapy use. This magnitude of risk reduction and trend in risk reduction was not observed in persons with medium-or dark-skin type or with localized breast cancer.

Prostate cancer. We found one fair-quality study designed to evaluate the association between sun exposure and prostate cancer.105 This case-control study was conducted by the same group of investigators and was similar in design and methodology to the previously well-done case-control study on breast cancer risk.107 However, this case-control analysis was limited to white persons because there was insufficient data to permit race-specific analyses. The findings in this case-control study were similar to those of the breast cancer study, with a statistically significant inverse trend between sun exposure (using both observed skin pigmentation and a sun exposure index) and risk for advanced prostate cancer. In nonHispanic whites, the highest sun exposure groups (by quintile) had an adjusted relative risk reduction of 0.51 (CI, 0.33–0.80) based on a sun exposure index (p=0.02). The analysis adjusted for age, family history of prostate cancer, and month of pigmentation measurement. However, there was no statistically significant trend between self-reported measures of lifetime outdoor activities or lifetime outdoor jobs and risk for advanced prostate cancer.

Colon cancer. We found only one fair-quality case-control study designed to evaluate the association between sun exposure and colon cancer.101 In this study, participants who were identified through a large health maintenance organization across three regions in the United States were interviewed to assess dietary intake and calcium and vitamin D intake, as well as sun exposure. Neither sun exposure nor dietary vitamin D intake were statistically significantly associated with risk for colon cancer after adjusting for age, BMI, family history of colon cancer, aspirin and/or nonsteroidal anti-inflammatory drug use, energy intake, long-term vigorous activity, fiber, and calcium. None of the analyses adjusted for skin type, although approximately 91 percent of the population was white.

NonHodgkin lymphoma. Three fair-quality case-control studies examined the association between sun exposure and nonHodgkin lymphoma. The largest case-control study, conducted in Denmark and Sweden, assessed the association between UV exposure (sun and sunbed/lamps) and lymphoma (both nonHodgkin lymphoma and Hodgkin lymphoma). 104 Cases and controls were identified through national population registries and were interviewed by telephone to determine host factors, sun exposure and sunbed/lamp use, and self-reported skin cancer. Cases with other hematologic malignancy or immunosupression (from organ transplantation or HIV) were excluded. After adjusting for age, sex, country, and skin type, increasing sun exposure (as measured by self-reported sunbathing, sunny vacations, or sunburn history)was statistically significantly associated with decreasing risk for nonHodgkin lymphoma. In addition, increasing indoor tanning use was also statistically significantly associated with decreasing risk for nonHodgkin lymphoma. Similar, albeit weaker, trends were found for Hodgkin lymphoma. Another case-control study conducted in Australia found a similar statistically significant association between self-reported measures of nonoccupational sun exposure (by quartile), as measured by sun exposure on nonworking days and vacation sun exposure, and risk for nonHodgkin lymphoma after adjusting for age, sex, state, and skin type.102,103 However, sun exposure on working days or lifetime occupational sun exposure was not significantly associated with risk for nonHodgkin lymphoma. Neither of these two studies assessed or adjusted for dietary vitamin D intake. The third case-control study, conducted in four geographic areas in the United States, was designed to examine the association between sun exposure or dietary vitamin D intake and nonHodgkin lymphoma in a predominately white population.106 This study used in-person interviews and mailed questionnaires to ascertain sun exposure and dietary intake, and had noticeably lower response rates than the other two case-control studies. In this study, there was no statistically significant association between midday sun exposure, use of sunlamps or sunbeds, or history of blistering sunburns and risk for nonHodgkin lymphoma, after adjusting for age, sex, ethnicity, and state (latitude).Other than a measure of “blistering sunburns ” this study, did not report on intermittent versus chronic sun exposure. This study assessed, but did not adjust for, dietary vitamin D intake, presumably because the study did not find a statistically significant association between dietary vitamin D and risk for nonHodgkin lymphoma. In addition, this study adjusted for ethnicity but not skin type.

Melanoma. As discussed in KQ 4, five fair-quality studies, one cohort and four case-control, examined the association between sunscreen use and risk for melanoma. Of these, two of the case-control studies conducted in Sweden found a statistically significant harmful effect of sunscreen, such that persons who reported always or almost always using sunscreen were at increased risk for melanoma, after adjusting for both skin phenotype and sun exposure.85,86