# Appendix E Glossary and Abbreviations

Behavioral counseling: Any intervention that includes some provision of education, skills training, and support providing guidance to clients/patients on how to change sun-protective behavior, delivered alone or in combination with other interventions intended to promote sun-protective behavior.
Confidence interval (CI): 95 percent confidence interval.
Melanoma: Cutaneous melanoma includes four major subtypes: superficial spreading, nodular, lentigo maligna, and acral lentiginous. For the purposes of this review, acral melanoma, as well as mucosal melanoma, ocular melanoma, and pre-pubertal melanoma (“childhood melanoma”), are excluded.
Nevus, nevi (plural): Benign pigmented spot on the skin, such as a mole, that is a cluster of melanocytes and supportive tissue. In contrast, dysplastic nevi, or atypical moles, are melanocytic lesions that can be precursors to melanoma. Dysplastic nevi are distinguished by histology; however, they may also have certain clinical characteristics (e.g., increased diameter, lack of pigment uniformity).
Not reported: (NR)
Odds ratio: (OR)
Primary care relevant: Behavioral counseling interventions conducted in primary care, judged to be feasible to conduct in primary care, or can be referred from primary care.
Randomized controlled trial: (RCT)
Relative risk: (RR), also risk ratio
Skin phenotype: Skin (as well as hair and eye) color and skin type (i.e., ability to tan or burn that is genetically determined). A common measure of skin type is the Fitzpatrick Skin Type Scale.
Sun exposure: Intermittent, chronic, or total exposure to ultraviolet light. Intermittent patterns of exposure are most often related to recreational activities, versus chronic or continuous patterns of exposure, which are related to occupational exposure. For the purposes of this review, studies that included only crude measures of sun exposure (e.g., place of residence or type of occupation) were excluded.
Indoor tanning: Home or commercial ultraviolet light for the purposes of sun tanning; in the early 1980s UVA was added (before, it was primarily UVB). For the purposes of this review, medical uses of sunlamps or sunbeds, primarily UVA, are excluded.
Sunburn: Inflammation of the skin in response to ultraviolet light, manifested by painful erythema with or without blistering.
Sunscreen or sunblock: Lotion with sun protection factor (SPF) 15 or higher that is used to protect against ultraviolet light, both UVA and UVB. Protection against UVA was added in 1989. SPF was introduced in 1978 and is reported when available. For the purposes of this review, sun tan lotions or oils were excluded.
Vitamin D: Fat-soluble prohormone, the two major forms of which are vitamin D2 (ergocalciferol) and vitamin D3 (cholecalciferol). Vitamin D3 is produced in the skin when it is exposed to sunlight (UVB); vitamin D3 can be made in the skin at least two times per week after only 10 to 15 minutes of sun exposure to the face, arms, hands, or back without sunscreen. Vitamin D3 is hydroxylated in the liver and stored as 25-hydroxyvitamin D3 (calcidiol); calcidiol is again hydroxylated in the kidney to the main biologically active hormone 1,25-dihydroxyvitamin D3 (calcitriol). Vitamin 25-hydroxyvitamin D3 (25-OHD) is the commonly accepted serum marker for vitamin D status.
VDR gene: Vitamin D receptor gene. The effects of 1,25-dihydroxyvitamin D3 are mediated by this gene, which is expressed in breast and many other types of tissue. The expression and/or function of the VDR protein may be influenced by polymorphisms in the gene.