# Appendix D Ongoing Trials

Principal investigators | Location | Population | Approximate size | Investigations | Outcomes | Status as of 2008
KQ1: Is there direct evidence that counseling patients in sun protective behaviors reduces intermediate outcomes or skin cancer (melanoma, SCC, or BCC)?
None
KQ2: Does primary care feasible counseling change sun protective behaviors?
Ellen R. Gritz, PhD^1^ | Houston, Texas | Melanoma patients with children ages ≥12 years | 570 | Describe the sun exposure and sun protection practices of patients and their children | Protective practices and sun exposure | Currently recruiting, expected completion April 2009
Ellen R. Gritz, PhD^2^ | Houston, Texas | Melanoma patients and their families | 170 | Collect information on the ultraviolet radiation (UVR-E) reduction and early detection practices of melanoma patients and their family members | | Expected primary completion November 2008
Richard G. Roetzheim, MD, MSPH^3^ | Florida | Children ages 8–11 years | 2000 | Effectiveness of a school-based intervention to increase hat use | Use of hats in and outside of school | Continuing through 2008–2009 school year, completion date unknown
KQ3: Do primary care feasible counseling interventions have adverse effects?
None
KQ4: Are sun protective behaviors associated with incidence of or morbidity and mortality from skin cancer?
Julia Newton Bishop, MD^4^ | United Kingdom | Families with melanoma | 3,700 | Determine what lifestyle factors and which genes govern relapse from melanoma Compare sun exposure and genes that cause melanoma in patients with melanoma vs healthy participants Assess how unusual moles relate to sun exposure and genes that cause melanoma | Melanoma | Currently recruiting, expected completion December 2020
KQ5: Are sun protective behaviors associated with adverse effects?
None

1 Available at: ClinicalTrials.gov: http://www.clinicaltrials.gov/ct2. Accessed on November 28, 2008.

2 Available at: ClinicalTrials.gov: http://www.clinicaltrials.gov/ct2. Accessed on November 28, 2008.

3 Available at: Sun Protection for Florida’s Children: http://www.safeplay.org. Accessed on November 28, 2008.

4 Available at: ClinicalTrials.gov: http://www.clinicaltrials.gov/ct2. Accessed on November 28, 2008.