# Appendix C Evidence Tables for KQ4-KQ5

Appendix C Table 1 Evidence Table for the Association Between Sun Exposure, Indoor Tanning, or Sunscreen Use and Skin Cancer

Study reference USPSTF quality | Skin cancer Study design Location Recruitment strategy | Participant inclusion/exclusion criteria | Baseline demographics | | | | | Intervention(s) evaluated (description with format, intensity, and delivery if applicable) | Followup | Main outcome measure(s) | | | | | | | Other positive outcome measures | Adverse events | Comments
Trials
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | Skin cancer: BCC & SCC Study design: Cohort within an RCT Location: Australia Recruitment strategy: Participants in Nambour Skin Cancer and Actinic Eye Disease Prevention Trial were randomly chosen from the 1986 Nambour electoral roll, those who could be contacted in 1992 were invited to be in the Skin Cancer Prevention Trial | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986, who attended a second survey in 1992 Exclusion: Taking vitamin supplements containing betacarotene, already applying sunscreen on a strict daily basis | N= 1,621 Mean age (SD): IG (Sunscreen + betacarotene): 48.5 (12.9) IG (Sunscreen): 48.7 (13.6) IG (Betacarotene): 48.1 (13.6) CG: 49.8 (12.7) Female: IG (Sunscreen + betacarotene): 225 (55.7%) IG (Sunscreen): 233 (57.1%) IG (Betacarotene): 246 (59.1%) CG: 209 (53.2%) Race/ethnicity: NR SES: NR | | | | | Description: IG (S+B): SPF 15+ broad-spectrum sunscreen and betacarotene tablets IG (S): SPF 15+ broad-spectrum sunscreen and placebo tablets IG (B): Betacarotene tablets plus usual sunscreen use CG: Placebo tablets plus usual sunscreen use Intensity: IG (S+B): sunscreen application to exposed sites every morning and reapplication if heavy sweating, bathing or prolonged exposure; 1 30mg betacarotene tablet per day for 4 years IG (S): sunscreen application to exposed sites every morning and reapplication if heavy sweating, bathing or prolonged exposure; 1 tablet per day for 4 years IG (B): 1 30mg tablet per day for 4 years CG: 1 tablet per day for 4 years Delivery: self-application of sunscreen and tablets self- administered. Received supplies every 3 months at followup clinic visits | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | [underlined: Measure] Newly treated skin lesions detected at followup clinics in 1994 and 1996 by dermatologists or participants carried treatment cards that they presented to their local doctors who recorded details. Also asked every 3 months whether they had any new skin cancers or other skin lesions treated since last contact. In 2000 they were offered a further full skin exam and followed through December 2004 [underlined: Results] Incidence of skin cancers in terms of people treated for skin cancer and tumours treated on the head, neck, arms, and hands by sunscreen treatment group (through 1996) | | | | | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999) | Pandeya 2005 Hazard ratios obtained from the multiple-failure time models for the combined effect of sunscreen intervention on repeated occurrence of basal cell carcinoma (BCC) among 1,621 participants, Nambour Skin Cancer Prevention Trial, 1992–1996
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | Skin type: | IG (S+B) | IG (S) | IG (B) | CG | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | | Participants | | Tumors | | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999) | Models | Crude HR (95% CI) | P
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | | | | | | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | | | | | | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999)
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | Always burn | 88 (21.8%) | 83 (20.3%) | 92 (22.1%) | 77 (19.6%) | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | | Daily Sunscreen | No Sunscreen | Daily Sunscreen | No Sunscreen | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999) | Time to first episode | 1.03 (0.77–1.38) | 0.83
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | | | | | | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | | | | | | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999)
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | Burn/tan | 270 (66.8%) | 282 (69.1%) | 276 (66.4%) | 271 (69.0%) | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | BCC | | | | | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999) | Andersen-Gill model | 0.90 (0.66–1.23) | 0.49
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | Only tan | 46 (11.4%) | 43 (10.5%) | 48 (11.5%) | 45 (11.4%) | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | Number | 65 | 63 | 153 | 146 | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999) | Wei-Lin-Weissfeld model | 0.89 (0.65–1.24) | 0.50
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | | | | | | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | Incidence/100,000 | 2588 | 2509 | 6092 | 5814 | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999) | Prentice-Williams-Peterson | 0.91 (0.72–1.15) | 0.42 | Model
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | | | | | | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | Rate ratio (95% CI) | 1.03 (0.73–1.46) | 1.00 | 1.05 (0.82–1.34) | 1.0 | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999)
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | | | | | | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | SCC | | | | | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999)
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | | | | | | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | Number | 22 | 25 | 28 | 46 | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999)
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | | | | | | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | Incidence/100,000 | 876 | 996 | 1115 | 1832 | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999)
Green 1999^57^ Green 1994^58^ Pandeya 2005^59^ Nambour Skin Cancer Prevention Trial (subgroup of people from Nambour Skin Cancer Study) | | | | | | | | | 4.5 years original trial 85% followup 8 additional years followup 59% active followup 41% passive followup (skin cancer through pathology records only) | Rate ratio (95% CI) | 0.88 (0.50–1.56) | 1.0 | 0.61 (0.46–1.81) | 1.0 | | | NR | Potential harms noted: contact allergy or skin irritation with daily use of sunscreen (p.726 of Green 1999)
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | Incidence per 100,000 (no.) of BCC and SCC on the head, neck, arms, and hands, by sunscreen treatment group (through 2004) | | | | | | | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | | BCC | | | SCC | | | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | | | | | | | | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | | Daily Sunscreen | No Sunscreen | RR (95% CI) | Daily Sunscreen | No Sunscreen | RR (95% CI) | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | | | | | | | | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | Persons affected | | | | | | | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | 1993–2004 | 1,296 (121) | 1,270 (119) | 1.02 (0.78–1.35) | 546 (51) | 811 (76) | 0.65 (0.45–0.94) | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | 1996–2004 | 1,516 (97) | 1,494 (96) | 1.02 (0.75–1.37) | 625 (40) | 934 (60) | 0.65 (0.43–0.98) | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | 2001–2004 | 1,820 (55) | 2,085 (63) | 0.86 (0.59–1.26) | 695 (21) | 1,390 (42) | 0.49 (0.28–0.83) | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | Total tumors | | | | | | | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | 1993–2004 | 2,474 (231) | 2,840 (266) | 0.87 (0.64–1.20) | 868 (81) | 1,516 (142) | 0.59 (0.38–0.90) | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | 1996–2004 | 2,422 (155) | 2,770 (178) | 0.89 (0.64–1.25) | 953 (61) | 1,587 (102) | 0.62 (0.38–0.99) | See Green et al 1999 | See Green et al 1999 | See Green et al 1999
van der Pols 2006^60^ | See Green 1999 | See Green 1999 | See Green 1999 | | | | | See Green et al 1999 | See Green et al 1999 | 2001–2004 | 2,548 (77) | 3,408 (103) | 0.75 (0.49–1.14) | 960 (29) | 1,952 (59) | 0.49 (0.27–0.87) | See Green et al 1999 | See Green et al 1999 | See Green et al 1999

Study reference USPSTF quality | Skin cancer Study design Location Population | Participant inclusion/exclusion criteria | Baseline demographics | Measurement of exposure | Confounders considered | Followup | Measurement of sun exposure | | | | | | Measurement of sunlamp or sunbed exposure | | | | | Measurement of sunscreen use | Measurement of sunburn | | | | | | | Comments
Cohort
Grodstein 1995^67^ Nurses' Health Study | Skin Cancer: SCC Study Design: cohort Location: US (11 states) | Inclusion: Female, registered nurse, 30–55 years of age, with first- incident invasive SCC diagnosed 1982–1990 Exclusion: Diagnosis of in situ SCC (Bowen's disease), any cancer before 1982, start of followup period, and each time period | N= 107,900 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | 8 years 92% (calculated from person-year followup) | Regular time outdoors and risk of SCC (95% CI) (calc)* | | | | | | NR | | | | | See measurement of sun exposure | Number of lifetime sunburns and risk of SCC (95% CI) (calc)*
Grodstein 1995^67^ Nurses' Health Study | Skin Cancer: SCC Study Design: cohort Location: US (11 states) | | N= 107,900 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | 8 years 92% (calculated from person-year followup) | | Cases | Age Adjusted RR | Multivariate** Adjusted RR | | | NR | | | | | See measurement of sun exposure | | Cases | Age Adjusted RR | Multivariate** Adjusted RR
Grodstein 1995^67^ Nurses' Health Study | Skin Cancer: SCC Study Design: cohort Location: US (11 states) | | N= 107,900 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | 8 years 92% (calculated from person-year followup) | | | | | | | NR | | | | | See measurement of sun exposure
Grodstein 1995^67^ Nurses' Health Study | Skin Cancer: SCC Study Design: cohort Location: US (11 states) | | N= 107,900 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | 8 years 92% (calculated from person-year followup) | Yes (use sunscreen) | 56 (32%) | 1.0 | 1.0 | | | NR | | | | | See measurement of sun exposure | None | 26 (16%) | 1.0 | 1.0
Grodstein 1995^67^ Nurses' Health Study | Skin Cancer: SCC Study Design: cohort Location: US (11 states) | | N= 107,900 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | 8 years 92% (calculated from person-year followup) | Yes (no sunscreen) | 94 (54%) | 0.7 (0.5–1.0) | 0.9 (0.6–1.2) | | | NR | | | | | See measurement of sun exposure | 1–2 | 38 (23%) | 1.2 (0.7–2.0) | 1.1 (0.6–1.8)
Grodstein 1995^67^ Nurses' Health Study | Skin Cancer: SCC Study Design: cohort Location: US (11 states) | | N= 107,900 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | 8 years 92% (calculated from person-year followup) | No | 25 (14%) | 0.7 (0.4–1.1) | 0.7 (0.4–1.1) | | | NR | | | | | See measurement of sun exposure | 3–5 | 39 (24%) | 2.2 (1.3–3.5) | 1.7 (1.0–2.8)
Grodstein 1995^67^ Nurses' Health Study | Skin Cancer: SCC Study Design: cohort Location: US (11 states) | | N= 107,900 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | 8 years 92% (calculated from person-year followup) | *Data missing for 22 ppts **Adjusted for age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | | | | | | NR | | | | | See measurement of sun exposure | ≥6 | 61 (37%) | 3.4 (2.2–5.3) | 2.4 (1.5–4.0)
Grodstein 1995^67^ Nurses' Health Study | Skin Cancer: SCC Study Design: cohort Location: US (11 states) | | N= 107,900 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | 8 years 92% (calculated from person-year followup) | *Data missing for 22 ppts **Adjusted for age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | | | | | | NR | | | | | See measurement of sun exposure | | | p<0.0001 | p<0.0001
Grodstein 1995^67^ Nurses' Health Study | Skin Cancer: SCC Study Design: cohort Location: US (11 states) | | N= 107,900 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | 8 years 92% (calculated from person-year followup) | *Data missing for 22 ppts **Adjusted for age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns | | | | | | NR | | | | | See measurement of sun exposure | *Data missing for 33 ppts **Adjusted for age, cigarette smoking, region, natural hair color, reaction to sun, and lifetime number of sunburns
Hunter 1990^68^ Nurses' Health Study | Skin Cancer: BCC Study Design: cohort Location: US (11 states) | Inclusion: Female, registered nurse, 30–55 years of age Exclusion: Diagnosis of cancer reported on 1980 or previous questionnaire, if information on one or more exposures missing on questionnaire | N= 73,366 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, time period, region, time spent outdoors in the summer and sunscreen habit, hair color, childhood tendency to sunburn, and lifetime number of severe and painful sunburns on the face and arms | 4 years 100% (because excluded women with missing data) | Regular time spent outdoors in summer (at least 8 hours/week) (95% CI) | | | | | | NR | | | | | See measurement of sun exposure | Lifetime number of severe and painful sunburns on the face or arms (95% CI)
Hunter 1990^68^ Nurses' Health Study | Skin Cancer: BCC Study Design: cohort Location: US (11 states) | Inclusion: Female, registered nurse, 30–55 years of age Exclusion: Diagnosis of cancer reported on 1980 or previous questionnaire, if information on one or more exposures missing on questionnaire | N= 73,366 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, time period, region, time spent outdoors in the summer and sunscreen habit, hair color, childhood tendency to sunburn, and lifetime number of severe and painful sunburns on the face and arms | 4 years 100% (because excluded women with missing data) | | Cases | Age Adjusted RR | Multivariate* Adjusted RR | | | NR | | | | | See measurement of sun exposure | | Cases | Age Adjusted RR | Multivariate* Adjusted RR
Hunter 1990^68^ Nurses' Health Study | Skin Cancer: BCC Study Design: cohort Location: US (11 states) | Inclusion: Female, registered nurse, 30–55 years of age Exclusion: Diagnosis of cancer reported on 1980 or previous questionnaire, if information on one or more exposures missing on questionnaire | N= 73,366 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, time period, region, time spent outdoors in the summer and sunscreen habit, hair color, childhood tendency to sunburn, and lifetime number of severe and painful sunburns on the face and arms | 4 years 100% (because excluded women with missing data) | | | | | | | NR | | | | | See measurement of sun exposure
Hunter 1990^68^ Nurses' Health Study | Skin Cancer: BCC Study Design: cohort Location: US (11 states) | Inclusion: Female, registered nurse, 30–55 years of age Exclusion: Diagnosis of cancer reported on 1980 or previous questionnaire, if information on one or more exposures missing on questionnaire | N= 73,366 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, time period, region, time spent outdoors in the summer and sunscreen habit, hair color, childhood tendency to sunburn, and lifetime number of severe and painful sunburns on the face and arms | 4 years 100% (because excluded women with missing data) | Yes (usually use sunscreen) | 265 | 1.0 | 1.0 | | | NR | | | | | See measurement of sun exposure | Never | 127 | 1.0 | 1.0
Hunter 1990^68^ Nurses' Health Study | Skin Cancer: BCC Study Design: cohort Location: US (11 states) | Inclusion: Female, registered nurse, 30–55 years of age Exclusion: Diagnosis of cancer reported on 1980 or previous questionnaire, if information on one or more exposures missing on questionnaire | N= 73,366 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, time period, region, time spent outdoors in the summer and sunscreen habit, hair color, childhood tendency to sunburn, and lifetime number of severe and painful sunburns on the face and arms | 4 years 100% (because excluded women with missing data) | Yes (no sunscreen) | 377 | 0.59 (0.50–0.69) | 0.70 (0.60–0.82) | | | NR | | | | | See measurement of sun exposure | 1–2 times | 216 | 1.40 (1.13–1.75) | 1.18 (0.94–1.48)
Hunter 1990^68^ Nurses' Health Study | Skin Cancer: BCC Study Design: cohort Location: US (11 states) | Inclusion: Female, registered nurse, 30–55 years of age Exclusion: Diagnosis of cancer reported on 1980 or previous questionnaire, if information on one or more exposures missing on questionnaire | N= 73,366 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, time period, region, time spent outdoors in the summer and sunscreen habit, hair color, childhood tendency to sunburn, and lifetime number of severe and painful sunburns on the face and arms | 4 years 100% (because excluded women with missing data) | No | 129 | 0.71 (0.58–0.88) | 0.73 (0.59–0.90) | | | NR | | | | | See measurement of sun exposure | 3–5 times | 165 | 1.78 (1.42–2.25) | 1.34 (1.05–1.71)
Hunter 1990^68^ Nurses' Health Study | Skin Cancer: BCC Study Design: cohort Location: US (11 states) | Inclusion: Female, registered nurse, 30–55 years of age Exclusion: Diagnosis of cancer reported on 1980 or previous questionnaire, if information on one or more exposures missing on questionnaire | N= 73,366 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, time period, region, time spent outdoors in the summer and sunscreen habit, hair color, childhood tendency to sunburn, and lifetime number of severe and painful sunburns on the face and arms | 4 years 100% (because excluded women with missing data) | | | p=0.0001 | p<0.0001 | | | NR | | | | | See measurement of sun exposure | 6+ times | 263 | 2.91 (2.37–3.58) | 1.90 (1.50–2.40)
Hunter 1990^68^ Nurses' Health Study | Skin Cancer: BCC Study Design: cohort Location: US (11 states) | Inclusion: Female, registered nurse, 30–55 years of age Exclusion: Diagnosis of cancer reported on 1980 or previous questionnaire, if information on one or more exposures missing on questionnaire | N= 73,366 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, time period, region, time spent outdoors in the summer and sunscreen habit, hair color, childhood tendency to sunburn, and lifetime number of severe and painful sunburns on the face and arms | 4 years 100% (because excluded women with missing data) | *Adjusted for age, time period, region, time spent outdoors in summer and sunscreen habit, hair color, childhood tendency to burn, lifetime number of severe and painful sunburns on the face and arms | | | | | | NR | | | | | See measurement of sun exposure | Test for trend | | p<0.001 | p<0.001
Hunter 1990^68^ Nurses' Health Study | Skin Cancer: BCC Study Design: cohort Location: US (11 states) | Inclusion: Female, registered nurse, 30–55 years of age Exclusion: Diagnosis of cancer reported on 1980 or previous questionnaire, if information on one or more exposures missing on questionnaire | N= 73,366 Age: 30–55 Sex: 100% Female Skin phenotype: NR <2% cohort African American | Sun exposure, sunscreen use Mailed questionnaires every 2 years | Age, time period, region, time spent outdoors in the summer and sunscreen habit, hair color, childhood tendency to sunburn, and lifetime number of severe and painful sunburns on the face and arms | 4 years 100% (because excluded women with missing data) | *Adjusted for age, time period, region, time spent outdoors in summer and sunscreen habit, hair color, childhood tendency to burn, lifetime number of severe and painful sunburns on the face and arms | | | | | | NR | | | | | See measurement of sun exposure | *Adjusted for age, time period, region, time spent outdoors in summer and sunscreen habit, hair color, childhood tendency to burn, lifetime number of severe and painful sunburns on the face and arms
van Dam 1999^69^ Health Professionals Followup Study | Skin Cancer: BCC Study Design: cohort Location: US | Inclusion: Male, health professionals, 40–75 years of age Exclusion: Any cancer before 1986 or at the beginning of each 2-year time period | N= 44,591 Age: 40–75 Sex: 100% Male Skin phenotype: NR 1.7% Asian 1.0% African American | Sun exposure Mailed questionnaires every 2 years | Age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, region of residence | 8 years 94% | Frequency outdoors in swimsuit as teenager in summer (95% CI)* | | | | | | NR | | | | | NR | Number lifetime blistering sunburns (95% CI)
van Dam 1999^69^ Health Professionals Followup Study | Skin Cancer: BCC Study Design: cohort Location: US | Inclusion: Male, health professionals, 40–75 years of age Exclusion: Any cancer before 1986 or at the beginning of each 2-year time period | N= 44,591 Age: 40–75 Sex: 100% Male Skin phenotype: NR 1.7% Asian 1.0% African American | Sun exposure Mailed questionnaires every 2 years | Age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, region of residence | 8 years 94% | | Cases | Age Adjusted RR | Multivariate** Adjusted RR | | | NR | | | | | NR | | Cases | Age Adjusted RR | Multivariate* Adjusted RR
van Dam 1999^69^ Health Professionals Followup Study | Skin Cancer: BCC Study Design: cohort Location: US | Inclusion: Male, health professionals, 40–75 years of age Exclusion: Any cancer before 1986 or at the beginning of each 2-year time period | N= 44,591 Age: 40–75 Sex: 100% Male Skin phenotype: NR 1.7% Asian 1.0% African American | Sun exposure Mailed questionnaires every 2 years | Age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, region of residence | 8 years 94% | | | | | | | NR | | | | | NR
van Dam 1999^69^ Health Professionals Followup Study | Skin Cancer: BCC Study Design: cohort Location: US | Inclusion: Male, health professionals, 40–75 years of age Exclusion: Any cancer before 1986 or at the beginning of each 2-year time period | N= 44,591 Age: 40–75 Sex: 100% Male Skin phenotype: NR 1.7% Asian 1.0% African American | Sun exposure Mailed questionnaires every 2 years | Age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, region of residence | 8 years 94% | <1 time/week | 557 | 1.00 | 1.00 | | | NR | | | | | NR | None | 348 | 1.00 | 1.00
van Dam 1999^69^ Health Professionals Followup Study | Skin Cancer: BCC Study Design: cohort Location: US | Inclusion: Male, health professionals, 40–75 years of age Exclusion: Any cancer before 1986 or at the beginning of each 2-year time period | N= 44,591 Age: 40–75 Sex: 100% Male Skin phenotype: NR 1.7% Asian 1.0% African American | Sun exposure Mailed questionnaires every 2 years | Age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, region of residence | 8 years 94% | 1 time/week | 425 | 1.28 (1.13–1.45) | 1.30 (1.14–1.47) | | | NR | | | | | NR | 1–2 | 616 | 1.26 (1.10–1.44) | 1.14 (1.00–1.30)
van Dam 1999^69^ Health Professionals Followup Study | Skin Cancer: BCC Study Design: cohort Location: US | Inclusion: Male, health professionals, 40–75 years of age Exclusion: Any cancer before 1986 or at the beginning of each 2-year time period | N= 44,591 Age: 40–75 Sex: 100% Male Skin phenotype: NR 1.7% Asian 1.0% African American | Sun exposure Mailed questionnaires every 2 years | Age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, region of residence | 8 years 94% | 2 times/week | 499 | 1.29 (1.15–1.46) | 1.34 (1.19–1.52) | | | NR | | | | | NR | 3–5 | 641 | 1.45 (1.27–1.65) | 1.20 (1.05–1.38)
van Dam 1999^69^ Health Professionals Followup Study | Skin Cancer: BCC Study Design: cohort Location: US | Inclusion: Male, health professionals, 40–75 years of age Exclusion: Any cancer before 1986 or at the beginning of each 2-year time period | N= 44,591 Age: 40–75 Sex: 100% Male Skin phenotype: NR 1.7% Asian 1.0% African American | Sun exposure Mailed questionnaires every 2 years | Age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, region of residence | 8 years 94% | Several times/week | 877 | 1.26 (1.13–1.40) | 1.36 (1.22–1.52) | | | NR | | | | | NR | 6–9 | 403 | 1.72 (1.49–1.99) | 1.33 (1.14–1.54)
van Dam 1999^69^ Health Professionals Followup Study | Skin Cancer: BCC Study Design: cohort Location: US | Inclusion: Male, health professionals, 40–75 years of age Exclusion: Any cancer before 1986 or at the beginning of each 2-year time period | N= 44,591 Age: 40–75 Sex: 100% Male Skin phenotype: NR 1.7% Asian 1.0% African American | Sun exposure Mailed questionnaires every 2 years | Age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, region of residence | 8 years 94% | Daily | 347 | 1.29 (1.13–1.48) | 1.42 (1.24–1.63) | | | NR | | | | | NR | ≥10 | 715 | 2.06 (1.81–2.36) | 1.49 (1.30–1.71)
van Dam 1999^69^ Health Professionals Followup Study | Skin Cancer: BCC Study Design: cohort Location: US | Inclusion: Male, health professionals, 40–75 years of age Exclusion: Any cancer before 1986 or at the beginning of each 2-year time period | N= 44,591 Age: 40–75 Sex: 100% Male Skin phenotype: NR 1.7% Asian 1.0% African American | Sun exposure Mailed questionnaires every 2 years | Age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, region of residence | 8 years 94% | *Data missing for 568 cases **Adjusted for age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, and region of residence | | | | | | NR | | | | | NR | Test for trend | | p<0.0001 | p<0.0001
van Dam 1999^69^ Health Professionals Followup Study | Skin Cancer: BCC Study Design: cohort Location: US | Inclusion: Male, health professionals, 40–75 years of age Exclusion: Any cancer before 1986 or at the beginning of each 2-year time period | N= 44,591 Age: 40–75 Sex: 100% Male Skin phenotype: NR 1.7% Asian 1.0% African American | Sun exposure Mailed questionnaires every 2 years | Age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, region of residence | 8 years 94% | *Data missing for 568 cases **Adjusted for age, time period, hair color, eye color, skin reaction to sun, ancestry, BMI, and region of residence | | | | | | NR | | | | | NR | Data missing for 550 cases* Adjusted for age, time period, hair color, eye color, ancestry, skin reaction to sun, and BMI
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | Inclusion: Female, aged 34–49 years in Norway, aged 30–50 years residing in the Uppsala Health Care Region in Sweden, drawn from population registers Exclusion: women who did not return completed questionnaires or with missing data for exposure or skin type | N= 106,379 Mean age (range): 40.4 (30–50) Sex: 100% Female Skin phenotype: Skin color after repeated skin exposure Deep brown: 16,776 (16%) Brown: 61,423 (59%) Light brown: 23,582 (23%) Never brown: 1531 (1%) | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | Annual weeks on sunbathing vacation, ages 10–19 years | | | | | | Solarium use, ages 10–19 years | | | | | NR | Annual number of sunburns, ages 10–19 years
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | | Frequencies | Cases | Age Adjusted RR | Multivariate* Adjusted RR | | | Frequencies | Cases | Age Adjusted RR | Multivariate* Adjusted RR | NR | | Frequencies | Cases | Age Adjusted RR | Multivariate* Adjusted RR
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | | | | | | | | | | | | NR
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | 0 | 45,298 (48%) | 77 | 1.00 | 1.00 | | Never | 84,185 (98%) | 152 | 1.00 | 1.00 | NR | 0 | 21,747 (23%) | 22 | 1.00 | 1.00
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | 1 wk/yr | 19,921 (21%) | 35 | 1.10 (0.74–1.65) | 1.21 (0.80–1.83) | | Rarely or ≥1 time/mo | 1,665 (2%) | 4 | 1.65 (0.61–4.47) | 1.52 (0.56–4.12) | NR | ≤1/year | 52,452 (55%) | 94 | 1.80 (1.13–2.86) | 1.64 (1.03–2.62)
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | 2–3 wks/yr | 20,086 (22%) | 32 | 1.02 (0.67–1.54) | 1.09 (0.71–1.65) | | | | | p=0.36 | p=0.44 | NR | ≥2/year | 21,273 (22%) | 55 | 2.70 (1.65–4.44) | 2.42 (1.46–4.02)
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | ≥4 wks/yr | 8,113 (9%) | 20 | 1.56 (0.95–2.55) | 1.67 (1.01–2.74) | | Solarium use, ages 10–39 years | | | | | NR | Trend | | | p<0.001 | p<0.001
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | Trend | | | p=0.22 | p=0.12 | | | Frequencies | Cases | Age Adjusted RR | Multivariate* Adjusted RR | NR | Annual number of sunburns, ages 10–39 years
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | | | | | | | | | | | | NR
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | Annual weeks on sunbathing vacation, ages 10–39 years | | | | | | Never/rarely 10–39 yrs | 65,239 (82%) | 111 | 1.00 | 1.00 | NR | | Frequencies | Cases | Age Adjusted RR | Multivariate* Adjusted RR
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | | | | | | | | | | | | NR
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | | Frequencies | Cases | Age Adjusted RR | Multivariate* Adjusted RR | | ≥1 1 time/mo 10–19, 20–29, or 30–39 years | 14,377 (18%) | 34 | 1.45 (0.98–2.14) | 1.55 (1.04–2.32) | NR | ≤1/yr, 10–39 yrs | 64,807 (72%) | 99 | 1.00 | 1.00
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | | | | | | | | | | | | NR
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | 0, 10–39 yrs | 15,799 (18%) | 21 | 1.00 | 1.00 | | *Adjusted for age, region of residence, hair color, and the corresponding number of age-specific sunburns and weeks on annual summer vacations | | | | | NR | ≥2/yr, 20–29yrs and/or 30–39 yrs | 5,873 (6%) | 13 | 1.47 (0.82–2.62) | 1.54 (0.86–2.75)
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | ≥1 wk/yr, 20–29 and/or 30–39 yrs | 27,851 (31%) | 53 | 1.42 (0.86–2.36) | 1.45 (0.87–2.40) | | *Adjusted for age, region of residence, hair color, and the corresponding number of age-specific sunburns and weeks on annual summer vacations | | | | | NR | ≥2/yr, 10–19 yrs | 7,357 (8%) | 20 | 1.82 (1.13–2.95) | 1.66 (1.02–2.70)
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | ≥1 wk/yr, 10–19 yrs | 1,751 (2%) | 3 | 1.37 (0.41–4.59) | 1.46 (0.43–4.92) | | *Adjusted for age, region of residence, hair color, and the corresponding number of age-specific sunburns and weeks on annual summer vacations | | | | | NR | ≥2/yr, 10–39 yrs | 12,595 (14%) | 34 | 1.83 (1.24–2.70) | 1.79 (1.20–2.68)
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | ≥1 wk/yr, 10–39 yrs | 43,049 (49%) | 79 | 1.44 (0.89–2.34) | 1.56 (0.95–2.56) | | *Adjusted for age, region of residence, hair color, and the corresponding number of age-specific sunburns and weeks on annual summer vacations | | | | | NR | Trend | | | p<0.001 | p=0.002
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | Trend | | | p=0.27 | p=0.13 | | *Adjusted for age, region of residence, hair color, and the corresponding number of age-specific sunburns and weeks on annual summer vacations | | | | | NR | *Adjusted for age, region of residence, and hair color
Veierod 2003^82^ Norwegian- Swedish Women's Lifestyle and Health Cohort Study | Skin Cancer: Melanoma Study Design: Cohort Location: Norway & Sweden | | | Sun exposure, sunbed exposure Mailed questionnaires | Age, region of residence, hair color, number of sunburns, and weeks on annual summer vacations | 8.1 years average 100% (because excluded women with missing data) | *Adjusted for age, region of residence, and hair color | | | | | | *Adjusted for age, region of residence, hair color, and the corresponding number of age-specific sunburns and weeks on annual summer vacations | | | | | NR | *Adjusted for age, region of residence, and hair color
Cho 2005^93^ Nurses' Health Study I & II, Health Professionals Followup Study | Skin Cancer: Melanoma Study Design: Prospective cohort Location: US (multi-state) | Inclusion: Participants in NHS I & II (1986) and the Health Professional Followup Study (1992) with a diagnosis of invasive melanoma including superficial spreading and nodular types Exclusion: Cancer other than nonmelanoma skin cancer, melanoma in situ, non-Whites, missing answers for traditional melanoma risk factors on questionnaire | N=178,155 Mean age (range): 25–75 Sex: 86% Female Skin phenotype: NR 100% White | Sun exposure, sunscreen exposure Mailed questionnaires, every 2 years | Age, family history of melanoma, number of nevi, hair color, history of severe and painful sunburn also evaluated other potential confounders (but did not make statistically significant contribution to the model): skin reaction to sun, latitude of residence at birth and age 1, and age 30, BMI, height, physical activity, reproductive factors, and use of sunscreen | Up to 14 years 100% (because excluded people with missing data) | NR | | | | | | NR | | | | | "Use of sunscreen was not related to a reduced risk of melanoma" (p. 2671) when this variable was added to the multivariate model to predict risk of melanoma | Number of severe and painful sunburns and relative risk of melanoma (calc)
Cho 2005^93^ Nurses' Health Study I & II, Health Professionals Followup Study | Skin Cancer: Melanoma Study Design: Prospective cohort Location: US (multi-state) | | N=178,155 Mean age (range): 25–75 Sex: 86% Female Skin phenotype: NR 100% White | Sun exposure, sunscreen exposure Mailed questionnaires, every 2 years | | Up to 14 years 100% (because excluded people with missing data) | NR | | | | | | NR | | | | | "Use of sunscreen was not related to a reduced risk of melanoma" (p. 2671) when this variable was added to the multivariate model to predict risk of melanoma | | N (%) | Regression Coefficient | SE | P | RR (95% CI)
Cho 2005^93^ Nurses' Health Study I & II, Health Professionals Followup Study | Skin Cancer: Melanoma Study Design: Prospective cohort Location: US (multi-state) | | N=178,155 Mean age (range): 25–75 Sex: 86% Female Skin phenotype: NR 100% White | Sun exposure, sunscreen exposure Mailed questionnaires, every 2 years | | Up to 14 years 100% (because excluded people with missing data) | NR | | | | | | NR | | | | | "Use of sunscreen was not related to a reduced risk of melanoma" (p. 2671) when this variable was added to the multivariate model to predict risk of melanoma
Cho 2005^93^ Nurses' Health Study I & II, Health Professionals Followup Study | Skin Cancer: Melanoma Study Design: Prospective cohort Location: US (multi-state) | | N=178,155 Mean age (range): 25–75 Sex: 86% Female Skin phenotype: NR 100% White | Sun exposure, sunscreen exposure Mailed questionnaires, every 2 years | | Up to 14 years 100% (because excluded people with missing data) | NR | | | | | | NR | | | | | "Use of sunscreen was not related to a reduced risk of melanoma" (p. 2671) when this variable was added to the multivariate model to predict risk of melanoma | None | 64 (12) | -- | -- | -- | 1.0
Cho 2005^93^ Nurses' Health Study I & II, Health Professionals Followup Study | Skin Cancer: Melanoma Study Design: Prospective cohort Location: US (multi-state) | | N=178,155 Mean age (range): 25–75 Sex: 86% Female Skin phenotype: NR 100% White | Sun exposure, sunscreen exposure Mailed questionnaires, every 2 years | | Up to 14 years 100% (because excluded people with missing data) | NR | | | | | | NR | | | | | "Use of sunscreen was not related to a reduced risk of melanoma" (p. 2671) when this variable was added to the multivariate model to predict risk of melanoma | 1–2 | 109 (20) | 0.3358 | 0.1579 | 0.0334 | 1.40 (1.03–1.91)
Cho 2005^93^ Nurses' Health Study I & II, Health Professionals Followup Study | Skin Cancer: Melanoma Study Design: Prospective cohort Location: US (multi-state) | | N=178,155 Mean age (range): 25–75 Sex: 86% Female Skin phenotype: NR 100% White | Sun exposure, sunscreen exposure Mailed questionnaires, every 2 years | | Up to 14 years 100% (because excluded people with missing data) | NR | | | | | | NR | | | | | "Use of sunscreen was not related to a reduced risk of melanoma" (p. 2671) when this variable was added to the multivariate model to predict risk of melanoma | 3–5 | 107 (20) | 0.4833 | 0.1599 | 0.0025 | 1.62 (1.19–2.22)
Cho 2005^93^ Nurses' Health Study I & II, Health Professionals Followup Study | Skin Cancer: Melanoma Study Design: Prospective cohort Location: US (multi-state) | | N=178,155 Mean age (range): 25–75 Sex: 86% Female Skin phenotype: NR 100% White | Sun exposure, sunscreen exposure Mailed questionnaires, every 2 years | | Up to 14 years 100% (because excluded people with missing data) | NR | | | | | | NR | | | | | "Use of sunscreen was not related to a reduced risk of melanoma" (p. 2671) when this variable was added to the multivariate model to predict risk of melanoma | 6–9 | 89 (17) | 0.6683 | 0.1670 | <0.0001 | 1.95 (1.41–2.71)
Cho 2005^93^ Nurses' Health Study I & II, Health Professionals Followup Study | Skin Cancer: Melanoma Study Design: Prospective cohort Location: US (multi-state) | | N=178,155 Mean age (range): 25–75 Sex: 86% Female Skin phenotype: NR 100% White | Sun exposure, sunscreen exposure Mailed questionnaires, every 2 years | | Up to 14 years 100% (because excluded people with missing data) | NR | | | | | | NR | | | | | "Use of sunscreen was not related to a reduced risk of melanoma" (p. 2671) when this variable was added to the multivariate model to predict risk of melanoma | 10+ | 166 (31) | 0.8574 | 0.1549 | <0.0001 | 2.36 (1.74–3.19)
Cho 2005^93^ Nurses' Health Study I & II, Health Professionals Followup Study | Skin Cancer: Melanoma Study Design: Prospective cohort Location: US (multi-state) | | N=178,155 Mean age (range): 25–75 Sex: 86% Female Skin phenotype: NR 100% White | Sun exposure, sunscreen exposure Mailed questionnaires, every 2 years | | Up to 14 years 100% (because excluded people with missing data) | NR | | | | | | NR | | | | | "Use of sunscreen was not related to a reduced risk of melanoma" (p. 2671) when this variable was added to the multivariate model to predict risk of melanoma | Adjusted for sex, age, family history of melanoma, moles larger than 3mm on arms or legs, hair color
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | N= 2,095 (baseline data provided for n=2049) Age: 20–39:870 (42%) 40–59:861 (42%) 60–69:318 (16%) Sex (calc): 56% Female Skin phenotype: Ability to tan (calc) Always burn: 467 (23%) Burn then tan: 1,263 (62%) Always tan: 319 (16%) | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | Relative rates of BCC and SCC according to occupational exposure | | | | | | NR | | | | | NR | Relative rates of BCC and SCC according to number of painful sunburns
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | | BCC (n=250) RR (95% CI) | P | SCC (n=94) RR (95% CI) | P | | NR | | | | | NR | | BCC (n=250) RR (95% CI) | P | SCC (n=94) RR (95% CI) | P
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | | | | | | | NR | | | | | NR
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | Mainly indoors | 1.00 | | 1.00 | | | NR | | | | | NR | None | 1.00 | | 1.00
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | Indoors and outdoors | 1.07 (0.79–1.46) | | 0.82 (0.47–1.43) | | | NR | | | | | NR | 1 | 0.91 (0.55–1.50) | | 1.71 (0.66–4.41)
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | Mainly outdoors | 1.25 (0.88–1.78) | 0.221 | 1.37 (0.80–2.34) | 0.224 | | NR | | | | | NR | 2–5 | 1.10 (0.73–1.67) | | 3.31 (1.48–7.43)
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | Relative rates of BCC and SCC according to leisure exposure | | | | | | NR | | | | | NR | 6+ | 1.68 (1.10–2.57) | 0.003 | 3.28 (1.41–7.59) | <0.001
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | | BCC (n=250) RR (95% CI) | P | SCC (n=94) RR (95% CI) | P | | NR | | | | | NR | Adjusted for sex and age
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | | | | | | | NR | | | | | NR | Adjusted for sex and age
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | Mainly indoors | 1.00 | | 1.00 | | | NR | | | | | NR | Adjusted for sex and age
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | Indoors and outdoors | 0.93 (0.63–1.37) | | 0.81 (0.37–1.80) | | | NR | | | | | NR | Adjusted for sex and age
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | Mainly outdoors | 0.85 (0.59–1.21) | 0.342 | 1.29 (0.66–2.52) | 0.223 | | NR | | | | | NR | Adjusted for sex and age
Green 1996^65^ Nambour Skin Cancer Study | Skin Cancer: BCC and SCC Study Design: Cohort Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986 Exclusion: NR | | Sun exposure Clinical examination with standardized questionnaires | Age, sex and skin color | 6 years 80% | Adjusted for age, sex, and skin color | | | | | | NR | | | | | NR | Adjusted for sex and age
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | Inclusion: Aged 20–69, resident of Nambour, Queensland from electoral roll 1986, who attended a second survey in 1992; subgroup of those with their first BCC on head and trunk only Exclusion: Taking vitamin supplements containing betacarotene, already applying sunscreen on a strict daily basis | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | Association between truncal BCC and BCC of the head and occupational type, compared to participants without lesions | | | | | | NR | | | | | NR | Association between truncal BCC and BCC of the head and lifetime sunburns, compared to participants without lesions
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | | Head OR (95% CI) | Trunk OR (95% CI) | | | | NR | | | | | NR | | Head OR (95% CI) | Trunk OR (95% CI)
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | | | | | | | NR | | | | | NR
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | Mainly indoors | 1.0 | 1.0 | | | | NR | | | | | NR | None | 1.0 | 1.0
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | Indoors & outdoors | 0.95 (0.60–1.49) | 1.07 (0.60–1.93) | | | | NR | | | | | NR | 1–5 | 0.96 (0.61–1.53) | 1.44 (0.73–2.84)
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | Mainly outdoors | 0.86 (0.53–1.40) | 1.12 (0.60–2.11) | | | | NR | | | | | NR | 6–10 | 1.37 (0.74–2.56) | 1.75 (0.74–4.17)
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | Association between truncal BCC and BCC of the head and leisure type, compared to participants without lesions | | | | | | NR | | | | | NR | >10 | 1.79 (0.93–3.45) | 2.49 (1.04–5.99)
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | | Head OR (95% CI) | Trunk OR (95% CI) | | | | NR | | | | | NR
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | | | | | | | NR | | | | | NR
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | Mainly indoors | 1.0 | 1.0 | | | | NR | | | | | NR
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | Indoors & outdoors | 0.93 (0.64–1.35) | 1.15 (0.62–2.12) | | | | NR | | | | | NR
Neale 2007^61^ Supplement to Green 1999^57^ | Skin Cancer: BCC of head and trunk Study Design: Cohort from Nambour Skin Cancer Trial Location: Australia | | N= 1517 N (no lesions)= 1248 N (BCC head or trunk)= 269 (head n=175, trunk n=94) Mean age (range): Head first: 61 Trunk first: 57 Sex: NR Skin phenotype: NR | Sun exposure | Age and sex | unclear (see Green 1999^57^) | Mainly outdoors | 0.99 (0.60–1.63) | 0.84 (0.32–2.17) | | | | NR | | | | | NR

Study reference USPSTF quality | Skin cancer Study design Location Population | Participant inclusion/exclusion criteria | Baseline demographics | | | | | | Measurement of exposure | Confounders considered | Measurement of sun exposure | | | | | | | | | | | | Measurement of sunlamp or sunbed exposure | | | | | | | | | | | | Measurement of sunscreen use | | | | | | | Measurement of sunburn | | | | | | | | | | | | Comments
Case-control
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | [underlined: Cases:] Selection: SEER cancer registry that were diagnosed between 1984–1987 in 3 counties. Only cases read in hospital pathology labs were eligible to be disclosed Eligibility criteria: age 25–65 years, living, white, currently residing in the 3 counties, had a telephone, and had a melanoma histology defined as eligible; excluded nodular melanoma and malignant Hutchinson's melanotic freckle [underlined: Controls:] Selection: age, sex, and residence matched from random digit dialing Eligibility criteria: otherwise NR | Cases n= 256 Controls n= 273 Age | | | | | | Sun exposure Telephone interview | Age, sex and educational level | Average yearly sun exposure (hours) for previous 10 years | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | Cases n= 256 Controls n= 273 Age | | | | | | Sun exposure Telephone interview | Age, sex and educational level | | | Cases | | Controls | | OR* (95%CI) | | P | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | Cases n= 256 Controls n= 273 Age | | | | | | Sun exposure Telephone interview | Age, sex and educational level | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | Cases n= 256 Controls n= 273 Age | | | | | | Sun exposure Telephone interview | Age, sex and educational level | 0 | | 97 (38%) | | 126 (46%) | | 1.0 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | Cases | Controls | | | Sun exposure Telephone interview | Age, sex and educational level | 1–201 | | 86 (34%) | | 63 (23%) | | 1.16 (0.72–1.87) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | 29–36 | | 52 (20%) | 31 (12%) | | | Sun exposure Telephone interview | Age, sex and educational level | 202–499 | | 47 (18%) | | 48 (18%) | | 0.80 (0.45–1.42) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | 37–47 | | 78 (31%) | 52 (19%) | | | Sun exposure Telephone interview | Age, sex and educational level | 500–2,880 | | 26 (10%) | | 36 (13%) | | 0.88 (0.47–1.64) | | 0.53 | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | 48–58 | | 82 (32%) | 124 (45%) | | | Sun exposure Telephone interview | Age, sex and educational level | Lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | 59–65 | | 44 (17%) | 66 (24%) | | | Sun exposure Telephone interview | Age, sex and educational level | | | Cases | | Controls | | OR* (95% CI) | | P | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | Sex | | | | | | Sun exposure Telephone interview | Age, sex and educational level | 0 | | 168 (66%) | | 165 (60%) | | 1.00 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | Cases | Controls | | | Sun exposure Telephone interview | Age, sex and educational level | <50% | | 72 (28%) | | 78 (29%) | | 0.89 (0.60–1.32) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | Male | | 129 (50%) | 128 (47%) | | | Sun exposure Telephone interview | Age, sex and educational level | ≥50% | | 16 (6%) | | 30 (11%) | | 0.64 (0.33–1.23) | | 0.13 | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | Skin phenotype Skin reaction to chronic sun | | | | | | Sun exposure Telephone interview | Age, sex and educational level | Sun exposure index, by skin type | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | Cases | Controls | | Sun exposure Telephone interview | Age, sex and educational level | | | Cases | | Controls | | OR* (95% CI) | | P | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | Deep tan | | | 46 (18%) | 87 (32%) | | Sun exposure Telephone interview | Age, sex and educational level | [underlined: Poor tanners (no tan, mild tan, or freckling in response to chronic sun)] | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | Moderate tan | | | 105 (41%) | 113 (41%) | | Sun exposure Telephone interview | Age, sex and educational level | Sun exposure index, age 2–10 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | Mild tan | | | 66 (26%) | 64 (23%) | | Sun exposure Telephone interview | Age, sex and educational level | low | | 50 (52%) | | 34 (49%) | | 1.00 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | None or freckles | | | 39 (15%) | 9 (4%) | | Sun exposure Telephone interview | Age, sex and educational level | med | | 23 (24%) | | 17 (24%) | | 0.96 (0.43–2.18) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | high | | 23 (24%) | | 19 (27%) | | 0.88 (0.39–1.96) | | 0.78 | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | Sun exposure index, age 11–20 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | low | | 53 (54%) | | 43 (60%) | | 1.00 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | med | | 24 (25%) | | 18 (25%) | | 0.94 (0.42–2.08) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | high | | 20 (21%) | | 11 (15%) | | 1.55 (0.61–3.99) | | 0.45 | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | [underlined: Deep tanners (moderate or deep tan in response to chronic sun)] | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | Sun exposure index, age 2–10 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | low | | 78 (54%) | | 71 (36%) | | 1.00 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | med | | 40 (28%) | | 55 (28%) | | 0.69 (0.40–1.21) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | high | | 26 (18%) | | 71 (36%) | | 0.30 (0.17–0.55) | | 0.001 | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | Sun exposure index, age 11–20 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | low | | 76 (52%) | | 64 (32%) | | 1.00 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | med | | 46 (31%) | | 81 (41%) | | 0.50 (0.30–0.85) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | high | | 25 (17%) | | 54 (27%) | | 0.31 (0.16–0.59) | | 0.001 | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
White 1994^72^ | Skin Cancer: Melanoma Study Design: Case control Location: Washington | | | | | | | | Sun exposure Telephone interview | Age, sex and educational level | *Adjusted for age, sex and education | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | [underlined: Cases:] Selection: incident cases 1982–1985 from the Danish Cancer Registry Eligibility criteria: age 20–79 years, any cutaneous melanoma except lentigo maligna melanoma [underlined: Controls:] Selection: age, sex matched from national population register in 1984 Eligibility criteria: otherwise NR | Cases n= 474 Controls n= 926 Average age at diagnosis: 52 Sex (calc) | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | Sunbathing habits (calc) | | | | | | | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | Number of painful sunburns before age 15 (calc)
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Cases n= 474 Controls n= 926 Average age at diagnosis: 52 Sex (calc) | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | | | Cases | | Controls | | Crude RR (95% CI) | | Adjusted* RR (95% CI) | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | | | Cases | | Controls | | Crude RR (95%CI) | | Adjusted RR* (95% CI)
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Cases n= 474 Controls n= 926 Average age at diagnosis: 52 Sex (calc) | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | | | | | | | | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Cases n= 474 Controls n= 926 Average age at diagnosis: 52 Sex (calc) | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | Never | | 42 (8.9%) | | 135 (14.6%) | | 1.0 | | 1.0 | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | Never | | 93 (19.6%) | | 277 (29.9%) | | 1.0 | | 1.0
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Cases n= 474 Controls n= 926 Average age at diagnosis: 52 Sex (calc) | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | At some time | | 432 (91.1%) | | 791 (85.4%) | | 1.8 (1.2–2.5) | | 1.6 (1.1–2.4) | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | 1 | | 35 (7.4%) | | 80 (8.6%) | | 1.3 (0.8–2.1) | | 1.2 (0.7–1.9)
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Cases n= 474 Controls n= 926 Average age at diagnosis: 52 Sex (calc) | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | 1–9 years | | 16 (3.4%) | | 27 (2.9%) | | 1.9 (0.9–3.9) | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | 2–4 | | 85 (17.9%) | | 121 (13.1%) | | 2.1 (1.5–3.0) | | 1.9 (1.3–2.9)
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Cases n= 474 Controls n= 926 Average age at diagnosis: 52 Sex (calc) | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | 10–24 years | | 99 (20.9%) | | 197 (21.3%) | | 1.6 (1.1–2.5) | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | 5+ | | 44 (9.3%) | | 35 (3.8%) | | 3.7 (2.3–6.1) | | 2.7 (1.6–4.8)
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | | Cases | Controls | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | 25–39 years | | 161 (34.0%) | | 313 (33.8%) | | 1.7 (1.1–2.5) | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | | | | | | | p<0.001 | | p<0.001
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | | | | | | | | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Male | 194 (41%) | NR | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | 40+ years | | 149 (31.4%) | | 248 (26.8%) | | 1.9 (1.3–2.9) | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Chronic reaction to sunlight (calc) | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | p=0.004 | | | | | | | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | | | Cases | Controls | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | *Adjusted for sex, naevi, freckles and hair color | | | | | | | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | | | | | | | | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Deep tan | | 125 (26.4%) | 326 (35.2%) | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | Vacations spent in sun (calc) | | | | | | | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Moderate tan | | 228 (48.1%) | 429 (46.3%) | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | | | Cases | | Controls | | Crude RR (95% CI) | | Adjusted* RR (95% CI) | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | | | | | | | | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | Mild tan | | 101 (21.3%) | 143 (15.4%) | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | Never | | 182 (38.4%) | | 406 (43.8%) | | 1.0 | | 1.0 | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | No tan | | 18 (3.8%) | 24 (2.6%) | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | Sunny | | 229 (48.3%) | | 433 (46.8%) | | 1.2 (0.9–1.5) | | 1.0 (0.8–1.3) | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | Very sunny | | 63 (13.3%) | | 84 (9.1%) | | 1.7 (1.2–2.4) | | 1.4 (1.0–2.1) | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | | | | | | | p<0.01 | | p=0.138 | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Osterlind 1988^83^ Osterlind 1988^129^ | Skin Cancer: Melanoma Study Design: Case control Location: East Denmark | | | | | | | | Sun exposure, sunscreen use, sunburnsmixed Telephone and in-person interviews | Constitutional factors, sex and age | *Adjusted for history of sunbathing and sunburning | | | | | | | | | | | | Ever used sunbed Cases (calc): 66 (14%) Controls (calc): 167 (18%) RR (95% CI): 0.7 (0.5–1.0) | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex, number of raised naevi, freckles and hair color
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | [underlined: Cases:] Selection: all first incident cases from SEER cancer registry that were diagnosed between 1987–1989 Eligibility criteria: ≥18 years, Caucasian, invasive melanoma, excluded melanoma in situ [underlined: Controls:] Selection: age and sex matched, random digit dialing Eligibility criteria: otherwise NR | Cases n=650 Controls n= 549 | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | Berwick 1996: Age, sex, sun exposure, nevi, family history, skin type, eye color, hair color, tendency to freckle, ever severely sunburned, Lea 2007: Age, sex, sun sensitivity, number of vacations and mean number of days per year in recreational activity, cumulative UVB | Total Sun Exposure | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Ever severely sunburned OR (95% CI): 1.26 (0.99–1.61) Adjusted* OR (95% CI): 0.97 (0.71–1.32) *Adjusted for skin self-examination, skin color, sun exposure, number of nevi, family history of skin cancer, skin type, eye color, hair color, and tendency to freckle before age 25
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | Cases n=650 Controls n= 549 | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | OR* (95% CI) | | Adjusted OR** (95% CI) | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | Age: | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Light | | 1.00 | | 1.00 | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | | | Cases | Controls | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Moderate | | 1.04 (0.65–1.66) | | 1.26 (0.69–2.29) | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | <40 | | 123 (19%) | 110 (20%) | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Heavy | | 1.80 (1.14–2.86) | | 2.20 (1.21–4.01) | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | 40–70 | | 380 (58.5%) | 320 (58.3%) | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Very heavy | | 2.11 (1.18–3.15) | | 2.63 (1.25–5.54) | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | ≥70 | | 147 (22.6%) | 119 (21.7%) | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | *Adjusted for age and sex **Adjusted for skin self-examination, total nevi, family hx skin cancer, skin type, eye color, hair color, freckle, and ever severely sunburned | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | Sex: | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | *Adjusted for age and sex **Adjusted for skin self-examination, total nevi, family hx skin cancer, skin type, eye color, hair color, freckle, and ever severely sunburned | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | | | Cases | Controls | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | *Adjusted for age and sex **Adjusted for skin self-examination, total nevi, family hx skin cancer, skin type, eye color, hair color, freckle, and ever severely sunburned | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | Male | | 343 (52.8%) | 316 (57.6%) | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Total recreational sun exposure index* | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | Skin phenotype* | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | Head/neck OR (95% CI) | | Upper limb OR (95% CI) | | Lower limb OR (95% CI) | | Trunk OR (95% CI) | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | | | Cases | Controls | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Level 1 | | -- | | -- | | -- | | -- | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | Acute Skin Response | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Level 2 | | 1.5 (0.7–3.3) | | 0.9 (0.4–1.8) | | 1.0 (0.5–2.2) | | 1.7 (1.0–2.9) | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | Tan | | 201 (53%) | 220 (60%) | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Level 3 | | 1.0 (0.7–2.1) | | 1.0 (0.5–2.0) | | 1.2 (0.6–2.7) | | 1.4 (0.7–2.2) | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | Burn | | 179 (47%) | 144 (40%) | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Level 4 | | 2.6 (1.2–5.6) | | 2.4 (1.2–4.8) | | 2.7 (1.2–5.8) | | 2.7 (1.6–4.5) | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | Prolonged Skin Response | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Total years in outdoor jobs** | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | Tan | | 233 (61%) | 283 (77%) | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | Head/neck OR (95% CI) | | Upper limb OR (95% CI) | | Lower limb OR (95% CI) | | Trunk OR (95% CI) | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | No tan | | 147 (39%) | 81 (23%) | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | 0 | | -- | | -- | | -- | | -- | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | <5 | | 0.8 (0.4–1.5) | | 0.7 (0.4–1.4) | | 0.7 (0.3–1.3) | | 0.7 (0.5–1.1) | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | 5+ | | 0.5 (0.2–1.1) | | 0.6 (0.2–1.1) | | 0.3 (0.1–0.9) | | 0.9 (0.6–1.3) | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | *Adjusted for sex, age, skin color, number of nevi on arms, and skin type **Due to missing values, 525 cases and 468 controls | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Number of vacations | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | Cases | | Controls | | OR (95% CI) | | P | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | Birth to age 15 | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | 0 | | 235 (61.8%) | | 238 (65.4%) | | 1.0 (R) | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | 1–14 | | 100 (26.3%) | | 83 (22.8%) | | 1.1 (0.8–1.7) | | 0.5 | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | 15–90 | | 45 (11.8%) | | 43 (11.8%) | | 0.9 (0.5–1.4) | | 0.7 | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | 10 years before interview | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | 0 | | 88 (23.2%) | | 93 (25.6%) | | 1.0 (R) | | | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | 1–3 | | 88 (23.2%) | | 93 (25.6%) | | 1.1 (0.7–1.7) | | 0.8 | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | 4–8 | | 81 (21.3%) | | 91 (25.0%) | | 1.0 (0.6–1.6) | | 0.9 | | | | NR | | | | | | | | | | | | NR
Berwick 1996^73^ Lea 2007^130^ Chen 1996^131^ | Skin Cancer: Melanoma Study Design: Case control Location: Connecticut | | *Missing information, lived aroad, lentigo maligna, and acral lentiginous melanoma excluded from analysis | | | | | | Sun exposure Nurse-administered questionnaire and examination of arms and back for nevi | | 9–40 | | 123 (32.4%) | | 87 (23.9%) | | 1.5 (0.9–2.4) | | 0.05 | | | | NR | | | | | | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | Ever used sunlamp (calc) | | | | | | | | | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | | | Cases | | Controls | | Crude* OR (95% CI) | | Adjusted** OR (95% CI) | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | No | | 483 (77.4%) | | 417 (81.4%) | | -- | | -- | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | Yes | | 141 (22.6%) | | 95 (18.6%) | | 1.30 (0.97–1.74) | | 1.13 (0.82–1.54) | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | Total # sunlamp uses | | | | | | | | | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | | | Cases | | Controls | | Crude* OR (95% CI) | | Adjusted** OR (95% CI) | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | Never | | 483 (77.4%) | | 417 (81.4%) | | -- | | -- | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | <10 | | 76 (12.2%) | | 50 (9.8%) | | 1.32 (0.91–1.92) | | 1.25 (0.84–1.84) | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | ≥10 | | 63 (10.1%) | | 40 (7.8%) | | 1.40 (0.93–2.12) | | 1.15 (0.60–2.20) | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | | | | | | | p=0.97 | | p=0.86 | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | Age at first use of sunlamp | | | | | | | | | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | | | Cases | | Controls | | Crude* OR (95% CI) | | Adjusted** OR (95% CI) | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | Never | | 483 (77.4%) | | 417 (81.4%) | | -- | | -- | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | <25 | | 74 (11.9%) | | 42 (8.2%) | | 1.58 (1.05–2.39) | | 1.35 (0.88–2.08) | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | 25–45 | | 39 (6.3%) | | 31 (6.1%) | | 1.11 (0.68–1.80) | | 1.02 (0.61–1.70) | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | >45 | | 23 (3.7%) | | 15 (2.9%) | | 1.27 (0.65–2.47) | | 1.13 (0.56–2.28) | | | | NR | | | | | | | NR
Chen 1998^89^ | See Berwick et al 1996 | See Berwick et al 1996 | Cases n= 624 Controls n= 512 Sample drawn from larger case control study Berwick 1996, RM 215 | | | | | | Sunlamp exposure Nurse-administered questionnaires in home, at place of employment, or public place | Hair color, eye color, skin color, skin type (ability to tan), total number of nevi on arms and back, history of recreational sun exposure and history of occupational sun exposure | NR | | | | | | | | | | | | *Adjusted for sex and age **Adjusted for sex, age, cutaneous phenotype index, and total recreational sun exposure index | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | [underlined: Cases:] Selection: members of Nurses’ Health Study with dx of melanoma 1976–1984 confirmed by examination of medical records Eligibility criteria: born between 1921–1946; excluded ppts who were black, Asian or Hispanic, ppts with family hx of melanoma; excluded acral lentigenous melanoma or lentigo maligna [underlined: Controls:] Selection: 2 age-matched controls per case from same cohort Eligibility criteria: excluded ppts who were black, Asian, Hispanic and fam hx of melanoma | Cases n= 130 Controls n= 300 Age: 52.1 (mean) | | | | | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | Annual frequency of any swimsuit use outdoors at ages 15–20 years | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | Cases n= 130 Controls n= 300 Age: 52.1 (mean) | | | | | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | | | Cases | | Controls | | RR (95% CI) | | P | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | Cases n= 130 Controls n= 300 Age: 52.1 (mean) | | | | | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | Cases n= 130 Controls n= 300 Age: 52.1 (mean) | | | | | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | Sun resistant* | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | Cases n= 130 Controls n= 300 Age: 52.1 (mean) | | | | | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | 0–10 | | 21 (44%) | | 37 (24%) | | 1.0 (R) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | Sex | | | | | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | 11–30 | | 17 (35%) | | 60 (39%) | | 0.6 (0.2–1.4) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | | | Cases | | Controls | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | ≥31 | | 10 (21%) | | 57 (37%) | | 0.3 (0.1–0.8) | | 0.02 | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | | | | | | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | Male | | 0 | | 0 | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | Sun sensitive** | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | Skin phenotype Depth of tan after repeated exposure (calc) | | | | | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | 0–10 | | 23 (32%) | | 47 (44%) | | 1.0 (R) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | | | Cases | | Controls | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | 11–30 | | 23 (32%) | | 39 (36%) | | 1.2 (0.6–2.6) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | | | | | | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | Deep | | 17 (13.1%) | | 75 (25.0%) | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | ≥31 | | 26 (36%) | | 21 (20%) | | 3.5 (1.3–9.3) | | 0.01 | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | Medium | | 52 (40.0%) | | 118 (39.3%) | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | *A priori sun sensitivity score <0.5 **A priori sun sensitivity score ≥0.5 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | Light | | 51 (39.2%) | | 79 (26.3%) | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | *A priori sun sensitivity score <0.5 **A priori sun sensitivity score ≥0.5 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Weinstock 1991^87^ Nurses Health Study | Skin Cancer: Melanoma Study Design: nested-Case control Location: US (multi-state) | | None | | 6 (4.6%) | | 17 (5.7%) | | Sun exposure Mixed mailed questionnaires and telephone interviews | Birth year, cycle of questionnaire, method of data collection, sun sensitivity, and latitude of residence at ages 15–20 years | *A priori sun sensitivity score <0.5 **A priori sun sensitivity score ≥0.5 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | [underlined: Cases:] Selection: incident cases between 1984–1986 from local lab pathology reports Eligibility criteria: aged 20–69; recurrent lesions excluded (lesion considered recurrent if dx within previous yr and located in same lymphatic drainage area). Blacks and non-English speaking subjects excluded [underlined: Controls:] Selection: age, sex, and municipality matched from property tax assessment rolls Eligibility criteria: Blacks and non-English speaking subjects excluded | Cases n= 583 Controls n= 608 Age: NR Sex (calc) | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | Beach vacation past 5 years (calc) | | | | | | | | | | | | Ever use (calc) | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Cases n= 583 Controls n= 608 Age: NR Sex (calc) | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | Cases | | Controls | | | | | | | | | | Cases | | Controls | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Cases n= 583 Controls n= 608 Age: NR Sex (calc) | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Cases n= 583 Controls n= 608 Age: NR Sex (calc) | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | Yes | | 295 (50.6%) | | 302 (49.7%) | | | | | | | | Yes | | 153 (26.2%) | | 109 (49.7%) | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Cases n= 583 Controls n= 608 Age: NR Sex (calc) | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | No | | 284 (47.7%) | | 303 (49.8%) | | | | | | | | No | | 431 (73.9%) | | 498 (81.9%) | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Cases n= 583 Controls n= 608 Age: NR Sex (calc) | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | Crude* OR (95%CI): 1.04 (0.82–1.32) Adjusted** OR (95% CI): 1.04 (0.82–1.32) *Adjusted for sex, age, and reaction to initial summer sun exposure **Adjusted for sex, age, reaction to initial summer sun exposure, and potential confounders | | | | | | | | | | | | Crude* OR (95%CI): 1.61 (1.21–2.15) Adjusted** OR (95% CI): 1.54 (1.16–2.05) *Adjusted for sex, age, and reaction to initial summer sun exposure **Adjusted for sex, age, reaction to initial summer sun exposure, and potential confounders | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | | | Cases | Controls | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Ever use (by sex) | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Male | | 277 (47.5%) | 283 (46.5%) | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | | | Cases | | Controls | | OR (95% CI) | | P | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Males | | 277 (24.2%) | | 283 (14.5%) | | 1.88 (1.20–2.98) | | <0.01 | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Females | | 306 (27.8%) | | 324 (21.0%) | | 1.45 (0.99–2.13) | | 0.06 | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Age-adjusted cumulative minutes use (by sex) | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | | | Cases | | Controls | | OR (95% CI) | | P | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Males | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | 0 | | 210 (77%) | | 242 (86%) | | 1.00 | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | <180 | | 25 (9%) | | 20 (7%) | | 1.44 (0.75–2.82) | | 0.31 | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | ≥180 | | 39 (14%) | | 18 (6%) | | 2.50 (1.34–4.80) | | <0.01 | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Females | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | 0 | | 222 (74%) | | 256 (80%) | | 1.00 | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | <180 | | 39 (13%) | | 39 (12%) | | 1.17 (0.70–1.95) | | 0.61 | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | ≥180 | | 38 (13%) | | 27 (8%) | | 1.62 (0.91–2.89) | | 0.10 | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Age-adjusted age at first use (by sex) | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | | | Cases | | Controls | | OR (95% CI) | | P | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Males | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Never | | 210 (76%) | | 242 (87%) | | 1.00 | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | <30 | | 33 (12%) | | 19 (7%) | | 2.13 (1.13–4.13) | | 0.02 | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | ≥30 | | 33 (12%) | | 18 (6%) | | 2.04 (1.07–3.99) | | 0.03 | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Females | | | | | | | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | Never | | 221 (73%) | | 256 (79%) | | 1.00 | | | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | <30 | | 51 (17%) | | 39 (12%) | | 1.55 (0.94–2.59) | | 0.09 | | | | NR | | | | | | | NR
Walter 1999^90^ Walter 1990^132^ | Skin Cancer: Melanoma Study Design: case control Location: Ontario, Canada | | Skin phenotype: NR | | | | | | Sun exposure, Sunbed exposure In-person interview | Sex, age, and skin reaction to initial summer sun exposure | | | | | | | | | | | | | ≥30 | | 30 (10%) | | 29 (9%) | | 1.19 (0.66–2.13) | | 0.63 | | | | NR | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | [underlined: Cases:] Selection: incident cases of primary invasive melanoma diagnosed in 1997 through the Seattle-Puget Sound SEER registry Eligibility criteria: aged 35–74, living, English-speaking; excluded for previous dx melanoma, diagnosis of melanoma in situ, Hutchinson’s melanotic freckle, or lentigo maligna melanoma, non-white race or Hispanic origin [underlined: Controls:] Selection: random digit dialing Eligibility criteria: excluded those of non-white race or Hispanic origin, and those with history of melanoma | Cases n= 386 Controls n= 727 | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Lifetime average days spent >4 hours in the sun (by quartile) (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | # sunburns, age 2–10 | | | | | | | | | | | | Controls were younger that cases for both sexes. Missing sun exposure estimates were assumed to be the same at the earliest age for which there were data. If any other data was missing, that participant was excluded from the analysis for that age period.
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | Cases n= 386 Controls n= 727 | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | NR | | | | | | | | | | | | NR | | | | | | | | | Cases | | Controls | | OR (95% CI)
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | Age: | Cases M | Controls M | Cases F | Control F | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 70 (19.6%) | | 168 (24.7%) | | 1.0 | | | | NR | | | | | | | | | | | | NR | | | | | | | 0 | | 173 (47.0%) | | 436 (62.0%) | | 1.0
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | (n=201) | (n=261) | (n=185) | (n=466) | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 89 (24.9%) | | 171 (25.2%) | | 1.3 (0.86–1.9) | | | | NR | | | | | | | | | | | | NR | | | | | | | 1 | | 37 (10.1%) | | 72 (10.2%) | | 1.4 (0.88–2.1)
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | 35–44 | 40 | 96 | 58 | 185 | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 95 (26.5%) | | 169 (24.9%) | | 1.4 (0.92–2.0) | | | | NR | | | | | | | | | | | | NR | | | | | | | 2 | | 33 (9.0%) | | 64 (9.1%) | | 1.3 (0.81–2.1)
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | 45–54 | 79 | 89 | 55 | 134 | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 104 (29.1%) | | 171 (25.2%) | | 1.4 (0.95–2.0) | | | | NR | | | | | | | | | | | | NR | | | | | | | 3+ | | 125 (34.0%) | | 131*(18.6%) | | 2.4 (1.8–3.4)
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | 55–64 | 44 | 46 | 40 | 90 | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | | | | | p=0.10 | | | | NR | | | | | | | | | | | | NR | | | | | | | p for trend | | | | | | p=0.001
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | 65–74 | 38 | 30 | 32 | 57 | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Age 2–10 days/month in sun (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *n reported as 1331, believe it is a typo # sunburns, age 11–20
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | Sex (calc) | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | NR | | | | | | | | | | | | NR | | | | | | | | | Cases | | Controls | | OR (95% CI)
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | Cases | Controls | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Men | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | 0 | | 93 (24.5%) | | 261 (36.3%) | | 1.0
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | Male | | 201 (52.1%) | 261 (35.9%) | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 24 (15.6%) | | 41 (20.3%) | | 1.00 | | | | NR | | | | | | | | | | | | NR | | | | | | | 1 | | 63 (16.6%) | | 151 (21.0%) | | 1.3 (0.91–2.0)
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | Skin phenotype Ability to tan (calc) | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 34 (22.1%) | | 38 (18.8%) | | 1.53 (0.76–3.07) | | | | NR | | | | | | | | | | | | NR | | | | | | | 2 | | 37 (9.7%) | | 89 (12.4%) | | 1.3 (0.80–2.0)
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | Skin phenotype Ability to tan (calc) | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 38 (24.7%) | | 47 (23.3%) | | 1.30 (0.66–2.55) | | | | NR | | | | | | | | | | | | NR | | | | | | | 3+ | | 187 (49.2%) | | 219 (30.4%) | | 2.7 (2.0–3.7)
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | Cases | Controls | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 58 (37.7%) | | 76 (37.6%) | | 1.14 (0.61–2.13) | | | | NR | | | | | | | | | | | | NR | | | | | | | p for trend | | | | | | p=0.001
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | Deep tan | | 77 (19.9%) | 164 (22.6%) | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | p=0.99 | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | Moderate tan | | 145 (37.6%) | 306 (42.1%) | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Women | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | Mild tan | | 121 (31.3%) | 192 (26.4%) | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 23 (15.9%) | | 79 (22.7%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | Freckle/no tan | | 42 (10.9%) | 55 (7.6%) | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 24 (16.6%) | | 80 (23.0%) | | 1.06 (0.55–2.05) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 39 (26.9%) | | 73 (21.0%) | | 1.81 (0.99–3.34) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 59 (40.7%) | | 116 (33.3%) | | 1.72 (0.98–3.02) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | p=0.02 | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Previous 20 years days/month in sun (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Men | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 47 (23.7%) | | 66 (25.4%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 43 (21.7%) | | 59 (22.7%) | | 1.07 (0.62–1.87) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 62 (31.3%) | | 47 (23.3%) | | 1.31 (0.78–2.20) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 46 (23.2%) | | 67 (25.8%) | | 1.04 (0.60–1.79) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | p=0.69 | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Women | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 39 (21.5%) | | 110 (23.7%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 35 (19.3%) | | 112 (24.1%) | | 0.97 (0.57–1.66) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 62 (34.3%) | | 129 (27.8%) | | 1.52 (0.94–2.47) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 45 (24.9%) | | 113 (24.4%) | | 1.23 (0.74–2.06) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | p=0.18 | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | *Adjusted for age in the combined analysis of men and women | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Lifetime overall UV exposure (time in sun, erythemal exposure) | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Men | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 50 (27.2%) | | 62 (25.1%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 31 (16.8%) | | 62 (25.1%) | | 0.51 (0.23–0.80) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 38 (20.7%) | | 62 (25.1%) | | 0.67 (0.31–1.03) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 65 (35.3%) | | 61 (24.7%) | | 1.24 (0.62–1.86) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | | | | | p=0.28 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Women | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 35 (20.2%) | | 110 (25.6%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 36 (20.8%) | | 105 (24.4%) | | 1.35 (0.64–2.05) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 56 (32.4%) | | 107 (24.9%) | | 2.45 (1.23–3.68) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 46 (26.6%) | | 108 (25.1%) | | 1.99 (0.95–3.03) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | | | | | p=0.008 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | *Adjusted for age, income, tendency to burn and number of sunburns age 2–10 yrs | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Age 1–10 yrs overall UV exposure (time in sun, erythemal exposure) | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Men | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 39 (20.7%) | | 64 (33.7%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 42 (22.3%) | | 61 (32.1%) | | 0.84 (0.38–1.29) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 38 (20.7%) | | 63 (25.1%) | | 0.87 (0.40–1.35) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 65 (35.3%) | | 62 (24.7%) | | 1.34 (0.65–2.03) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | | | | | p=0.28 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Women | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 32 (18.1%) | | 109 (25.2%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 44 (24.9%) | | 107 (24.8%) | | 1.69 (0.85–2.53) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 51 (28.8%) | | 108 (25.0%) | | 1.69 (0.83–2.55) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 50 (28.2%) | | 108 (25.0%) | | 2.14 (1.08–3.20) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | | | | | p=0.002 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | *Adjusted for age in the combined analysis of men and women | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Age 11–20 overall UV exposure (time in sun, erythemal exposure) | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Men | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 45 (23.1%) | | 62 (24.2%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 44 (22.6%) | | 66 (25.8%) | | 0.95 (0.46–1.44) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 43 (22.1%) | | 63 (24.6%) | | 0.96 (0.46–1.45) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 63 (32.3%) | | 65 (25.4%) | | 1.19 (0.60–1.78) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | | | | | p=0.56 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Women | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 35 (18.9%) | | 118 (25.6%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 37 (20.0%) | | 112 (24.3%) | | 1.39 (0.68–2.09) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 59 (31.9%) | | 116 (25.2%) | | 2.37 (1.25–3.48) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 54 (29.2%) | | 115 (24.9%) | | 2.33 (1.19–3.46) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | | | | | p=0.001 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | *Adjusted for age in the combined analysis of men and women Previous 20 years overall UV exposure (time in sun, erythemal exposure) | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Men | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 44 (22.3%) | | 65 (25.0%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 40 (20.3%) | | 65 (25.0%) | | 1.00 (0.47–1.53) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 59 (29.9%) | | 65 (25.0%) | | 1.72 (0.85–2.59) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 54 (27.4%) | | 65 (25.0%) | | 1.53 (0.74–2.33) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | | | | | p=0.07 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Women | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | First quartile | | | | 43 (23.8%) | | 117 (25.2%) | | 1.00 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Second quartile | | | | 39 (21.5%) | | 115 (24.8%) | | 1.01 (0.52–1.49) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Third quartile | | | | 54 (29.8%) | | 116 (25.0%) | | 1.82 (0.96–2.68) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | Fourth quartile | | | | 45 (24.9%) | | 116 (25.0%) | | 1.30 (0.67–1.94) | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | p for trend | | | | | | | | p=0.14 | | | | NR | | | | | | | | | | | | NR
Shors 2001^74^ Soloman 2004^134^ | Skin Cancer: Melanoma Study Design: case control Location: Washington | | | | | | | | Sun exposure Telephone interviews | Adjusted for age, income, tendency to burn, number of sunburns age 2–10, and sex | *Adjusted for age in the combined analysis of men and women | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | [underlined: Cases:] Selection: (varied by country) all first incident cases from dermatologists, pathologists, plastic surgeons, oncologists and melanoma databases between 1998–2001 Eligibility criteria: aged 18–49, Caucasian, excluded lentigo malignant melanoma or in situ melanoma [underlined: Controls:] Selection: (varied by country) age, sex matched, random selection from population registries, from general practices matched by geographical area, and from door-to-door search Eligibility criteria: otherwise NR | Cases n= 597 Controls n= 622 Mean age (SD) Cases: 38 (7.8) Controls: 37 (7.8) Sex: | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | Ever used sunbed | | | | | | | | | | | | NR | | | | | | | Sunburn before age 15
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | Cases n= 597 Controls n= 622 Mean age (SD) Cases: 38 (7.8) Controls: 37 (7.8) Sex: | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | | | Cases | | Controls | | Crude OR (95% CI) | | Adjusted* OR (95% CI) | | | | NR | | | | | | | | | Cases | | Controls | | Crude OR (95%CI) | | Adjusted* OR (CI 95% CI)
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | Cases n= 597 Controls n= 622 Mean age (SD) Cases: 38 (7.8) Controls: 37 (7.8) Sex: | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | | | | | | | | | | | | | NR
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | Cases n= 597 Controls n= 622 Mean age (SD) Cases: 38 (7.8) Controls: 37 (7.8) Sex: | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | <age 15 | | 23 (4%) | | 14 (2%) | | 1.74 (0.89–3.42) | | 1.82 (0.92–3.62) | | | | NR | | | | | | | No | | 308 (52%) | | 375 (61%)
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | Cases n= 597 Controls n= 622 Mean age (SD) Cases: 38 (7.8) Controls: 37 (7.8) Sex: | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | Ever | | 315 (53%) | | 354 (57%) | | 0.84 (0.67–1.06) | | 0.90 (0.71–1.14) | | | | NR | | | | | | | Yes | | 289 (48%) | | 247 (39%) | | 1.42 (1.13–1.79) | | 1.20 (0.95–1.54)
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | Cases n= 597 Controls n= 622 Mean age (SD) Cases: 38 (7.8) Controls: 37 (7.8) Sex: | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | Cumulative lifetime sunbed use (in hours) | | | | | | | | | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | Cases n= 597 Controls n= 622 Mean age (SD) Cases: 38 (7.8) Controls: 37 (7.8) Sex: | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | | | Cases | | Controls | | Crude OR (95% CI) | | Adjusted* OR (95% CI) | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | Cases n= 597 Controls n= 622 Mean age (SD) Cases: 38 (7.8) Controls: 37 (7.8) Sex: | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | Cases n= 597 Controls n= 622 Mean age (SD) Cases: 38 (7.8) Controls: 37 (7.8) Sex: | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | 0 | | 282 (47%) | | 268 (43%) | | 1.00 | | 1.00 | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | | | Cases | Controls | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | <10 | | 163 (28%) | | 168 (28%) | | 0.92 (0.70–1.21) | | 0.95 (0.71–1.25) | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | Male | | 219 (37%) | 214 (34%) | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | 10–30 | | 56 (10%) | | 76 (13%) | | 0.70 (0.48–1.03) | | 0.75 (0.50–1.11) | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | Skin phenotype (Fitzpatrick classification) | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | 31–60 | | 25 (4%) | | 37 (6%) | | 0.64 (0.38–1.09) | | 0.75 (0.43–1.30) | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | | | Cases | Controls | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | 61–100 | | 17 (3%) | | 17 (3%) | | 0.95 (0.47–1.89) | | 1.10 (0.55–2.24) | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | | | | | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | IV (good tanner) | | 61 (10%) | 118 (19%) | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | >100 | | 40 (7%) | | 38 (6%) | | 1.00 (0.62–1.60) | | 1.19 (0.73–1.93) | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | III | | 194 (32%) | 273 (44%) | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | *Adjusted for age, sex, skin phototype | | | | | | | | | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | II | | 245 (41%) | 171 (27%) | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | *Adjusted for age, sex, skin phototype | | | | | | | | | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Bataille 2005^91^ | Skin Cancer: Melanoma Study Design: Case control Location: Sweden, The Netherlands, UK, Belgium, France | | I (never tan) | | 97 (16%) | 60 (10%) | | | Sunbed exposure In-person interviews | Age, sex, skin type | NR | | | | | | | | | | | | *Adjusted for age, sex, skin phototype | | | | | | | | | | | | NR | | | | | | | *Adjusted for age, sex, and skin type
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | [underlined: Cases:] Selection: 200 consecutive patients presenting at dermato-oncologic followup clinic in 1987 Eligibility criteria: German origin [underlined: Controls:] Selection: age and sex matched nonmelanoma patients at the clinic with any skin disease other than melanoma Eligibility criteria: German origin; excluded if had consultation due to pigmented nevi, or previously treated by UV radiation | Cases n= 200 Controls n= 200 | | | | | | Sun exposure 20 minute interview and physical exam | NR | The skin type as well as the occupational sun exposure appeared to represent a significant increase of RR, but, the duration of the occupational sun exposure in years had no significant influence | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | Mean age: | | | | | | Sun exposure 20 minute interview and physical exam | NR | Relative risk for occupational sun exposure to upper part of the body and/or the extremities on the occasion of sunshine | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | | | Cases | Controls | | | Sun exposure 20 minute interview and physical exam | NR | Relative risk for occupational sun exposure to upper part of the body and/or the extremities on the occasion of sunshine | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | | | | | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | Male | | 50.7 | 51.0 | | | Sun exposure 20 minute interview and physical exam | NR | | | Cases | | Controls | | Nonadjusted RR (95% CI) | | Adjusted RR (95% CI) | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | | | | | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | Female | | 56.6 | 57.0 | | | Sun exposure 20 minute interview and physical exam | NR | None | | 159 (79.5%) | | 174 (87.0%) | | 1.00 | | 1.00 | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | Sex (calc) | | | | | | Sun exposure 20 minute interview and physical exam | NR | Sometimes | | 31 (15.5%) | | 24 (12.0%) | | 1.41 (0.80–2.51) | | 1.18 (0.56–2.48) | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | | | Cases | Controls | | | Sun exposure 20 minute interview and physical exam | NR | Nearly every time | | 10 (5.0%) | | 2 (1.0%) | | 5.47 (1.18–25.30) | | 11.62 (2.13–63.33) | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | | | | | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | Male | | 79 (39.5%) | NR | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | Skin phenotype: | | | | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | | | Cases | Controls | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | | | | | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | IV | | 18 (9.0%) | 21 (10.5%) | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | III | | 76 (38.0%) | 94 (47.0%) | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | II | | 71 (35.5%) | 65 (32.5%) | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Garbe 1989^78^ | Skin Cancer: Melanoma Study Design: case control Location: Germany | | I | | 35 (17.5%) | 20 (10.0%) | | | Sun exposure 20 minute interview and physical exam | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | [underlined: Cases:] Selection: newly diagnosed from province cancer registries between 1979–1981 Eligibility criteria: aged 20–79 years. Excluded lentigo maligna and acral lentiginous melanoma [underlined: Controls]: Selection: from medical insurance plan list of subscribers, age and sex matched Eligibility criteria: NR | Cases n= 595 Controls n= 595 Age (mean): NR Sex (calc) | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | Occupational sun exposure (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Childhood sunburn (calc)
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | Cases | Controls | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | Equivalent hours^*^ | | | | Cases | | Adjusted RR^**^ | | | | | | NR | | | | | | | | | | | | NR | | | | | | | | | Cases | | RR Crude | | RR Adjusted^*^
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | Male | | 234 (39%) | 234 (39%) | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | <1 | | | | 143 (24%) | | 1.0 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Rare or mild | | 143 (24%) | | 1.0 | | 1.0
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | Skin phenotype (calc): | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 1–99 | | | | 196 (33%) | | 1.8 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Moderate or infrequent | | 161 (27%) | | 1.4 | | 1.1
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | Skin reaction to sun | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 100–199 | | | | 101 (17%) | | 1.0 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Severe or frequent | | 292 (49%) | | 1.9 | | 1.3
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | Cases | Controls | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 200–399 | | | | 89 (15%) | | 0.9 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | p=NS
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | Tan, no burn | | 184 (31%) | 280 (47%) | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 400+ | | | | 71 (12%) | | 0.9 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | Tan with protection | | 77 (13%) | 60 (10%) | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | p<0.01 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | Burn then tan | | 250 (42%) | 202 (34%) | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | Recreational sun exposure in summer season (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | Burn only | | 83 (14%) | 60 (10%) | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | Equivalent hours^*^ | | | | Cases | | Adjusted RR^**^ | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | <1 | | | | 173 (29%) | | 1.0 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 1–19 | | | | 89 (15%) | | 1.1 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 20–79 | | | | 167 (28%) | | 1.7 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 80–159 | | | | 89 (15%) | | 1.8 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 160+ | | | | 77 (13%) | | 1.7 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | p<0.01 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | Vacation sun exposure in summer season (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | Equivalent hours^*^ | | | | Cases | | Adjusted RR^**^ | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | <1 | | | | 196 (33%) | | 1.0 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 1–6 | | | | 149 (25%) | | 0.9 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 7–19 | | | | 77 (13%) | | 0.9 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 20–39 | | | | 89 (15%) | | 1.9 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 40+ | | | | 83 (14%) | | 1.5 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | p<0.01 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | ^*^1 hour of sun exposure to the whole body. Converted using estimates of proportion of body area exposed. ^**^Adjusted for hair color, skin color, freckling, and ethnic origin | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | Occupational, summer, hr/season (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | Cases | | Controls | | Crude RR | | Adjusted RR^*^ (95%CI) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | <1 | | 141 (23.7%) | | 156 (26.2%) | | 1.0 (R) | | 1.0 | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 1–99 | | 195 (32.8%) | | 136 (22.9%) | | 1.6 | | 1.8 (1.2–2.5) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 100–199 | | 100 (16.8%) | | 103 (17.3%) | | 1.1 | | 1.0 (0.7–1.5) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 200–399 | | 87 (14.6%) | | 110 (18.5%) | | 0.9 | | 0.9 (0.6–1.4) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 400+ | | 72 (12.1%) | | 90 (15.1%) | | 0.9 | | 0.9 (0.6–1.5) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | p<0.01 | | p<0.01 | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | Recreational, summer, hr/season (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | Cases | | Controls | | Crude RR | | Adjusted RR^*^ (95%CI) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | <1 | | 172 (28.9%) | | 230 (38.7%) | | 1.0 | | 1.0 | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 1–19 | | 92 (15.5%) | | 105 (17.6%) | | 1.3 | | 1.1 (0.7–1.6) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 20–79 | | 165 (27.7%) | | 122 (20.5%) | | 2.0 | | 1.7 (1.2–2.5) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 80–159 | | 89 (15.0%) | | 79 (13.3%) | | 1.7 | | 1.8 (1.2–2.7) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 160+ | | 77 (12.9%) | | 59 (10.0%) | | 2.0 | | 1.7 (1.1–2.7) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | p<0.001 | | p<0.01 | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | Vacation, summer, hr/season (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | Cases | | Controls | | Crude RR | | Adjusted RR^*^ (95%CI) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | <1 | | 194 (32.6%) | | 216 (36.3%) | | 1.0 | | 1.0 | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 1–6 | | 151 (25.4%) | | 175 (29.4%) | | 1.0 | | 0.9 (0.7–1.3) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 7–19 | | 79 (13.3%) | | 91 (15.3%) | | 1.0 | | 0.9 (0.6–1.4) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 20–39 | | 90 (15.1%) | | 50 (8.4%) | | 2.1 | | 1.9 (1.3–3.0) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 40+ | | 81 (13.6%) | | 63 (10.6%) | | 1.5 | | 1.5 (1.0–2.3) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | p<0.001 | | p<0.01 | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | Sunny vacations per decade (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | Cases | | Controls | | Crude RR | | Adjusted RR^*^ (95%CI) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 0 | | 174 (29.2%) | | 189 (31.8%) | | 1.0 (R) | | 1.0 | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | <1 | | 150 (25.%) | | 187 (31.4%) | | 1.1 | | 1.1 (1.0–1.1) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 1–3 | | 145 (24.4%) | | 133 (22.4%) | | 1.3 | | 1.3 (1.1–1.5) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 4+ | | 126 (21.2%) | | 86 (14.5%) | | 1.8 | | 1.7 (1.2–2.3) | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | p<0.001 | | p<0.001 | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | ^*^ Adjusted for hair color, skin color, history of freckles, and ethnic origin Annual sun exposure, hours (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | Cases | | Controls | | RR (95% CI) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | <49 | | 36 (6.1%) | | 45 (7.6%) | | 1.0 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 50–99 | | 49 (8.2%) | | 42 (7.1%) | | 1.5 (0.8–2.7) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 100–149 | | 64 (10.8%) | | 53 (8.9%) | | 1.5 (0.9–2.7) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 150–199 | | 64 (10.8%) | | 49 (8.2%) | | 1.6 (0.9–2.9) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 200–299 | | 93 (15.6%) | | 116 (19.5%) | | 1.0 (0.6–1.7) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 300–399 | | 70 (11.8%) | | 79 (13.3%) | | 1.1 (0.6–1.9) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 400–499 | | 76 (12.8%) | | 61 (10.3%) | | 1.6 (0.9–2.7) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | 500+ | | 143 (24.0%) | | 150 (25.2%) | | 1.2 (0.7–2.0) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Gallagher 1986^75^ Elwood 1985^135^ Elwood 1984^136^ Western Canada Melanoma Study | Skin Cancer: Melanoma Study Design: Case control Location: Western Canada | | | | | | | | Sun exposure In-person interviews | Hair color, skin color, history of freckles and ethnic origin | | | | | | | p<0.1 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for other pigmentation factors and for freckling, childhood sunburn and ethnic origin
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | [underlined: Cases:] Selection: BCC or SCC diagnosed at the Geraldton prevalence survey in 1987 or within the preceding 12 months Eligibility criteria: 40–64 years of age, resident in Geraldton [underlined: Controls]: Selection: from same survey, subjects who had no diagnosis of BCC, SCC, keratocanthoma, or intraepithelial carcinoma. Stratified by sex and age Eligibility criteria: NR | Cases n= 248 (23 persons with both BCC and SCC) BCC cases n=226 SCC cases n=45 Controls n= 1,015 BCC controls n= 1,021 (6 cases of SCC) SCC controls n= 1,064 (49 cases of BCC) Age (mean): NR Sex: NR Skin phenotype: Ability to tan (calc) | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Risk of BCC in relation to intermittency of sun exposure in 15–19-year-olds before diagnosis estimated from a typical week in each of the warmer and cooler months at each place of residence and adjusted for age, sex, ability to tan and total sun exposure (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | Risk of BCC in relation to use of SPF10+ sunscreen on the site: frequency and duration of use (calc) ^*^ | | | | | | | Risk of BCC in relation to frequency of painful sunburn to the site (calc) ^*^
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | | Cases | Controls | OR (95%CI) | P | | | | | Cases | | Controls | | OR (95%CI) | | P
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 0–40% | | 36 (17.9%) | | 177 (25.3%) | | 1.00 | | | | | | NR | | | | | | | | | | | | <half the time | 117 (60.9%) | 476 (68.0%) | 1.00 | | | | None | | 87 (45.3%) | | 378 (54.0%) | | 1.00
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 41–58% | | 50 (24.9%) | | 183 (26.1%) | | 1.49 (0.88–2.52) | | | | | | NR | | | | | | | | | | | | ≥ half the time | | | | | | | 1–2 times | | 27 (14.1%) | | 105 (15.0%) | | 1.09 (0.67–1.79)
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 59–99% | | 49 (24.4%) | | 156 (22.3%) | | 1.82 (1.01–3.28) | | 0.001 | | | | NR | | | | | | | | | | | | 1–9 years | 31 (16.1%) | 75 (10.7%) | 1.92 (1.17–3.13) | | | | 3–10 times | | 31 (16.1%) | | 77 (11.0%) | | 1.75 (1.08–2.85)
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 100% | | 66 (32.8%) | | 184 (26.3%) | | 3.86 (1.93–7.75) | | <0.001 for trend | | | | NR | | | | | | | | | | | | 10+ years | 44 (22.9%) | 149 (21.3%) | 1.25 (0.82–1.90) | 0.04 | | | 11+ times | | 47 (24.5%) | | 140 (20.0%) | | 1.50 (0.99–2.26) | | 0.07
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Risk of BCC in relation to the interaction between ability to tan and intermittency of sun exposure adjusted for age, sex and total outdoor exposure for 15–19-year-olds (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site Risk of SCC in relation to frequency of painful sunburn to the site (calc)^*^
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | Cases | | Controls | | OR (95%CI) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | | | Cases | | Controls | | OR (95%CI) | | P
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Very Brown | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | None | | 53 (52.0%) | | 584 (56.6%) | | 1.0
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 0–40% | | 3 (8.3%) | | 65 (27.0%) | | 1.00 | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | 1–2 times | | 9 (8.8%) | | 141 (13.7%) | | 0.84 (0.39–1.8)
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 41–58% | | 8 (22.2%) | | 64 (26.6%) | | 0.96 (0.36–2.54) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | 3–10 times | | 17 (16.7%) | | 109 (10.6%) | | 1.8 (0.99–3.4)
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 59–99% | | 8 (22.2%) | | 48 (20.0%) | | 1.09 (0.40–3.00) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | 11+ times | | 23 (22.5%) | | 197 (19.1%) | | 1.4 (0.82–2.5) | | 0.08
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 100% | | 17 (47.2%) | | 64 (26.6%) | | 0.87 (0.26–2.99) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | BCC | | SCC | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Moderately brown, peel, freckle | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | Cases | Controls | Cases | Controls | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 0–40% | | 44 (26.7%) | | 120 (26.1%) | | 1.11 (0.52–2.38) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | Very brown | 43 (19.0%) | 369 (36.2%) | 7 (15.6%) | 320 (34.2%) | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 41–58% | | 45 (27.3%) | | 111 (24.2%) | | 1.91 (0.91–4.00) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | Moderate tan | 100 (44.2%) | 436 (43.1%) | 19 (42.2%) | 409 (43.7%) | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 59–99% | | 49 (29.7%) | | 112 (24.4%) | | 2.46 (1.11–5.47) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | Mild tan | 66 (29.2%) | 176 (17.3%) | 12 (26.7%) | 171 (18.3%) | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 100% | | 27 (16.4%) | | 116 (25.3%) | | 5.89 (2.44–14.22) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | Freckle/no tan | 17 (7.5%) | 37 (3.6%) | 7 (15.6%) | 35 (3.7%) | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Risk of BCC in relation to lifetime hours of sun exposure on holidays between 9am and 5pm when the site was exposed (calc) ^*^ | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 0–602 | | 40 (20.8%) | | 174 (24.9%) | | 1.00 | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 602–2268 | | 54 (28.1%) | | 176 (25.1%) | | 1.65 (1.01–2.70) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 2268–3794 | | 49 (25.5%) | | 174 (24.9%) | | 1.68 (1.00–2.80) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 3794+ | | 49 (25.5%) | | 176 (25.1%) | | 1.85 (1.09–3.13) | | 0.09 | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Risk of BCC in relation to lifetime frequency of sunbathing when the site was exposed (calc) ^*^ | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | None | | 95 (49.0%) | | 342 (48.9%) | | 1.00 | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 1–200 | | 35 (18.0%) | | 91 (13.0%) | | 1.57 (0.98–2.51) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 201–700 | | 34 (17.5%) | | 136 (19.4%) | | 1.08 (0.68–1.72) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 701–9000 | | 30 (15.5%) | | 131 (18.7%) | | 1.02 (0.63–1.64) | | 0.31 | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Risk of BCC in relation to accumulated hours sun exposure between 9am and 5pm estimated from a typical week in each of the warmer and cooler months at each place of residence, controlling for age, sex, and ability to tan (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 0–40.5 | | 50 (24.9%) | | 176 (25.1%) | | 1.00 | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 40.5–56.4 | | 48 (23.9%) | | 177 (25.3%) | | 0.99 (0.61–1.58) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 46.4–81.6 | | 59 (29.4%) | | 166 (23.7%) | | 1.42 (0.86–2.35) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 81.6+ | | 44 (21.9%) | | 181 (25.9%) | | 0.77 (0.43–1.40) | | 0.10 | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Risk of BCC in relation to measures of ambient solar radiation at places of residence for the whole year, controlling for age, sex and ability to tan (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 0–8.8 | | 39 (19.4%) | | 186 (26.6%) | | 1.00 | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 8.8–10.1 | | 52 (25.9%) | | 174 (24.9%) | | 1.32 (0.69–2.55) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 10.1–11.4 | | 54 (26.9%) | | 174 (24.9% | | 1.72 (0.72–4.09) | | 0.47 | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 11.4+ | | 56 (27.9%) | | 166 (23.7%) | | 2.18 (0.82–5.82) | | 0.11 for trend | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Risk of BCC in relation to accumulated sun exposure between 9am and 5pm on working days and on non-working days from 15 years of age estimated from a typical week in each of the warmer and cooler months at each place of residence, controlling for age, sex, and ability to tan (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Thousands of Hours | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 0–14.7 | | 47 (23.4%) | | 179 (25.6%) | | 1.00 | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 14.8–27.7 | | 58 (28.9%) | | 168 (24.0%) | | 1.25 (0.79–1.97) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 27.8–49.3 | | 52 (25.9%) | | 174 (24.9%) | | 1.17 (0.72–1.90) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 49.4+ | | 44 (21.9%) | | 179 (25.6%) | | 0.86 (0.50–1.51) | | 0.46 | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Relationship of SCC to ambient sunlight in accumulated global radiance (mWh cm-2 X 105) at places of residence from birth until 1987, adjusted for age, sex, year of interview, ability to tan and propensity to burn (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | <8.8410 | | 17 (20.7%) | | 249 (24.2%) | | 1.0 | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 8.8410–10.1399 | | 25 (30.5%) | | 236 (22.9%) | | 1.4 (0.51–3.6) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 10.1400–11.4509 | | 54 (65.9%) | | 291 (28.2%) | | 2.7 (0.84–8.6) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 11.4510+ | | 36 (43.9%) | | 255 (24.7%) | | 2.3 (0.62–8.3) | | 0.17 | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Relationship of SCC to hours of sun exposure to the anatomic site according to whether the site was usually exposed to sunlight (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Working days | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 0–11,499 | | 15 (18.1%) | | 137 (25.3%) | | 1.0 | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 11,500–19,999 | | 16 (19.3%) | | 144 (26.6%) | | 0.93 (0.42–2.1) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 20,000–32,999 | | 25 (30.1%) | | 123 (22.7%) | | 1.7 (0.81–3.8) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 33,000+ | | 27 (32.5%) | | 138 (25.5%) | | 1.3 (0.58–2.8) | | 0.32 | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Non-working days | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 0–4,999 | | 14 (16.9%) | | 146 (26.9%) | | 1.0 | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 5,000–8,499 | | 20 (24.1%) | | 124 (22.9%) | | 2.0 (0.89–4.4) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 8,500–13,999 | | 24 (28.9%) | | 128 (23.6%) | | 1.9 (0.86–4.2) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 14,000+ | | 25 (30.1%) | | 144 (26.6%) | | 1.3 (0.57–2.9) | | 0.68 | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | Risk of SCC in relation to lifetime hours of sun exposure to the site on holidays (calc)^*^ | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | | | | | | | | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | <600 | | 19 (18.6%) | | 252 (24.4%) | | 1.0 | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 600–2,268 | | 28 (27.5%) | | 288 (27.9%) | | 0.89 (0.44–1.8) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 2,269–3,793 | | 28 (27.5%) | | 241 (23.4%) | | 1.0 (0.51–2.1) | | | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Kricker 1991^62^ Kricker 1995^116^ Kricker 1995^36^ English 1998^63^ English 1998^33^ | Skin Cancer: BCC & SCC Study Design: Case- control Location: Western Australia | | | | | | | | Sun exposure, sunscreen exposure Interviews (location NR) | Ethnicity, pigmentary traits and sensitivity of the skin to sunlight, sun exposure, sun damage, skin conditions | 3,794+ | | 27 (26.5%) | | 250 (24.2%) | | 0.93 (0.44–1.9) | | 0.97 | | | | NR | | | | | | | | | | | | ^*^Adjusted for age, sex, ability to tan, and site | | | | | | | ^*^Adjusted for age, sex, year of interview, and anatomic site
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | [underlined: Cases:] Selection: consecutive cases at City Departments for Skin and Venereal Diseases Eligibility criteria: diagnosis of BCC [underlined: Controls] : Selection: consecutive patients presenting at the same institutions for dermatologic diseases other than cancer Eligibility criteria: aged >30 years | Cases n= 200 Controls n= 399 Age (calc): | | | | | | Sun exposure Physician interviews | | Risk of BCC in relation to number of vacations at seaside before age 10 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Risk of BCC in relation to sunburn pain
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Cases n= 200 Controls n= 399 Age (calc): | | | | | | Sun exposure Physician interviews | | Risk of BCC in relation to number of vacations at seaside before age 10 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | | | Cases | | Controls | | OR (95%CI) | | P
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Cases n= 200 Controls n= 399 Age (calc): | | | | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Cases n= 200 Controls n= 399 Age (calc): | | | | | | Sun exposure Physician interviews | | | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | NR | | | | | | | Lifetime | | 67 (33.5%) | | 67 (16.8%) | | NR | | NS
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Cases n= 200 Controls n= 399 Age (calc): | | | | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Cases n= 200 Controls n= 399 Age (calc): | | | | | | Sun exposure Physician interviews | | 0 | | 162 (81.0%) | | 307 (76.9%) | | NR | | NS | | | | NR | | | | | | | | | | | | NR | | | | | | | Before age 15 | | 24 (12.0%) | | 21 (5.3%) | | NR | | NS
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Cases n= 200 Controls n= 399 Age (calc): | | | | | | Sun exposure Physician interviews | | 1–4 | | 21 (10.5%) | | 41 (10.3%) | | NR | | NS | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | | | Cases | Controls | | | Sun exposure Physician interviews | | 5–9 | | 17 (8.5%) | | 51 (12.8%) | | NR | | NS | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | | | | | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | ≤59 years | | 60 (30.0%) | 114 (28.6%) | | | Sun exposure Physician interviews | | not significant in adjusted analyses therefore NR Risk of BCC in relation to average number of weeks per year spent at seaside during vacation | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | ≥60 years | | 140 (70.0%) | 285 (71.4%) | | | Sun exposure Physician interviews | | | | Cases | | Controls | | OR (95%CI) | | P | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | | | | | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Sex | | | | | | Sun exposure Physician interviews | | 0 | | 47 (23.5%) | | 125 (31.3%) | | NR | | NS | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | | | Cases | Controls | | | Sun exposure Physician interviews | | 1–6 | | 34 (17.0%) | | 267 (66.9%) | | NR | | NS | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | | | | | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Male | | 124 (62.0%) | 239 (59.9%) | | | Sun exposure Physician interviews | | 7+ | | 19 (9.5%) | | 7 (1.8%) | | 1.81 (1.24–2.64) | | 0.0022 | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Skin phenotype: | | | | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Skin reaction to sun exposure | | | | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | | | Cases | Controls | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | | | | | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Usually burns with no or little tan | | 78 (39.0%) | 91 (22.8%) | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Vlajinac 2000^127^ | Skin Cancer: BCC Study Design: Case- control Location: Yugoslavia | | Never or rarely burns and always tans | | 122 (61.0%) | 308 (77.2%) | | | Sun exposure Physician interviews | | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | not significant in adjusted analyses therefore NR
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | [underlined: Cases:] Selection: consecutive cases presenting at the Department of Dermatology of the University of L'Aquila between 2000–2001 Eligibility criteria: sporadic primary cutaneous melanoma of any stage either as a first diagnosis or during periodic followup. Excluded those with family history of melanoma or with visceral malignant tumors [underlined: Controls] : Selection: age, sex, ethnicity and residential area matched recruited consecutively from same department with allergic disorders, skin infections, psoriasis, ulcers or autoimmune diseases Eligibility criteria: excluded those with family history of melanoma, visceral malignant tumors, melanocytic naevi or skin cancer with a history of phototherapy | Cases n= 100 Controls n= 200 Mean age (SD): Cases: 48.16 (14.8) Controls: NR Sex (calc): | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Melanoma risk associated with recreational sun exposure (h/year) | | | | | | | | | | | | Melanoma risk associated with use of sunlamps | | | | | | | | | | | | Melanoma risk associated with use of sunscreens | | | | | | | Melanoma risk associated with childhood sunburns
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | Cases n= 100 Controls n= 200 Mean age (SD): Cases: 48.16 (14.8) Controls: NR Sex (calc): | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | | | Cases | | Controls | | OR (95% CI) | | Adjusted OR (95% CI) | | | | | | Cases | | Controls | | OR (95% CI) | | Adjusted OR (95% CI) | | | | | Cases | Controls | OR (95% CI) | Adjusted OR (95% CI) | | | | | Cases | | Controls | | OR (95% CI) | | Adjusted OR (95% CI)
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | Cases n= 100 Controls n= 200 Mean age (SD): Cases: 48.16 (14.8) Controls: NR Sex (calc): | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | Cases n= 100 Controls n= 200 Mean age (SD): Cases: 48.16 (14.8) Controls: NR Sex (calc): | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | <60 | | 38 (38%) | | 97 (48.5%) | | 1.0 | | 1.0 | | | | Yes | | 7 (7%) | | 25 (12.5%) | | 0.527 (0.204–1.204) | | 0.634 (0.247–1.625) | | | | Yes | 51 (51%) | 106 (53.0%) | 0.923 (0.570–1.494) | 0.634 (0.247–1.625) | | | Yes | | 62 (62%) | | 113 (56.0%) | | 1.256 (0.771–2.063) | | 0.958 (0.554–1.655)
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | Cases n= 100 Controls n= 200 Mean age (SD): Cases: 48.16 (14.8) Controls: NR Sex (calc): | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | 60–120 | | 26 (26%) | | 63 (31.5%) | | 1.053 (0.580–1.897) | | 0.761 (0.420–1.378)
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | Cases n= 100 Controls n= 200 Mean age (SD): Cases: 48.16 (14.8) Controls: NR Sex (calc): | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | 120–240 | | 18 (18%) | | 29 (14.5%) | | 1.584 (0.781–3.171) | | 1.641 (0.799–3.370)
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | Cases n= 100 Controls n= 200 Mean age (SD): Cases: 48.16 (14.8) Controls: NR Sex (calc): | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | >240 | | 18 (18%) | | 11 (5.5%) | | 4.177 (1.831–9.928) | | 5.010 (2.110–11.891)
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | Cases n= 100 Controls n= 200 Mean age (SD): Cases: 48.16 (14.8) Controls: NR Sex (calc): | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Melanoma risk associated with occupational sun exposure
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | | | Cases | Controls | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | | | Cases | | Controls | | OR (95% CI) | | Adjusted OR (95% CI)
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | Male | | 47 (47.0%) | NR | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Yes | | 33 (33%) | | 34 (17.0%) | | 2.405 (1.377–4.207) | | 2.573 (1.399–4.732)
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | Skin phenotype: | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Adjusted for hair color, eye color, and skin type
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | Fitzpatrick scale | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Adjusted for hair color, eye color, and skin type
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | | | Cases | Controls | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Adjusted for hair color, eye color, and skin type
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | | | | | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Adjusted for hair color, eye color, and skin type
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | IV | | 8 (8%) | 39 (19.5%) | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Adjusted for hair color, eye color, and skin type
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | III | | 39 (39%) | 101 (50.5%) | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Adjusted for hair color, eye color, and skin type
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | II | | 49 (49%) | 57 (28.5%) | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Adjusted for hair color, eye color, and skin type
Fargnoli 2004^79^ | Skin Cancer: Melanoma Study Design: Case- control Location: Central Italy | | I | | 4 (4%) | 3 (1.5%) | | | Sun exposure, use of sunscreen, sunlamp exposure Physician interviews | Hair color, eye color, skin type for pigmentation factors | Adjusted for hair color, eye color, and skin type
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | [underlined: Cases:] Selection: diagnosed with melanoma between 1981–1986 from the San Francisco Bay Area SEER database Eligibility criteria: women aged 25–59 years, Caucasian, able to complete interview in English [underlined: Controls:] Selection: Age, sex, and county matched, random digit dialing Eligibility criteria: women aged 25–59 years, Caucasian, lived in the same counties as the cases | Cases (calc) n= 452 Controls n= 930 Mean age: 42 Sex: | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | Risk for cutaneous malignant melanoma by time spent outdoors on weekdays with arms and legs exposed to the sun (past 10 years) | | | | | | | | | | | | Risk for cutaneous malignant melanoma by use of sunlamp | | | | | | | | | | | | Risk of cutaneous malignant melanoma by use of sunscreen (before diagnosis) | | | | | | | Risk for cutaneous malignant melanoma by number of painful sunburns during elementary school | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Cases (calc) n= 452 Controls n= 930 Mean age: 42 Sex: | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | | | | | OR (95% CI) | | | | | | | | | | | | OR (95% CI) | | | | | | | | Risk of cutaneous malignant melanoma by use of sunscreen (before diagnosis) | | | | | | | | | | | OR (95% CI) | | P | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Cases (calc) n= 452 Controls n= 930 Mean age: 42 Sex: | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Cases (calc) n= 452 Controls n= 930 Mean age: 42 Sex: | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | None | | | | 1.0 | | | | | | | | Never used | | | | 1.0 | | | | | | | | | | OR (95% CI) | P | Adjusted^*^OR (95% CI) | | | None | | | | 1.0 | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Cases (calc) n= 452 Controls n= 930 Mean age: 42 Sex: | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Cases (calc) n= 452 Controls n= 930 Mean age: 42 Sex: | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | <1/4 of time | | | | 0.71 (0.49–1.0) | | | | | | | | Ever used | | | | 0.94 (0.74–1.2) | | | | | | | | Almost always | | 1.0 | | 1.0 | | | 1–3 | | | | 1.3 (0.96–1.7) | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Cases (calc) n= 452 Controls n= 930 Mean age: 42 Sex: | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | 1/4 – 1/2 of time | | | | 0.83 (0.53–1.3) | | | | | | | | crude odds ratios only | | | | | | | | | | | | Sometimes | | 1.3 (0.93–1.8) | | 1.5 (1.1–2.2) | | | 4–6 | | | | 2.2 (1.5–3.1) | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Cases (calc) n= 452 Controls n= 930 Mean age: 42 Sex: | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | ≥ 1/2 of time | | | | 0.83 (0.46–1.5) | | | | | | | | crude odds ratios only | | | | | | | | | | | | Never | | 1.6 (1.2–2.1) | 0.002 | 2.1 (1.5–3.0) | | | ≥7 | | | | 2.0 (1.4–2.9) | | <0.001 | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | | | Cases | Controls | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | Risk for cutaneous malignant melanoma by time spent outdoors on weekends with arms and legs exposed to the sun (past 10 years) | | | | | | | | | | | | crude odds ratios only | | | | | | | | | | | | ^*^Adjusted for history of sunburn up to age 12 years, skin's reaction after a few days of exposure to the sun, hair color, number of large nevi, complexion, maternal ethnicity, history of skin cancer, and age | | | | | | | Risk for cutaneous malignant melanoma by number of painful sunburns during high school | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | | | | | | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Male | | 0 (0%) | 0 (0%) | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | | | | | OR (95% CI) | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | | | | | OR (95% CI) | | P | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | | | | | | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | None | | | | 1.0 | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | None | | | | 1.0 | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | <1/4 of time | | | | 0.72 (0.35–1.4) | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | 1–3 | | | | 1.2 (0.87–1.5) | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | 1/4 – 1/2 of time | | | | 0.71 (0.37–1.4) | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | 4–6 | | | | 1.6 (1.2–2.3) | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | 1/2 – 3/4 of time | | | | 0.86 (0.42–1.8) | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | ≥7 | | | | 2.4 (1.6–3.5) | | <0.001 | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | ≥ 3/4 of time | | | | 0.84 (0.37–1.9) | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | Risk for cutaneous malignant melanoma by history of sunburn up to age 12 years | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | Risk for cutaneous malignant melanoma by how often subject sunbathed in a typical year (past 10 years) | | | | | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | | | | | | | | | Adjusted^*^ OR (95% CI) | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | | | | | | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | | | | | OR (95% CI) | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | Rare, mild, and/or no burns | | | | | | | | 1.0 | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | | | | | | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | Never | | | | 1.0 | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | Moderate and/or infrequent burns | | | | | | | | 1.7 (1.2–2.3) | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | <Once/month | | | | 0.75 (0.52–1.1) | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | Severe and/or frequent burns | | | | | | | | 1.9 (1.2–3.0) | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | Once/month | | | | 0.57 (0.36–0.89) | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | ^*^Adjusted for use of sunscreen, skin's reaction after a few days of exposure to the sun, hair color, number of large nevi, complexion, maternal ethnicity, history of skin cancer, and age | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | 2–3 times/month | | | | 0.67 (0.46–0.98) | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | ^*^Adjusted for use of sunscreen, skin's reaction after a few days of exposure to the sun, hair color, number of large nevi, complexion, maternal ethnicity, history of skin cancer, and age | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | ≥Once/week | | | | 0.79 (0.56–1.1) | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | ^*^Adjusted for use of sunscreen, skin's reaction after a few days of exposure to the sun, hair color, number of large nevi, complexion, maternal ethnicity, history of skin cancer, and age | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Holly 1995^80^ | Skin Cancer: Melanoma Study Design: Case- control Location: San Francisco, CA | | Skin phenotype: NR | | | | | | Sun exposure, use of sunscreen, sunlamp exposure In-person interviews | Skin phenotype | crude odds ratios only | | | | | | | | | | | | crude odds ratios only | | | | | | | | | | | | | | | | | | | ^*^Adjusted for use of sunscreen, skin's reaction after a few days of exposure to the sun, hair color, number of large nevi, complexion, maternal ethnicity, history of skin cancer, and age | | | | | | | | | | | | When sun exposure on weekends and weekdays was adjusted for skin phenotype, all risk estimates were at 1.0 or slightly above (specific data NR)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | [underlined: Cases:] Selection: newly diagnosed SCC in males between 1983–1984 from the Alberta Cancer Registry Eligibility criteria: men aged 25–79 years [underlined: Controls:] Selection: age and sex matched, from the Alberta Health Care Insurance Plan Eligibility criteria: no previous diagnosis of nonmelanocytic skin cancer | Cases n= 180 Controls n= 406 Mean age: NR Sex: | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | Mean recreational sun exposure per year, ages 0–19 years, and risk of SCC (calc) | | | | | | | | | | | | Use of sunlamps and risk of SCC (calc) | | | | | | | | | | | | NR | | | | | | | Sunburn history, age 5–15 years, and risk of SCC (calc)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Cases n= 180 Controls n= 406 Mean age: NR Sex: | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI) | | | | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI) | | | | NR | | | | | | | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Cases n= 180 Controls n= 406 Mean age: NR Sex: | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | | | | | | | | | | | | | | | | | | | | | NR
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Cases n= 180 Controls n= 406 Mean age: NR Sex: | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | <100/y WBE, <3.8 h/wk summer | | | | 52 (29%) | | 97 (24%) | | 1.0 | | | | Never | | | | 162 (90%) | | 371 (91%) | | 1.0 | | | | NR | | | | | | | Never burned | | | | 66 (37%) | | 175 (43%) | | 1.0
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Cases n= 180 Controls n= 406 Mean age: NR Sex: | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 100–199/y WBE, 3.8–7.4 h/wk summer | | | | 49 (27%) | | 113 (28%) | | 1.2 (0.6–2.5) | | | | Ever | | | | 18 (10%) | | 33 (8%) | | 1.4 (0.7–2.7) | | | | NR | | | | | | | Rare or mild burns | | | | 27 (15%) | | 86 (21%) | | 0.8 (0.5–1.6)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | Cases | Controls | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 200–332/y WBE, 7.5–12.4 h/wk summer | | | | 36 (20%) | | 101 (25%) | | 1.1 (0.5–2.6) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Moderate burns | | | | 52 (29%) | | 92 (23%) | | 1.3 (0.7–2.2)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Male | | 100% | 100% | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 333+/y WBE, 12.5+ h/wk summer | | | | 25 (14%) | | 76 (19%) | | 1.6 (0.6–4.5) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Frequent or severe burns | | | | 35 (19%) | | 53 (13%) | | 0.6 (0.6–1.4)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Skin phenotype: | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | p (trend) = NS | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | p (trend)=NS
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Skin reaction to 1-week sun exposure (calc) | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | Mean recreational sun exposure per year, lifetime, and risk of SCC (calc) | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Sunburn pain ≥2 days, age 5–15 years, and risk of SCC (calc)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | Cases | Controls | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Tan without burning | | 58 (32%) | 155 (37%) | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | <75/y WBE, <2.8 h/wk summer | | | | 38 (21%) | | 75 (18%) | | 1.0 | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Never | | | | 150 (83%) | | 375 (92%) | | 1.0
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Tan with protection | | 6 (3%) | 14 (3%) | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 75–149/y WBE, 2.8–5.5 h/wk summer | | | | 43 (24%) | | 106 (26%) | | 0.6 (0.3–1.1) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Once per year | | | | 14 (8%) | | 24 (6%) | | 1.9 (0.8–4.4)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Burn then tan | | 77 (43%) | 193 (48%) | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 150–224/y WBE, 5.6–8.4 h/wk summer | | | | 32 (18%) | | 72 (18%) | | 0.8 (0.3–1.8) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Twice or more per year | | | | 16 (9%) | | 7 (2%) | | 10.5 (2.9–38.0)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | Burn, never tan | | 39 (22%) | 43 (11%) | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 225+/y WBE, 8.5+ h/wk summer | | | | 23 (13%) | | 73 (18%) | | 0.3 (0.1–0.9) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | p (trend)=0.001
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | p (trend) = 0.09 | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Sunburn pain ≥2 days, lifetime, and risk of SCC (calc)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | Mean recreational sun exposure per year, last 10 years, and risk of SCC (calc) | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Never | | | | 121 (67%) | | 291 (72%) | | 1.0
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | <65/y WBE, <2.4 h/wk summer | | | | 53 (29%) | | 75 (18%) | | 1.0 | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Ever | | | | 59 (33%) | | 115 (28%) | | 1.2 (0.8–1.8)
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 65–119/y WBE, 2.4–4.4 h/wk summer | | | | 29 (16%) | | 99 (24%) | | 0.4 (0.2–0.7) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | p (trend)=NS
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 120–199/y WBE, 4.5–7.4 h/wk summer | | | | 60 (33%) | | 115 (28%) | | 0.7 (0.4–1.2) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 200+/y WBE, 7.5+ h/wk summer | | | | 25 (14%) | | 83 (20%) | | 0.4 (0.2–0.7) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | p (trend)=0.06 | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | WBE-whole body equivalent is 1 h of sun exposure to the whole surface of the body ^*^Adjusted for effects of mother's ethnic origin, hair color, and skin color Mean occupational sun exposure per year, lifetime, and risk of SCC (calc) | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | <15/y WBE, 3.5 h/wk summer | | | | 26 (14%) | | 87 (21%) | | 1.0 | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 15–59/y WBE, 3.5–13.9 h/wk summer | | | | 36 (20%) | | 105 (26%) | | 0.8 (0.3–2.0) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 60–104/y WBE, 14.0–24.9 h/wk summer | | | | 42 (23%) | | 86 (21%) | | 1.5 (0.6–4.2) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 105+/y WBE, 25.0 h/wk summer | | | | 76 (42%) | | 128 (32%) | | 1.4 (0.4–4.3) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | p (trend)=NS | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | Mean occupational sun exposure per year, last 10 years, and risk of SCC (calc) | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 0/y WBE, 0 h/wk summer | | | | 61 (34%) | | 161 (40%) | | 1.0 | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 1–29/y WBE, <7.0 h/wk summer | | | | 18 (10%) | | 45 (11%) | | 1.9 (0.6–5.6) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 30–99/y WBE, 7.0–22.9 h/wk summer | | | | 46 (26%) | | 113 (28%) | | 2.2 (0.8–6.4) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 100+/y WBE, 23+ h/wk summer | | | | 55 (31%) | | 87 (21%) | | 4.0 (1.2–13.1) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | p (trend)<0.05 | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | Mean cumulative sun exposure per year, lifetime, and risk of SCC (calc) | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | <120/y WBE, <11.5 h/wk summer | | | | 32 (18%) | | 85 (21%) | | 1.0 | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 120–189/y WBE, 11.5–18.9 h/wk summer | | | | 47 (26%) | | 84 (21%) | | 1.8 (0.9–3.3) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 190–279/y WBE, 19.0–27.9 h/wk summer | | | | 35 (19%) | | 90 (22%) | | 1.2 (0.6–2.3) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 280+/y WBE, 28+ h/wk summer | | | | 22 (12%) | | 67 (17%) | | 1.0 (0.4–2.1) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | p (trend)=NS | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | Mean cumulative sun exposure per year, last 10 years, and risk of SCC (calc) | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | Cases | | Controls | | Adjusted^*^ OR (95% CI) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | <100/y WBE, 9.5 h/wk summer | | | | 41 (23%) | | 107 (26%) | | 1.0 | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 100–159/y WBE, 9.5–15.9 h/wk summer | | | | 45 (25%) | | 88 (22%) | | 1.5 (0.9–2.7) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 160–239/y WBE, 16.0–23.9 h/wk summer | | | | 43 (24%) | | 78 (19%) | | 1.7 (0.9–3.1) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | 240+/y WBE, 24+ h/wk summer | | | | 38 (21%) | | 99 (24%) | | 1.1 (0.6–2.1) | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | p (trend)=NS | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^66^ Bajdik 1996^128^ | Skin Cancer: SCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp use In-home interviews | Age, pigment, and phenotype | WBE-whole body equivalent is 1 h of sun exposure to the whole surface of the body ^*^Adjusted for effects of mother's ethnic origin, hair color, and skin color | | | | | | | | | | | | ^*^Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | ^*^Adjusted for age, mother's ethnic origin, hair color, and skin color
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | [underlined: Cases:] Selection: newly diagnosed BCC in males between 1983–1984 from the Alberta Cancer Registry Eligibility criteria: men aged 25–79 years [underlined: Controls:] Selection: age and sex matched, from the Alberta Health Care Insurance Plan Eligibility criteria: no previous diagnosis of skin cancer | Cases n=226 Controls n=406 Mean age: NR Sex: | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | Mean recreational sun exposure per year, ages 0–19 years, and risk of BCC (calc) | | | | | | | | | | | | Sunlamp use and risk of BCC (calc) | | | | | | | | | | | | NR | | | | | | | Sunburn, age 5–15 years, and risk of BCC (calc)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Cases n=226 Controls n=406 Mean age: NR Sex: | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | NR | | | | | | | | | | | Cases | | Controls | | Adjusted*OR (95% CI)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Cases n=226 Controls n=406 Mean age: NR Sex: | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | | | | | | | | | | | | | | | | | | | | | | | | | NR
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Cases n=226 Controls n=406 Mean age: NR Sex: | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | <100/y WBE, <3.8 h/wk summer | | | | 49 (22%) | | 97 (24%) | | 1.0 | | | | Never | | | | 203 (90%) | | 371 (91%) | | 1.0 | | | | NR | | | | | | | Never burned | | | | 77 (34%) | | 175 (43%) | | 1.0
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Cases n=226 Controls n=406 Mean age: NR Sex: | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | 100–199/y WBE, 3.8–7.4 h/wk summer | | | | 56 (25%) | | 113 (28%) | | 1.1 (0.6–2.0) | | | | Ever | | | | 23 (10%) | | 33 (8%) | | 1.2 (0.7–2.2) | | | | NR | | | | | | | Rare or mild burns | | | | 29 (13%) | | 86 (21%) | | 0.8 (0.5–1.4)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | Cases | Controls | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | 200–332/y WBE, 7.5–12.4 h/wk summer | | | | 54 (24%) | | 101 (25%) | | 1.4 (0.7–3.0) | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Moderate burns | | | | 68 (30%) | | 92 (23%) | | 1.3 (0.8–2.1)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | | | | | | | | | | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Male | | 100% | 100% | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | 333+/y WBE, 12.5+ h/wk summer | | | | 57 (25%) | | 76 (19%) | | 2.6 (1.1–6.5) | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Frequent or severe burns | | | | 25 (11%) | | 53 (13%) | | 1.6 (1.0–2.7)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Skin phenotype: | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | p (trend)=0.03 | | | | | | | | | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | p=0.05
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Skin reaction to 1 week of exposure (calc) | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | Mean recreational sun exposure per year, lifetime, and risk of BCC (calc) | | | | | | | | | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Sunburn pain ≥2 days, age 5–15 years, and risk of BCC (calc)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | Cases | Controls | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | | | | | Cases | | Controls | | Adjusted* OR (95% CI)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | | | | | | | | | | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Tan without burning | | 72 (32%) | 155 (38%) | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | <75/y WBE, <2.8 h/wk summer | | | | 47 (21%) | | 75 (18%) | | 1.0 | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Never | | | | 188 (83%) | | 375 (92%) | | 1.0
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Tan with protection | | 9 (4%) | 14 (3%) | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | 75–149/y WBE, 2.8–5.5 h/wk summer | | | | 65 (29%) | | 106 (26%) | | 0.9 (0.5–1.7) | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Once per year | | | | 22 (10%) | | 24 (6%) | | 1.7 (0.9–3.4)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Burn, then tan | | 100 (56%) | 193 (48%) | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | 150–224/y WBE, 5.6–8.4 h/wk summer | | | | 42 (19%) | | 72 (18%) | | 0.6 (0.3–1.3) | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | 2+ per year | | | | 16 (7%) | | 7 (2%) | | 4.5 (1.7–12.3)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | Burn, never tan | | 45 (25%) | 43 (11%) | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | 225+/y WBE, 8.5+ h/wk summer | | | | 32 (14%) | | 73 (18%) | | 0.4 (0.2–1.0) | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | p<0.001
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | p (trend)=0.03 | | | | | | | | | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Sunburn pain ≥2 days, lifetime, and risk of BCC (calc)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | Mean occupational sun exposure per year, lifetime, and risk of BCC (calc) | | | | | | | | | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | | | | | Cases | | Controls | | Adjusted* OR (95% CI)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | | | | | | | | | | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Never | | | | 160 (71%) | | 291 (72%) | | 1.0
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | | | | | | | | | | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | <15/y WBE, <3.5 h/wk summer | | | | 56 (25%) | | 87 (21%) | | 1.0 | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | Ever | | | | 66 (29%) | | 115 (28%) | | 0.9 (0.6–1.3)
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | 15–59/y WBE, 3.5–13.9 h/wk summer | | | | 56 (25%) | | 105 (26%) | | 1.0 (0.6–1.8) | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | p=NS; *Adjusted for age, mother's ethnic origin, skin color, and hair color
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | 60–104/y WBE, 14.0–24.9 h/wk summer | | | | 46 (20%) | | 86 (21%) | | 1.3 (0.8–2.3) | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | p=NS; *Adjusted for age, mother's ethnic origin, skin color, and hair color
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | 105+/y WBE, 25+ h/wk summer | | | | 68 (30%) | | 128 (32%) | | 1.4 (0.8–2.4) | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | p=NS; *Adjusted for age, mother's ethnic origin, skin color, and hair color
Gallagher 1995^70^ Bajdik 1996^128^ | Skin Cancer: BCC Study Design: Case- control Location: Alberta, Canada | | | | | | | | Sun exposure, sunlamp exposure In-home interviews | Age, mother's ethnic origin, skin color, and hair color | p (trend)=NS | | | | | | | | | | | | *Adjusted for age, ethnic origin, skin and hair color, and lifetime occupational sun exposure | | | | | | | | | | | | NR | | | | | | | p=NS; *Adjusted for age, mother's ethnic origin, skin color, and hair color
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | [underlined: Cases:] Selection: newly diagnosed SCC, BCC or melanoma in females between 1989–1998/2000 from the Nurses' Health Study, who gave blood specimen Eligibility criteria: Caucasian women [underlined: Controls:] selection: women from the NHS who gave a blood sample in 1989–90, matched by birth year (±1 year) Eligibility criteria: free of diagnosed skin cancer up to and including the questionnaire cycle in which the case was diagnosed | Cases n=758 (melanoma n=200, SCC n=275, BCC n=283) Controls n=804 Mean age: 58.7 (range: 43–68) Sex: | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Risk for skin cancer according to cumulative sun exposure while wearing a bathing suit (tertile) | | | | | | | | | | | | Risk for skin cancer according to sunlamp use or tanning salon attendance | | | | | | | | | | | | NR | | | | | | | Risk for skin cancer according to lifetime severe sunburns which blistered
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Cases n=758 (melanoma n=200, SCC n=275, BCC n=283) Controls n=804 Mean age: 58.7 (range: 43–68) Sex: | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | | Melanoma | | | SCC | | | BCC | | | Control | | | Melanoma | | | SCC | | | BCC | | | Control | | NR | | | | | | | | Melanoma | | | SCC | | | BCC | | | Control
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Cases n=758 (melanoma n=200, SCC n=275, BCC n=283) Controls n=804 Mean age: 58.7 (range: 43–68) Sex: | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | | | | | | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Cases n=758 (melanoma n=200, SCC n=275, BCC n=283) Controls n=804 Mean age: 58.7 (range: 43–68) Sex: | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | | N(%) | Age-adjusted OR (95% CI) | Multivariate OR (95% CI) | N(%) | Age-adjusted OR (95% CI) | Multivariate OR (95% CI) | N(%) | Age-adjusted OR (95% CI) | Multivariate OR (95% CI) | N(%) | | | N(%) | Age-adjusted OR (95% CI) | Multivariate OR (95% CI) | N(%) | Age-adjusted OR (95% CI) | Multivariate OR (95% CI) | N(%) | Age-adjusted OR (95% CI) | Multivariate OR (95% CI) | N(%) | | NR | | | | | | | | N(%) | Age-adjusted OR (95% CI) | Multivariate OR (95% CI) | N(%) | Age-adjusted OR (95% CI) | Multivariate OR (95% CI) | N(%) | Age-adjusted OR (95% CI) | Multivariate OR (95% CI) | N(%)
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Cases n=758 (melanoma n=200, SCC n=275, BCC n=283) Controls n=804 Mean age: 58.7 (range: 43–68) Sex: | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | | | | | | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Cases n=758 (melanoma n=200, SCC n=275, BCC n=283) Controls n=804 Mean age: 58.7 (range: 43–68) Sex: | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Low | 37(20.6) | 1.00 | 1.00 | 58(23.7) | 1.00 | 1.00 | 55(21.5) | 1.00 | 1.00 | 227(33.2) | | No | 140(76.9) | 1.00 | 1.00 | 212(83.8) | 1.00 | 1.00 | 215(83.0) | 1.00 | 1.00 | 625(87.8) | | NR | | | | | | | None | 29(17.1) | 1.00 | 1.00 | 46(20.0) | 1.00 | 1.00 | 49(20.1) | 1.00 | 1.00 | 231(34.5)
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Cases n=758 (melanoma n=200, SCC n=275, BCC n=283) Controls n=804 Mean age: 58.7 (range: 43–68) Sex: | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Intermediate | 47(26.1) | 1.25 (0.78–2.00) | 1.20 (0.73–1.97) | 74(30.2) | 1.28 (0.87–1.90) | 1.28 (0.85–1.93) | 92(35.9) | 1.66 (1.13–2.43) | 1.71 (1.14–2.56) | 228(33.4) | | Yes | 42(23.1) | 1.98 (1.30–3.02) | 2.06 (1.30–3.26) | 41(16.2) | 1.47 (0.98–2.22) | 1.44 (0.93–2.24) | 44(17.0) | 1.45 (0.97–2.16) | 1.32 (0.87–2.03) | 87(12.2) | | NR | | | | | | | 1–4 | 48(28.2) | 1.63(0.99–2.68) | 1.43(0.85–2.42) | 80(34.8) | 1.85(1.23–2.79) | 1.65(1.08–2.53) | 82(33.6) | 1.70(1.14–2.54) | 1.38(0.90–2.11) | 226(33.7)
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | Cases | Controls | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | High | 96(53.3) | 2.58 (1.69–3.94) | 2.37 (1.51–3.73) | 113(46.1) | 1.97 (1.37–2.85) | 2.15 (1.45–3.19) | 109(42.6) | 1.95 (1.34–2.83) | 2.05 (1.38–3.06) | 228(33.4) | | LRT | | | 0.01 | | | 0.24 | | | 0.35 | | | NR | | | | | | | 5–9 | 33(19.4) | 2.57(1.48–4.48) | 1.75(0.97–3.16) | 46(20.0) | 2.47(1.53–3.98) | 1.88(1.14–3.11) | 49(20.1) | 2.33(1.47–3.71) | 1.55(0.95–2.55) | 98(14.6)
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | | | | | | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Male | 0% | 0% | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Trend | | <0.001 | <0.001 | | <0.001 | <0.001 | | <0.001 | <0.001 | | | P=0.15 | | | | | | | | | | | | NR | | | | | | | ≥10 | 60(35.3) | 3.90(2.36–6.47) | 2.24(1.30–3.84) | 58(25.2) | 2.72(1.73–4.29) | 1.67(1.02–2.72) | 64(26.2) | 2.62(1.69–4.06) | 1.37(0.84–2.21) | 115(17.2)
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Skin phenotype: Skin reaction | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | LRT | | | <0.001 | | | <0.001 | | | <0.001 | | | LRT- likelihood ratio test. Adjusted for: age, constitutional susceptibility, family history of skin cancer, number of lifetime severe sunburns which blistered, cumulative sun exposure while wearing a bathing suit, geographic region | | | | | | | | | | | | NR | | | | | | | Trend | | <0.001 | 0.003 | | <0.001 | 0.04 | | <0.001 | 0.15
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | Melanoma | SCC | BCC | Control | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | P=0.15; adjusted for: age, constitutional susceptibility, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region Interaction between constitutional susceptibility score and sun exposure with a bathing suit on melanoma risk | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | LRT | | | 0.04 | | | 0.01 | | | 0.37
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | | | | | | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Practically none | 12 (6.6%) | 12 (4.8%) | 17 (6.7%) | 92 (13.0%) | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Susceptibility score (tertile) | | Sun exposure with a bathing suit (tertile) | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | P=0.43
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Some redness | 62 (33.9%) | 94 (37.3%) | 82 (32.2%) | 327 (46.3%) | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Susceptibility score (tertile) | | Low | Intermediate | High | | | | | | | | | | | | | | | | | | | | NR | | | | | | | LRT- likelihood ratio test. Adjusted for: age, constitutional susceptibility, family history of skin cancer, cumulative sun exposure while wearing a bathing suit, sunlamp use or tanning salon attendance, geographic region
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | | | | | | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Burn | 72 (39.3%) | 81 (32.1%) | 91 (35.7%) | 201 (28.4%) | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Low | | | | | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | Painful burn | 37 (20.2%) | 65 (25.8%) | 65 (25.5%) | 87 (12.3%) | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Cases (%) | | 5 (20.0) | 12 (48.0) | 8 (32.0) | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Controls (%) | | 62 (27.9) | 70 (31.5) | 90 (40.5) | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | OR (95% CI) | | 1.00 | 1.92 (0.63–5.90) | 0.97 (0.30–3.16) | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Intermediate | | | | | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Cases (%) | | 11 (21.2) | 12 (23.1) | 29 (55.8) | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Controls (%) | | 78 (33.3) | 86 (36.8) | 70 (29.9) | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | OR (95% CI) | | 1.73 (0.56–5.32) | 1.39 (0.46–4.23) | 4.13 (1.47–11.61) | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | High | | | | | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Cases (%) | | 21 (20.4) | 23 (22.3) | 59 (57.3) | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | Controls (%) | | 87 (38.3) | 72 (31.7) | 68 (30.0) | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | OR (95% CI) | | 2.65 (0.93–7.60) | 3.02 (1.06–8.62) | 8.37 (3.07–22.84) | | | | | | | | | | | | | | | | | | | | NR
Han 2006^71^ Nurses' Health Study | Skin Cancer: SCC, BCC & melanoma Study Design: Nested case-control Location: US (11 states) | | | | | | | | Sun exposure, sun lamp/bed exposure Mailed questionnaire | Age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region, sun exposure while wearing a bathing suit | adjusted for: age, family history of skin cancer, number of lifetime severe sunburns which blistered, sunlamp use or tanning salon attendance, geographic region | | | | | | | | | | | | | | | | | | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | [underlined: Cases:] Selection: People with malignant melanoma living in kibbutzim who participated in a health survey conducted in 1992 were recruited by the kibbutz nurses Eligibility criteria: Level 1 non-invasive melanomas and all other histological forms of melanoma [underlined: Controls:] Selection: People living in kibbutzim who participated in a health survey conducted in 1992 were recruited by the kibbutz nurses Eligibility criteria: Sex and age matched (±3 years) | Cases n= 168 Controls n= 325 Mean age (SD): Cases: 53.5 (13.9) Controls: 53.1 (13.6) Sex: | | | | | | Sun exposure Structured questionnaire | NR | Number of hours of sun exposure, age 6–13 (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | Cases n= 168 Controls n= 325 Mean age (SD): Cases: 53.5 (13.9) Controls: 53.1 (13.6) Sex: | | | | | | Sun exposure Structured questionnaire | NR | | | | | Cases | | Controls | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | Cases n= 168 Controls n= 325 Mean age (SD): Cases: 53.5 (13.9) Controls: 53.1 (13.6) Sex: | | | | | | Sun exposure Structured questionnaire | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | Cases n= 168 Controls n= 325 Mean age (SD): Cases: 53.5 (13.9) Controls: 53.1 (13.6) Sex: | | | | | | Sun exposure Structured questionnaire | NR | 3+ hours/day | | | | 34 (20.0%) | | 40 (12.3%) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | Cases n= 168 Controls n= 325 Mean age (SD): Cases: 53.5 (13.9) Controls: 53.1 (13.6) Sex: | | | | | | Sun exposure Structured questionnaire | NR | p<0.05 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | Cases n= 168 Controls n= 325 Mean age (SD): Cases: 53.5 (13.9) Controls: 53.1 (13.6) Sex: | | | | | | Sun exposure Structured questionnaire | NR | Number of hours of sun exposure, age 14–18, 18–21, and above 21 p=NS in conditional logistic regression, exposure to sun at various ages was not significantly associated with malignant melanoma (results not shown), only hair color, skin sensitivity and other skin lesions were independently associated with malignant melanoma Odds ratios and exposure to sun at work from age 21 (number of years at work x number of hours per day exposed) (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | | | Cases | Controls | | | Sun exposure Structured questionnaire | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | | | | | | | Sun exposure Structured questionnaire | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | Male | | 75 (44.6%) | 144 (44.3%) | | | Sun exposure Structured questionnaire | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | Skin phenotype: Skin sensitivity* | | | | | | Sun exposure Structured questionnaire | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | | | Cases | Controls | | | Sun exposure Structured questionnaire | NR | | | Cases | | Controls | | OR (95% CI) | | P | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | | | | | | | Sun exposure Structured questionnaire | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | Sensitive | | 151 (91.5%) | 242 (76.3%) | | | Sun exposure Structured questionnaire | NR | None | | 8 (5%) | | 33 (10%) | | 2.44 (1.01–5.91) | | <0.05 | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | Not sensitive | | 14 (8.5%) (c) | 75 (23.7%) | | | Sun exposure Structured questionnaire | NR | 1+ | | NR | | NR | | NR | | NS | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Tabenkin 1999^76^ | Skin Cancer: Melanoma Study Design: Case-control Location: Israel | | *These numbers don't add up to 168 and 325 | | | | | | Sun exposure Structured questionnaire | NR | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | NR
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | [underlined: Cases:] Selection: First primary cutaneous melanoma diagnosed between 1979–80 in residents of Queensland from pathology laboratories throughout the state Eligibility criteria: excluded those with acral lentiginous melanoma and lentigo maligna melanoma analyzed separately (not included in the 183 cases) [underlined: Controls:] Selection: Sex, age (±5 years), and area of residence matched from Electoral Roll Eligibility criteria: NR | Cases n= 183 (excludes lentigo maligna) Controls n= 183 Mean age: NR | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Relative risk of melanoma and number of cumulative hours of sun exposure - excluding cases of lentigo malignant melanoma (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Risk of melanoma in relation to experience of severe sunburns in life
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | Cases n= 183 (excludes lentigo maligna) Controls n= 183 Mean age: NR | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | | | | | Cases | | Controls | | Crude RR | | Adjusted* RR (95% CI) | | NR | | | | | | | | | | | | NR | | | | | | | | | Unadjusted RR
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | Cases n= 183 (excludes lentigo maligna) Controls n= 183 Mean age: NR | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | Cases n= 183 (excludes lentigo maligna) Controls n= 183 Mean age: NR | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | <2,000 | | | | 12 (6.6%) | | 21 (11.5%) | | 1.0 | | 1.0 | | NR | | | | | | | | | | | | NR | | | | | | | # sunburns | | Unmatched | | Matched | | Adjusted RR* (95% CI)
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | Cases n= 183 (excludes lentigo maligna) Controls n= 183 Mean age: NR | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | Cases n= 183 (excludes lentigo maligna) Controls n= 183 Mean age: NR | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | 2,000− | | | | 78 (42.6%) | | 78 (42.6%) | | 1.8 | | | | NR | | | | | | | | | | | | NR | | | | | | | 0–1 | | 1.0 | | 1.0 | | 1.0
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | Age range | | Controls only (183 controls) | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | 20,000− | | | | 53 (29.0%) | | 53 (29.0%) | | 1.8 | | 3.2 (0.9–12.4) | | NR | | | | | | | | | | | | NR | | | | | | | 2–5 | | 2.4 | | 1.9 | | 1.5 (0.7–3.2)
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | <35 | | 46 (25%) | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | 50,000–100,000 | | | | 31 (16.9%) | | 24 (13.1%) | | 2.3 | | | | NR | | | | | | | | | | | | NR | | | | | | | ≥6 | | 3.3 | | 5.0 | | 2.4 (1.0–6.1)
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | 35–49 | | 58 (32%) | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | >100,000 | | | | 9 (4.9%) | | 7 (3.8%) | | 2.3 | | 5.3 (0.9–30.8) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | 50+ | | 79 (43%) | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | *Adjusted for exact age, presence of nevi on the arms, hair color, and sunburn propensity Relative risk of melanoma and cumulative hours sun exposure (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | Sex: NR Skin phenotype: Propensity to sunburn | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | | | | | Cases | | Controls | | Crude RR | | Adjusted* RR (95% CI) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | Cases | Controls | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Whole of life | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | Tan only | | 12 (7%) | 31 (17%) | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | <2000 | | | | 12 (9.9%) | | 21 (17.1%) | | 1.0 | | 1.0 | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | Burn, then tan | | 41 (22%) | 58 (32%) | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | 2000− | | | | 78 (64.5%) | | 78 (63.4%) | | 1.7 | | 2.3 (1.0–5.1) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | Burn, then peel | | 130 (71%) | 94 (71%) | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | 50,000− | | | | 31 (25.6%) | | 24 (19.5%) | | 2.3 | | 1.7 (0.4–7.8) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Ages 10–19 years | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | <500 | | | | 42 (27.5%) | | 52 (34.2%) | | 1.0 | | 1.0 | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | 500− | | | | 70 (45.8%) | | 81 (52.6%) | | 1.1 | | 1.0 (0.5–2.0) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | 5000− | | | | 41 (26.8%) | | 21 (13.6%) | | 1.8 | | 4.4 (1.8–184.5) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | The 5 years prior to diagnosis | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | <500 | | | | 87 (49.2%) | | 74 (42.0%) | | 1.0 | | 1.0 | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | 500− | | | | 78 (44.1%) | | 92 (52.3%) | | 0.7 | | 0.9 (0.5–1.6) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | 5000− | | | | 12 (6.8%) | | 10 (5.7%) | | 0.9 | | 1.2 (0.5–2.9) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | *Adjusted for age and presence of naevi on arms Recreational hours spent on the beach in the sun during different life periods and associated risk of melanoma, crude and adjusted for presence of naevi on the arms and age | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Life period | | Hours | | Cases | | Controls | | Crude RR | | Adjusted RR (95% CI) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Whole life | | 0 | | 18 (9.8%) | | 13 (7.1%) | | 1.0 | | 1.0 | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Whole life | | 1− | | 79 (43.2%) | | 72 (39.3%) | | 0.8 | | 0.6 (0.2–1.4) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Whole life | | 500− | | 70 (38.3%) | | 92 (50.3%) | | 0.5 | | 0.3 (0.1–0.8) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Whole life | | 5000− | | 16 (8.7%) | | 6 (3.3%) | | 1.9 | | 1.3 (0.4–4.3) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Ages 10–19 | | 0 | | 54 (29.5%) | | 64 (35.0%) | | 1.0 | | 1.0 | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Ages 10–19 | | 1− | | 99 (54.1%) | | 85 (46.4%) | | 1.4 | | 1.1 (0.6–2.0) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | Ages 10–19 | | 500− | | 30 (16.4%) | | 34 (18.6%) | | 1.0 | | 0.8 (0.4–1.9) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | The 5 years prior to dx | | 0 | | 61 (33.3%) | | 49 (26.8%) | | 1.0 | | 1.0 | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | The 5 years prior to dx | | 1− | | 104 (56.8%) | | 122 (66.7%) | | 0.7 | | 0.6 (0.0–1.0) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Green 1985^77^ Green 1986^133^ Green 1985^140^ Green 1984^141^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Queensland, Australia | | | | | | | | Sun exposure Interviewed at home, work, or hospital outpatient departments using a standard questionnaire | Age, presence of nevi on the arms, hair color, sunburn propensity | The 5 years prior to dx | | 500− | | 18 (9.8%) | | 12 (6.6%) | | 1.2 | | 0.9 (0.3–3.1) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for presence of naevi on the arms and exact age
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | [underlined: Cases:] Selection: All new cases of cutaneous malignant melanoma diagnosed between 1984–86 in residents of Turin, Italy from the local Cancer Registry Eligibility criteria: NR [underlined: Controls:] Selection: From the roster of the National Health Service of Turin Eligibility criteria: NR | Cases n= 260 Controls n= 416 Mean age: Cases: 56, range 19–92 Controls: 55, range 17–92 Sex: | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | Odds ratios of melanoma and number of weeks of sunny vacation (beach holiday), childhood and teenage (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Odds ratios of melanoma by sunburns in childhood (calc) | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Cases n= 260 Controls n= 416 Mean age: Cases: 56, range 19–92 Controls: 55, range 17–92 Sex: | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | | | Cases | | Controls | | OR* (95% CI) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | | | | | Cases | | Controls | | OR* (95% CI) | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Cases n= 260 Controls n= 416 Mean age: Cases: 56, range 19–92 Controls: 55, range 17–92 Sex: | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Cases n= 260 Controls n= 416 Mean age: Cases: 56, range 19–92 Controls: 55, range 17–92 Sex: | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | 0 | | 182 (79.5%) | | 326 (78.7%) | | 1.0 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Never | | | | 186 (71.5%) | | 382 (92.3%) | | 1.0 | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Cases n= 260 Controls n= 416 Mean age: Cases: 56, range 19–92 Controls: 55, range 17–92 Sex: | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | 1–59 | | 42 (18.3%) | | 37 (8.9%) | | 2.8 (1.6–4.6) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Sometimes | | | | 48 (18.5%) | | 26 (6.3%) | | 4.4 (2.5–7.5) | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Cases n= 260 Controls n= 416 Mean age: Cases: 56, range 19–92 Controls: 55, range 17–92 Sex: | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | ≥60 | | 35 (18.3%) | | 51 (12.3%) | | 1.7 (1.0–2.9) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Often | | | | 26 (10.0%) | | 6 (1.4%) | | 12.0 (4.6–31.0) | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Cases n= 260 Controls n= 416 Mean age: Cases: 56, range 19–92 Controls: 55, range 17–92 Sex: | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | p=0.003 | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | p<0.001 | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Cases n= 260 Controls n= 416 Mean age: Cases: 56, range 19–92 Controls: 55, range 17–92 Sex: | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | Odds ratios of melanoma and number of sunny vacations (beach holidays) in lifetime (calc) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Odds ratios of melanoma by severe sunburns lifelong (calc) | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | | | Cases | Controls | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | | | Cases | | Controls | | OR* (95% CI) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | | | | | Cases | | Controls | | OR* (95% CI) | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Male | | 74 (28.5%) | 211 (50.7%) | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | 0 | | 74 (28.9%) | | 148 (36.3%) | | 1.0 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Never | | | | 180 (70.9%) | | 328 (80.0%) | | 1.0 | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | 1–29 | | 25 (9.8%) | | 62 (15.2%) | | 0.9 (0.5–1.6) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | 1 | | | | 50 (19.7%) | | 53 (12.9%) | | 1.7 (1.1–2.6) | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | 30–59 | | 34 (13.3%) | | 50 (12.3%) | | 1.6 (0.9–2.8) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | ≥2 | | | | 24 (9.4%) | | 29 (7.1%) | | 1.5 (0.8–2.7) | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | 60–89 | | 36 (14.1%) | | 51 (12.5%) | | 1.6 (0.9–2.9) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | p=0.04 | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | 90–119 | | 28 (10.9%) | | 42 (10.3%) | | 1.5 (0.8–2.7) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | ≥120 | | 59 (23.0%) | | 55 (13.5%) | | 2.3 (1.4–3.8) | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | | | | | | | p=0.001 | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | *Adjusted for sex and age in decades | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | Hazard ratios for risk of DEATH FOR MELANOMA and number of weeks of on the beach during childhood and adulthood, HR (95% CI) | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | # weeks on beach adulthood | | | | | | # weeks on beach childhood | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | | | | | | | 0 | | 1–59 | | >60 | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | 0 | | | | | | ref | | 1.87 (0.49, 7.2) | | 0.75 (0.10, 5.7) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | 1–59 | | | | | | 0.40 (0.17, 0.94) | | 0.14 (0.02, 0.96) | | 0.13 (0.01, 5.1) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | >60 | | | | | | 0.42 (0.18, 0.98) | | 0.36 (0.10, 1.3) | | 0.68 (0.25, 1.9) | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Zanetti 1992^84^ Rosso 2008^142^ | Skin Cancer: Melanoma Study Design: Case-control Location: Turin, Italy | | Skin phenotype: NR | | | | | | Sun exposure Interviewed by trained interviewers using a standard questionnaire | Sex and age in decades | *Adjusted for age, sex, education and follow-up period | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | *Adjusted for sex and age in decades | | | | | | | | | | | | Long-term follow-up mortality data from Rosso 2008, it was not possible to identify the cause of death in 17% of deaths (22/128)
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | [underlined: Cases:] Selection: All new cases of SCC and BCC diagnosed between 1994–96 from the Sion Cancer Registry Eligibility criteria: Aged 20–75 years [underlined: Controls:] Selection: Recruited from lists of contributors and supporters of the Swiss League for the Fight Against Cancer and volunteer associations of blood donors (approx. 65% of population) Eligibility criteria: Age and sex matched | Cases n= 146 Controls n= 144 Mean age: NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | Odds ratio of BCC and SCC by lifetime hours of outdoor work (calc) | | | | | | | | | | | | Odds ratio of BCC and SCC by use of a sunlamp (calc) | | | | | | | | | | | | Odds ratio for BCC and SCC by use of sunscreens (calc) | | | | | | | Odds ratio of BCC and SCC by number of painful sunburns in a lifetime (calc)
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Cases n= 146 Controls n= 144 Mean age: NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | | | BCC | | SCC | | Controls | | BCC OR* (95% CI) | | SCC OR* (95% CI) | | | | | | Never | | Yes | | | | | | | BCC | SCC | Controls | BCC OR* (95% CI) | SCC OR* (95% CI) | | | | BCC | | SCC | | Controls | | BCC OR* (95% CI) | | SCC OR* (95% CI)
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Cases n= 146 Controls n= 144 Mean age: NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Cases n= 146 Controls n= 144 Mean age: NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | Never | | 61 (51.3%) | | 7 (28.0%) | | 69 (47.9%) | | 1.0 | | 1.0 | | BCC | | | | 110 (91.7%) | | 10 (8.3%) | | | | | | Never | 56 (46.7%) | 16 (64.0%) | 93 (64.6%) | 1.0 | 1.0 | | Never | | 82 (68.3%) | | 23 (92.0%) | | 119 (82.6%) | | 1.0 | | 1.0
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Cases n= 146 Controls n= 144 Mean age: NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | −12,000 | | 19 (16.0%) | | 3 (12.0%) | | 19 (13.2%) | | 0.98 (0.58–1.66) | | 1.84 (0.30–11.09) | | SCC | | | | 25 (100%) | | 0 (0%) | | | | | | Yes | 64 (53.3%) | 9 (36.0%) | 51 (35.4%) | 1.69 (1.14–2.05) | 1.63 (0.41–6.53) | | 1 | | 14 (11.7%) | | 2 (8.0%) | | 19 (13.2%) | | 0.97 (0.59–1.59) | | not estimable (sparse data)
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Cases n= 146 Controls n= 144 Mean age: NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | −47,900 | | 19 (16.0%) | | 2 (8.0%) | | 19 (13.2%) | | 1.30 (0.69–2.46) | | | | Controls | | | | 135 (93.8%) | | 9 (6.2%) | | | | | | *Adjusted for sex and age | | | | | | | 2 | | 5 (4.2%) | | 0 (0%) | | 3 (2.1%) | | 1.26 (0.41–3.86) | | --
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | Cases | Controls | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | −77,200 | | 12 (10.1%) | | 9 (7.6%) | | 19 (13.2%) | | 0.78 (0.52–1.19) | | 2.02 (0.60–6.78) | | BCC OR* (95% CI) | | | | 1.0 | | 1.24 (0.53–2.88) | | | | | | *Adjusted for sex and age | | | | | | | 3+ | | 14 (11.7%) | | 0 (0%) | | 3 (2.1%) | | 2.42 (1.74–3.36) | | --
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | | | | | | | | | | | | | | | | | | | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Male | | 76 (52.4%) | NR | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | 77,200+ | | 8 (6.7%) | | 4 (16.0%) | | 18 (12.5%) | | 0.90 (0.51–1.59) | | 1.88 (0.30–11.70) | | SCC OR* (95% CI) | | | | 1.0 | | -- | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Skin phenotype: Skin reaction to sun exposure | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | Odds ratio of BCC and SCC by lifetime hours at the beach on vacation (calc) | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | BCCs | SCCs | Controls | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | | | BCC | | SCC | | Controls | | BCC OR* (95% CI) | | SCC OR* (95% CI) | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Tan no burn | | 16(13.3%) | 7(28.0%) | 41(28.5%) | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | Never | | 50 (41.7%) | | 15 (60.0%) | | 75 (52.1%) | | 1.0 | | 1.0 | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Rare burn then tan | | 48(40.0%) | 8(32.0%) | 62(43.1%) | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | <300 | | 24 (20.0%) | | 2 (8.8%) | | 19 (13.2%) | | 1.46 (0.52–4.07) | | | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Often burn then tan | | 35(29.2%) | 6(24.0%) | 31(21.5%) | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | −1,140 | | 15 (12.5%) | | 3 (12.0%) | | 16 (11.1%) | | 1.39 (0.72–2.66) | | | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Burn never tan | | 16(13.3%) | 2(8.0%) | 10(6.9%) | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | −2,260 | | 7 (5.8%) | | 2 (8.8%) | | 16 (11.1%) | | 0.92 (0.44–1.91) | | | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | Missing data | | 5(4.2%) | 2(8.0%) | 0(0%) | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | 2,260+ | | 24 (20.0%) | | 3 (12.0%) | | 18 (12.5%) | | 1.20 (0.61–2.34) | | 0.78 (0.26–2.40) | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | Odds ratio of BCC and SCC by lifetime hours of sun exposure (calc) | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | | | BCC | | SCC | | Controls | | BCC OR* (95% CI) | | SCC OR* (95% CI) | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | <5,000 | | 33 (27.5%) | | 5 (20.0%) | | 37 (25.7%) | | 1.0 | | 1.0 | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | −15,800 | | 37 (30.8%) | | 2 (8.0%) | | 36 (25.0%) | | 1.09 (0.62–1.92) | | | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | −64,200 | | 33 (27.5%) | | 9 (36.0%) | | 36 (25.0%) | | 0.99 (0.35–2.79) | | 1.78 (0.18–17.67) | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | 64,200+ | | 17 (14.2%) | | 9 (36.0%) | | 35 (24.3%) | | 0.70 (0.20–2.39) | | 1.42 (0.53–3.85) | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Rosso 1999^64^ | Skin Cancer: SCC and BCC Study Design: Casecontrol Location: Valais, Switzerland | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Interviewed by trained interviewers using the standard questionnaire from the HELIOS study | Age and sex | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | | | | | | *Adjusted for sex and age | | | | | | | *Adjusted for sex and age
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | [underlined: Cases:] Selection: Newly diagnosed BCC and SCC between 1993–95 from a collaborative network of dermatologists and pathology laboratories throughout New Hampshire and its bordering regions Eligibility criteria: Aged 25–74 years [underlined: Controls:] Selection: New Hampshire residents from the New Hampshire Department of Transportation listing and the Medicare Program of the Centers for Medicare and Medicaid Services Eligibility criteria: Age and sex matched | Cases n= 896 (BCC n=603, SCC n=293) Controls n= 540 Mean age: NR Sex (calc): | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | Odds ratios for BCC and SCC associated with tanning device use | | | | | | | | | | | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Cases n= 896 (BCC n=603, SCC n=293) Controls n= 540 Mean age: NR Sex (calc): | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | | | BCC | | SCC | | Controls | | BCC OR (95% CI) | | SCC OR (95% CI) | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Cases n= 896 (BCC n=603, SCC n=293) Controls n= 540 Mean age: NR Sex (calc): | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Cases n= 896 (BCC n=603, SCC n=293) Controls n= 540 Mean age: NR Sex (calc): | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | No | | 474 (78.9%) | | 229 (78.4%) | | 464 (86.1%) | | 1.0 | | 1.0 | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Cases n= 896 (BCC n=603, SCC n=293) Controls n= 540 Mean age: NR Sex (calc): | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | Yes | | 127 (21.1%) | | 63 (21.6%) | | 75 (13.9%) | | 1.5 (1.1–2.1) | | 2.5 (1.7–3.8) | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | | | Cases | Controls | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | effects similar in men and women (data not shown) | | | | | | | | | | | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Male | | 527 (59%) | 325 (60.3%) | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | Odds ratios for BCC and SCC associated with age at first tanning device use | | | | | | | | | | | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Skin phenotype: NR | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | | | BCC | | SCC | | Controls | | BCC OR (95% CI) | | SCC OR (95% CI) | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Skin phenotype: NR | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Skin phenotype: NR | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | No use | | 474 (78.9%) | | 229 (78.4%) | | 464 (86.1%) | | 1.0 | | 1.0 | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Skin phenotype: NR | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | <20 | | 46 (7.7%) | | 24 (8.2%) | | 23 (4.3%) | | 1.8 (1.0–3.0) | | 3.6 (1.9–6.9) | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Skin phenotype: NR | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | 20–35 | | 42 (7.0%) | | 20 (6.9%) | | 26 (4.8%) | | 1.4 (0.8–2.3) | | 2.8 (1.4–5.5) | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Skin phenotype: NR | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | >35 | | 39 (6.5%) | | 19 (6.5%) | | 26 (4.8%) | | 1.4 (0.8–2.3) | | 1.7 (0.9–3.2) | | NR | | | | | | | NR
Karagas 2002^88^ | Skin Cancer: BCC and SCC Study Design: Casecontrol Location: New Hampshire and bordering regions | | Skin phenotype: NR | | | | | | Sunlamp exposure Structured personal interviews | Age, sex, skin sensitivity | NR | | | | | | | | | | | | Test for trend | | | | | | | | p=0.46 | | p=0.15 | | NR | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | [underlined: Cases:] Selection: Oahu residents diagnosed with melanoma 1986–87 (prevalent cases) or newly diagnosed 1988–92 (incident cases) from the Hawaii SEER database Eligibility criteria: Four grandparents of pure Caucasian origin, aged 18–79 years, invasive or in situ malignant melanoma. Excluded those with previous history of melanoma [underlined: Controls:] Selection: From a list of Caucasian Oahu residents interviewed by the Hawaii State Department of Health as part of a health survey of a 2% random sample of state households Eligibility criteria: Age and sex matched, four grandparents of pure Caucasian origin | Cases n= 278 Controls n= 278 Mean age (SD): Cases: 53.7 (15.0) Controls: 52.1 (15.0) Sex (calc): | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | Risk of melanoma and number of hours during summer in bathing suit, age 8–10 years | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Risk of melanoma and number of blistering sunburns age 0–9
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Cases n= 278 Controls n= 278 Mean age (SD): Cases: 53.7 (15.0) Controls: 52.1 (15.0) Sex (calc): | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | Males | | | | | Females | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Males | | | | | Females
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Cases n= 278 Controls n= 278 Mean age (SD): Cases: 53.7 (15.0) Controls: 52.1 (15.0) Sex (calc): | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Cases n= 278 Controls n= 278 Mean age (SD): Cases: 53.7 (15.0) Controls: 52.1 (15.0) Sex (calc): | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | No. | | Cases | Controls | OR (95% CI) | No. | Cases | Controls | OR (95% CI) | | | | NR | | | | | | | | | | | | NR | | | | | | | No. | | Cases | Controls | OR (95% CI) | No. | Cases | Controls | OR (95% CI)
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Cases n= 278 Controls n= 278 Mean age (SD): Cases: 53.7 (15.0) Controls: 52.1 (15.0) Sex (calc): | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Cases n= 278 Controls n= 278 Mean age (SD): Cases: 53.7 (15.0) Controls: 52.1 (15.0) Sex (calc): | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | 0 | | 74 (44.3%) | 88 (52.7%) | 1.0 | 0 | 35 (31.8%) | 52 (47.3%) | 1.0 | | | | NR | | | | | | | | | | | | NR | | | | | | | 0 | | 130 (77.8%) | 131(78.4%) | 1.0 | 0 | 83 (75.5%) | 91 (82.7%) | 1.0
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Cases n= 278 Controls n= 278 Mean age (SD): Cases: 53.7 (15.0) Controls: 52.1 (15.0) Sex (calc): | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | 1–32 | | 32 (19.2%) | 30 (18.0%) | 1.2 (0.6–2.3) | 1–20 | 28 (25.5%) | 17 (15.5%) | 2.1 (0.8–5.4) | | | | NR | | | | | | | | | | | | NR | | | | | | | 1–4 | | 19 (11.4%) | 16 (9.6%) | 0.9 (0.4–2.2) | 1–3 | 10 (9.1%) | 8 (7.3%) | 1.2 (0.3–4.4)
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Cases n= 278 Controls n= 278 Mean age (SD): Cases: 53.7 (15.0) Controls: 52.1 (15.0) Sex (calc): | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | 33–80 | | 27 (16.2%) | 31 (18.6%) | 0.9 (0.4–1.8) | 21–64 | 21 (19.1%) | 23 (20.9%) | 1.4 (0.5–3.7) | | | | NR | | | | | | | | | | | | NR | | | | | | | ≥5 | | 18 (10.8%) | 20 (18.2%) | 0.7 (0.4–1.5) | ≥4 | 17 (15.5%) | 11 (10.0%) | 1.2 (0.4–3.8)
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Cases n= 278 Controls n= 278 Mean age (SD): Cases: 53.7 (15.0) Controls: 52.1 (15.0) Sex (calc): | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | ≥80 | | 34 (20.4%) | 18 (10.8%) | 2.0 (0.9–4.4) | ≥65 | 26 (23.6%) | 18 (16.4%) | 3.4 (1.2–9.1) | | | | NR | | | | | | | | | | | | NR | | | | | | | | | | | p=0.34 | | | | p=0.58
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | Cases | Controls | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | p=0.14 | | | | p=0.03 | | | | NR | | | | | | | | | | | | NR | | | | | | | Risk of melanoma and number of blistering sunburns age 10–17
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Male | 167 (60.1%) | 167 (60.1%) | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | Risk of melanoma and number of hours during summer in bathing suit, past 5 years | | | | | | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | Males | | | | | Females
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Skin phenotype: Propensity to sunburn (calc) | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | Males | | | | | Females | | | | | | | NR | | | | | | | | | | | | NR | | | | | | | No. | | Cases | Controls | OR (95% CI) | No. | Cases | Controls | OR (95% CI)
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | Cases | Controls | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | No. | | Cases | Controls | OR (95% CI) | No. | Cases | Controls | OR (95% CI) | | | | NR | | | | | | | | | | | | NR | | | | | | | 0 | | 94 (56.3%) | 111 (66.5%) | 1.0 | 0 | 50 (45.5%) | 73 (66.4%) | 1.0
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Tan only | | 19 (6.9%) | 34 (12.4%) | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | 0 | | 86 (51.5%) | 108 (64.7%) | 1.0 | 0 | 31 (28.2%) | 56 (50.9%) | 1.0 | | | | NR | | | | | | | | | | | | NR | | | | | | | 1–4 | | 27 (16.2%) | 23 (13.8%) | 1.2 (0.6–2.2) | 1–3 | 25 (22.7%) | 13 (11.8%) | 2.4 (0.9–6.2)
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Mild burn and tanning | | 135 (49.1%) | 139 (50.5%) | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | 1–12 | | 29 (17.4%) | 26 (15.6%) | 1.4 (0.6–3.0) | 1–8 | 31 (28.2%) | 26 (15.6%) | 2.1 (0.8–5.6) | | | | NR | | | | | | | | | | | | NR | | | | | | | 5–12 | | 22 (13.2%) | 18 (10.8%) | 1.2 (0.6–2.6) | 4–10 | 15 (13.6%) | 12 (10.9%) | 3.3 (1.0–10.0)
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Severe burn and peeling | | 102 (37.1%) | 84 (30.5%) | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | 13–24 | | 23 (13.8%) | 16 (9.6%) | 1.9 (0.8–4.4) | 9–20 | 25 (22.7%) | 13 (11.8%) | 4.8 (1.7–13.4) | | | | NR | | | | | | | | | | | | NR | | | | | | | ≥13 | | 24 (14.4%) | 15 (9.0%) | 2.0 (0.9–4.6) | ≥11 | 20 (18.2%) | 12 (10.9%) | 1.9 (0.7–6.7)
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | Severe burn and blistering | | 19 (6.9%) | 18 (6.5%) | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | ≥25 | | 29 (17.4%) | 17 (10.2%) | 2.5 (1.2–5.4) | ≥21 | 23 (20.9%) | 15 (13.6%) | 3.3(1.1–10.10) | | | | NR | | | | | | | | | | | | NR | | | | | | | | | | | p=0.09 | | | | p=0.13
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | p=0.01 | | | | p=0.01 | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | Risk of melanoma and number of hours worked outdoors over lifetime | | | | | | | | | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | Males | | | | | Females | | | | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | No. | | Cases | Controls | OR (95% CI) | No. | Cases | Controls | OR (95% CI) | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | | | | | | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | ≤438 | | 42 (25.1%) | 42 (25.1%) | 1.0 | 0 | 45 (40.9%) | 58 (52.7%) | 1.0 | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | 439–1,644 | | 41 (24.6%) | 43 (25.7%) | 1.0 (0.5–2.0) | 1–330 | 17 (15.5%) | 16 (14.5%) | 1.3(0.6–3.8) | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | 1,645–3,360 | | 38 (22.8%) | 46 (27.5%) | 0.7 (0.4–1.5) | 331–864 | 22 (20.0%) | 13 (11.8%) | 1.8 (0.8–4.2) | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | ≥3,361 | | 46 (27.5%) | 36 (21.6%) | 1.3 (0.7–2.7) | ≥865 | 18 (16.4%) | 15 (13.6%) | 1.2 (0.5–3.0) | | | | NR | | | | | | | | | | | | NR
LeMarchand 2006^81^ | Skin Cancer: Melanoma Study Design: Casecontrol Location: Hawaii | | | | | | | | Sun exposure In-home interviews by trained interviewers | Height, education, hair color, ability to tan, and drinking status | | | | | p=0.36 | | | | p=0.59 | | | | NR | | | | | | | | | | | | NR
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | [underlined: Cases:] Selection: First diagnosis of malignant melanoma between 1988–1990 from the South Swedish Health Care Region Tumour Registry Eligibility criteria: Aged 15–75 years, physician consented [underlined: Controls:] Selection: Randomly selected from the National Population Registry of residents of the South Swedish Health Care Region Eligibility criteria: Parish-, sex-, and age- (within a year) matched | Cases n= 400 Controls n= 640 Mean age (SD): NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | The frequency of sunbathing or the duration of the practice of sunbathing was not related to melanoma risk (data not shown) Odds ratios for developing malignant melanoma in relation to sunbathing frequently during the summer (April–September) (calc) | | | | | | | | | | | | Odds ratio of malignant melanoma in individuals younger than age 30 by sunbed or sunlamp exposure | | | | | | | | | | | | Odds ratios for developing malignant melanoma in relation to use of sunscreen (calc) | | | | | | | Relative risk of malignant melanoma according to number of painful sunburns in different age groups (calc)
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Cases n= 400 Controls n= 640 Mean age (SD): NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | | | | | | | | | | | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | | | | Cases | Controls | Crude OR(95% CI) | Adjusted* OR(95% CI) | P | | | | Cases | | Controls | | Adjusted RR (95% CI) | | Crude RR (95% CI) | | Test for trend p value
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Cases n= 400 Controls n= 640 Mean age (SD): NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Cases n= 400 Controls n= 640 Mean age (SD): NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | | | | | | | | | | | | | Never | | 8 (32%) | | 19 (54%) | | 1.0 | | | | | | Never | 84(21.5%) | 182(28.8%) | 1.0 | 1.0 | | | Before age 15
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Cases n= 400 Controls n= 640 Mean age (SD): NR Sex (calc): | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | | | | | | | | | | | | | Ever | | 17 (68%) | | 16 (46%) | | 2.7 (0.7–9.8) | | | | | | Sometimes | 208(53.2%) | 334(52.8%) | 1.4(1.0–2.0) | 1.3(0.9–1.9) | | | Never | | 143(42.2%) | | 259(47.3%) | | 1.0 | | 1.0
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | | | Cases | Controls | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | | | Cases | | Controls | | Adjusted* OR (95% CI) | | | | | | *Adjusted for history of sunburns, blond hair color, red hair color, raised nevi, and history of frequent sunbathing during the summer | | | | | | | | | | | | Almost always | 99(25.3%) | 116(18.4%) | 2.1(1.4–3.2) | 1.8(1.1–2.8) | 0.01 | | 1–5 | | 149(44.0%) | | 224(40.9%) | | 1.4(1.0–1.9) | | 1.0(0.6–1.5)
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | | | | | | | | | | | | | *Adjusted for history of sunburns, blond hair color, red hair color, raised nevi, and history of frequent sunbathing during the summer
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Male | | 48.8% | 48.9% | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | No | | 301 (75.3%) | | 501 (78.3%) | | 1.0 | | | | | | *Adjusted for history of sunburns, blond hair color, red hair color, raised nevi, and history of frequent sunbathing during the summer | | | | | | | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | >5 | | 47(13.9%) | | 65(11.9%) | | 1.6(1.0–2.6) | | 1.0(0.5–2.1) | | >0.05
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | Yes | | 99 (24.7%) | | 139 (21.7%) | | 1.2 (0.9–1.7) | | | | | | Odds ratios for developing malignant melanoma in relation to use of sunbeds or sunlamps (times/year) in different age groups (calc) | | | | | | | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | Ages 15–19
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | p=0.25 | | | | | | | | | | | | Odds ratios for developing malignant melanoma in relation to use of sunbeds or sunlamps (times/year) in different age groups (calc) | | | | | | | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | Never | | 108(29.4%) | | 209(39.7%) | | 1.0 | | 1.0
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | | | Cases | | Controls | | Adjusted* Test for trend p value OR (95% CI) | | p value | | Test for trend p value | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | 1–5 | | 213(58.0%) | | 312(59.3%) | | 1.4(1.0–1.9) | | 1.3(0.8–2.0)
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | | | | | | | | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling)
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | <30 years | | | | | | | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | >5 | | 46(12.5%) | | 65(12.4%) | | 1.6(1.0–2.5) | | 0.9(0.4–2.1) | | >0.05
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | Never | | 8 (32.0%) | | 19 (54.3%) | | 1.0 | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | adjusted for raised nevi, red hair color, and blond/fair hair color
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | 1–10 | | 9 (36.0%) | | 13 (37.1%) | | 2.0 (0.5–8.0) | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | adjusted for raised nevi, red hair color, and blond/fair hair color
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | >10 | | 8 (32.0%) | | 3 (8.6%) | | 7.7 (1.0–63.6) | | 0.09 | | 0.02 | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | adjusted for raised nevi, red hair color, and blond/fair hair color
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | 30–60 years | | | | | | | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | adjusted for raised nevi, red hair color, and blond/fair hair color
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | Never | | 142 (65.4%) | | 230 (65.5%) | | 1.0 | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | adjusted for raised nevi, red hair color, and blond/fair hair color
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | 1–10 | | 51 (23.5%) | | 90 (25.6%) | | 1.0 (0.7–1.6) | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | adjusted for raised nevi, red hair color, and blond/fair hair color
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | 10 | | 24 (11.1%) | | 31 (8.8%) | | 1.4 (0.7–2.7) | | 0.21 | | 0.69 | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | adjusted for raised nevi, red hair color, and blond/fair hair color
Westerdahl 1994^86^ Westerdahl 1994^40^ Westerdahl 1995^41^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: NR | | | | | | Sun exposure, sunlamp exposure, sunscreen exposure Mailed questionnaires | History of sunburns, blond hair color, red hair color, raised nevi, outdoor employment during the summer, eye color, freckling, and history of frequent sunbathing during the summer | *Adjusted for exposure to sunbeds or sunlamps, history of sunburns, hair color, number of raised nevi, and history of malignant melanoma in immediate family | | | | | | | | | | | | *Adjusted for history of sunburns, blond/fair and red hair color, raised nevi, and history of frequent sunbathing during the summer | | | | | | | | | | | | *Adjusted for history of sunburns, history of frequent sunbathing during the summer, outdoor employment during the summer, and host factors (i.e. raised naevi, hair colour, eye colour, and freckling) | | | | | | | adjusted for raised nevi, red hair color, and blond/fair hair color
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | [underlined: Cases:] Selection: First diagnosis of cutaneous invasive malignant melanoma between 1995–1997 from the South Swedish Health Care Region Tumour Registry Eligibility criteria: Aged 16–80, physician consented [underlined: Controls:] Selection: Random sample from the National Population Registry of residents of the South Swedish Health Care Region Eligibility criteria: Sex-, age- (within a year), and parish-matched | Cases n= 558 Controls n= 891 Mean age (calc): | | | | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | Odds ratios for developing malignant melanoma in relation to frequency of sunbathing April–September by use of sunscreen | | | | | | | | | | | | NR | | | | | | | | | | | | Odds ratios for developing malignant melanoma in relation to sunscreen use (calc) | | | | | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Cases n= 558 Controls n= 891 Mean age (calc): | | | | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | | | OR (95% CI) Use of sunscreen | | | | OR* (95% CI) Use of sunscreen | | | | | | NR | | | | | | | | | | | | | Cases | Controls | OR (95% CI) | Adjusted* OR (95% CI) | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Cases n= 558 Controls n= 891 Mean age (calc): | | | | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | | | | | | | | | | | | | NR | | | | | | | | | | | | | | | | | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Cases n= 558 Controls n= 891 Mean age (calc): | | | | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | | | Never | | Ever | | Never | | Ever | | | | NR | | | | | | | | | | | | Use of sunscreens | | | | | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | | | | | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | | | | | | | | | | | | | NR | | | | | | | | | | | | | | | | | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | | | Cases | Controls | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | <15 times | | 1.0 | | 1.3 (1.0–1.9) | | 1.0 | | 1.3 (0.8–2.2) | | | | NR | | | | | | | | | | | | Never | 145(26.0%) | 275(30.9%) | 1.0 | 1.0 | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | | | | | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | | | | | | | | | | | | | NR | | | | | | | | | | | | | | | | | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | 18–50 | | NR | 292 (32.8%) | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | ≥15 times | | 0.8 (0.5–1.3) | | 1.1 (0.8–1.6) | | 0.9 (0.5–1.8) | | 1.2 (0.7–2.0) | | | | NR | | | | | | | | | | | | Sometimes | 269(48.2%) | 409(45.9%) | 1.3(1.0–1.7) | 1.3(0.9–1.9) | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | 51–80 | | NR | 599 (67.2%) | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | *Adjusted for sunburns after age 19 years, skin phototype, and hair color | | | | | | | | | | | | NR | | | | | | | | | | | | Always initially sometimes | +52 (9.3%) | 104 (11.7%) | 1.0 (0.7–1.5) | 0.9 (0.6–1.5) | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Sex (calc): | | | | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | *Adjusted for sunburns after age 19 years, skin phototype, and hair color | | | | | | | | | | | | NR | | | | | | | | | | | | Always | 92(16.5%) | 103(11.6%) | 1.9(1.3–2.7) | 1.8(1.1–2.9) | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | | | Cases | Controls | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | *Adjusted for sunburns after age 19 years, skin phototype, and hair color | | | | | | | | | | | | NR | | | | | | | | | | | | Number of years of regular use | | | | | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | | | | | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | *Adjusted for sunburns after age 19 years, skin phototype, and hair color | | | | | | | | | | | | NR | | | | | | | | | | | | | | | | | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Male | | NR | 443 (49.7%) | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | *Adjusted for sunburns after age 19 years, skin phototype, and hair color | | | | | | | | | | | | NR | | | | | | | | | | | | None | 145(61.2%) | 275(72.8%) | 1.0 | 1.0 | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | Skin phenotype: | | | | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | *Adjusted for sunburns after age 19 years, skin phototype, and hair color | | | | | | | | | | | | NR | | | | | | | | | | | | 1–20 | 48(20.3%) | 40(10.6%) | 3.8(1.5–9.6) | 4.3(0.8–21.9) | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | | | Cases | Controls | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | *Adjusted for sunburns after age 19 years, skin phototype, and hair color | | | | | | | | | | | | NR | | | | | | | | | | | | >20 | 44(18.6%) | 63(16.7%) | 1.3(0.6–2.7) | 1.7(0.5–5.6) | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | | | | | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | *Adjusted for sunburns after age 19 years, skin phototype, and hair color | | | | | | | | | | | | NR | | | | | | | | | | | | | | | | | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | III–IV | | NR | 588 (68.1%) | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | *Adjusted for sunburns after age 19 years, skin phototype, and hair color | | | | | | | | | | | | NR | | | | | | | | | | | | *Adjusted for hair color, history of sunburns, frequency of sunbathing during the summer, and the duration of each sunbathing occasion | | | | | | | NR
Westerdahl 2000^85^ | Skin Cancer: Melanoma Study Design: Case-control Location: Sweden | | I–II | | NR | 276 (31.9%) | | | Sun exposure, sunbed exposure, sunscreen exposure Mailed questionnaires | Hair color, history of sunburns, skin phototype, history of sunbathing, and number of raised naevi | *Adjusted for sunburns after age 19 years, skin phototype, and hair color | | | | | | | | | | | | NR | | | | | | | | | | | | *Adjusted for hair color, history of sunburns, frequency of sunbathing during the summer, and the duration of each sunbathing occasion | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | Cases n= 571 Controls n= 913 Mean age (calc): | | | | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | Odds ratios for developing cutaneous malignant melanoma in relation to sunbed use (calc) | | | | | | | | | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | Cases n= 571 Controls n= 913 Mean age (calc): | | | | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | | | Cases | | Controls | | OR (95% CI) | | Adjusted* OR (95% CI) | | Test for trend P-value | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | Cases n= 571 Controls n= 913 Mean age (calc): | | | | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | Cases n= 571 Controls n= 913 Mean age (calc): | | | | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | Exposure to sunbed | | | | | | | | | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | | | Cases | Controls | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | Never | | 319 (56.1%) | | 538 (59.1%) | | 1.0 | | 1.0 | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | | | | | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | 18–35 | | NR | 87 (9.6%) | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | Sometimes | | 162 (28.5%) | | 270 (29.7%) | | 1.1 (0.8–1.4) | | 1.1 (0.8–1.4) | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | 36–60 | | NR | 381(41.9%) | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | Regular | | 88 (15.5%) | | 102 (11.2%) | | 1.6 (1.1–2.4) | | 1.8 (1.2–2.7) | | 0.05 | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | 61–80 | | NR | 442 (48.6%) | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | Total number of sunbed uses | | | | | | | | | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | Sex: | | | | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | None | | 319 (78.6%) | | 538 (84.3%) | | 1.0 | | 1.0 | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | | | Cases | Controls | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | 1–125 | | 22 (4.1%) | | 32 (5.0%) | | 1.7 (0.8–3.7) | | 2.8 (1.0–7.8) | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | | | | | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | Male | | 49.7% | 49.2% | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | 126–250 | | 34 (8.4%) | | 31 (4.9%) | | 2.2 (1.1–4.4) | | 3.1 (1.3–7.1) | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | Skin phenotype (calc): skin reaction to sun exposure | | | | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | >250 | | 31 (7.6%) | | 37 (5.8%) | | 1.3 (0.7–2.5) | | 1.5 (0.7–3.2) | | 0.26 | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | | | Cases | Controls | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | Age at first exposure | | | | | | | | | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | | | | | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | Tan/noburn | | NR | 118 (13.0%) | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | Never | | 319 (78.4%) | | 538 (84.3%) | | 1.0 | | 1.0 | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | Moderate tan | | NR | 479 (52.6%) | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | ≤35 | | 50 (12.3%) | | 56 (8.8%) | | 2.0 (1.2–3.5) | | 2.3 (1.2–4.2) | | | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | Light tan | | NR | 272(29.9%) | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | >35 | | 38 (9.3%) | | 44 (6.9%) | | 1.6 (0.9–2.5) | | 1.6 (0.9–2.9) | | NR | | NR | | | | | | | NR
Westerdahl 2000^42^ | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | No tan | | NR | 10 (1.1%) | | | See Westerdahl et al 2000^85^ | See Westerdahl et al 2000^85^ | NR | | | | | | | | | | | | *Adjusted for hair color, number of raised naevi, skin type, and number of sunburns | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | [underlined: Cases:] Selection: First diagnosis of cutaneous malignant melanoma between 1995–1998 from the New Hampshire State Cancer Registry Eligibility criteria: Aged 20–69 years, working telephone number, English speaking, physician of record consent [underlined: Controls:] Selection: Randomly selected from the New Hampshire Department of Motor Vehicles Eligibility criteria: sex-, and age- (within 5 year age groups) matched | Cases n= 423 Controls n= 678 Mean age (SD): Cases: 50.1 (12.2) Controls: 50.3 (11.6) Sex: | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Odds ratios for developing cutaneous malignant melanoma in relation to sunlamp use | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Cases n= 423 Controls n= 678 Mean age (SD): Cases: 50.1 (12.2) Controls: 50.3 (11.6) Sex: | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | | | Cases | | Controls | | Adjusted* OR (95% CI) | | Adjusted** OR (95% CI) | | Test for trend P-value | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Cases n= 423 Controls n= 678 Mean age (SD): Cases: 50.1 (12.2) Controls: 50.3 (11.6) Sex: | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Cases n= 423 Controls n= 678 Mean age (SD): Cases: 50.1 (12.2) Controls: 50.3 (11.6) Sex: | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Exposure to sunlamp | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Cases n= 423 Controls n= 678 Mean age (SD): Cases: 50.1 (12.2) Controls: 50.3 (11.6) Sex: | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Never | | 337 (79.7%) | | 576 (85.1%) | | 1.0 | | 1.0 | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Cases n= 423 Controls n= 678 Mean age (SD): Cases: 50.1 (12.2) Controls: 50.3 (11.6) Sex: | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Ever | | 86 (20.3%) | | 102 (15.0%) | | 1.46 (1.06–2.01) | | 1.39 (1.00–1.96) | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Cases n= 423 Controls n= 678 Mean age (SD): Cases: 50.1 (12.2) Controls: 50.3 (11.6) Sex: | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Frequency of sunlamp use | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Cases n= 423 Controls n= 678 Mean age (SD): Cases: 50.1 (12.2) Controls: 50.3 (11.6) Sex: | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Never | | 337 (79.9%) | | 576 (85.1%) | | 1.0 | | 1.0 | | p=0.02 | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | Cases | Controls | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | <6 times | | 52 (11.6%) | | 67 (9.4%) | | 1.33 (0.89–1.98) | | 1.29 (0.84–1.99) | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Male | | 223 (52.7%) | 348 (51.3%) | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | 6+ times | | 33 (8.5%) | | 34 (5.5%) | | 1.69 (1.05–2.73) | | 1.54 (0.93–2.57) | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Skin phenotype: Sun sensitivity from acute exposure | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Age at first use | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | Cases | Controls | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Never | | 337 (79.9%) | | 576 (85.1%) | | 1.0 | | 1.0 | | p=0.05 | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Tan only | | 14 (3.3%) | 68 (10.0%) | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | ≤20 | | 52 (12.3%) | | 67 (9.9%) | | 1.34 (0.91–1.98) | | 1.23 (0.81–1.88) | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Sunburn, then tan | | 185 (43.8%) | 286 (41.6%) | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | >20 | | 33 (7.8%) | | 34 (5.0%) | | 1.70 (1.03–2.80) | | 1.71 (1.00–2.92) | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Sunburn, peeling/freckling | | 20 (4.7%) | 42 (6.2%) | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Odds ratios for developing cutaneous malignant melanoma in relation to tanning bed use | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | Sunburn, then no tan | | 204 (48.2%) | 282 (42.2%) | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | | | Cases | | Controls | | OR (95% CI) | | Adjusted* OR (95% CI) | | Test for trend P-value | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Exposure to tanning bed | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Never | | 326 (77.1%) | | 536 (79.1%) | | 1.0 | | 1.0 | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Ever | | 97 (22.9%) | | 142 (20.9%) | | 1.15 (0.83–1.58) | | 1.14 (0.80–1.61) | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Frequency of tanning bed use | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Never | | 326 (77.1%) | | 536 (79.1%) | | 1.0 | | 1.0 | | p=0.42 | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | <10 times | | 43 (10.2%) | | 78 (12%) | | 0.93 (0.62–1.41) | | 1.05 (0.67–1.64) | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | 10+ times | | 54 (12.7%) | | 63 (9%) | | 1.46 (0.96–2.21) | | 1.25 (0.79–1.98) | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Age at first use | | | | | | | | | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | Never | | 326 (77.1%) | | 536 (79.2%) | | 1.0 | | 1.0 | | p=0.65 | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | ≤20 | | 18 (4.3%) | | 17 (2.5%) | | 1.89 (0.90 –3.97) | | 1.78 (0.76–4.15) | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | >20 | | 79 (18.6%) | | 124 (18.3%) | | 1.07 (0.78–1.51) | | 1.08 (0.75–1.55) | | | | NR | | | | | | | NR
Clough-Gorr 2008^92^ | Skin Cancer: Melanoma Study Design: Case-control Location: New Hampshire, US | | | | | | | | Sun sunbed exposure Telephone interview | Age, sex, education level, family history of melanoma, pigmentary characteristics, sunburn history, solar exposure history | NR | | | | | | | | | | | | *Adjusted for age and gender **Adjusted for age, gender, family history of melanoma, hair color, freckles, sun sensitivity, and total sun exposure hours | | | | | | | | | | | | NR | | | | | | | NR

Abbreviations: BCC=basal cell carcinoma; SCC=squamous cell carcinoma; RCT=randomized controlled trial; IG=intervention group; CG=control group; S=sunscreen; B=betacarotene; (S+B)=sunscreen and betacarotene; ppt=participant; CI=confidence interval; NR=not reported; RR=relative risk; BMI=body mass index; NHS=Nurses’ Health Study; OR=odds ratio; dx=diagnosis; fam hx=family history; SPF=sun protection factor; NS=not significant; LRT=likelihood ratio test; (c)=calculated.

Appendix C Table 2 Studies Excluded From the Review for Key Question 4

Reference | Reason for exclusion
Abdulla FR, Feldman SR, Williford PM, Krowchuk D, Kaur M. Tanning and skin cancer. Pediatr Dermatol. 2005;22:501–512. | Study design
Adam SA, Sheaves JK, Wright NH, Mosser G, Harris RW, Vessey MP. A case-control study of the possible association between oral contraceptives and malignant melanoma. Br J Cancer 1981;44(1):45–50. | Quality
Almahroos M, Kurban AK. Ultraviolet carcinogenesis in nonmelanoma skin cancer part II: review and update on epidemiologic correlations. Skinmed. 2004;3:132–139. | Study design
Araki K, Nagano T, Ueda M, et al. Incidence of skin cancers and precancerous lesions in Japanese—risk factors and prevention. J Epidemiol. 1999;9(6 Suppl):S14–21. | No relevant outcomes
Aubry F, MacGibbon B. Risk factors of squamous cell carcinoma of the skin. A case-control study in the Montreal region. Cancer. 1985;55:907–911. | Study design
Autier P, Dore JF, Cattaruzza MS, et al. Sunscreen use, wearing clothes, and number of nevi in 6- to 7-year-old European children. European Organization for Research and Treatment of Cancer Melanoma Cooperative Group. J Natl Cancer Inst. 1998;90:1873–1880. | Study design
Autier P, Dore JF, Gefeller O, et al. Melanoma risk and residence in sunny areas. EORTC Melanoma Cooperative Group. European Organization for Research and Treatment of Cancer. Br J Cancer. 1997;76:1521–1524. | Study design
Autier P, Dore JF, Lejeune F, et al. Cutaneous malignant melanoma and exposure to sunlamps or sunbeds: an EORTC multicenter case-control study in Belgium, France and Germany. EORTC Melanoma Cooperative Group. Int J Cancer. 1994;58:809–813. | Study design
Autier P, Dore JF, Schifflers E, et al. Melanoma and use of sunscreens: an EORTC case-control study in Germany, Belgium and France. EORTC Melanoma Cooperative Group. Int J Cancer. 1995;61:749–755. | Study design
Autier P. Cutaneous malignant melanoma: facts about sunbeds and sunscreen. Expert Rev Anticancer Ther. 2005;5:821–833. | Study design
Autier P. Perspectives in melanoma prevention: the case of sunbeds. Eur J Cancer. 2004;40:2367–2376. | Study design
Bajdik CD, Gallagher RP, Hill GB, Fincham S. Sunlight exposure, hat use, and squamous cell skin cancer on the head and neck. J Cutan Med Surg. 1998;3:68–73. | Outcome/exposure of interest not reported
Bakos L, Wagner M, Bakos RM, et al. Sunburn, sunscreens, and phenotypes: some risk factors for cutaneous melanoma in southern Brazil. Int J Dermatol. 2002;41:557–562. | Study design
Bastuji-Garin S, Diepgen TL. Cutaneous malignant melanoma, sun exposure, and sunscreen use: epidemiological evidence. Br J Dermatol. 2002;146(Suppl 61):24–30. | Study design
Bataille V, Winnett A, Sasieni P, Newton Bishop JA, Cuzick J. Exposure to the sun and sunbeds and the risk of cutaneous melanoma in the UK: a case-control study. Eur J Cancer. 2004;40:429–435. | Study design
Beitner H, Norell SE, Ringborg U, Wennersten G, Mattson B. Malignant melanoma: aetiological importance of individual pigmentation and sun exposure. Br J Dermatol. 1990;122:43–51. | Study design
Beral V, Evans S, Shaw H, Milton G. Malignant melanoma and exposure to fluorescent lighting at work. Lancet. 1982;2:290–293. | Study design
Beral V, Robinson N. The relationship of malignant melanoma, basal and squamous skin cancers to indoor and outdoor work. Br J Cancer. 1981;44:886–891. | No relevant outcomes
Berwick M, Armstrong BK, Ben-Porat L, et al. Sun exposure and mortality from melanoma. J Natl Cancer Inst. 2005;97:195–199. | Study design
Berwick M, Wiggins C. The current epidemiology of cutaneous malignant melanoma. Front Biosci. 2006;11:1244–1254. | Study design
Boniol M, Autier P, Dore JF. Photoprotection. Lancet. 2007;370:1481–1482. | Study design
Boscoe FP, Schymura MJ. Solar ultraviolet-B exposure and cancer incidence and mortality in the United States, 1993–2002. BMC Cancer. 2006;6:264. | Study design
Boyd AS, Shyr Y, King LE Jr. Basal cell carcinoma in young women: an evaluation of the association of tanning bed use and smoking. J Am Acad Dermatol. 2002;46:706–709. | Quality
Carey FA, Hogan JM. The relationship of sun exposure and solar elastosis to skin cancer in a high risk population. Ir J Med Sci. 1990;159:44–47. | Study design
Cho E, Rosner BA, Colditz GA. Risk factors for melanoma by body site. Cancer Epidemiol Biomarkers Prev. 2005;14:1241–1244. | No relevant outcomes
Cockburn M, Black W, McKelvey W, Mack T. Determinants of melanoma in a case-control study of twins (United States). Cancer Causes Control. 2001;12:615–625. | No relevant outcomes. Measures of sun exposure are very different from other studies
Cooke KR, Skegg DC, Fraser J. Socio-economic status, indoor and outdoor work, and malignant melanoma. Int J Cancer. 1984;34:57–62. | No relevant outcomes
Corona R, Dogliotti E, D’Errico M, et al. Risk factors for basal cell carcinoma in a Mediterranean population: role of recreational sun exposure early in life. Arch Dermatol. 2001;137:1162–1168. | Study design
Cress RD, Holly EA, Ahn DK. Cutaneous melanoma in women, V: characteristics of those who tan and those who burn when exposed to summer sun. Epidemiology. 1995;6:538–543. | Outcome/exposure of interest not reported
Dal H, Boldemann C, Lindelof B. Does relative melanoma distribution by body site 1960–2004 reflect changes in intermittent exposure and intentional tanning in the Swedish population? Eur J Dermatol. 2007;17:428–434. | Study relevance
Dennis LK, Beane Freeman LE, VanBeek MJ. Sunscreen use and the risk for melanoma: a quantitative review. Ann Intern Med. 2003;139:966–978. | Used as source document
Dixon A. Arc welding and the risk of cancer. Aust Fam Physician. 2007;36:255–256. | Study design
Dubin N, Moseson M, Pasternack BS. Epidemiology of malignant melanoma: pigmentary traits, ultraviolet radiation, and the identification of high-risk populations. Recent Results Cancer Res. 1986;102:56–75. | Study design
Dubin N, Moseson M, Pasternack BS. Sun exposure and malignant melanoma among susceptible individuals. Environ Health Perspect. 1989;81:139–151. | Study design
Dubin N, Pasternack BS, Moseson M. Simultaneous assessment of risk factors for malignant melanoma and non-melanoma skin lesions, with emphasis on sun exposure and related variables. Int J Epidemiol. 1990;19:811–819. | Study design
Dunn-Lane J, Herity B, Moriarty MJ, Conroy R. A case control study of malignant melanoma. Ir Med J. 1993;86:57–59. | Study design
el Khwsky F, Bedwani R, D’Avanzo B, et al. Risk factors for non-melanomatous skin cancer in Alexandria, Egypt. Int J Cancer. 1994;56:375–378. | Study design
Elwood JM, Jopson J. Melanoma and sun exposure: an overview of published studies. Int J Cancer. 1997;73:198–203. | Used as source document
Elwood JM, Williamson C, Stapleton PJ. Malignant melanoma in relation to moles, pigmentation, and exposure to fluorescent and other lighting sources. Br J Cancer. 1986;53:65–74. | Study design
Engel A, Johnson ML, Haynes SG. Health effects of sunlight exposure in the United States. Results from the first National Health and Nutrition Examination Survey, 1971–1974. Arch Dermatol. 1988;124:72–79. | Study design
English DR, Armstrong BK, Kricker A, Fleming C. Sunlight and cancer. Cancer Causes Control. 1997;8:271–283. | Study design
English DR, Milne E, Simpson JA. Sun protection and the development of melanocytic nevi in children. Cancer Epidemiol Biomarkers Prev. 2005;14:2873–2876. | No relevant outcomes
Espinosa AJ, Sanchez Hernandez JJ, Bravo FP, et al. Cutaneous malignant melanoma and sun exposure in Spain. Melanoma Res. 1999;9:199–205. | Study design
Evans RD, Kopf AW, Lew RA, et al. Risk factors for the development of malignant melanoma, I: review of case-control studies. J Dermatol Surg Oncol. 1988;14:393–408. | Study design
Farmer KC, Naylor MF. Sun exposure, sunscreens, and skin cancer prevention: a year-round concern. Ann Pharmacother. 1996;30:662–673. | Study design
Faurschou A, Wulf HC. Ecological analysis of the relation between sunbeds and skin cancer. Photodermatol Photoimmunol Photomed. 2007;23:120–125. | Study design
Fears TR, Gail MH. Analysis of a two-stage case-control study with cluster sampling of controls: application to nonmelanoma skin cancer. Biometrics. 2000;56:190–198. | Study relevance
Fears TR, Scotto J, Schneiderman MA. Mathematical models of age and ultraviolet effects on the incidence of skin cancer among whites in the United States. Am J Epidemiol. 1977;105:420–427. | Study design
Freedman DM, Zahm SH, Dosemeci M. Residential and occupational exposure to sunlight and mortality from non-Hodgkin’s lymphoma: composite (threefold) case-control study. BMJ. 1997;314:1451–1455. | No relevant outcomes
Fritschi L, Siemiatycki J. Melanoma and occupation: results of a case-control study. Occup Environ Med. 1996;53:168–173. | No relevant outcomes
Gafa L, Filippazzo MG, Tumino R, Dardanoni G, Lanzarone F, Dardanoni L. Risk factors of nonmelanoma skin cancer in Ragusa, Sicily: a case-control study. Cancer Causes Control. 1991;2:395–399. | Quality
Gallagher RP, Rivers JK, Lee TK, Bajdik CD, McLean DI, Coldman AJ. Broad-spectrum sunscreen use and the development of new nevi in white children: a randomized controlled trial. JAMA. 2000;283:2955–2960. | No relevant outcomes
Gallagher RP, Spinelli JJ, Lee TK. Tanning beds, sunlamps, and risk of cutaneous malignant melanoma. Cancer Epidemiol Biomarkers Prev. 2005;14:562–566. | Used as source document
Gamble JF, Lerman SE, Holder WR, Nicolich MJ, Yarborough CM. Physician-based case-control study of non-melanoma skin cancer in Baytown, Texas. Occup Med (Lond). 1996;46:186–196. | Quality
Gandini S, Sera F, Cattaruzza MS, et al. Meta-analysis of risk factors for cutaneous melanoma, III: family history, actinic damage and phenotypic factors. Eur J Cancer. 2005;41:2040–2059. | Study relevance
Gandini S, Sera F, Cattaruzza MS, et al. Meta-analysis of risk factors for cutaneous melanoma, I: common and atypical naevi. Eur J Cancer. 2005;41:28–44. | Study relevance
Gandini S, Sera F, Cattaruzza MS, et al. Meta-analysis of risk factors for cutaneous melanoma, II: sun exposure. Eur J Cancer. 2005;41:45–60. | Used as source document
Garbe C, Weiss J, Kruger S, et al. The German melanoma registry and environmental risk factors implied. Recent Results Cancer Res. 1993;128:69–89. | Quality
Gefeller O, Pfahlberg A. Sunscreen use and melanoma: a case of evidence-based prevention? Photodermatol Photoimmunol Photomed. 2002;18:153–156. | Study design
Geller AC, Colditz G, Oliveria S, et al. Use of sunscreen, sunburning rates, and tanning bed use among more than 10,000 US children and adolescents. Pediatrics. 2002;109:1009–1014. | No relevant outcomes
Giles GG, Marks R, Foley P. Incidence of non-melanocytic skin cancer treated in Australia. BMJ. 1988;296:13–17. | Study design
Goodman KJ, Bible ML, London S, Mack TM. Proportional melanoma incidence and occupation among white males in Los Angeles County (California, United States). Cancer Causes Control. 1995;6:451–459. | No relevant outcomes
Gorham ED, Mohr SB, Garland CF, Chaplin G, Garland FC. Do sunscreens increase risk of melanoma in populations residing at higher latitudes? Ann Epidemiol. 2007;17:956–963. | Used as source document
Graham S, Marshall J, Haughey B, et al. An inquiry into the epidemiology of melanoma. Am J Epidemiol. 1985;122:606–619. | Study design
Green A, Battistutta D. Incidence and determinants of skin cancer in a high-risk Australian population. Int J Cancer. 1990;46:356–361. | Study design
Green A, Beardmore G, Hart V, Leslie D, Marks R, Staines D. Skin cancer in a Queensland population. J Am Acad Dermatol. 1988;19:1045–1052. | Study design
Green A, McCredie M, MacKie R, et al. A case-control study of melanomas of the soles and palms (Australia and Scotland). Cancer Causes Control. 1999;10:21–25. | Study relevance
Green AE, Findley GB Jr, Klenk KF, Wilson WM, Mo T. The ultraviolet dose dependence of non-melanoma skin cancer incidence. Photochem Photobiol. 1976;24:353–362. | Study design
Hakansson N, Floderus B, Gustavsson P, Feychting M, Hallin N. Occupational sunlight exposure and cancer incidence among Swedish construction workers. Epidemiology. 2001;12:552–557. | No relevant outcomes
Harvey I, Frankel S, Marks R, Shalom D, Nolan-Farrell M. Non-melanoma skin cancer and solar keratoses, II: analytical results of the South Wales Skin Cancer Study. Br J Cancer. 1996;74:1308–1312. | No relevant outcomes
Harvey I, Frankel S, Marks R, Shalom D, Nolan-Farrell M. Non-melanoma skin cancer and solar keratoses, I: methods and descriptive results of the South Wales Skin Cancer Study. Br J Cancer. 1996;74:1302–1307. | No relevant outcomes
Heckmann M, Zogelmeier F, Konz B. Frequency of facial basal cell carcinoma does not correlate with site-specific UV exposure. Arch Dermatol. 2002;138:1494–1497. | Study design
Herity B, O’Loughlin G, Moriarty MJ, Conroy R. Risk factors for non-melanoma skin cancer. Ir Med J. 1989;82:151–152. | Study design
Herzfeld PM, Fitzgerald EF, Hwang SA, Stark A. A case-control study of malignant melanoma of the trunk among white males in upstate New York. Cancer Detect Prev. 1993;17(6):601–608. | Quality
Hogan DJ, Lane PR, Gran L, Wong D. Risk factors for squamous cell carcinoma of the skin in Saskatchewan, Canada. J Dermatol Sci. 1990;1:97–101. | No relevant outcomes
Hogan DJ, To T, Gran L, Wong D, Lane PR. Risk factors for basal cell carcinoma. Int J Dermatol. 1989;28:591–594. | Quality
Holly EA, Kelly JW, Shpall SN, Chiu SH. Number of melanocytic nevi as a major risk factor for malignant melanoma. J Am Acad Dermatol. 1987;17:459–468. | No relevant outcomes
Holman CD, Armstrong BK, Heenan PJ, et al. The causes of malignant melanoma: results from the West Australian Lions Melanoma Research Project. Recent Results Cancer Res. 1986;102:18–37. | Population
Holman CD, Armstrong BK, Heenan PJ. Relationship of cutaneous malignant melanoma to individual sunlight-exposure habits. J Natl Cancer Inst. 1986;76:403–414. | Population
Holman CD, Armstrong BK. Pigmentary traits, ethnic origin, benign nevi, and family history as risk factors for cutaneous malignant melanoma. J Natl Cancer Inst. 1984;72:257–266. | Population
Huncharek M, Kupelnick B. Use of topical sunscreens and the risk of malignant melanoma: a meta-analysis of 9067 patients from 11 case-control studies. Am J Public Health. 2002;92:1173–1177. | Used as source document
Ibrahim SF, Brown MD. Tanning and cutaneous malignancy. Dermatol Surg. 2008;34:460–474. | Study design
Ivry GB, Ogle CA, Shim EK. Role of sun exposure in melanoma. Dermatol Surg. 2006;32:481–492. | Study design
John EM, Dreon DM, Koo J, Schwartz GG. Residential sunlight exposure is associated with a decreased risk of prostate cancer. J Steroid Biochem Mol Biol. 2004;89–90:549–552. | Study design
Karagas MR, Greenberg ER, Spencer SK, Stukel TA, Mott LA. Increase in incidence rates of basal cell and squamous cell skin cancer in New Hampshire, USA. New Hampshire Skin Cancer Study Group. Int J Cancer. 1999;81:555–559. | Study relevance
Kaskel P, Sander S, Kron M, Kind P, Peter RU, Krahn G. Outdoor activities in childhood: a protective factor for cutaneous melanoma? Results of a case-control study in 271 matched pairs. Br J Dermatol. 2001;145:602–609. | Quality
Klepp O, Magnus K. Some environmental and bodily characteristics of melanoma patients. A case-control study. Int J Cancer. 1979;23:482–486. | Study design
Kricker A, Armstrong BK, English DR. Sun exposure and non-melanocytic skin cancer. Cancer Causes Control. 1994;5:367–392. | Study design
Kricker A, Armstrong BK, Goumas C, et al. Ambient UV, personal sun exposure and risk of multiple primary melanomas. Cancer Causes Control. 2007;18:295–304. | Study design
Landi MT, Baccarelli A, Calista D, et al. Combined risk factors for melanoma in a Mediterranean population. Br J Cancer. 2001;85:1304–1310. | Quality
Lazovich D, Sweeney C, Weinstock MA, Berwick M. A prospective study of pigmentation, sun exposure, and risk of cutaneous malignant melanoma in women. J Natl Cancer Inst. 2004;96:335–338. | Study design
Lear JT, Harvey I, de Berker D, Strange RC, Fryer AA. Basal cell carcinoma. J R Soc Med. 1998;91:585–588. | Study design
Lee JA, Strickland D. Malignant melanoma: social status and outdoor work. Br J Cancer. 1980;41:757–763. | No relevant outcomes
Leiter U, Garbe C. Epidemiology of melanoma and nonmelanoma skin cancer—the role of sunlight. Adv Exp Med Biol. 2008;624:89–103. | Study design
Lim JL, Stern RS. High levels of ultraviolet B exposure increase the risk of non-melanoma skin cancer in psoralen and ultraviolet A-treated patients. J Invest Dermatol. 2005;124:505–513. | Population
Lock-Andersen J, Drzewiecki KT, Wulf HC. Eye and hair colour, skin type and constitutive skin pigmentation as risk factors for basal cell carcinoma and cutaneous malignant melanoma. A Danish case-control study. Acta Derm Venereol. 1999;79:74–80. | No relevant outcomes
Lock-Andersen J, Drzewiecki KT, Wulf HC. Naevi as a risk factor for basal cell carcinoma in Caucasians: a Danish case-control study. Acta Derm Venereol. 1999;79:314–319. | No relevant outcomes
Loria D, Matos E. Risk factors for cutaneous melanoma: a case-control study in Argentina. Int J Dermatol. 2001;40:108–114. | Study design
Lovatt TJ, Lear JT, Bastrilles J, et al. Associations between UVR exposure and basal cell carcinoma site and histology. Cancer Lett. 2004;216:191–197. | Study design
MacKie RM, Freudenberger T, Aitchison TC. Personal risk-factor chart for cutaneous melanoma. Lancet. 1989;2:487–490. | Study design
Maia M, Proenca NG, de Moraes JC. Risk factors for basal cell carcinoma: a case-control study. Rev Saude Publica. 1995;29:27–37. | Quality
Marks R, Jolley D, Dorevitch AP, Selwood TS. The incidence of non-melanocytic skin cancers in an Australian population: results of a five-year prospective study. Med J Aust. 1989;150:475–478. | No relevant outcomes
Marks R, Ponsford MW, Selwood TS, Goodman G, Mason G. Non-melanotic skin cancer and solar keratoses in Victoria. Med J Aust. 1983;2:619–622. | Study design
Marks R, Rennie G, Selwood T. The relationship of basal cell carcinomas and squamous cell carcinomas to solar keratoses. Arch Dermatol. 1988;124:1039–1042. | Study design
Memon AA, Tomenson JA, Bothwell J, Friedmann PS. Prevalence of solar damage and actinic keratosis in a Merseyside population. Br J Dermatol. 2000;142:1154–1159. | Study design
Moore DH, Patterson HW, Hatch F, et al. Case-control study of malignant melanoma among employees of the Lawrence Livermore National Laboratory. Am J Ind Med. 1997;32:377–391. | Quality
Morales Suarez-Varela M, Llopis GA, Ferrer CE. Non-melanoma skin cancer: an evaluation of risk in terms of ultraviolet exposure. Eur J Epidemiol. 1992;8:838–844. | Study design
Naldi L, Altieri A, Imberti GL, et al. Cutaneous malignant melanoma in women. Phenotypic characteristics, sun exposure, and hormonal factors: a case-control study from Italy. Ann Epidemiol. 2005;15:545–550. | Study design
Naldi L, Altieri A, Imberti GL, et al. Sun exposure, phenotypic characteristics, and cutaneous malignant melanoma. An analysis according to different clinico-pathological variants and anatomic locations (Italy). Cancer Causes Control. 2005;16:893–899. | Study design
Naldi L, DiLandro A, D’Avanzo B, Parazzini F. Host-related and environmental risk factors for cutaneous basal cell carcinoma: evidence from an Italian case-control study. J Am Acad Dermatol. 2000;42:446–452. | Study design
Naldi L, Gallus S, Imberti GL, Cainelli T, Negri E, La Vecchia C. Sunlamps and sunbeds and the risk of cutaneous melanoma. Italian Group for Epidemiological Research in Dermatology. Eur J Cancer Prev. 2000;9:133–134. | Study design
Naldi L, Gallus S, Imberti GL, Cainelli T, Negri E, La Vecchia C. Sunscreens and cutaneous malignant melanoma: an Italian case-control study. Int J Cancer. 2000;86:879–882. | Study design
Naylor MF, Boyd A, Smith DW, Cameron GS, Hubbard D, Neldner KH. High sun protection factor sunscreens in the suppression of actinic neoplasia. Arch Dermatol. 1995;131:170–175. | No relevant outcomes
Nelemans PJ, Groenendal H, Kiemeney LA, Rampen FH, Ruiter DJ, Verbeek AL. Effect of intermittent exposure to sunlight on melanoma risk among indoor workers and sun-sensitive individuals. Environ Health Perspect. 1993;101:252–255. | No relevant outcomes
Nelemans PJ, Rampen FH, Ruiter DJ, Verbeek AL. An addition to the controversy on sunlight exposure and melanoma risk: a meta-analytical approach. J Clin Epidemiol. 1995;48:1331–1342. | Used as source document
Nijsten T, Leys C, Verbruggen K, et al. Case-control study to identify melanoma risk factors in the Belgian population: the significance of clinical examination. J Eur Acad Dermatol Venereol. 2005;19:332–339. | Study design
Nikolaou NA, Sypsa V, Stefanaki I, et al. Risk associations of melanoma in a Southern European population: results of a case/control study. Cancer Causes Control 2008;19(7):671–679. | Quality
Oliveria SA, Saraiya M, Geller AC, Heneghan MK, Jorgensen C. Sun exposure and risk of melanoma. Arch Dis Child. 2006;91:131–138. | Used as source document
Pelucchi C, Di Landro A, Naldi L, La Vecchia C; Oncology Study Group of the Italian Group for Epidemiologic Research in Dermatology (GISED). Risk factors for histological types and anatomic sites of cutaneous basal-cell carcinoma: an italian case-control study. J Invest Dermatol. 2007;127:935–944. | Study design
Pion IA, Rigel DS, Garfinkel L, Silverman MK, Kopf AW. Occupation and the risk of malignant melanoma. Cancer. 1995;75:637–644. | No relevant outcomes
Prawer SE. Sun-related skin diseases. Postgrad Med. 1959;89:51–54. | Study design
Pukkala E, Saarni H. Cancer incidence among Finnish seafarers, 1967–92. Cancer Causes Control. 1996;7:231–239. | Study relevance
Purdue MP, From L, Armstrong BK, et al. Etiologic and other factors predicting nevus-associated cutaneous malignant melanoma. Cancer Epidemiol Biomarkers Prev. 2005;14:2015–2022. | Study design
Rafnsson V, Hrafnkelsson J, Tulinius H, Sigurgeirsson B, Olafsson JH. Risk factors for malignant melanoma in an Icelandic population sample. Prev Med. 2004;39:247–252. | Study design
Ramos J, Villa J, Ruiz A, Armstrong R, Matta J. UV dose determines key characteristics of nonmelanoma skin cancer. Cancer Epidemiol Biomarkers Prev. 2004;13:2006–2011. | Study design
Robinson JK, Rademaker AW. Relative importance of prior basal cell carcinomas, continuing sun exposure, and circulating T lymphocytes on the development of basal cell carcinoma. J Invest Dermatol. 1992;99:227–231. | Study design
Rodenas JM, Gado-Rodriguez M, Herranz MT, Tercedor J, Serrano S. Sun exposure, pigmentary traits, and risk of cutaneous malignant melanoma: a case- control study in a Mediterranean population. Cancer Causes Control. 1996;7:275–283. | Study design
Rosso S, Zanetti R, Martinez C, et al. The multicentre south European study “Helios,” II: different sun exposure patterns in the aetiology of basal cell and squamous cell carcinomas of the skin. Br J Cancer. 1996;73:1447–1454. | Study design
Rosso S, Zanetti R, Pippione M, Sancho-Garnier H. Parallel risk assessment of melanoma and basal cell carcinoma: skin characteristics and sun exposure. Melanoma Res. 1998;8:573–583. | Study design
Sahl WJ, Glore S, Garrison P, Oakleaf K, Johnson SD. Basal cell carcinoma and lifestyle characteristics. Int J Dermatol. 1995;34:398–402. | Quality
Saladi RN, Persaud AN. The causes of skin cancer: a comprehensive review. Drug Today. 2005;41:37–53. | Study design
Schmieder GJ, Yoshikawa T, Mata SM, Streilein JW, Taylor JR. Cumulative sunlight exposure and the risk of developing skin cancer in Florida. J Dermatol Surg Oncol. 1992;18:517–522. | Quality
Scrivener Y, Grosshans E, Cribier B. Variations of basal cell carcinomas according to gender, age, location and histopathological subtype. Br J Dermatol. 2002;147:41–47. | No relevant outcomes
Shah CP, Weis E, Lajous M, Shields JA, Shields CL. Intermittent and chronic ultraviolet light exposure and uveal melanoma: a meta-analysis. Ophthalmology. 2005;112:1599–1607. | Study relevance
Singh B, Bhaya M, Shaha A, Har-El G, Lucente FE. Presentation, course, and outcome of head and neck skin cancer in African Americans: a case-control study. Laryngoscope. 1998;108:t-63. | Study design
Siskind V, Aitken J, Green A, Martin N. Sun exposure and interaction with family history in risk of melanoma, Queensland, Australia. Int.J.Cancer 2002;97(1):90–95. | Quality
Stender IM, Andersen JL, Wulf HC. Sun exposure and sunscreen use among sunbathers in Denmark. Acta Derm Venereol. 1996;76:31–33. | Study design
Strickland PT, Vitasa BC, West SK, Rosenthal FS, Emmett EA, Taylor HR. Quantitative carcinogenesis in man: solar ultraviolet B dose dependence of skin cancer in Maryland watermen. J Natl Cancer Inst. 1989;81:1910–1913. | Study design
Suarez-Varela MM, Llopis GA, Ferrer CE. Non-melanoma skin cancer: a case- control study on risk factors and protective measures. J Environ Pathol Toxicol Oncol. 1996;15:255–261. | Study design
Sunscreen use in children may lower risk of developing future skin cancer. Oncology (Williston Park). 2005;19:1139–1140. | No relevant outcomes
Swerdlow AJ, English JS, MacKie RM, et al. Fluorescent lights, ultraviolet lamps, and risk of cutaneous melanoma. BMJ. 1988;297:647–650. | Study design
The association of use of sunbeds with cutaneous malignant melanoma and other skin cancers: a systematic review. Int J Cancer. 2007;120:1116–1122. | Used as source document
Thompson SC, Jolley D, Marks R. Reduction of solar keratoses by regular sunscreen use. N Engl J Med. 1993;329:1147–1151. | No relevant outcomes
Ting W, Schultz K, Cac NN, Peterson M, Walling HW. Tanning bed exposure increases the risk of malignant melanoma. Int J Dermatol. 2007;46(12):1253–1257. | Quality
Vagero D, Ringback G, Kiviranta H. Melanoma and other tumors of the skin among office, other indoor and outdoor workers in Sweden 1961–1979. Br J Cancer. 1986;53:507–512. | No relevant outcomes
Vainio H, Bianchini F. Cancer-preventive effects of sunscreens are uncertain. Scand J Work Environ Health. 2000;26:529–531. | Study design
Vainio H, Miller AB, Bianchini F. An international evaluation of the cancer- preventive potential of sunscreens. Int J Cancer. 2000;88:838–842. | Study design
Vajdic CM, Kricker A, Giblin M, et al. Artificial ultraviolet radiation and ocular melanoma in Australia. Int J Cancer. 2004;112:896–900. | Study relevance
van-der-Pols JC, Williams GM, Neale RE, Clavarino A, Green AC. Long-term increase in sunscreen use in an Australian community after a skin cancer prevention trial. Prev Med. 2006;42:171–176. | No relevant outcomes
Vitaliano PP, Urbach F. The relative importance of risk factors in nonmelanoma carcinoma. Arch Dermatol. 1980;116:454–456. | Study design
Vitaliano PP. The use of logistic regression for modelling risk factors: with application to non-melanoma skin cancer. Am J Epidemiol. 1978;108:402–414. | Study relevance
Vitasa BC, Taylor HR, Strickland PT, et al. Association of nonmelanoma skin cancer and actinic keratosis with cumulative solar ultraviolet exposure in Maryland watermen. Cancer. 1990;65:2811–2817. | Study design
Walther U, Kron M, Sander S, et al. Risk and protective factors for sporadic basal cell carcinoma: results of a two-centre case-control study in southern Germany. Clinical actinic elastosis may be a protective factor. Br J Dermatol. 2004;151:170–178. | Study design
Weinstock MA, Colditz GA, Willett WC, et al. Moles and site-specific risk of nonfamilial cutaneous malignant melanoma in women. J Natl Cancer Inst. 1989;81:948–952. | No relevant outcomes
Weinstock MA. Do sunscreens increase or decrease melanoma risk: an epidemiologic evaluation. J Invest Dermatol Sym Proc. 1999;4:97–100. | Study design
Weinstock MA. Sunscreen use can reduce melanoma risk. Photodermatol Photoimmunol Photomed. 2001;17:234–236. | Study design
Whiteman DC, Stickley M, Watt P, Hughes MC, Davis MB, Green AC. Anatomic site, sun exposure, and risk of cutaneous melanoma. J Clin Oncol. 2006;24:3172–3177. | Study design
Whiteman DC, Valery P, McWhirter W, Green AC. Risk factors for childhood melanoma in Queensland, Australia. Int J Cancer. 1997;70:26–31. | Study design
Whiteman DC, Whiteman CA, Green AC. Childhood sun exposure as a risk factor for melanoma: a systematic review of epidemiologic studies. Cancer Causes Control. 2001;12:69–82. | Used as source document
Wiecker TS, Luther H, Buettner P, Bauer J, Garbe C. Moderate sun exposure and nevus counts in parents are associated with development of melanocytic nevi in childhood: a risk factor study in 1,812 kindergarten children. Cancer. 2003;97:628–638. | No relevant outcomes
Wolf P, Quehenberger F, Mullegger R, Stranz B, Kerl H. Phenotypic markers, sunlight-related factors and sunscreen use in patients with cutaneous melanoma: an Austrian case-control study. Melanoma Res. 1998;8:370–378. | Quality
Woolley T, Buettner PG, Lowe J. Sun-related behaviors of outdoor working men with a history of non-melanoma skin cancer. J Occup Environ Med. 2002;44:847–854. | Study design
Xu LY, Koo J. Predictive value of phenotypic variables for skin cancer: risk assessment beyond skin typing. Int J Dermatol. 2006;45:1275–1283. | Study relevance
Youl P, Aitken J, Hayward N, et al. Melanoma in adolescents: a case-control study of risk factors in Queensland, Australia. Int J Cancer. 2002;98:92–98. | Population
Zanetti R, Rosso S, Martinez C, et al. The multicentre south European study “Helios,” I: skin characteristics and sunburns in basal cell and squamous cell carcinomas of the skin. Br J Cancer. 1996;73:1440–1446. | Study design

Appendix C Table 3 Evidence Table for Adverse Effects of Sun-Protective Behaviors

Study reference USPSTF quality | Study objective | Study design Location Population | Participant inclusion/exclusion criteria | Baseline demographics | | | | | | Intervention description (if trial) | Measurement of exposure (or intervention if applicable) | Confounders considered (if observational study) | Followup | Measurement of adverse outcomes | | | | | Comments
Vitamin D deficiency
Marks 1995^98^ Fair | To determine whether the regular use of sunscreens in the normal adult population may put individuals at risk of vitamin D deficiency (measures of 25 and 1,25 OHD) | RCT Victoria, Australia General population undergoing longitudinal intervention study on the effect of regular sunscreen use in people with solar keratoses | Age 40 yr or more, White, with 1–30 solar keratoses | N: 153 randomized, 113 analyzed IG: 58 CG:55 Age: 52% under age 70 yr Sex: 41% men Skin phenotype: 27% burn 50% burn/tan 23% tan | | | | | | IG: SPF 17 sunscreen, participants were given specific instructions on the application of sunscreen; in addition they were given other ‘sun protective behavior’ instructions CG: placebo cream, given same instructions | All participants given diaries to record sunscreen use and sunscreen container were weighed to determine amount of cream used In addition, participants were also given polysulfone film badges and diaries to record sun exposure | Age, sex, self-reported skin type; NOT adjusted for UV exposure, but trial reports not detectable difference in UV exposure between the two groups | 7 months: 74% | (Table 2) change in 25 and 1,25 OHD at 7 mo 25 OHD (nmol/L) mean change, [95% CI], % change, p-value IG: 11.8, [7.6, 15.9], 21% CG: 12.8, [8.4, 17.1], 25% p=0.75 1,25 OHD (nmol/L) mean change, [95% CI], % change, p-value IG: 1.3, [−2.3, 4.9], 1% CG: 10.8, [6.7, 14.8], 14% p=0.0009 (Table 3) change in 25 and 1,25 OHD at 7 mo by age, sex, and skin type No statistically significant changes Also reported “no person using sunscreen developed serum vitamin D levels below the reference range over the period of the study” | | | | | These vitamin D levels appear to be low
Brot 2001^99^ Fair | To assess the prevalence of vitamin D insufficiency in a population of normal perimenopausal women, to estimate the relative influences of sun exposure and vitamin D intake on the concentration of 25OHD and to examine the relationship between PTH and 25OHD | Prospective cohort from larger multicenter RCT Denmark General perimenopausal women | Age 45–58 years and 3–24 months past last menstrual bleeding or perimenopausal symptoms and elevated FSH; if hysterectomized, age 45–52 with elevated FSH Excluded women with osteoporotic fractures, metabolic bone disease, current estrogen use, hyper or hypothyroidism, newly diagnosed or uncontrolled chronic disease, liver disease, unstable cardiac disease, current or past malignant disease, hospitalization for alcohol or drug abuse, history of deep thrombophlebitis or stroke | N: 2016 Age range: 45–58 yr Sex: 0% men Skin phenotype: NR | | | | | | N/A | All participants were interviewed by 2 physicians to determine sun exposure (never, occasionally, regularly); and sunbed use (no, yes) | Dietary vitamin D, and vitamin D supplementation (no, yes); did NOT assess for sunscreen use | 2.5 years: unclear, 95% with diet records | (Table 2) prevalence of low vit D status during winter and spring according to sun exposure and vitamin supplementation mean serum 25OHD (nmol/L) no vitamin supplement, vitamin supplement Never: 36.5, 45.3 Occasionally: 41.5, 49.3 Regularly: 53.5, 62.3 Percent of subgroup with low vitamin D status, 25 OHD ≤25nmol/L Never: 32.8, 12.9 Occasionally: 17.6, 10.7 Regularly: 9.8, 2.8
Decreased physical activity (see KQ3 which has one trial in addition to Milne 2007)
Milne 2007^94^ Fair | To determine if adherence to the sun safety message could inadvertently have a detrimental effect on children’s body mass index (BMI) | Cluster CCT by school (non-randomized to minimize contamination) Perth, Australia General grade school children | Children, age 5 or 6 in 1995 attending participating schools (schools within 30km of Perth with 50 or more first-grade students) | N: 33 schools randomized, N: 1615 children analyzed IG high: 8 schools IG moderate: 11 schools CG: 14 schools Age: 5–6 yrs at entry; 11–12 years at last followup Sex: NR Skin phenotype: 100% of European ethnicity | | | | | | IG high and moderate: specially designed sun protection curriculum that was administered over 4 consecutive years beginning at age 6, curriculum integrated into a range of subjects, including physical education; children in the high intervention group were sent program materials over the summer vacation and offered low-cost sun protective swimwear CG: standard Western Australian health education curriculum | Parents of children were sent self-administered questionnaire to determine total time spent outdoors | Random effects model for school, and adjusted for study group, total time spent outdoors at baseline, gender, ethnicity, parental education level, and tendency to sunburn | 4 years: 90% 6 years: 69% | (Table 3) adjusted differences in z scores (BMI for age), adjusted for sex, ethnicity, parent education, z score at baseline @ 4 years, z-score [95%CI] IG high: −0.08 [−0.22, 0.06] IG moderate: 0.01 [−0.12, 0.14] CG: ref @ 6 years, z-score [95%CI] IG high: −0.11 [−0.27, 0.05] IG moderate: 0.05 [−0.09, 0.20] CG: ref Adjusted relative difference, total time spent otudoors, adjusted for sex, ethnicity, parent education, tendency to burn, and total time spent outdoors at baseline @ 4 years, relative difference [95%CI] IG high: 0.90 [0.78, 1.05] IG moderate: 1.0 [0.87, 1.15] CG: ref @ 6 years, relative difference [95%CI] IG high: 0.98 [0.83, 1.15] IG moderate: 0.94 [0.81, 1.09] CG: ref | | | | | Non-randomized, were differences at baseline among children; time spent outdoors is a proxy for physical activity, lack of adjustment for nutritional intake
Increased sun exposure (with sunscreen use)
Autier 1999^95^ Good | To determine if sunscreen use encourages longer sun exposure duration | RCT Lyon, France and Lausanne, Switzerland Healthy volunteers from universities | Age 18–24 years, positive history of sunburn in the past and regular sunscreen users intending to have at least 15 days of holiday in sunny areas during the next 2 months Excluded persons with current or history of skin diseases that lasted for more than 1 year, pregnant women, persons with chronic physical illness, persons taking photosensitizing medication | N: 87 IG1: 44 IG2: 43 (42 analyzed) Age range: 18–24 years Sex: 41% men Skin phenotype: 2% skin type I, burns 33% skin type II, burns/tans 65% skin type III, tans 0% skin type IV, tans/never burns | | | | | | IG1: SPF 10 sunscreen IG2: SPF 30 sunscreen | Daily diary to record detailed data about sun exposure (hours and type of sun exposure, amount of clothing, number of sunscreen applications, time of application, and sunburn or skin-reddening experience, as well as use of other sunscreen products (if applicable) | Skin phenotype, lifetime sun exposure habits, sunburn experience, sunscreen use | 2 months: 99% | (Table 2) mean total hours of sun exposure per participant @ 2 months mean hours, [95%CI], p-value IG1: 58.2 [52.0, 64.4] IG2: 72.6 [63.5, 81.7] p=0.011 @ 2 months mean hours daily sun exposure, [95%CI], p-value IG1: 4.0 [3.3, 4.7] IG2: 4.6 [3.9, 5.3] p=<0.0001 @ 2 months mean hours daily outdoor activity, [95%CI], p- value IG1: 3.6 [2.9, 4.3] IG2: 3.8 [3.0, 4.6] p=0.62 @ 2 months mean hours daily sunbathing, [95%CI], p-value IG1: 2.6 [2.1, 3.1] IG2: 3.1 [2.5, 3.7] p=0.0013 Number of sunburn or skin-reddening episodes, p-value IG1: 159 IG2: 159 p=0.99 Number of sunburns, p-value IG1: 42 IG2: 34 p=0.90
Autier 2000^96^ Good | To determine if sunscreen use encourages longer sun exposure duration, and sunbathing in particular | RCT Paris and Thionville, France and Brussels, Belgium Healthy volunteers from hospitals | Age 18–24 years, positive history of sunburn in the past and regular sunscreen users intending to have at least 15 days of holiday in sunny areas during the next 2 months Excluded persons with current or history of skin diseases that lasted for more than 1 year | N: 62 randomized, 58 analyzed IG1: 29 IG2: 29 Age range: 18–24 years Sex: 26% men Skin phenotype: 5% skin type I, burns 53% skin type II, burns/tans 41% skin type III, tans 0% skin type IV, tans/never burns | | | | | | IG1: SPF 10 sunscreen IG2: SPF 30 sunscreen | Daily diary to record detailed data about sun exposure and personal dosimeters (n=50) to measure UVA and UVB exposure | Sunscreen use (SPF and quantity), in-trial sunburn experience, skin phenotype | After particpants’ summer holiday: 94% (only 71% for dosimeters) | (Table 2) median hours daily sunbathing, [95%CI], % change, p-value IG1: 2.4 [NR] IG2: 3.0 [NR] +25% p=0.054 Median UVB exposure (Joules/m2) per day with sunbathing, [95%CI], % change, p-value IG1: 841 [NR] IG2: 984 [NR] +17% p=0.15 Median UVA exposure (KJoules/m2) per day with sunbathing, [95%CI], % change, p-value IG1: 136 [NR] IG2: 125 [NR] −8% p=0.50
Dupuy 2005^97^ Fair | To determine whether high- SPF sunscreens have an impact on the sun-exposure behavior in people spending family holidays; and to determine the impact of the actual high protection and the impact of the impression of being well protected | RCT French Mediterranean and Atlantic coasts Healthy volunteers from holiday resorts | Adults on holiday who considered themselves sunscreen users Excluded persons with history of skin cancer, recent history of severe sunburn, contraindication to sun exposure, known contact dermatitis to sunscreen, pregnancy or breast feeding, participation of another family member in the study | N: 367 randomized, 359 analyzed IG1: 122 IG2: 121 CG: 124 Mean age: 39 ± yr Sex: 18% men Skin phenotype: 35% fair complexion: blond, red, or light brown hair 15% neither fair nor dark complexion 49% dark complexion; dark hair | | | | | | IG1: High protection label, SPF 40 sunscreen IG2: Basic protection label, SPF 40 sunscreen CG: Basic protection label, SPF 12 sunscreen | Daily self-administered questionnaire to record details of sun exposure, final exit interview to detail occurrences of sunburn or painful skin reddening, and sunscreen consumption by weighing sunscreen tubes | Sunscreen use, center, week, skin phenotype | 1 week: 95% | (Table 2) mean total hours of sun exposure per participant @ 1 week mean hours while sunbathing, [SD], p-value IG1: 14.2 [7.6] IG2: 12.9 [7.2] CG: 14.6 [6.7] Label comparison (IG1 vs. IG2): p=0.13; SPF Comparison (IG2 vs. CG): p=0.06 @ 1 week proportion of persons with sunburn, [SD], p-value; OR [95%CI] IG1: 0.15 [NR] IG2: 0.14 [NR] CG: 0.24 [NR] Label comparison (IG1 vs. IG2): p=0.80; SPF Comparison (IG2 vs. CG): p=0.06 Label comparison (IG1 vs. IG2): OR 0.91 [0.43, 1.91]; SPF comparison (IG2 vs. CG): OR 1.96 [0.98, 3.92]
Green 1999^57,108^ Good | To investigate the effectiveness of daily sunscreen application and dietary betacarotene supplement in reducing the incidence of BCC and SCC; secondary endpoint reported in “letter to editor” included sun exposure behaviors, self reported and dosimetry (in a random sub-sample) | RCT Queensland, Australia Community sample | Adults age 20–69, residents of Nambour, Queensland from electoral roll 1986, who attended a second survey in 1992 Excluded persons taking vitamin supplements containing betacarotene, already applying sunscreen on a strict daily basis | N= 1,621 IG1: 404 IG2: 408 IG3: 416 CG: 393 Mean age: IG1: 48.5 (12.9) IG2: 48.7 (13.6) IG3: 48.1 (13.6) CG: 49.8 (12.7) Sex: (% men) IG1: 44.3 IG2: 42.9 IG3: 40.9 CG: 46.8 Skin type: | | | | | | IG1: Sunscreen, SPF 15 plus betacarotene IG2: Sunscreen, SPF 15 and placebo tablet IG3: Betacarotene 30mg, and placebo cream CG: no sunscreen and placebo tablet | 7 day diaries to record refquency of sun exposure habits and ambient ultraviolet light by polysulphone badges (dosimetry) in the penultimate year of the trial in a random sub-sample of 175 participants | | 4.5 years: 85% For sub- sample of persons with dosimetry: 98% | Spent less than 50% of time outdoors on weekends in the previous summer @ 4.5 years IG1 and IG2: 79.3% (549/692), p value NR IG3 and CG: 77.4% (535/691) Median (range) % of ambient UV exposure received by polysuphone badges Over summer IG1 and IG2: 2.8 (0–32.2), p=0.55 IG3 and CG: 3.5 (0–23.8) Over winter IG1 and IG2: 6.5 (0–36.2), p=0.36 IG3 and CG: 7.1 (1.0–35.8)
Green 1999^57,108^ Good | | RCT Queensland, Australia Community sample | | | IG1 | IG2 | IG3 | CG | | IG1: Sunscreen, SPF 15 plus betacarotene IG2: Sunscreen, SPF 15 and placebo tablet IG3: Betacarotene 30mg, and placebo cream CG: no sunscreen and placebo tablet | | | 4.5 years: 85% For sub- sample of persons with dosimetry: 98%
Green 1999^57,108^ Good | | RCT Queensland, Australia Community sample | | | | | | | | IG1: Sunscreen, SPF 15 plus betacarotene IG2: Sunscreen, SPF 15 and placebo tablet IG3: Betacarotene 30mg, and placebo cream CG: no sunscreen and placebo tablet | | | 4.5 years: 85% For sub- sample of persons with dosimetry: 98%
Green 1999^57,108^ Good | | RCT Queensland, Australia Community sample | | % Burn | 22 | 20 | 22 | 20 | | IG1: Sunscreen, SPF 15 plus betacarotene IG2: Sunscreen, SPF 15 and placebo tablet IG3: Betacarotene 30mg, and placebo cream CG: no sunscreen and placebo tablet | | | 4.5 years: 85% For sub- sample of persons with dosimetry: 98%
Green 1999^57,108^ Good | | RCT Queensland, Australia Community sample | | %Burn/tan | 67 | 69 | 66 | 69 | | IG1: Sunscreen, SPF 15 plus betacarotene IG2: Sunscreen, SPF 15 and placebo tablet IG3: Betacarotene 30mg, and placebo cream CG: no sunscreen and placebo tablet | | | 4.5 years: 85% For sub- sample of persons with dosimetry: 98%
Green 1999^57,108^ Good | | RCT Queensland, Australia Community sample | | % Tan | 11 | 11 | 12 | 11 | | IG1: Sunscreen, SPF 15 plus betacarotene IG2: Sunscreen, SPF 15 and placebo tablet IG3: Betacarotene 30mg, and placebo cream CG: no sunscreen and placebo tablet | | | 4.5 years: 85% For sub- sample of persons with dosimetry: 98%
Gallagher 2002^109^ Fair | To determine whether use of broad-spectrum, high SPF sunscreen attenuates development of nevi in White children; secondary endpoint included sun exposure | RCT British Columbia, Canada White children | Children in grades 1 (ages 6 and 7), and 4 (ages 9 and 10) and their parents from six Vancouver area elementary schools in 1993 Excluded non-White children after randomization | N: 458 randomized, 309 analyzed IG1: 222, 145 CG: 236, 164 Mean age: 50.9% ages 6–7, 49.1% ages 9–10 Sex: NR Skin phenotype: | | | | | | IG: SPF 30 sunscreen plus advice CG: no advice, no placebo | Activity-based questionnaire at the end of each summer vacation, and after the Christmas and spring breaks each year Minimal erythemal dose (MED) information for clear sky conditions by latitude and month were obtained from standard tables | Clothing adjustment based on type of activity and clothing preference | 3 years: 67.5% | Median UV exposure from 1993 to 1996 Time spent outdoors IG: 357.0, p value NR CG: 361.5 Vacation sun exposure (MED) IG: 962.5, p value NR CG: 962.5 Total sunlight exposure for whole body, adjusted for clothing coverage (MED) IG: 1252.2 p value NR CG: 1214.3
Gallagher 2002^109^ Fair | To determine whether use of broad-spectrum, high SPF sunscreen attenuates development of nevi in White children; secondary endpoint included sun exposure | RCT British Columbia, Canada White children | Children in grades 1 (ages 6 and 7), and 4 (ages 9 and 10) and their parents from six Vancouver area elementary schools in 1993 Excluded non-White children after randomization | | | IG | | CG | | IG: SPF 30 sunscreen plus advice CG: no advice, no placebo | | Clothing adjustment based on type of activity and clothing preference | 3 years: 67.5%
Gallagher 2002^109^ Fair | To determine whether use of broad-spectrum, high SPF sunscreen attenuates development of nevi in White children; secondary endpoint included sun exposure | RCT British Columbia, Canada White children | Children in grades 1 (ages 6 and 7), and 4 (ages 9 and 10) and their parents from six Vancouver area elementary schools in 1993 Excluded non-White children after randomization | % skin reflectance (c) | | | | | | IG: SPF 30 sunscreen plus advice CG: no advice, no placebo | | Clothing adjustment based on type of activity and clothing preference | 3 years: 67.5%
Gallagher 2002^109^ Fair | To determine whether use of broad-spectrum, high SPF sunscreen attenuates development of nevi in White children; secondary endpoint included sun exposure | RCT British Columbia, Canada White children | Children in grades 1 (ages 6 and 7), and 4 (ages 9 and 10) and their parents from six Vancouver area elementary schools in 1993 Excluded non-White children after randomization | Dark | | 33% | | 34% | | IG: SPF 30 sunscreen plus advice CG: no advice, no placebo | | Clothing adjustment based on type of activity and clothing preference | 3 years: 67.5%
Gallagher 2002^109^ Fair | To determine whether use of broad-spectrum, high SPF sunscreen attenuates development of nevi in White children; secondary endpoint included sun exposure | RCT British Columbia, Canada White children | Children in grades 1 (ages 6 and 7), and 4 (ages 9 and 10) and their parents from six Vancouver area elementary schools in 1993 Excluded non-White children after randomization | Medium | | 32% | | 34% | | IG: SPF 30 sunscreen plus advice CG: no advice, no placebo | | Clothing adjustment based on type of activity and clothing preference | 3 years: 67.5%
Gallagher 2002^109^ Fair | To determine whether use of broad-spectrum, high SPF sunscreen attenuates development of nevi in White children; secondary endpoint included sun exposure | RCT British Columbia, Canada White children | Children in grades 1 (ages 6 and 7), and 4 (ages 9 and 10) and their parents from six Vancouver area elementary schools in 1993 Excluded non-White children after randomization | Light | | 35% | | 32% | | IG: SPF 30 sunscreen plus advice CG: no advice, no placebo | | Clothing adjustment based on type of activity and clothing preference | 3 years: 67.5%
Bauer 2005^110^ Fair | To determine if children receiving education or education and sunscreen develop less incident nevi; secondary endpoint included sun exposure and sun protection habits | Cluster RCT Stuttgart and Bochum, Germany White children, skin type I-IV | Children age 2–7 in public nursery schools and their parents in two cities in Germany with similar latitude Excluded parents who did not attend the first educational session, non-White children, or children with skin Type V or VI, immunosurpressed children, or those who refused skin exam | N: 1887 IG1: 626 IG2: 624 CG: 637 Mean age: 4.3 years Sex: 51.4% boys Skin phenotype: 10.1% skin Type I | | | | | | IG1: education (see below) and sunscreen (SPF 25) with instructions on how to apply sunscreen IG2: education only, letter three times a year with more detailed information on proper sunscreen use and sun protection, and melanoma CG: control, initial educational session only | Questionnaire at approximately 3 year follow-up | Multivariate analysis done for nevi, but unclear if conducted for sun exposure | 3 years: 65.3% | Sun exposure 2001 and changes between 1998–2001 Median weeks on holidays in sunny climates (IQR) IG1: 4 (2,7.5), p=0.021 IG2: 6 (2,8) CG: 5 (2,8) Median difference in h/day in sun during sunny holidays (IQR) IG1: 0 (−1,1), p=0.061 IG2: 0 (−1,1) CG: 0 (−1,1) Mean difference of h/day outside at home (SD) IG1: 0.15 (1.12), p=0.353 IG2: 0.14 (1.13) CG: 0.24 (1.09)
Cancer risk
John 1999^100^ Fair | To examine the possible protective role of vitamin D (sun exposure and dietary and supplemental vitamin D) on breast cancer risk | Retrospective cohort (information collected prospectively, but analytic cohort for this study was established retrospectively) US General, non- institutionalized, population (from NHANES) | Adult women ages 25–74 from the NHANES I cohort, those who participated in at least one of four follow-up surveys Excluded women with personal history of cancer, women without dietary or dermatological data, and non-White women | N=5009 (analytic cohort derived from larger cohort n=8596) Age: range: 25–74 yr Sex: 0% men Skin phenotype: NR, however all women were White | | | | | | N/A | In-person interviews, medical examinations to determine usual sunlight exposure, sun-induced skin damage, residential sulight exposure, and dietary and supplemental intake of vitamin D | Age, education, income, age at menarche, age at menopause, nulliparity/age at first birth, BMI, measure of physical activity, frequency of alcohol consumption, and family history of breast cancer | 17–21 years (average 17.3): cannot calculate followup | (Table 1) sun exposure and breast cancer risk Recreational sun exposure, # ca cases, age-adj RR, [95%CI], multivar-adj RR, [95%CI] Rare or never: 40, 1.0 [n/a], 1.0 [n/a] Occasional: 55, 0.70 [0.46, 1.06], 0.65 [0.43, 0.98] Frequent: 60, 0.70 [0.47, 1.05], 0.66 [0.44, 0.99] p-value (trend): 0.12, 0.08 Occupational sun exposure, # ca cases, age-adj RR, [95%CI], multivar-adj RR, [95%CI] Rare or never: 81, 1.0 [n/a], 1.0 [n/a] Occasional: 44, 1.05 0.73, 1.51], 1.06 [0.73, 1.53] Frequent: 29, 0.60 [0.39, 0.91], 0.64 [0.41, 0.98] p-value (trend): 0.03, 0.07 Combined recreational and occupational sun exposure, # cases, age-adj RR, [95%CI], multivar-adj RR, [95%CI] Low: 32, 1.0 [n/a], 1.0 [n/a] Medium: 99, 0.67 [0.45, 1.01], 0.81 [0.56, 1.17] High: 23, 0.50 [0.29, 0.86], 0.67 [0.42, 1.06] p-value (trend): 0.01, 0.06 (Table 3) sunlight exposure by region of residence (low, medium, or high solar radiation) Combined recreational and occupational sun exposure, # cases, multivar-adj RR, [95%CI] | | | | | Did not adjust for skin phenotype
John 1999^100^ Fair | To examine the possible protective role of vitamin D (sun exposure and dietary and supplemental vitamin D) on breast cancer risk | Retrospective cohort (information collected prospectively, but analytic cohort for this study was established retrospectively) US General, non- institutionalized, population (from NHANES) | | N=5009 (analytic cohort derived from larger cohort n=8596) Age: range: 25–74 yr Sex: 0% men Skin phenotype: NR, however all women were White | | | | | | N/A | In-person interviews, medical examinations to determine usual sunlight exposure, sun-induced skin damage, residential sulight exposure, and dietary and supplemental intake of vitamin D | Age, education, income, age at menarche, age at menopause, nulliparity/age at first birth, BMI, measure of physical activity, frequency of alcohol consumption, and family history of breast cancer | 17–21 years (average 17.3): cannot calculate followup | | Low | Medium | High | | Did not adjust for skin phenotype
John 1999^100^ Fair | To examine the possible protective role of vitamin D (sun exposure and dietary and supplemental vitamin D) on breast cancer risk | Retrospective cohort (information collected prospectively, but analytic cohort for this study was established retrospectively) US General, non- institutionalized, population (from NHANES) | | N=5009 (analytic cohort derived from larger cohort n=8596) Age: range: 25–74 yr Sex: 0% men Skin phenotype: NR, however all women were White | | | | | | N/A | In-person interviews, medical examinations to determine usual sunlight exposure, sun-induced skin damage, residential sulight exposure, and dietary and supplemental intake of vitamin D | Age, education, income, age at menarche, age at menopause, nulliparity/age at first birth, BMI, measure of physical activity, frequency of alcohol consumption, and family history of breast cancer | 17–21 years (average 17.3): cannot calculate followup | | | | | | Did not adjust for skin phenotype
John 1999^100^ Fair | To examine the possible protective role of vitamin D (sun exposure and dietary and supplemental vitamin D) on breast cancer risk | Retrospective cohort (information collected prospectively, but analytic cohort for this study was established retrospectively) US General, non- institutionalized, population (from NHANES) | | N=5009 (analytic cohort derived from larger cohort n=8596) Age: range: 25–74 yr Sex: 0% men Skin phenotype: NR, however all women were White | | | | | | N/A | In-person interviews, medical examinations to determine usual sunlight exposure, sun-induced skin damage, residential sulight exposure, and dietary and supplemental intake of vitamin D | Age, education, income, age at menarche, age at menopause, nulliparity/age at first birth, BMI, measure of physical activity, frequency of alcohol consumption, and family history of breast cancer | 17–21 years (average 17.3): cannot calculate followup | Low: | 15, 1.0 [n/a] | 9, 1.0 [n/a] | 8, 1.0 [n/a] | | Did not adjust for skin phenotype
John 1999^100^ Fair | To examine the possible protective role of vitamin D (sun exposure and dietary and supplemental vitamin D) on breast cancer risk | Retrospective cohort (information collected prospectively, but analytic cohort for this study was established retrospectively) US General, non- institutionalized, population (from NHANES) | | N=5009 (analytic cohort derived from larger cohort n=8596) Age: range: 25–74 yr Sex: 0% men Skin phenotype: NR, however all women were White | | | | | | N/A | In-person interviews, medical examinations to determine usual sunlight exposure, sun-induced skin damage, residential sulight exposure, and dietary and supplemental intake of vitamin D | Age, education, income, age at menarche, age at menopause, nulliparity/age at first birth, BMI, measure of physical activity, frequency of alcohol consumption, and family history of breast cancer | 17–21 years (average 17.3): cannot calculate followup | Medium: | 44, 0.53 [0.29, 0.97] | 34, 0.83 [0.39, 1.76] | 19, 0.54 [0.23, 1.25] | | Did not adjust for skin phenotype
John 1999^100^ Fair | To examine the possible protective role of vitamin D (sun exposure and dietary and supplemental vitamin D) on breast cancer risk | Retrospective cohort (information collected prospectively, but analytic cohort for this study was established retrospectively) US General, non- institutionalized, population (from NHANES) | | N=5009 (analytic cohort derived from larger cohort n=8596) Age: range: 25–74 yr Sex: 0% men Skin phenotype: NR, however all women were White | | | | | | N/A | In-person interviews, medical examinations to determine usual sunlight exposure, sun-induced skin damage, residential sulight exposure, and dietary and supplemental intake of vitamin D | Age, education, income, age at menarche, age at menopause, nulliparity/age at first birth, BMI, measure of physical activity, frequency of alcohol consumption, and family history of breast cancer | 17–21 years (average 17.3): cannot calculate followup | High: | 9, 0.40 [0.17, 0.94] | 10, 0.77 [0.31, 1.93] | 4, 0.35 [0.10, 1.20] | | Did not adjust for skin phenotype
John 1999^100^ Fair | To examine the possible protective role of vitamin D (sun exposure and dietary and supplemental vitamin D) on breast cancer risk | Retrospective cohort (information collected prospectively, but analytic cohort for this study was established retrospectively) US General, non- institutionalized, population (from NHANES) | | N=5009 (analytic cohort derived from larger cohort n=8596) Age: range: 25–74 yr Sex: 0% men Skin phenotype: NR, however all women were White | | | | | | N/A | In-person interviews, medical examinations to determine usual sunlight exposure, sun-induced skin damage, residential sulight exposure, and dietary and supplemental intake of vitamin D | Age, education, income, age at menarche, age at menopause, nulliparity/age at first birth, BMI, measure of physical activity, frequency of alcohol consumption, and family history of breast cancer | 17–21 years (average 17.3): cannot calculate followup | (Table 5) vitamin D from sun exposure and diet (sun exposure as determined by physician) Sun exposure and dietary vit D, # ca cases, age-adj RR, [95%CI], multivar-adj RR, [95%CI] Low sun and <200IU: 71, 1.0 [n/a], 1.0 [n/a] Low sun and ≥200IU: 18, 0.79 [0.57, 1.11], 0.75 [0.54, 1.06] High sun and <200IU: 65, 0.78 [0.46, 1.31], 0.77 [0.46, 1.29] High sun and ≥200IU: 22, 0.72 [0.45, 1.17], 0.71 [0.44, 1.14] p-value (trend): 0.11, 0.08 Multi-var adj for age, education, age at menarche, age at menopause, BMI, alcohol consumption, physical activity, and calcium | | | | | Did not adjust for skin phenotype
Kampman 2000^101^ Fair | To evaluate potential sources of inconsistencies of the association between calcium and vitamin D (dietary or sun exposure) and colon cancer | Case-control Multi-state, US General population from large HMO | Cases: diagnosis of first primary colon cancer from HMO database, identified from Oct 1991 through Sep 1994, age 30–79 at diagnosis, English speaking, and mentally competent; cases with tumors of the rectum, rectosigmoid, history of familial adenomatous polyposis, ulcerative colitis, or Crohn’s disease were excluded Controls: age, sex matched persons from HMO database; same criteria as cases, and in addition without a history of colon cancer | | | Men | | Women | | N/A | In-person interviews to recall behaviors 2 years before the date of selection to determine dietary intake, supplement use, and sun exposure | Adjusted for age, BMI, family history of colorectal cancer, lifetime vigorous physical activity, total energy intake, dietary fiber, and regular use of ASA or NSAIDs, and calcium intake Additionally all analyses were stratified by sex, age at diagnosis, location of cancer, and family history of colon cancer | Response rate: 76% cases, 64% controls Additional attrition after interview due to ineligibility and missing data: 66% cases, 62% controls | (Table 2) association between sun exposure (per quintile) and colon cancer Quintile of sun exposure, # cases/controls, multivar-adj OR, [95%CI] | | | | | Did not adjust for skin phenotype
Kampman 2000^101^ Fair | To evaluate potential sources of inconsistencies of the association between calcium and vitamin D (dietary or sun exposure) and colon cancer | Case-control Multi-state, US General population from large HMO | | | | Cases | Controls | Cases | Controls | N/A | In-person interviews to recall behaviors 2 years before the date of selection to determine dietary intake, supplement use, and sun exposure | | Response rate: 76% cases, 64% controls Additional attrition after interview due to ineligibility and missing data: 66% cases, 62% controls | | men | women | | | Did not adjust for skin phenotype
Kampman 2000^101^ Fair | To evaluate potential sources of inconsistencies of the association between calcium and vitamin D (dietary or sun exposure) and colon cancer | Case-control Multi-state, US General population from large HMO | | | | | | | | N/A | In-person interviews to recall behaviors 2 years before the date of selection to determine dietary intake, supplement use, and sun exposure | | Response rate: 76% cases, 64% controls Additional attrition after interview due to ineligibility and missing data: 66% cases, 62% controls | | | | | | Did not adjust for skin phenotype
Kampman 2000^101^ Fair | To evaluate potential sources of inconsistencies of the association between calcium and vitamin D (dietary or sun exposure) and colon cancer | Case-control Multi-state, US General population from large HMO | | N: | | 1095 | 1286 | 888 | 1114 | N/A | In-person interviews to recall behaviors 2 years before the date of selection to determine dietary intake, supplement use, and sun exposure | | Response rate: 76% cases, 64% controls Additional attrition after interview due to ineligibility and missing data: 66% cases, 62% controls | Low | 236, 260, 1.0 [n/a] | 196, 239, 1.0 [n/a] | | | Did not adjust for skin phenotype
Kampman 2000^101^ Fair | To evaluate potential sources of inconsistencies of the association between calcium and vitamin D (dietary or sun exposure) and colon cancer | Case-control Multi-state, US General population from large HMO | | Age (SD): | | 65 (9.8) | 64 (10.3) | 65 (10.0) | 65 (10.3) | N/A | In-person interviews to recall behaviors 2 years before the date of selection to determine dietary intake, supplement use, and sun exposure | | Response rate: 76% cases, 64% controls Additional attrition after interview due to ineligibility and missing data: 66% cases, 62% controls | 2 | 224, 264, 1.0 [0.8, 1.3] | 198, 203, 1.3 [1.0, 1.7] | | | Did not adjust for skin phenotype
Kampman 2000^101^ Fair | To evaluate potential sources of inconsistencies of the association between calcium and vitamin D (dietary or sun exposure) and colon cancer | Case-control Multi-state, US General population from large HMO | | Sex: n/a Skin phenotype: NR Text states that population was 91.3% White, but skin phenotype is not otherwise recorded/reported | | | | | | N/A | In-person interviews to recall behaviors 2 years before the date of selection to determine dietary intake, supplement use, and sun exposure | | Response rate: 76% cases, 64% controls Additional attrition after interview due to ineligibility and missing data: 66% cases, 62% controls | 3 | 230, 252, 1.1 [0.8, 1.4] | 155, 231, 0.9 [0.7, 1.2] | | | Did not adjust for skin phenotype
Kampman 2000^101^ Fair | To evaluate potential sources of inconsistencies of the association between calcium and vitamin D (dietary or sun exposure) and colon cancer | Case-control Multi-state, US General population from large HMO | | Sex: n/a Skin phenotype: NR Text states that population was 91.3% White, but skin phenotype is not otherwise recorded/reported | | | | | | N/A | In-person interviews to recall behaviors 2 years before the date of selection to determine dietary intake, supplement use, and sun exposure | | Response rate: 76% cases, 64% controls Additional attrition after interview due to ineligibility and missing data: 66% cases, 62% controls | 4 | 211, 273, 0.9 [0.7, 1.2] | 171, 216, 1.1 [0.8, 1.5] | | | Did not adjust for skin phenotype
Kampman 2000^101^ Fair | To evaluate potential sources of inconsistencies of the association between calcium and vitamin D (dietary or sun exposure) and colon cancer | Case-control Multi-state, US General population from large HMO | | Sex: n/a Skin phenotype: NR Text states that population was 91.3% White, but skin phenotype is not otherwise recorded/reported | | | | | | N/A | In-person interviews to recall behaviors 2 years before the date of selection to determine dietary intake, supplement use, and sun exposure | | Response rate: 76% cases, 64% controls Additional attrition after interview due to ineligibility and missing data: 66% cases, 62% controls | High | 185, 235, 0.9 [0.7, 1.1] | 160, 216, 1.0 [0.8, 1.4] | | | Did not adjust for skin phenotype
Kampman 2000^101^ Fair | To evaluate potential sources of inconsistencies of the association between calcium and vitamin D (dietary or sun exposure) and colon cancer | Case-control Multi-state, US General population from large HMO | | Sex: n/a Skin phenotype: NR Text states that population was 91.3% White, but skin phenotype is not otherwise recorded/reported | | | | | | N/A | In-person interviews to recall behaviors 2 years before the date of selection to determine dietary intake, supplement use, and sun exposure | | Response rate: 76% cases, 64% controls Additional attrition after interview due to ineligibility and missing data: 66% cases, 62% controls | Multi-var adj for age, BMI, family history, aspirin or NSAIDs, energy intake, physical activity, fiber and calcium | | | | | Did not adjust for skin phenotype
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | Cases: Diagnosis of NHL from regional cancer registry (and dx independently validated), identified from Jan 1990 through Aug 2001, age 20–74, English speaking, and able to complete a 60 min telephone interview; cases with chronic lymphocytic leukemia, plama cell meyloma, precursor B and T lymphoblastic leukemia, and lymphomatoid granulomatosis grades 1 and 2, or history of immunosupression for organ transplantation or HIV infection were excluded Controls: Age, sex, and residence matched persons from electoral roles, with same exclusion criteria, although HIV status was not asked of controls | | | Cases | Controls | | | N/A | Brief paper questionnaire and telephone interview to determine sun exposure In addition three measures of ambient solar irradiance were assigned to each residential location for each subject using latitude/longitude coordinates, SES assessed using census data | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | (Table 1) risk of NHL with sun exposure (per quartile) Sun exposure during the decade years, multivar-adj OR, [95% CI] Lowest: 1.0 [n/a] 25–50%: 0.72 [0.53, 0.98] 50–75%: 0.66 [0.48, 0.91] Highest: 0.65 [0.46, 0.91] p-value (trend): 0.01 Lifetime occupational sun exposure, multivar-adj OR, [95% CI] Lowest: 1.0 [n/a] 25–50%: 1.03 [0.76, 1.40] 50–75%: 1.04 [0.76, 1.43] Highest: 1.21 [0.87, 1.69] p-value (trend): 0.30 (Table 2) risk of NHL with vacation sun exposure Sun exposure during the decade years, multivar-adj OR, [95% CI] Lowest: 1.0 [n/a] 25–50%: 0.98 [0.72, 1.32] 50–75%: 0.82 [0.60, 1.12] Highest: 0.60 [0.43, 0.85] p-value (trend): 0.003 Multi-var adj for age, sex, state, ethnicity, skin colour and ability to tan | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | | | | | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | N: | | 704 | 694 | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Age (%<50): | | 73.9 | 73.3 | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Sex (% men): | | 26.6 | 26.1 | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Skin phenotype: | | | | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Skin color (%) | | | | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Brown or olive | | 31.5 | 31.1 | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Fair | | 53.7 | 57.6 | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Very fair | | 14.8 | 11.2 | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Ability to tan (%) | | | | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Deep tan | | 27.0 | 29.1 | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Moderate tan | | 43.6 | 42.1 | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | Mild tan | | 20.9 | 22.8 | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | No tan | | 8.1 | 5.8 | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Hughes 2004^103^ Hughes 2004^102^ Fair | To determine whether high sun exposure is associated with an increased risk of NHL | Case-control New South Wales, Australia General population from regional cancer registry and electoral rolls | | (skin phenotype calculated from Table 2, I1a) | | | | | | N/A | | Adjusted for age, sex, state of residence, skin phenotype, and ethnicity | Response rate: 85% cases, 61% controls | | | | | | Baseline data from I1a Hughes 2004, RM 4564
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | Cases: Diagnosis of lymphoma from national pathology registries (and diagnosis independently validated in random subsample), identified from October 1999/June 2000 through April/August 2002, ages 18–74, Danish or Swedish speaking, and able to complete telephone interview; cases with other hematopeietic malignancy or with history of immunosupression for organ transplantation or HIV infection were excluded Controls: Age, sex, and country matched persons from comprehensive population registers | | | | Cases | Controls | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | (Table 3) risk of lymphoma with sun exposure Sunbathing past 5–10 years, multivar-adj OR, [95%CI]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | N: | | | 3740 | 3187 | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | | | # controls | NHL | Hodgkin
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | Age (median): | | | 59 | 59 | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | Never | | 799 | 946, 1.0 [n/a] | 122, 1.0 [n/a]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | Sex (% men): | | | 58 | 55 | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | Once/wk or less | | 1013 | 938, 0.9 [0.7, 1.0] | 236, 0.8 [0.6, 1.0]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | [underlined: Skin phenotype (%):] | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | 2–3x/week | | 666 | 555, 0.8 [0.7, 0.9] | 141, 0.7 [0.5, 1.0]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | Type I, burns | | | 17 | 15 | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | 4x/week or more | | 666 | 581, 0.7 [0.6, 0.9] | 118, 0.7 [0.5, 1.0]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | Type II, burns/tans | | | 20 | 25 | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | p-value (trend) | | | <0.001 | 0.06
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | Type III, tans | | | 28 | 31 | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | Sunbathing @20 years old, multivar-adj OR, [95%CI]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | Type IV, tans/never burns | | | 32 | 29 | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | | | # controls | NHL | Hodgkin
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | Never | | 434 | 568, 1.0 [n/a] | 49, 1.0 [n/a]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | Once/wk or less | | 931 | 918, 0.8 [0.7, 0.9] | 84, 0.8 [0.5, 1.2]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | 2–3x/wk | | 674 | 635, 0.7 [0.6, 0.9] | 50, 0.6 [0.4, 1.0]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | 4x/wk or more | | 653 | 642, 0.7 [0.6, 0.9] | 73, 0.9 [0.6, 1.4]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | p-value (trend) | | | 0.001 | 0.84
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | Sun vacations abroad, multivar-adj OR, [95%CI]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | | | # controls | NHL | Hodgkin
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | Never | | 830 | 910, 1.0 [n/a] | 146, 1.0 [n/a]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | 1–5x | | 1002 | 1000, 1.0 [0.9, 1.1] | 234, 0.8 [0.6, 1.0]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | 6–20x | | 919 | 822, 0.9 [0.8, 1.0] | 177, 0.7 [0.5, 0.9]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | >20x | | 410 | 305, 0.7 [0.6, 0.8] | 60, 0.8 [0.6, 1.2]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | p-value (trend) | | | <0.001 | 0.06
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | Sunbed/sunlamp use, multivar-adj OR, [95%CI]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | | | # controls | NHL | Hodgkin
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | Never | | 1254 | 1317, 1.0 [n/a] | 203, 1.0 [n/a]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | <10x | | 742 | 790, 1.0 [0.9, 1.2] | 134, 0.8 [0.6, 1.0]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | 10–49x | | 765 | 643, 0.9 [0.8, 1.0] | 161, 0.7 [0.5, 0.9]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | 50+x | | 377 | 270, 0.8 [0.7, 1.0] | 116, 0.7 [0.5, 0.9]
Smedby 2005^104^ Fair | To determine whether exposure to UV radiation increases lymphoma risk | Case-control Denmark and Sweden General population from SCALE study (Scandinavian lymphoma etiology) and population registers | | | | | | | | N/A | Telephone interview to determine host factors and exposure (sun, and sunbed/lamps), as well as self-reported skin cancers | Adjusted for skin type, occupational exposure to pesticides | Response rate: 81–91% of cases, 71% of controls | p-value (trend) | | | 0.01 | 0.004
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | Cases: diagnosis of advanced prostate cancer from SEER registry, identified from Jul 1997 to Feb 2000, age 40–79, English speaking, non-Hispanic White, (African American initially included but ultimately excluded from analysis); cases with prior prostate cancer, or those living outside designated area were excluded Controls: age, race and residence matched persons from random digit dialing or Health Care Financing Administration rosters with same exclusion criteria | | | Cases | Controls | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) in addition solar radiation level by state of residence assessed from National Weather Service Stations | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | (Table 2) risk of advanced prostate cancer with sun exposure lifetime outdoor activities (h/wk), # cases, # controls, age-adj OR, [95%CI], mutivar-adj OR [95%CI]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | n: | | 450 | 455 | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | <2.7: | 85, 91, 1.0 [n/a], 1.0 [n/a]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | Age (median): | | 64 | 65 | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 2.7–5.6 | 99, 91, 1.16 [0.77, 1.75], 1.15 [0.76, 1.73]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | Sex (% men): | | 100 | 100 | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 5.7–10.4 | 92, 91, 1.08 [0.72, 1.64], 1.09 [0.72, 1.65]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | Skin phenotype: | | NR | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 10.5–19.8 | 94, 91, 1.11 [0.73, 1.67], 1.10 [0.73, 1.67]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | Ethnicity: | | 100% non-Hispanic White | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 19.9+ | 80, 91, 0.94 [0.62, 1.44], 0.95 [0.62, 1.45]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | p-value (trend) | 0.8
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | lifetime outdoor jobs (h/wk), # cases, # controls, age-adj OR, [95%CI], mutivar-adj OR [95%CI]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 0 | 123, 120, 1.0 [n/a], 1.0 [n/a]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | <1.4 | 84, 84, 0.99 [0.67, 1.47], 0.96 [0.65, 1.43]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 1.4–5.6 | 100, 83, 1.19 [0.81, 1.75], 1.20 [0.81, 1.77]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 5.7–14.7 | 81, 84, 0.94 [0.63, 1.40], 0.95 [0.64, 1.41]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 14.8+ | 62, 84, 0.73 [0.48, 1.10], 0.73 [0.48, 1.11]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | p-value (trend) | 0.3
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | facultative pigmentation, # cases, # controls, age-adj OR, [95%CI], mutivar-adj OR [95%CI]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | light | 100, 90, 1.0 [n/a], 1.0 [n/a]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 2 | 107, 90, 1.08 [0.73,1.61], 1.08 [0.73,1.62]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 3 | 86, 91, 0.85 [0.56,1.28], 0.83 [0.55,1.26]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 4 | 86, 91, 0.85 [0.56,1.28], 0.83 [0.55,1.26]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | dark | 68, 90, 0.68 [0.44,1.03], 0.66 [0.43,1.01]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | p-value (trend) | 0.03
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | sun exposure index ((facultative pigmentation-constitutive pigmentation)/constitutive pigmentation) # cases, # controls, age-adj OR, [95%CI], mutivar-adj OR [95%CI]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | low | 106, 89, 1.0 [n/a], 1.0 [n/a]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 2 | 93, 90, 0.85 [0.57,1.28], 0.87 [0.58,1.30]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 3 | 89, 92, 0.81 [0.54,1.21], 0.80 [0.53,1.20]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | 4 | 103, 91, 0.94 [0.63,1.40], 0.95 [0.64,1.42]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | high | 56, 90, 0.52 [0.33, 0.80], 0.51 [0.33,0.80]
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | p-value (trend) | 0.02
John 2005^105^ Fair | To determine whether measures of sun exposure is associated with an increased risk of advanced prostate cancer | Case-control California General population from SEER cancer registry, random digit dialing, and beneficiaries of Health Care Financing Administration | | | | | | | | | | adjusted for age, family history of prostate cancer | response rate: 72% cases, 63% controls | multivar adj for age, family history of prostate cancer, +/− month of pigmentation measurements
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | Cases: Diagnosis of first primary NHL from SEER registry, identified from July 1998 to June 2000, age 20–74, assumed English speaking; cases with HIV were excluded Controls: Age, sex, race and study area matched persons from random digit dialing or Centers for Medicare and Medicaid Services population roster | | | Cases | Controls | | | | in-person interviews, plus mailed questionnaire, to determine demographic, diet, and sun exposure history in addition measurements of solar radiation obtained from Robertson-Berger (RB) meters located in many states | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | (Table 3) risk of NHL with various measures of sun exposure hours mid-day sun last 10 years, # cases, #controls, multivar-adj OR [95%CI]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | n: | | 551 | 462 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <7 | 216, 159, 1.0 [n/a]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | Age (%<55): | | 41 | 27 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <14 | 145, 126, 0.85 [0.62, 1.18]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | Sex (% men): | | 53 | 52 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <28 | 131, 123, 0.75 [0.54, 1.05]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | Skin phenotype: | | | | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | 28+ | 59, 51, 0.73 [0.46, 1.15]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | dark | | 30 | 20 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | p-value (trend) | 0.07
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | medium | | 306 | 252 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | hours mid-day sun during teens years, # cases, #controls, multivar-adj OR [95%CI]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | light | | 215 | 189 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <7 | 62, 46, 1.0 [n/a]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | [underlined: Ethnicity:] | | | | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <14 | 89, 68, 0.97 [0.59, 1.61]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % White | | 90 | 91 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <28 | 185, 155, 0.81 [0.52, 1.27]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % African Amer | | NR (assumed 0, not c/w descrip in methods) | | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | 28+ | 211, 187, 0.75 [0.48, 1.18]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Hispanic | | 5 | 5 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | p-value (trend) | 0.12
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | hours mid-day sun during twenties, # cases, #controls, multivar-adj OR [95%CI]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <7 | 143, 107, 1.0 [n/a]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <14 | 143, 124, 0.86 [0.60, 1.22]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <28 | 156, 132, 0.83 [0.58, 1.18]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | 28+ | 105, 94, 0.75 [0.50, 1.11]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | p-value (trend) | 0.15
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | hours mid-day sun during thirties, # cases, #controls, multivar-adj OR [95%CI]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <7 | 183, 137, 1.0 [n/a]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <14 | 135, 135, 0.75 [0.54, 1.04]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <28 | 145, 112, 0.95 [0.68, 1.33]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | 28+ | 68, 66, 0.78 [0.50, 1.19]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | p-value (trend) | 0.44
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | use of sunlamp or sunbed, # cases, #controls, multivar-adj OR [95%CI]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | never | 401, 338, 1.0 [n/a]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | <5x | 32, 33, 0.78 [0.46, 1.32]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | 5–9x | 32, 25, 0.90 [0.52, 1.58]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | 10+x | 84, 66, 0.90 [0.61, 1.30]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | p-value (trend) | 0.49
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | history of blistering sunburns, # cases, #controls, multivar-adj OR [95%CI]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | never | 224, 177, 1.0 [n/a]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | 1x | 117, 103, 0.87 [0.62, 1.23]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | 2–4x | 114, 84, 1.02 [0.72, 1.46]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | 5+x | 92, 96, 0.68 [0.47, 0.97]
Hartge 2006^106^ Fair | To determine whether measures of UV exposure is associated with an increased risk of Non-Hodgkin Lymphoma | Case-control Multi-state, US General population from SEER cancer registry and random digit dialing and Centers for Medicare and Medicare population rosters | | % Asian | | 4 | 3 | | | | | adjusted for age, sex, center, ethnicity, education, alcohol consumption, weekly exercise, residential UV radiation, dietary vitamin D | response rate: 59% cases, 44% controls | p-value (trend) | 0.10
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | Cases: diagnosis of primary invasive breast cancer from SEER registry, identified from 1995 to 1999, age 35–79, English or Spanish speaking, Hispanic, non-Hispanic White, African American Controls: age, race matched persons from RDD | | | Cases | Controls | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | adjusted for age, race/ethnicity, education, family history of breast cancer, personal history of benign breast disease, age at menarche, number of full-term pregnancies, breastfeeding, menopausal status, hormone therapy use, BMI, height, lifetime physical activity, alcohol consumption; and stratified by constitutive skin pigmentation | response rate: 87% cases, 84% controls | (Table 3) risk of advanced breast cancer with sun exposure lifetime outdoor activities (h/wk by quartile), # cases, # controls, mutivar-adj OR [95%CI]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | n: | | 1786 | 2127 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | | light pigmentation | medium pigmentation | dark pigmentation
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | Age (%50–64): | | 40 | 39 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | low | 37, 153, 1.0 [n/a] | 43,180, 1.0 [n/a] | 49,174, 1.0 [n/a]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | Sex (% men): | | 0 | 0 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 2 | 41, 167, 0.97 [0.58,1.62] | 47,154, 1.17 [0.72, 1.91] | 52,180, 1.01 [0.65, 1.59]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | Skin phenotype: | | NR | | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 3 | 59, 188, 1.29 [0.80,2.09] | 55,169, 1.23 [0.76, 1.97] | 61,165, 1.31 [0.84, 2.03]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | [underlined: Ethnicity] | | | | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | high | 37, 180, 0.86 [0.51,1.45] | 36,175, 0.77 [0.46, 1.29] | 50,153, 1.14 [0.72, 1.81]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % White | | 33.4 | 30.4 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | p-value (trend) | 0.90 | 0.82 | 0.36
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % African Amer | | 30.4 | 28.1 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | facultative pigmentation, # cases, # controls, mutivar-adj OR [95%CI]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | | light pigmentation | medium pigmentation | dark pigmentation
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | light | 55, 171, 1.0 [n/a] | 48,171, 1.0 [n/a] | 53,169, 1.0 [n/a]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 2 | 48, 183, 0.73 [0.45,1.17] | 54,161, 1.22 [0.76, 1.98] | 48,169, 0.89 [0.52, 1.55]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 3 | 35, 167, 0.56 [0.33,0.94] | 38,180, 0.86 [0.51, 1.46] | 56,169, 1.00 [0.56, 1.81]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | dark | 37, 173, 0.54 [0.32,0.94] | 41,171, 1.07 [0.62, 1.85] | 57,174, 1.00 [0.55, 1.81]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | p-value (trend) | 0.02 | 0.88 | 0.81
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | sun exposure index ((facultative pigmentation-constitutive pigmentation)/constitutive pigmentation)
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | | light pigmentation | medium pigmentation | dark pigmentation
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | low | 56, 174, 1.0 [n/a] | 47,172, 1.0 [n/a] | 50,171, 1.0 [n/a]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 2 | 47, 174, 0.78 [0.49,1.26] | 55,173, 1.29 [0.80, 2.08] | 52,170, 1.15 [0.73, 1.82]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 3 | 37, 171, 0.62 [0.37,1.04] | 35,167, 0.90 [0.53, 1.55] | 59,168, 1.39 [0.89, 2.17]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | high | 35, 175, 0.53 [0.31, 0.91] | 44,171, 1.26 [0.74, 2.15] | 53,172, 1.28 [0.81, 2.05]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | p-value (trend) | 0.01 | 0.68 | 0.20
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | (Table 3) risk of localized breast cancer with sun exposure lifetime outdoor activities (h/wk by quartile), # cases, # controls, mutivar-adj OR [95%CI]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | | light pigmentation | medium pigmentation | dark pigmentation
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | low | 85, 153, 1.0 [n/a] | 97,180, 1.0 [n/a] | 101,174, 1.0 [n/a]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 2 | 91, 167, 0.95 [0.65,1.40] | 70,154, 0.79 [0.53, 1.17] | 89,180, 0.80 [0.56, 1.15]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 3 | 103, 188, 0.89 [0.61,1.29] | 129,169, 1.35 [0.94, 1.93] | 96,165, 0.94 [0.66, 1.35]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | high | 107, 180, 1.05 [0.72,1.54] | 92,175, 1.02 [0.70, 1.50] | 64,153, 0.70 [0.47, 1.04]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | p-value (trend) | 0.85 | 0.20 | 0.18
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | facultative pigmentation, # cases, # controls, mutivar-adj OR [95%CI]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | | light pigmentation | medium pigmentation | dark pigmentation
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | light | 95, 171, 1.0 [n/a] | 101,171, 1.0 [n/a] | 73,169, 1.0 [n/a]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 2 | 109, 183, 1.18 [0.82,1.71] | 118,161, 1.34 [0.93, 1.94] | 87,169, 1.22 [0.76, 1.97]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 3 | 97, 167, 1.10 [0.75,1.61] | 90,180, 1.04 [0.70, 1.54] | 88,169, 1.20 [0.71, 2.01]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | dark | 89, 173, 1.11 [0.74,1.67] | 81,177, 1.12 [0.73, 1.71] | 102,174, 1.40 [0.83, 2.33]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | p-value (trend) | 0.72 | 0.80 | 0.24
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | sun exposure index ((facultative pigmentation-constitutive pigmentation)/constitutive pigmentation)
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | | light pigmentation | medium pigmentation | dark pigmentation
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | low | 104, 174, 1.0 [n/a] | 108,172, 1.0 [n/a] | 75,171, 1.0 [n/a]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 2 | 103, 174, 1.09 [0.76,1.58] | 107,173, 1.12 [0.78, 1.62] | 99,170, 1.43 [0.97, 2.10]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | 3 | 87, 171, 0.96 [0.65,1.41] | 90,167, 1.01 [0.68, 1.49] | 87,168, 1.30 [0.88, 1.93]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | high | 96, 175, 1.10 [0.74,1.63] | 84,171, 1.06 [0.71, 1.60] | 89,172, 1.11 [0.74, 1.67]
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | p-value (trend) | 0.81 | 0.86 | 0.74
John 2007^107^ Good | To determine whether measures of sun exposure is associated with an increased risk of breast cancer | Case-control California General population from SEER cancer registry and RDD | | % Hispanic | | 36.2 | 41.5 | | | | in-person interviews, administered structured questionnaires, plus exam with measurement of skin pigmentation with portable reflectometer, DNA sample (blood or mouthwash) | | response rate: 87% cases, 84% controls | multivar adj for age, race/ethnicity, education, family history of breast cancer, personal history of breast disease, age at menarche, number full-term pregnancies, breastfeeding, BMI, height, physical activity, alcohol consumption

OHD=hydroxyvitamin D; RCT=randomized controlled trial; IG=intervention group; CG=control group; SPF=sun protection factor; N/A=not applicable; PTH=parathyroid hormone; FSH=follicle stimulating hormone; UV=ultraviolet; nmol=nanomole; L=liter; BMI=body mass index; CCT=clinical controlled trial; km=kilometer; CI=confidence interval; NR=not reported; NHANES=National Health and Nutrition Examination Survey; multivar=multivariate; adj=adjusted; RR=relative risk; IU=international unit; HMO=health maintenance organization; NSAID=nonsteroidal anti-inflammatory drug; SES=socioeconomic status; HIV=human immunodeficiency virus; x=times; NHL=nonHodgkins lymphoma

Appendix C Table 4 Studies Excluded From the Review for Key Question 5

Reference | Reason for Exclusion
Adami J, Gridley G, Nyren O, et al. Sunlight and non-Hodgkin’s lymphoma: a population-based cohort study in Sweden. Int J Cancer. 1999;80:641–645. | No relevant outcomes
Armstrong BK, Kricker A. Sun exposure and non-Hodgkin lymphoma. Cancer Epidemiol Biomarkers Prev. 2007;16:396–400. | Study design
Autier P, Boniol M, Dore JF. Sunscreen use and increased duration of intentional sun exposure: still a burning issue. Int J Cancer. 2007;121(1):1–5. | Study quality
Autier P, Dore JF, Cattaruzza MS, et al. Sunscreen use, wearing clothes, and number of nevi in 6- to 7-year-old European children. European Organization for Research and Treatment of Cancer Melanoma Cooperative Group. J Natl Cancer Inst. 1998;90:1873–1880. | Study design
Autier P, Dore JF, Lejeune F, et al. Cutaneous malignant melanoma and exposure to sunlamps or sunbeds: an EORTC multicenter case-control study in Belgium, France and Germany. EORTC Melanoma Cooperative Group. Int J Cancer. 1994;58:809–813. | Study design
Autier P, Dore JF, Schifflers E, et al. Melanoma and use of sunscreens: an EORTC case-control study in Germany, Belgium and France. EORTC Melanoma Cooperative Group. Int J Cancer. 1995;61:749–755. | Study design
Bodiwala D, Luscombe CJ, French ME, et al. Associations between prostate cancer susceptibility and parameters of exposure to ultraviolet radiation. Cancer Lett. 2003;200:141–148. | Study quality
Boniol M, Autier P, Dore JF. Photoprotection. Lancet. 2007;370:1481–1482. | Study design
Boscoe FP, Schymura MJ. Solar ultraviolet-B exposure and cancer incidence and mortality in the United States, 1993–2002. BMC Cancer. 2006;6:264. | Study design
De Vries E, Soerjomataram I, Houterman S, et al. Decreased risk of prostate cancer after skin cancer diagnosis: a protective role of ultraviolet radiation? Am J Epidemiol. 2007;165:966–972. | No relevant outcomes
Dixon A. Arc welding and the risk of cancer. Aust Fam Physician. 2007;36:255–256. | No relevant outcomes
English DR, Milne E, Simpson JA. Sun protection and the development of melanocytic nevi in children. Cancer Epidemiol Biomarkers Prev. 2005;14:2873–2876. | No relevant outcomes
Farrerons J, Barnadas M, Lopez-Navidad A, et al. Sunscreen and risk of osteoporosis in the elderly: a two-year follow-up. Dermatology. 2001;202(1):27–30. | Study quality
Farrerons J, Barnadas M, Rodriguez J, et al. Clinically prescribed sunscreen (sun protection factor 15) does not decrease serum vitamin D concentration sufficiently either to induce changes in parathyroid function or in metabolic markers. Br J Dermatol.1998;139 (3):422–427. | Study quality
Freedman DM, Dosemeci M, McGlynn K. Sunlight and mortality from breast, ovarian, colon, prostate, and non-melanoma skin cancer: a composite death certificate based case-control study. Occup Environ Med. 2002;59:257–262. | No relevant outcomes
Geller AC, Colditz G, Oliveria S, et al. Use of sunscreen, sunburning rates, and tanning bed use among more than 10,000 US children and adolescents. Pediatrics. 2002;109:1009–1014. | No relevant outcomes
Grant WB. A meta-analysis of second cancers after a diagnosis of nonmelanoma skin cancer: additional evidence that solar ultraviolet-B irradiance reduces the risk of internal cancers. J Steroid Biochem Mol Biol. 2007;103:668–674. | Study design
Gruber SB, Armstrong B. Cutaneous and ocular melanoma. In: Schottenfeld D, Fraumeni JF, eds. Cancer Epidimiology and Prevention. 2006:1196–229. | Study design
Heckmann M, Zogelmeier F, Konz B. Frequency of facial basal cell carcinoma does not correlate with site-specific UV exposure. Arch Dermatol. 2002;138:1494–1497. | Study design
Holick MF, Chen TC, Lu Z, Sauter E. Vitamin D and skin physiology: a D-lightful story. J Bone Mineral Res. 2007;22(Suppl 2):28–33. | Study quality
Holick MF. Sunlight “D”ilemma: risk of skin cancer or bone disease and muscle weakness. Lancet. 2001;357:4–6. | Study design
John EM, Dreon DM, Koo J, et al. Residential sunlight exposure is associated with a decreased risk of prostate cancer. J Steroid Biochem Mol Biol. 2004;89–90:549–552. | No relevant outcomes
Lawler S, Sugiyama T, Owen N. Sun exposure concern, sun protection behaviors and physical activity among Australian adults. Cancer Causes Control. 2007;18:1009–1014. | Study quality
Lim JL, Stern RS. High levels of ultraviolet B exposure increase the risk of non- melanoma skin cancer in psoralen and ultraviolet A-treated patients. J Invest Dermatol. 2005;124:505–513. | Population
Lucas RM, Repacholi MH, McMichael AJ. Is the current public health message on UV exposure correct? Bull World Health Organ. 2006;84:485–491. | Study design
Matsuoka LY, Wortsman J, Hanifan N, Holick MF. Chronic sunscreen use decreases circulating concentrations of 25-hydroxyvitamin D. A preliminary study. Arch.Dermatol. 1988;124(12):1802–1804. | Study quality
Moan J, Porojnicu AC, Robsahm TE, et al. Solar radiation, vitamin D and survival rate of colon cancer in Norway. J Photochem Photobiol B. 2005;78:189–193. | Study relevance
Ness AR, Frankel SJ, Gunnell DJ, Smith GD. Are we really dying for a tan? BMJ. 1999;319:114–116. | Study design
Porojnicu AC, Robsahm TE, Ree AH, Moan J. Season of diagnosis is a prognostic factor in Hodgkin’s lymphoma: a possible role of sun-induced vitamin D. Br J Cancer. 2005;93:571–574. | Study relevance
Reichrath J. Protecting against adverse effects of sun protection. J Am Acad Dermatol. 2003;49:1204–1206. | Study design
Reichrath J. Sunlight, skin cancer and vitamin D: What are the conclusions of recent findings that protection against solar ultraviolet (UV) radiation causes 25- hydroxyvitamin D deficiency in solid organ-transplant recipients, xeroderma pigmentosum, and other risk groups? J Steroid Biochem Mol Biol. 2007;103:664–667. | Study design
Robsahm TE, Tretli S, Dahlback A, et al. Vitamin D3 from sunlight may improve the prognosis of breast-, colon- and prostate cancer (Norway). Cancer Causes Control. 2004;15:149–158. | No relevant outcomes
Samanek AJ, Croager EJ, Gies P, et al. Estimates of beneficial and harmful sun exposure times during the year for major Australian population centres. Med J Aust. 2006;184:338–341. | Study design
Sayre RM, Dowdy JC. Darkness at noon: sunscreens and vitamin D3. Photochem Photobiol. 2007;83:459–463. | Study design
The Cancer Council Australia. Risks and benefits of sun exposure: position statement. 2005. | Study design
Thompson SC, Jolley D, Marks R. Reduction of solar keratoses by regular sunscreen use. N Engl J Med. 1993;329:1147–1151. | No relevant outcomes
Thieden E, Philipsen PA, Sandby-Moller J, Wulf HC. Sunscreen use related to UV exposure, age, sex, and occupation based on personal dosimeter readings and sun-exposure behavior diaries. Arch Dermatol. 2005;141(8):967–973. | Study quality
van der Rhee HJ, De Vries E, Coebergh JW. Does sunlight prevent cancer? A systematic review. Eur J Cancer. 2006;42:2222–2232. | Reported only intermediate outcomes
Weinstock MA. Do sunscreens increase or decrease melanoma risk: an epidemiologic evaluation. J Invest Dermatol Sym Proc. 1999;4:97–100. | Study design
Westerdahl J, Olsson H, Masback A, et al. Use of sunbeds or sunlamps and malignant melanoma in southern Sweden. Am J Epidemiol. 1994;140(8):691–699. | No relevant outcomes
Westerdahl J, Olsson H, Masback A, Ingvar C, Jonsson N. Is the use of sunscreens a risk factor for malignant melanoma? Melanoma Res. 1995;5(1):59–65. | No relevant outcomes
Wiecker TS, Luther H, Buettner P, et al. Moderate sun exposure and nevus counts in parents are associated with development of melanocytic nevi in childhood: a risk factor study in 1,812 kindergarten children. Cancer. 2003;97:628–638. | No relevant outcomes
Xu LY, Koo J. Predictive value of phenotypic variables for skin cancer: risk assessment beyond skin typing. Int J Dermatol. 2006;45:1275–1283. | Study relevance
Youl P, Aitken J, Hayward N, et al. Melanoma in adolescents: a case-control study of risk factors in Queensland, Australia. Int J Cancer. 2002;98:92–98. | No relevant outcomes
Zlotkin S. Vitamin D concentrations in Asian children living in England. Limited vitamin D intake and use of sunscreens may lead to rickets. BMJ. 1999;318:1417. | Study design