# Appendix B Evidence Tables for KQ1-KQ3

Appendix B Table 1 Evidence Table for Effectiveness and Adverse Effects of Counseling for Sun Protective Behaviors

Study reference, USPSTF quality rating | Study design, Location, Population | Participant inclusion/exclusion criteria | Baseline demographics | | Intervention theory description | Study intervention | Follow-up | Intermediate outcomes | Behavioral outcomes: sun avoidance, sun protection | | | | Behavioral outcomes: sunscreen use | Behavioral outcomes: sunlamps and tanning bed avoidance | Composite behavioral outcomes | | | | Other behavioral outcomes | Adverse outcomes | Other positive outcomes | Comments
Study reference, USPSTF quality rating | Study design, Location, Population | Participant inclusion/exclusion criteria | | | Intervention theory description | Study intervention | Follow-up | Intermediate outcomes | Behavioral outcomes: sun avoidance, sun protection | | | | Behavioral outcomes: sunscreen use | Behavioral outcomes: sunlamps and tanning bed avoidance | Composite behavioral outcomes | | | | Other behavioral outcomes | Adverse outcomes | Other positive outcomes | Comments
Study reference, USPSTF quality rating | Study design, Location, Population | Participant inclusion/exclusion criteria | Baseline | Follow-up | Intervention theory description | Study intervention | Follow-up | Intermediate outcomes | Behavioral outcomes: sun avoidance, sun protection | | | | Behavioral outcomes: sunscreen use | Behavioral outcomes: sunlamps and tanning bed avoidance | Composite behavioral outcomes | | | | Other behavioral outcomes | Adverse outcomes | Other positive outcomes | Comments
Adults
Glazebrook 2006 46 Fair | Study Design Cluster RCT (by practice) Location 10 primary care practices (5 pairs: 1 rural, 1 urban, 3 suburban), in Nottinghamshire, UK Population Adults with "higher risk skin characteristics" | Inclusion "higher risk skin characteristics"- any one of the following risk factors: red hair, multiple moles, history of sunburn as a child, freckling, family history of melanoma, fair sun-sensitive skin); patients from 'control' family practices were invited to participate if they appeared to match the skin and demographic profile of participants in the intervention group Exclusion NR | N participants, (10 sites randomized) Total: 589 IG: 259 CG: 330 Mean age (SD) Total: NR IG: 38.2 (14.3) CG: 38.4 (15.2) % Male Total: 19.7 (c) IG: 17.4 CG: 21.5 Race % White: NR SES Highest educational level (% with further or higher education) Total: 52.5 (c) IG: 54.1 CG: 51.2 Occupation (% with professional or skilled) Total: 41.3 (c) IG: 39.8 CG: 42.4 High risk % with high risk characteristic, not specified Total: 100.0 % sought advice for suspicious lesion in past year Total: 12.8 (c) IG: 14.2 CG: 11.6 | | Skinsafe intervention based on the Health Belief Model, developed by multidisciplinary team of health psychologists, dermatologists, and a multimedia developer. | Intervention IG: Prescription for "Skinsafe program": 8 sections designed to be completed in a single 10–15 minute sitting, using animation, photographs, and simple text to inform users about dangers of excessive sun exposure, how to protect skin from the sun, characteristics of skin at risk, early signs of melanoma, how to reduce risk for melanoma, how to check skin for suspicious lesions CG: Usual care, details not given Format IG: Self-directed computer workstation in quiet area CG: N/A Intensity IG: Approximately 10–15 minute single session CG: N/A Delivery IG: Computer CG: N/A | % followup, @ 6mo IG: 82.6, p=0.02 CG: 74.2 | Sunburn is included in sun protective behavior score, NR separately | NR | | | | Use of sunscreen is included in sun protective behavior score, NR separately | NR | Sun protection behavior score (8-item, range 0–8 with higher scores indicating safer behavior) @ 6mo Mean score (SD), pre-, post- (complete case analysis), post- (missing values imputed) IG: 4.60 (1.82); 5.70 (1.51); 5.36 (1.72) CG: 4.66 (1.55), 5.30 (1.57); 5.06 (1.59) Mean difference between IG and CG [95%CI] Complete case analysis: 0.33 [0.09, 0.57], p=0.007 Missing values at followup replaced by baseline values: 0.30 [0.10, 0.51], p=0.004 | | | | # of participants checking moles | Specific harms not mentioned, no paradoxical behavior change | Melanoma knowledge, perceived risk | No financial incentives
Geller 2006 50 Fair | Study Design Cluster RCT by sibship Location Home-based by phone, but patient recruited through dermatologists at teaching hospitals (Boston University) Boston area, MA Population Adult siblings of melanoma patients | Inclusion At least 18 years old, being contacted by the 'case' relative Exclusion Current or previous diagnosis of melanoma | N Randomized Total: 494 IG: 237 CG: 257 Age % age 18–50 years Total: 58.3 (c) IG: 55.7 CG: 60.6% Male Total: 46.6 IG: 48.1 CG: 45.1 Race % White Total: 100% SES Highest educational level (% with at least some college) Total: 76.7 IG: 75.6 CG: 78.0 Sun sensitivity Skin type (% fair skin) Total: 84.8 IG: 81.3 CG: 88.0 | | Intervention based on Social Cognitive Theory, Theory of Planned Behavior, the Health Belief Model, the Precaution Adoption Model, and the Transtheoretical Model | Intervention IG: Initial motivational and goal-setting phone intervention by health educator, computer generated tailored print materials with 3 phone counseling sessions by health educator timed to follow receipt of mailed materials, and linkages to free screening programs CG: Usual care (receipt of written nontailored study materials after completion of 12-month survey) Format IG: Individual phone counseling with computer support CG: N/A Intensity IG: Four 10–15 minute counseling sessions at 0, 1, 3, and 5 months CG: N/A Delivery IG: Health educator (by phone) and computer system CG: N/A | % followup@ 6mo Total: 81.6 IG: 81.9 CG: 81.3 @ 12mo Total: 63.6 IG: 62.9 CG: 64.2 | NR | % tanned by end of last summer @ 6mo IG: 36.8 CG: 38.0 @ 12mo IG: 25.7 CG: 35.6 Odds ratio, adjusted [95% CI] 0.72 [0.47, 1.09] | | | | % routinely use sunscreen with SPF15+ @ 6mo IG: 66.7 CG: 64.4 @ 12mo G: 67.4 CG: 66.1 Odds ratio, adjusted [95% CI] 0.96 [0.67, 1.38] | NR | NR | | | | Skin self-exam and dermatologic skin exam | Specific harms not mentioned, no paradoxical behavior change | Melanoma knowledge, attitudes (confidence, intentions) | Unclear generalizability of siblings with melanoma to general PC population. Minimal financial incentives
Prochaska 2005 51 Fair | Study Design RCT Location Home-based by phone, but patients recruited through large health insurance organization from 79 nonhospital based primary care practices (family medicine, internal medicine, obstetrics/gynecology) Population Adults | Inclusion Patients of participating primary care practices, persons at risk (defined as being in precontemplation, contemplation, or preparation stage of change) for at least one of the four health risk behaviors targeted for intervention in the study, women over 50 years could be eligible even if they were in action or maintenance stage for mammography screening because of risk of relapse Exclusion NR | N Randomized Total: 5407, subset of 3834 at risk for sun exposure IG: 2667, subset of 1822 CG: 2740, subset of 2012 Mean age (SD) Total: 44.7 (12.7) IG: 45.8 (13.2) CG: 44.2 (12.5) % Male Total: 30.1 IG: 30.1 CG: 30.1 Race % White Total: 96.7 IG: 96.4 CG: 97.3 SES Mean education, years (SD) Total: 14.5 (3.2) IG: 14.5 (3.2) CG: 14.5 (3.2) Sun sensitvity Total: NR % in precontemplation stage of change for sun exposure Total: 32.1 % in contemplation stage of change for sun exposure Total: 23.9 % in preparation stage of change for sun exposure Total: 44.0 | | Expert System Intervention, stage-based tailored communications targeting multiple health behavior changes based on the transtheoretical model | Intervention IG: Phone and written survey assessments with mailed printed tailored feedback using computerized support (3), intervention materials provided for each risk only when subject was identified as at-risk; for reducing sun exposure, focused on limiting sun exposure to 15 min or always using SPF 15 or higher sunscreen CG: Assessment only Format IG: Phone or written assessment followed by tailored feedback generated using expert system computer support CG: N/A Intensity IG: Assessments of unknown duration at 0, 6, 12 and 24 months, 6 and 12 month assessments were mailed (nonresponders, ~70% were surveyed by phone), 3 to 5 page mailed feedback reports divided into 5 sections CG: Only had assessments at 0, 12 and 24 months Delivery IG: Assesors (by phone), and computer system CG: N/A | % followup @12mo IG: 75 CG: 82 @ 24mo IG: 71 CG: 78 | NR | Sun avoidance subscale of Sun Protection Behavior Scale (subset of n=3834) Mean raw score (SD) @ baseline, 12, 24 mo IG: 12.7 (3.6), 13.5 (3.5), 13.7 (3.5) CG: 12.4 (3.7), 12.9 (3.6), 12.9 (3.6) p<0.005 | | | | Sunscreen use subscale of Sun Protection Behavior Scale (subset of n=3834) Mean raw score (SD) @ baseline, 12, 24 mo IG: 8.6 (3.9), 9.8 (3.8), 10.0 (3.9) CG: 8.5 (3.9), 8.9 (3.9), 9.2 (3.9) p<0.0001 | NR | NR | | | | Movement to the action and maintenance stage of change | Specific harms not mentioned, no paradoxical behavior change | NR | Expert system NOT widely available. There appears to be a larger study context ongoing with practice level intervention
Prochaska 2004 52 Fair | Study Design RCT Location Home-based by phone, but participants recruited through schools (parents of 9th graders) Population Parents of teenagers | Inclusion Parents (of 9th graders) at risk (defined as being in precontemplation, contemplation, or preparation stage of change) for at least one of the three health risk behaviors targeted for intervention in the study Exclusion NR | N Randomized Total: 2460, subset of 1802 at risk for sun exposure IG: 1209, subset of 863 CG: 1251, subset of 939 Mean age (SD) Total: 42.5 (5.5) IG: 42.7 (5.7) CG: 42.4 (5.4) % Male Total: 25 IG: 24 CG: 25 Race % White Total: 92 IG: 93 CG: 91 SES Mean education, years (SD) Total: 14 (3.2) IG: 14 (3.1) CG: 14 (3.2) Sun sensitvity Total: NR % in precontemplation stage of change for sun exposure Total: 36 % in contemplation stage of change for sun exposure Total: 20 % in preparation stage of change for sun exposure Total: 44 | | Expert System Intervention, stagebased tailored communications targeting multiple health behavior changes based on the transtheoretical model | Intervention IG: Phone and written survey assessments with subsequent mailed printed tailored feedback using computerized support (3), intervention materials were provided for each risk only when the subject was identified as at-risk; for reducing sun exposure, focused on limiting sun exposure to 15 minutes or always using SPF 15 or higher sunscreen CG: Assessment only Format IG: Phone or written assessment followed by tailored feedback generated using expert system computer support CG: N/A Intensity IG: Assessments of unknown duration at 0, 6, 12 and 24 months, 6 and 12 month assessments were mailed (non-responders were surveyed by phone), 3 to 5 page mailed feedback reports divided into 5 sections CG: Only had assessments at 0, 12 and 24 months Delivery IG: Assesors (by phone), and computer system CG: N/A Other components (multimodal) See computerized support as described above | % followup @ 12mo IG: 71 CG: 78 @ 24mo IG: 67 CG: 74 | NR | Sun avoidance subscale of Sun Protection Behavior Scale (subset of n=1784) Mean raw score (SD) @ baseline, 12, 24 mo IG: 12.65 (3.86), 13.71 (3.52), 13.99 (3.39) CG: 12.60 (3.90), 13.22 (3.64), 13.35 (3.73) p for interaction term, p>0.05 | | | | Sunscreen use subscale of Sun Protection Behavior Scale (subset of n=1781) Mean raw score (SD) @ baseline, 12, 24 mo IG: 8.32 (4.00), 9.96 (3.87), 10.21 (3.94) CG: 8.16 (3.99), 9.29 (3.98), 9.18 (3.82) p for interaction term, p<0.05 | NR | NR | | | | Movement to the action and maintenance stage of change | Specific harms not mentioned, no paradoxical behavior change | NR | Expert system NOT widely available. These are parents of adolescents involved in another study by Prochaska.
Young adults
Hillhouse 2008 49 Fair | Study Design RCT Location Two universities, US Population Female students (young adults) who reported indoor tanning | Inclusion Female university students who tanned indoors last year or reported an indoor tanning score of 5+ (7-point scale that measured intentions to tan in the next year) on an email screening survey Exclusion NR | N randomized (analyzed) Total: 430 (412) IG: 200 (195) CG: 230 (217) Mean age (SD) Total: NR IG: 18.6 (0.74) CG: 18.7 (0.82) % Male Total: 0 Race % White: NR SES Family SES (% below average) Total: NR IG: 11.9 (c) CG: 11.1 (c) Sun sensitivity % Fitzpatrick skin type I or II Total: NR IG: 34.6 (c) CG: 27.6 (c) | | Appearance-focused interventions based on decision-theoretical models of health behaviors and the Jaccard behavioral alternative model to reduce indoor tanning behavior. | Intervention IG: Professionally produced booklet with 5 sections: history of tanning and context for tanning norms, analysis of tanning norms and media/peer image norms, effects of UV radiation on skin, effects of indoor tanning, and indoor tanning guidelines emphasizing tanning abstinence as well as harm reduction CG: Assessment only, details NR Format IG: Self-directed booklet CG: N/A Intensity IG: N/A CG: N/A Delivery IG: Self-administered CG: N/A | % followup, @ 6mo IG: 97.5 CG: 94.3 | NR | NR | | | | NR | Means (SE) of indoor tanning in past 3 months , pre-, post- @ 6mo IG: 4.67 (0.60); 6.80 (0.93) CG: 4.48 (0.55), 10.90 (0.93) P<0.001 | NR | | | | NR | Specific harms not mentioned, no paradoxical behavior change | Intention to use indoor tanning, attitudes toward tanning alternatives, and beliefs about tanning and image norms | $20 incentive for completed assessments
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | N Randomized Total: 133 IG (UV photo plus video): 30 IG (UV photo only): 35 IG (video only): 34 CG (no photo or video): 34 Mean Age (SD) Total: 20.13 (3.38) Range (18–44 yrs) % Male: 19.5 Race % White Total: 45% Family history of skin cancer Total: 27.1% Sun sensitivity NR | | Appearance-focused intervention, theory not specified | Intervention [underlined: IG (video)]: 11-min videotape slide show depicting photo-aging, how UV exposure leads to photoaging, and effective practices for minimizing photoaging (protective clothing, minimum SPF 15 sunscreen) [underlined: IG (UV photo)]: UV facial photographs using instant camera modified to include a 315- to 390- mmUV filter and naturallight instant photo Format IG: Individual or in pairs (with partition) CG: Assessment only Intensity IG (video): One session, 11-min videotape slide show IG (UV photo): One session, details NR CG: Details NR Delivery IG/CG: Details NR | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Results presented for photoaging video groups (n=38) vs. no video groups (n=46) and UV photo (n=42) vs. no photo (n=42) at 12 months [underlined: Skin color using skin reflectance spectrophotometry] (b* higher is more tan; L* higher is lighter, , exact numbers NR) | | | | NR | NR | Sun protection behavior score z-scores adjusted for baseline (SE) | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR | Participants received course credit. Analyses not presented with true control, authors state “none of the primary analyses indicated any significant interactions between the two interventions.” Use of Cohen d statistic to help interpret effect size.
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Video | No video | p-value | | NR | NR | | Video | no video | p-value | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Higher exposure site, b* scale | | | | NR | NR | Index | −0.02 (0.10) | −0.07 (0.09) | NS | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | 0.82 (0.28) | 0.90 (0.25) | NS | | NR | NR | | Photo | no photo | p-value | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Lower exposure site, b* scale | | | | NR | NR | Index | −0.05 (0.09) | 0.03 (0.09) | NS | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | 0.32 (0.28) | 0.39 (0.25) | NS | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Higher exposure site, L* scale | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | ~ 1.6 (NR) | ~ −0.6 (NR) | sig | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Lower exposure site, L* scale | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | ~ 2.3 (NR) | ~ 0.9 (NR) | sig | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Photo | No photo | p-value | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Higher exposure site, b* scale | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | 1.03 (0.26) | 0.69 (0.26) | NS | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Lower exposure site, b* scale | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | 0.51 (0.26) | 0.21 (0.26) | NS | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Higher exposure site, L* scale | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | ~ 0.9 (NR) | ~ 0.2 (NR) | NS | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Lower exposure site, L* scale | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | ~ 2.1 (NR) | ~ 1.1 (NR) | NS | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | [underlined: Sun exposure z-scores adjusted for baseline (SE)] | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Video | No video | p-value | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Intentional exposure | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | −0.12 (0.16) | 0.10 (0.14) | NS | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Incidental exposure | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | −0.23 (0.16) | 0.28 (0.15) | sig | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Photo | No photo | p-value | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Intentional exposure | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | 0.21 (0.15) | −0.24 (0.15) | NS | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | Incidental exposure | | | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Mahler 2007 53 Fair | Study Design RCT Location University, US Population Undergraduate students | Inclusion At least 18 years old, participants signed up through the Psychology Department participant pool Exclusion Graduating seniors | | | Appearance-focused intervention, theory not specified | | % followup @ ~5 mo 85% @ 12mo 80% for self-reported behaviors but only 70% for spectro-photometry readings 63% had both follow-ups Follow-up by group(s) NR | NR | 0.15 (0.15) | −0.11 (0.15) | NS | | NR | NR | | | | | Cognitive mediators | Specific harms not mentioned, no paradoxical behavior change | NR
Adolescents
Norman 2007 54 Fair | Study Design RCT Location 6 primary care clinics and patient homes, San Diego, CA Population Adolescents aged 11–15 | Inclusion Age 11–15 years attending primary care, parental consent Exclusion Health conditions that would limit participation with physical activity or diet recommendations | N Randomized Total: 819 IG: 395 CG: 424 Mean Age (SD) Total: 12.7 (1.3) IG: 12.7 (1.4) CG: 12.7 (1.3) % Male Total: 46.5 IG: 45.3 CG: 47.6 Race % White Total: 58.4 IG: 62.3 CG: 54.7 SES Highest household educational level (% with graduate/professional degree) Total: 36.7 IG: 40.0 CG: 33.7 Sun sensitvity (% with high sensitivity) Total: 25.2 IG: 26.8 CG: 23.6 | | Sun Smart expert system based on the Social Cognitive Theory and the Transtheoretical Model and included assessment and feedback of the stage of change, decisional balance, self-efficacy, and the processes of change | Intervention IG: Brief counseling by primary care providers, interactive computer sessions, phone assessments, printed tailored feedback, a brief printed manual, mailed tip sheets, and samples of SPF 15 sunscreen CG: Physical activity and diet intervention (physical activity, sedentary behavior, total intake of fat, and servings per day of fruits and vegetables) with computerized expert system kiosk in primary care provider's office, monthly phone calls, a printed manual, and mail contact Format IG: Individual counseling coupled with expert system computer support CG: Expert system computer support Intensity IG: 2 to 3 minute counseling session, initial 20 minute Sun Smart assessment with 2 page feedback report, and subsequent 3-, 6-, 15-, and 18-month phone followup CG: No counseling session, otherwise matched intensity Delivery IG: Primary care provider (in person), health counselors (by phone), and computer system CG: Health counselors (by phone), and computer system | % follow-up @ 6mo IG: 93.9 CG: 86.1 @ 12mo IG: 75.2 CG: 83.3 @ 24mo IG: 79.7 CG: 80.4 | NR | Sun Protection Behavior Scale @ 6, 12, and 24 mo adjusted sample means: IG with statistically significant increase in sun protection scores compared with CG, with trajectory of scores flattening (but still statistically significant) between 12 and 24 months Sun protection behaviors @ 24 mo % response "often" or "always" Wear a shirt? IG: ~84, NS CG: ~85 Stay in shade? IG: ~44, NS CG: ~45 Avoid sun exposure midday? IG: ~40, CI do not overlap CG: ~30 Limit sun exposure midday? IG: ~38, CI do not overlap CG: ~31 | | | | Sun protection behaviors @ 24 mo % response "often" or "always" Use sunscreen? IG: ~55, NS CG: ~48 Use sunscreen on face? IG: ~62, CI do not overlap CG: ~48 Use sunscreen on all sun exposed areas? IG: ~56, CI do not overlap CG: ~40 | NR | NR | | | | Movement to the action and maintenance stage of change | Specific harms not mentioned, no paradoxical behavior change | NR | Expert system NOT widely available. Financial incentive for completed assessments.
Patrick 2006 55 Rosenberg 2007 56 | For the purposes of analyzing harms this study is a prospective cohort (one arm of a RCT) | see Norman 2007 | see Norman 2007 | | see Norman 2007 | see Norman 2007 | see Norman 2007 | see Norman 2007 | see Norman 2007 | | | | see Norman 2007 | see Norman 2007 | see Norman 2007 | | | | see Norman 2007 | 12 mo followup Sedentary behaviors, mean hours/day (SD) girls, pre, post, % change IG (skin cancer): 4.2 (3.4), 4.4 (3.7), 4.8% CG (physical activity): 4.3 (3.4), 3.4 (2.6), −21% boys, pre, post, % change IG (skin cancer): 4.2 (2.8), 4.3 (3.5), 2.4% CG (physical activity): 4.2 (3.7), 3.2 (2.6), −24% 7 Day Physical Activity Recall (moderate and vigorous activity), mean minutes/week (SD) girls, pre, post, % change IG (skin cancer): 284.3 (45.8), 313.9 (62.2), 10.4% CG (physical activity): 316.1 (49.2), 324.6 (61.5), 2.7% boys, pre, post, % change IG (skin cancer): 374.0 (55.0), 419.8 (79.2), 12.2% CG (physical activity): 418.4 (54.5), 486.0 (75.3), 16.2% Active, mean days/week (SD) girls, pre, post, % change IG (skin cancer): 3.1 (2.0), 3.3 (2.1), 0.06% CG (physical activity): 3.3 (2.1), 3.4 (2.1), 0.03% boys, pre, post, % change IG (skin cancer): 3.8 (2.1), 3.8 (2.1), 0% CG (physical activity): 4.1 (2.0), 4.4 (2.1), 7.3% | see Norman 2007 | Article is same study reported in Norman 2007, but using skin cancer counseling intervention as the control. It is included because it reports on physical activity related outcomes, which were considered as potential harms. Reports outcomes by sex. Rosenberg 2007 reports on the covariation among changes in dietary, physical activity, and sedentary behaviors and showed that there was little covariation within or between diet, physical activity, and sedentary behavior domains.
Children and parents
Crane 2006 45 Fair | Study Design Cluster RCT (by office) Location 14 primary care offices of a large managed care organization, Denver/Boulder, CO Population Parents and their infants | Inclusion Parents of children born April to September 1998, parents whose children had dark skin, eye, and hair color were informed that the program may be of minimal benefit to their child Exclusion NR | N, parents and their infants Total: 728 (c) IG: 363 CG: 365 Age, of parents (c) % age 20–29 years Total: 29.7 IG: 28.4 CG: 31.0 % age 30–39 years Total: 58.9 IG: 59.2 CG: 58.6 % Male, of infants, (<2% male of parents) Total: 50.3 (c) IG: 52.1 CG: 48.5 Race, of infants (180 missing), of parents % White Total: 81.9, 76.1 (c) IG: 79.8, 76.0 CG: 84.1, 76.2 SES Parent's highest educational level (% with graduate/professional degree) (c) Total: 42.4 IG: 43.8 CG: 41.1 Sun sensitivity % with fair to medium white skin, of infants, of parents (c) Total: 78.3, 75.5 IG: 76.9, 77.1 CG: 79.7, 74.0 % with painful burn, no to light tan a week later, of parents (c) Total: 39.8 IG: 40.2 CG: 39.5 | | Sun protection promotion (Kaiser Kids Sun Care Program) based on informational, expert, and legitimate power of health care providers and the Health Belief Model, designed to be delivered at well-child visits between 2 and 36 months | Intervention IG: Assessment and counseling by primary care providers using anticipatory guidance messages (provider orientations, boosters at luncheon meetings) + packets of information for parents including tote bag, sun hat, Skin Cancer Foundation brochures, magnet, age specific tip sheets, sunscreen samples (SPF 30), and UV protective sunglasses CG: usual care, anticipatory guidance at 6 month visit included prompt to discuss sunscreen use, offices were not given provider orientations and boosters Format IG: Counseling, packets of information, and samples for parents CG: Usual care Intensity IG: 4 well-child visits (@2, 6, 18, 36 mo) with counseling at discretion of provider, packets of information and samples CG: Usual care at well-child visits Delivery IG: Primary care provider (pediatrician or family physician) CG: Primary care provider (pediatrician or family physician) | % followup @ 12mo Total: 86.0 @ 24mo Total: 81.7 @ 36mo Total: 75.3 Completed all 3 follow-ups Total: 64.4 Skin exam @ 36mo Total: 38.5 | Tanning (mean difference in b color space between exposed and non-exposed skin) IG: 4.2, p=0.14 CG: 4.6 % with freckling IG: 12.8, p=0.20 CG: 17.1 # of nevi IG: 6.30, p=0.56 CG: 5.64 | % response "frequently" or "always" @ 12, 24 and 36 mo clothing use? IG: 51.0, 38.4, 24.2, p=0.22 CG: 43.8, 32.4, 25.5 Midday sun avoidance? IG: 70.6, 63.2, 64.2, p=0.14 CG: 64.9, 62.0, 59.0 Limit time in sun? IG: 48.9, 38.1, 32.1, p=0.97 CG: 47.5, 35.4, 34.3 Shade use? IG: 90.0, 79.2, 72.6, p=0.03 CG: 87.3, 71.9, 65.2 Hat use? IG: 61.9, 61.9, 57.3, p=0.08 CG: 60.8, 56.1, 47.4 Sunglasses use? IG: 5.2, 24.2, 39.4, p=0.22 CG: 8.3, 22.3, 29.9 | | | | % response “frequently" or "always" @ 12, 24 and 36 mo sunscreen use? IG: 90.0, 92.4, 94.2, p=0.46 CG: 87.9, 92.2, 93.1 | NR | Sun protection practice score @ 12mo IG: 18.55, NS CG: 18.40 @ 24mo IG: 18.52, p=0.04 CG: 18.05 @ 36mo IG: 18.18, p=0.05 CG: 17.71 p=0.04 for overall trend | | | | Provider delivery of sun protection advice | Specific harms not mentioned, no paradoxical behavior change | NR | No financial incentives
Multicomponent interventions
Olson 2007 48 | Study Design Cluster RCT (by school) Location 10 geographically- distinct towns in New Hampshire and Vermont Population Children entering grades 6 to 8 at beaches or swimming pools | Inclusion Towns: separated by at least 20 miles, had not participated in earlier SunSafe project, middle school with grades 6–8 within 1 building, at least 1 primary care practice, freshwater beach or town swimming pool used primarily by local residents Evaluation subjects: children entering grades 6–8 who were at community beaches and swimming pools or attending a school-sponsored function with water activities between 11 am and 3 pm from June to August 2000 Exclusion NR | Baseline N, adolescents Total: 797 (c) IG: 357 (c) CG: 440 (c) Age % in 6th, 7th, and 8th grade Total: 98, 1, 1 IG: 97, 2, 1 CG: 98, 1, 1 % Male Total: 43 (c) IG: 44 CG: 42 Race % White: 94% of all middle school students SES NR Sun sensitivity % usually or always burn Total: 28 (c) IG: 28 (c) CG: 28 (c) | Follow up: 1 yr, 2 yr N, adolescents Total: 637, 493 (c) IG: 404, 352 (c) CG: 233, 141 (c) Age % in 6th, 7th, and 8th grade Total: 1 yr: 0, 90, 10 (c) 2 yr: 0, 0, 100 (c) IG: 1 yr: 0, 89, 11 2 yr: 0, 0, 100 CG: 1 yr: 0, 93, 7 2 yr: 0, 0, 100 % Male Total: 46, 45 (c) IG: 48, 44 CG: 43, 50 Race % White: 94% of all middle school students SES NR Sun sensitivity % usually or always burn Total: 33, 27 (c) IG: 32, 25 (c) CG: 36, 31 (c) | SunSafe multicomponent intervention aimed to; 1. educate and activate adults and peers to role model and actively promote sun-protection practices and; 2. create a pro-sun protection community environmentTargeted school personnel, athletic coaches, lifeguards, and clinicians through schools, athletic and recreational facilities, primary care practices, and other community venues; Program materials and training for adult role models emphasized protecting themselves and being an effective role model and educator for teens; teen materials emphasized being protected while having outdoor fun; community environmental cues used to increase awareness of sun protection Socioecologic approach of intervention based on social cognitive theory and education sessions for students and adult role models based on protection motivation theory | Intervention IG: [underlined: Primary care practices:] clinician training focused on incorporating sun-protection messages into well visits, patient-education materials, posters, temporary tattoos; [underlined: Schools:] curricular activies including EPA’s SunWise curricular materials, interactive slide show about UV radiation, skin cancer, and sun-protection strategies, Dermascan viewing, peer-education activities led by 8th- to 12th-grade students; [underlined: Athletic and recreational facilities:] sun protection promotion including pool announcements, sun-protection breaks, team hat/sunscreen policy; [underlined: Community venues:] SunSafe bookmarks at libraries, sun protection posters in local stores CG: no intervention Format IG: Individual counseling during well visits (primary care practices), classroom curriculum and group activities (schools), announcements and team policies (athletic and recreational facilities), posted information (community venues) CG: N/A Intensity IG: NR (primary care practices), curriculum intensity NR, 45-minute group activity, at lease 3 activities led by “sun team” (schools), NR (athletic and recreational facilities), N/A (community venues) CG: N/A Delivery IG: Primary care provider (in person), teachers, 8th- to 12-grade students, athletic coaches and lifeguards CG: N/A | N/A: different sample of children at follow-up | NR | Body surface area covered (by direct observation and interview) Adjusted mean percentage (SE) @ baseline and 2 yr follow up IG: 71.8 (1.6), 66.1 (1.5) CG: 73.7 (1.4), 56.8 (2.3) p<0.01 for difference in means at 24 mos Means adjusted for gender, skin reaction to sun, UV level, year of observation, and temperature | | | | Any sunscreen use % @ baseline, 1 yr follow-up, 2 yr follow up IG: 58.0, 47.0, 47.0 CG: 65.8, 59.6, 13.8 p value: <0.05, <0.01, <0.001 | NR | NR | | | | Predictors of sun protection, number of different sources of advice about sun protection reported by adolescents | Specific harms not mentioned, no paradoxical behavior change | NR | All subjects considered baseline in first year, as were subjects entering 6th grade in subsequent years. Subjects entering 7th or 8th grade in the second year were classified as 1 yr follow up, as were subjects entering 7th grade in the third year. Subjects entering 8th grade in the third year were classified as 2 yr follow up.
Multicomponent interventions
Dietrich 1998 47 Dietrich 2000 125 Grant-Petersson 1999 126 Fair | Study Design Cluster RCT (by community) Location 10 geographically- distinct, lower-income towns in New Hampshire Population Children visiting town freshwater beaches and their caregivers | Inclusion Towns: New Hampshire towns with populations of 4,000–15,000 that included at least 500 children ages 2–9 years; at least 20% of households with 1990 incomes below the federal poverty level; at least 1 elementary school, at least 1 nearby primary care practice serving children, and at least 1 nearby Head Start program; and a freshwater beach used primarily by local residents Evaluation Subjects: Children ages 2–9 years visiting town freshwater beaches between 10 am and 3 pm from last week in June to late August 1995 (upper age limit increased to 11 years for follow-up); children living in town or within 8 miles of its border Caregivers: Adults at beach caring for children meeting eligibility criteria Exclusion Towns: Towns that shared any school or recreational areas with towns already selected Evaluation Subjects: Children in water above their knees | N, children Total: 865 (c) IG: 456 CG: 409 Age % age <5 years Total: 38 (c) IG: 39 CG: 36 % age ≥5 years Total: 62 (c) IG: 61 CG: 64 % Male Total: 52 (c) IG: 55 CG: 49 Race % White:NR (implied 99%) SES at least 20% of households with 1990 incomes below federal poverty level Sun sensitivity % burn easily (caregiver report) Total: 54 (c) IG: 54 CG: 54 | N, children Total: 1,065 (c) IG: 561 CG: 504 Age % age <5 years Total: 28 (c) IG: 26 CG: 31 % age ≥5 years Total: 72 (c) IG: 74 CG: 69 % Male Total: 48 (c) IG: 47 CG: 50 Race % White: NR (implied 99%) SES at least 20% of households with 1990 incomes below federal poverty level Sun sensitivity % burn easily (caregiver report) Total: 48 (c) IG: 47 CG: 49 | SunSafe multicomponent intervention directed at children, their families, and other caregivers through schools, day care centers, primary care practices, and beach areas Modeled after “Slip, Slop, Slap” and SunSmart programs: all intervention components promoted the same message: avoid sun 11 am to 3 pm, cover up using hats and protective clothing, use sun block with SPF ≥15, and encourage sun protection among family and friends | Intervention IG: [underlined: Primary care practices:] sun protection manual for providers, educational materials to enhance counseling, SunSafe tattoos and stickers to offer at well-child and illness visits during summer; [underlined: Schools and day care centers:] age- and grade-specific sun protection curriculum and 1 parent outreach program; [underlined: Beach areas:] poster display (daily UV index and sun protection), educational pamphlets, free sunscreen CG: No intervention Format IG: Individual counseling during well-child and illness visits (primary care practices), classroom curriculum (schools and day care centers), posted information and sunscreen (beach areas) CG: N/A Intensity IG: NR (primary care practices), min 2 class periods (schools and day care centers), N/A (beach areas) CG: N/A Delivery IG: Primary care provider (in person), teachers (in classroom), lifeguards (beach areas) CG: N/A | N/A: different sample of children at follow-up | NR | Any protective clothing (by direct observation) Mean proportions @ baseline, 12 mo IG: 0.30, 0.24 CG: 0.26, 0.18 Difference of change (IG-CG): 0.02, p=0.78 Protection by shade (by direct observation) Mean proportions @ baseline, 12 mo IG: 0.14, 0.14 CG: 0.18, 0.24 Difference of change (IG-CG): −0.06, p=0.38 All values corrected by age, sex, ease with which child burns, and weather conditions at time of interviews | | | | Sunscreen used on ≥1 body area Mean proportions @ baseline, 12 mo IG: 0.57, 0.75 CG: 0.65, 0.66 Difference of change (IG-CG): 0.17, p=0.011 All values corrected by age, sex, ease with which child burns, and weather conditions at time of interviews | NR | Protection on ≥1 body area by sunscreen, clothes, and/or shade Mean proportions @ baseline, 12 mo IG: 0.78, 0.87 CG: 0.85, 0.80 Difference of change (IG-CG): 0.13, p=0.029 Protection on all 3 body areas by any means Mean proportions @ baseline, 12 mo IG: 0.53, 0.74 CG: 0.66, 0.72 Difference of change (IG-CG): 0.15, p=0.18 All values corrected by age, sex, ease with which child burns, and weather conditions at time of interviews | | | | Effect of intervention on subsets of children protected by sunscreen on one or more body areas (age, sex, ease with which child burns) | Specific harms not mentioned, no paradoxical behavior change | NR | Unable to comment on intervention effect of primary care component, this is truly a community based intervention Unclear validity of results at 2y, reported in followup articles Dietrich 2000

Abbreviations: CG=control group; (c)=calculated; IG=intervention group; N/A=not applicable; NR=not reported; SES=socioeconomic status; SPF=sun protection factor.

Appendix B Table 2 Studies Excluded From the Review for Key Question 1

Reference | Reason for Exclusion
Benjes LS, Brooks DR, Zhang Z, et al. Changing patterns of sun protection between the first and second summers for very young children. Arch Dermatol. 2004;140:925–930. | Setting
Brandberg Y, Bergenmar M, Michelson H, et al. Six-month follow-up of effects of an information programme for patients with malignant melanoma. Patient Educ Couns. 1996;28:201–208. | Population
Branstrom R, Ullen H, Brandberg Y. A randomised population-based intervention to examine the effects of the ultraviolet index on tanning behaviour. Eur J Cancer. 2003;39:968–974. | Study design
Brodkin RH, Altman EM. Controlling malignant melanoma. A focus on pediatricians. Am J Dis Child. 1993;147:875–881. | Study relevance
Buller DB, Buller MK, Beach B, et al. Sunny days, healthy ways: evaluation of a skin cancer prevention curriculum for elementary school-aged children. J Am Acad Dermatol. 1996;35:911–922. | Setting
Buller DB, Hall JR, Powers PJ, et al. Evaluation of the “Sunny Days, Healthy Ways” sun safety CD-ROM program for children in grades 4 and 5. Cancer Prev Control. 1999;3:188–195. | Setting
Crane LA, Schneider LS, Yohn JJ, et al. “Block the sun, not the fun”: evaluation of a skin cancer prevention program for child care centers. Am J Prev Med. 1999;17: 31–37. | Setting
Dey P, Collins S, Will S, et al. Randomised controlled trial assessing effectiveness of health education leaflets in reducing incidence of sunburn. BMJ. 1995;311:1062–1063. | Setting
Dietrich AJ, Olson AL, Sox CH, et al. Sun protection counseling for children: primary care practice patterns and effect of an intervention on clinicians. Arch Fam Med. 2000;9:155–159. | Study relevance
Geller AC, Cantor M, Miller DR, et al. The Environmental Protection Agency’s National SunWise School Program: sun protection education in US schools (1999–2000). J Am Acad Dermatol. 2002;46:683–689. | Setting
Geller AC, Sayers L, Koh HK, et al. The New Moms Project: educating mothers about sun protection in newborn nurseries. Pediatr Dermatol. 1999;16:198–200. | Setting
Gerbert B, Wolff M, Tschann JM, et al. Activating patients to practice skin cancer prevention: response to mailed materials from physicians versus HMOs. Am J Prev Med. 1997;13:214–220. | No relevant outcomes
Girgis A, Sanson-Fisher RW, Tripodi DA, et al. Evaluation of interventions to improve solar protection in primary schools. Health Educ Q. 1993;20:275–287. | Setting
Glanz K, Chang L, Song V, et al. Skin cancer prevention for children, parents, and caregivers: a field test of Hawaii’s SunSmart program. J Am Acad Dermatol. 1998;38:413–417. | Setting
Harris JM Jr, Salasche SJ, Harris RB. Using the Internet to teach melanoma management guidelines to primary care physicians. J Eval Clin Pract. 1999;5:199–211. | Study relevance
Harris JM, Salasche SJ, Harris RB. Can Internet-based continuing medical education improve physicians’ skin cancer knowledge and skills? J Gen Intern Med. 2001;16:50–56. | Study relevance
Harris RB, Alberts DS. Strategies for skin cancer prevention. Int J Dermatol. 2004;43:243–251. | Study design
Hillhouse JJ, Turrisi R. Examination of the efficacy of an appearance-focused intervention to reduce UV exposure. J Behav Med. 2002;25:395–409. | Study design
Hornung RL, Lennon PA, Garrett JM, et al. Interactive computer technology for skin cancer prevention targeting children. Am J Prev Med. 2000;18:69–76. | Setting
Jackson KM, Aiken LS. Evaluation of a multicomponent appearance-based sun- protective intervention for young women: uncovering the mechanisms of program efficacy. Health Psychol. 2006;25:34–46. | Setting
Johnson EY, Lookingbill DP. Sunscreen use and sun exposure. Trends in a white population. Arch Dermatol. 1984;120:727–731. | Study design
Kiekbusch S, Hannich HJ, Isacsson A, et al. Impact of a cancer education multimedia device on public knowledge, attitudes, and behaviors: a controlled intervention study in Southern Sweden. J Cancer Educ. 2000;15:232–236. | Study design
Lopez-Jornet P, Camacho-Alonso F, Molina MF. Knowledge and attitude towards risk factors in oral cancer held by dental hygienists in the Autonomous Community of Murcia (Spain): a pilot study. Oral Oncol. 2007;43:602–606. | Study relevance
Lowe JB, Balanda KP, Stanton WR, et al. Evaluation of a three-year school-based intervention to increase adolescent sun protection. Health Educ Behav. 1999;26: 396–408. | Setting
Mahler HI, Kulik JA, Harrell J, et al. Effects of UV photographs, photoaging information, and use of sunless tanning lotion on sun protection behaviors. Arch Dermatol. 2005;141:373–380. | Study design
Mayer JA, Eckhardt L, Stepanski BM, et al. Promoting skin cancer prevention counseling by pharmacists. Am J Public Health. 1998;88:1096–1099. | Study design
Mayer JA, Slymen DJ, Eckhardt L, et al. Skin cancer prevention counseling by pharmacists: specific outcomes of an intervention trial. Cancer Detect Prev. 1998;22:367–375. | Study relevance
McCormick LK, Masse LC, Cummings SS, et al. Evaluation of a skin cancer prevention module for nurses: change in knowledge, self-efficacy, and attitudes. Am J Health Promot. 1999;13:282–289. | Study relevance
Mikkilineni R, Weinstock MA, Goldstein MG, et al. The impact of the basic skin cancer triage curriculum on provider’s skin cancer control practices. J Gen Intern Med. 2001;16:302–307. | Study relevance
Miller DR, Geller AC, Wood MC, et al. The Falmouth Safe Skin Project: evaluation of a community program to promote sun protection in youth. Health Educ Behav. 1999;26:369–384. | Setting
O’Keefe DJ, Jensen JD. The relative persuasiveness of gain-framed and loss- framed messages for encouraging disease prevention behaviors: a meta-analytic review. J Health Commun. 2007;12:623–644. | Study relevance
Patrick K, Calfas KJ, Norman GJ, et al. Randomized controlled trial of a primary care and home-based intervention for physical activity and nutrition behaviors: PACE+ for adolescents. Arch Ped Adolesc Med. 2006;160:128–136. | No relevant outcomes
Richard MA, Martin S, Gouvernet J, et al. Humour and alarmism in melanoma prevention: a randomized controlled study of three types of information leaflet. Br J Dermatol. 1999;140:909–914. | No relevant outcomes
Robinson JK, Rademaker AW. Skin cancer risk and sun protection learning by helpers of patients with nonmelanoma skin cancer. Prev Med. 1995;24:333–341. | Study design
Robinson JK. Behavior modification obtained by sun protection education coupled with removal of a skin cancer. Arch Dermatol. 1990;126:477–481. | Population
Robinson JK. Compensation strategies in sun protection behaviors by a population with nonmelanoma skin cancer. Prev Med. 1992;21:754–765. | Population
Rosenberg DE, Norman GJ, Sallis JF, et al. Covariation of adolescent physical activity and dietary behaviors over 12 months. J Adolesc Health. 2007;41:472–478. | No relevant outcomes
Stanton WR, Janda M, Baade PD, et al. Primary prevention of skin cancer: a review of sun protection in Australia and internationally. Health Promot Int. 2004;19:369–378. | Study relevance
Turrisi R, Hillhouse J, Heavin S, et al. Examination of the short-term efficacy of a parent-based intervention to prevent skin cancer. J Behav Med. 2004;27:393–412. | Study design
Turrisi R, Hillhouse J, Robinson J, et al. Influence of parent and child characteristics on a parent-based intervention to reduce unsafe sun practices in children 9 to 12 years old. Arch Dermatol. 2006;142:1009–1014. | Study design

Appendix B Table 3 Studies Excluded From the Review for Key Question 2

Reference | Reason for Exclusion
Benjes LS, Brooks DR, Zhang Z, et al. Changing patterns of sun protection between the first and second summers for very young children. Arch Dermatol. 2004;140:925–930. | Setting
Brandberg Y, Bergenmar M, Michelson H, et al. Six-month follow-up of effects of an information programme for patients with malignant melanoma. Patient Educ Couns. 1996;28:201–208. | Population
Branstrom R, Ullen H, Brandberg Y. A randomised population-based intervention to examine the effects of the ultraviolet index on tanning behaviour. Eur J Cancer. 2003;39:968–974. | Study design
Brodkin RH, Altman EM. Controlling malignant melanoma. A focus on pediatricians. Am J Dis Child. 1993;147:875–881. | Study relevance
Buller DB, Buller MK, Beach B, et al. “Sunny days, healthy ways”: evaluation of a skin cancer prevention curriculum for elementary school-aged children. J Am Acad Dermatol. 1996;35:911–922. | Setting
Buller DB, Hall JR, Powers PJ, et al. Evaluation of the “Sunny Days, Healthy Ways” sun safety CD-ROM program for children in grades 4 and 5. Cancer Prev Control. 1999;3:188–195. | Setting
Crane LA, Schneider LS, Yohn JJ, et al. “Block the sun, not the fun”: evaluation of a skin cancer prevention program for child care centers. Am J Prev Med. 1999;17:31–37. | Setting
Dey P, Collins S, Will S, et al. Randomised controlled trial assessing effectiveness of health education leaflets in reducing incidence of sunburn. BMJ. 1995;311:1062–1063. | Setting
Dietrich AJ, Olson AL, Sox CH, et al. Sun protection counseling for children: primary care practice patterns and effect of an intervention on clinicians. Arch Fam Med. 2000;9:155–159. | Study relevance
Emmons KM, Geller AC, Viswanath V, et al. The SunWise Policy intervention for school-based sun protection: a pilot study. J Sch Nurs. 2008;24(4):215–221. | No relevant outcomes
Falk M, Anderson C. Prevention of skin cancer in primary healthcare: an evaluation of three different prevention effort levels and the applicability of a phototest. Eur J Gen Pract 2008;14(2):68–75. | Quality
Geller AC, Cantor M, Miller DR, et al. The Environmental Protection Agency’s National SunWise School Program: sun protection education in US schools (1999–2000). J Am Acad Dermatol. 2002;46:683–689. | Setting
Geller AC, Sayers L, Koh HK, et al. The New Moms Project: educating mothers about sun protection in newborn nurseries. Pediatr Dermatol. 1999;16:198–200. | Setting
Gerbert B, Wolff M, Tschann JM, et al. Activating patients to practice skin cancer prevention: response to mailed materials from physicians versus HMOs. Am J Prev Med. 1997;13:214–220. | No relevant outcomes
Girgis A, Sanson-Fisher RW, Tripodi DA, et al. Evaluation of interventions to improve solar protection in primary schools. Health Educ Q. 1993;20:275–287. | Setting
Glanz K, Chang L, Song V, et al. Skin cancer prevention for children, parents, and caregivers: a field test of Hawaii’s SunSmart program. J Am Acad Dermatol. 1998;38:413–417. | Setting
Greene K, Brinn LS. Messages influencing college women’s tanning bed use: statistical versus narrative evidence format and a self-assessment to increase perceived susceptibility. J Health Commun. 2003;8:443–461. | Study design
Harris JM Jr, Salasche SJ, Harris RB. Using the Internet to teach melanoma management guidelines to primary care physicians. J Eval Clin Pract. 1999;5:199–211. | Study relevance
Harris JM, Salasche SJ, Harris RB. Can Internet-based continuing medical education improve physicians’ skin cancer knowledge and skills? J Gen Intern Med. 2001;16:50–56. | Study relevance
Harris RB, Alberts DS. Strategies for skin cancer prevention. Int J Dermatol. 2004;43:243–251. | Study design
Hart KM, Demarco RF. Primary prevention of skin cancer in children and adolescents: a review of the literature. J Pediatr Oncol Nurs. 2008;25:67–78. | Study design
Hillhouse JJ, Turrisi R. Examination of the efficacy of an appearance-focused intervention to reduce UV exposure. J Behav Med. 2002;25:395–409. | Study design
Hornung RL, Lennon PA, Garrett JM, et al. Interactive computer technology for skin cancer prevention targeting children. Am J Prev Med. 2000;18:69–76. | Setting
Jackson KM, Aiken LS. Evaluation of a multicomponent appearance-based sun- protective intervention for young women: uncovering the mechanisms of program efficacy. Health Psychol. 2006;25:34–46. | Setting
Johnson EY, Lookingbill DP. Sunscreen use and sun exposure. Trends in a white population. Arch Dermatol. 1984;120:727–731. | Study design
Kiekbusch S, Hannich HJ, Isacsson A, et al. Impact of a cancer education multimedia device on public knowledge, attitudes, and behaviors: a controlled intervention study in Southern Sweden. J Cancer Educ. 2000;15:232–236. | Study design
Lopez ML, Iglesias JM, del Valle MO, et al. Impact of a primary care intervention on smoking, drinking, diet, weight, sun exposure, and work risk in families with cancer experience. Cancer Causes Control. 2007;18:525–535. | Quality
Lopez-Jornet P, Camacho-Alonso F, Molina MF. Knowledge and attitude towards risk factors in oral cancer held by dental hygienists in the Autonomous Community of Murcia (Spain): a pilot study. Oral Oncol. 2007;43:602–606. | Study relevance
Lowe JB, Balanda KP, Stanton WR, et al. Evaluation of a three-year school-based intervention to increase adolescent sun protection. Health Educ Behav. 1999;26:396–408. | Setting
Mahler HI, Kulik JA, Harrell J, et al. Effects of UV photographs, photoaging information, and use of sunless tanning lotion on sun protection behaviors. Arch Dermatol. 2005;141:373–380. | Study design
Mahler HI, Kulik JA, Butler HA, Gerrard M, Gibbons FX. Social norms information enhances the efficacy of an appearance-based sun protection intervention. Soc Sci Med 2008;67(2):321–329. | Study design
Mayer JA, Eckhardt L, Stepanski BM, et al. Promoting skin cancer prevention counseling by pharmacists. Am J Public Health. 1998;88:1096–1099. | Study design
Mayer JA, Slymen DJ, Eckhardt L, et al. Skin cancer prevention counseling by pharmacists: specific outcomes of an intervention trial. Cancer Detect Prev. 1998;22:367–375. | Study relevance
McCormick LK, Masse LC, Cummings SS, et al. Evaluation of a skin cancer prevention module for nurses: change in knowledge, self-efficacy, and attitudes. Am J Health Promot. 1999;13:282–289. | Study relevance
Mikkilineni R, Weinstock MA, Goldstein MG, et al. The impact of the basic skin cancer triage curriculum on provider’s skin cancer control practices. J Gen Intern Med. 2001;16:302–307. | Study relevance
Miller DR, Geller AC, Wood MC, et al. The Falmouth Safe Skin Project: evaluation of a community program to promote sun protection in youth. Health Educ Behav. 1999;26:369–384. | Setting
Patrick K, Calfas KJ, Norman GJ, et al. Randomized controlled trial of a primary care and home-based intervention for physical activity and nutrition behaviors: PACE+ for adolescents. Arch Ped Adolesc Med. 2006;160:128–136. | No relevant outcomes
Richard MA, Martin S, Gouvernet J, et al. Humour and alarmism in melanoma prevention: a randomized controlled study of three types of information leaflet. Br J Dermatol. 1999;140:909–914. | No relevant outcomes
Robinson JK, Rademaker AW. Skin cancer risk and sun protection learning by helpers of patients with nonmelanoma skin cancer. Prev Med. 1995;24:333–341. | Study design
Robinson JK. Behavior modification obtained by sun protection education coupled with removal of a skin cancer. Arch Dermatol. 1990;126:477–481. | Population
Robinson JK. Compensation strategies in sun protection behaviors by a population with nonmelanoma skin cancer. Prev Med. 1992;21:754–765. | Population
Rosenberg DE, Norman GJ, Sallis JF, et al. Covariation of adolescent physical activity and dietary behaviors over 12 months. J Adolesc Health. 2007;41:472–478. | No relevant outcomes
Saraiya M, Glanz K, Briss PA, et al. Interventions to prevent skin cancer by reducing exposure to ultraviolet radiation: a systematic review. Am J Prev Med. 2004;27:422–466. | Used as source document
Stanton WR, Janda M, Baade PD, et al. Primary prevention of skin cancer: a review of sun protection in Australia and internationally. Health Promot Int. 2004;19:369–378. | Study relevance
Turrisi R, Hillhouse J, Heavin S, et al. Examination of the short-term efficacy of a parent-based intervention to prevent skin cancer. J Behav Med. 2004;27:393–412. | Study design
Turrisi R, Hillhouse J, Robinson J, et al. Influence of parent and child characteristics on a parent-based intervention to reduce unsafe sun practices in children 9 to 12 years old. Arch Dermatol. 2006;142:1009–1014. | Study design
van Osch L, Reubsaet A, Lechner L, de Vries H. The formation of specific action plans can enhance sun protection behavior in motivated parents. Prev.Med. 2008;47(1):127–132. | Quality

Appendix B Table 4 Studies Excluded From the Review for Key Question 3

Reference | Reason for Exclusion
Benjes LS, Brooks DR, Zhang Z, et al. Changing patterns of sun protection between the first and second summers for very young children. Arch Dermatol. 2004;140:925–930. | Setting
Brandberg Y, Bergenmar M, Michelson H, et al. Six-month follow-up of effects of an information programme for patients with malignant melanoma. Patient Educ Couns. 1996;28:201–208. | Population
Branstrom R, Ullen H, Brandberg Y. A randomised population-based intervention to examine the effects of the ultraviolet index on tanning behaviour. Eur J Cancer. 2003;39:968–974. | Study design
Brodkin RH, Altman EM. Controlling malignant melanoma. A focus on pediatricians. Am J Dis Child. 1993;147:875–881. | Study relevance
Buller DB, Buller MK, Beach B, et al. “Sunny days, healthy ways”: evaluation of a skin cancer prevention curriculum for elementary school-aged children. J Am Acad Dermatol. 1996;35:911–922. | Setting
Buller DB, Hall JR, Powers PJ, et al. Evaluation of the “Sunny Days, Healthy Ways” sun safety CD-ROM program for children in grades 4 and 5. Cancer Prev Control. 1999;3:188–195. | Setting
Crane LA, Schneider LS, Yohn JJ, et al. “Block the sun, not the fun”: evaluation of a skin cancer prevention program for child care centers. Am J Prev Med. 1999;17:31–37. | Setting
Dey P, Collins S, Will S, et al. Randomised controlled trial assessing effectiveness of health education leaflets in reducing incidence of sunburn. BMJ. 1995;311:1062–1063. | Setting
Dietrich AJ, Olson AL, Sox CH, et al. Sun protection counseling for children: primary care practice patterns and effect of an intervention on clinicians. Arch Fam Med. 2000;9:155–159. | Study relevance
Geller AC, Sayers L, Koh HK, et al. The New Moms Project: educating mothers about sun protection in newborn nurseries. Pediatr Dermatol. 1999;16:198–200. | Setting
Gerbert B, Wolff M, Tschann JM, et al. Activating patients to practice skin cancer prevention: response to mailed materials from physicians versus HMOs. Am J Prev Med. 1997;13:214–220. | No relevant outcomes
Girgis A, Sanson-Fisher RW, Tripodi DA, et al. Evaluation of interventions to improve solar protection in primary schools. Health Educ Q. 1993;20:275–287. | Setting
Glanz K, Chang L, Song V, et al. Skin cancer prevention for children, parents, and caregivers: a field test of Hawaii’s SunSmart program. J Am Acad Dermatol. 1998;38:413–417. | Setting
Harris JM Jr, Salasche SJ, Harris RB. Using the Internet to teach melanoma management guidelines to primary care physicians. J Eval Clin Pract. 1999;5:199–211. | Study relevance
Harris JM, Salasche SJ, Harris RB. Can Internet-based continuing medical education improve physicians’ skin cancer knowledge and skills? J Gen Intern Med. 2001;16:50–56. | Study relevance
Harris RB, Alberts DS. Strategies for skin cancer prevention. Int J Dermatol. 2004;43:243–251. | Study design
Hillhouse JJ, Turrisi R. Examination of the efficacy of an appearance-focused intervention to reduce UV exposure. J Behav Med. 2002;25:395–409. | Study design
Hornung RL, Lennon PA, Garrett JM, et al. Interactive computer technology for skin cancer prevention targeting children. Am J Prev Med. 2000;18:69–76. | Setting
Jackson KM, Aiken LS. Evaluation of a multicomponent appearance-based sun- protective intervention for young women: uncovering the mechanisms of program efficacy. Health Psychol. 2006;25:34–46. | Setting
Johnson EY, Lookingbill DP. Sunscreen use and sun exposure. Trends in a white population. Arch Dermatol. 1984;120:727–731. | No relevant outcomes
Kiekbusch S, Hannich HJ, Isacsson A, et al. Impact of a cancer education multimedia device on public knowledge, attitudes, and behaviors: a controlled intervention study in Southern Sweden. J Cancer Educ. 2000;15:232–236. | Study design
Lopez-Jornet P, Camacho-Alonso F, Molina MF. Knowledge and attitude towards risk factors in oral cancer held by dental hygienists in the Autonomous Community of Murcia (Spain): a pilot study. Oral Oncol. 2007;43:602–606. | Study relevance
Lowe JB, Balanda KP, Stanton WR, et al. Evaluation of a three-year school-based intervention to increase adolescent sun protection. Health Educ Behav. 1999;26:396–408. | Setting
Mahler HI, Kulik JA, Harrell J, et al. Effects of UV photographs, photoaging information, and use of sunless tanning lotion on sun protection behaviors. Arch Dermatol. 2005;141:373–380. | Study design
Mayer JA, Eckhardt L, Stepanski BM, et al. Promoting skin cancer prevention counseling by pharmacists. Am J Public Health. 1998;88:1096–1099. | Study design
Mayer JA, Slymen DJ, Eckhardt L, et al. Skin cancer prevention counseling by pharmacists: specific outcomes of an intervention trial. Cancer Detect Prev. 1998;22:367–375. | Study relevance
McCormick LK, Masse LC, Cummings SS, et al. Evaluation of a skin cancer prevention module for nurses: change in knowledge, self-efficacy, and attitudes. Am J Health Promot. 1999;13:282–289. | Study relevance
Mikkilineni R, Weinstock MA, Goldstein MG, et al. The impact of the basic skin cancer triage curriculum on provider's skin cancer control practices. J Gen Intern Med. 2001;16:302–307. | Study relevance
Miller DR, Geller AC, Wood MC, et al. The Falmouth Safe Skin Project: evaluation of a community program to promote sun protection in youth. Health Educ Behav. 1999;26:369–384. | Setting
Richard MA, Martin S, Gouvernet J, et al. Humour and alarmism in melanoma prevention: a randomized controlled study of three types of information leaflet. Br J Dermatol. 1999;140:909–914. | No relevant outcomes
Robinson JK, Rademaker AW. Skin cancer risk and sun protection learning by helpers of patients with nonmelanoma skin cancer. Prev Med. 1995;24:333–341. | Study design
Robinson JK. Behavior modification obtained by sun protection education coupled with removal of a skin cancer. Arch Dermatol. 1990;126:477–481. | Population
Robinson JK. Compensation strategies in sun protection behaviors by a population with nonmelanoma skin cancer. Prev Med. 1992;21:754–765. | Population
Saraiya M, Glanz K, Briss PA, et al. Interventions to prevent skin cancer by reducing exposure to ultraviolet radiation: a systematic review. Am J Prev Med. 2004;27:422–466. | Used as source document
Stanton WR, Janda M, Baade PD, et al. Primary prevention of skin cancer: a review of sun protection in Australia and internationally. Health Promot Int. 2004;19:369–378 | Study relevance
Turrisi R, Hillhouse J, Heavin S, et al. Examination of the short-term efficacy of a parent-based intervention to prevent skin cancer. J Behav Med. 2004;27:393–412. | Study design
Turrisi R, Hillhouse J, Robinson J, et al. Influence of parent and child characteristics on a parent-based intervention to reduce unsafe sun practices in children 9 to 12 years old. Arch Dermatol. 2006;142:1009–1014. | Study design