# Appendix A Study Selection and Data Extraction

Appendix A Figure 1 Search Results and Article Flow

Appendix A Figure 1 is a flow chart that summarizes the search and selection of articles. There were 5,387 citations identified by searching MEDLINE and Cochrane databases (including the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews) and 165 citations were identified from other sources (such as reference lists and suggestions by peer reviewers). Of these, 5,228 citations were excluded after abstract review. The full text of the remaining 324 articles were assessed for eligibility by key question. Of the 40 articles reviewed for key question 1 (counseling and outcomes), no articles were deemed eligible for inclusion. Of the 59 articles reviewed for key question 2 (counseling and behavior), 12 articles (representing 10 studies) were deemed eligible for inclusion. Of the 39 articles reviewed for key question 3 (counseling and adverse effects), 13 articles (representing 9 studies) were deemed eligible for inclusion; including 11 articles that were also included for key question 2. Of the 221 articles reviewed for key question 4 (sun exposure and outcomes), 56 articles (representing 32 studies) were deemed eligible for inclusion. Of the 63 articles reviewed for key question 5 (sun-protective behavior and adverse effects), 18 articles (representing 16 studies) were deemed eligible for inclusion.

Appendix A Table 1 Search Strategies

Key Questions 1 to 3
Database: Ovid MEDLINE(R), Cochrane Central Controlled Trials Registry
Search Period: 1996 to December 2008>
Search Strategy:
1 | Skin Neoplasms/(30148)
2 | Melanoma/(20680)
3 | Hutchinson's Melanotic Freckle/(234)
4 | melanoma$.ti,ab. (27508)
5 | lentigo maligna.ti,ab. (270)
6 | Carcinoma, Basal Cell/(3871)
7 | Carcinoma, Squamous Cell/(32609)
8 | neoplasms, basal cell/(223)
9 | neoplasms, squamous cell/(591)
10 | skin cancer.ti,ab. (4103)
11 | (carcinoma and (skin or cutaneous)).ti,ab. (6804)
12 | Nevus/(1187)
13 | Nevus, Pigmented/(1794)
14 | (nevus or naevus or nevi or naevi).ti,ab. (4385)
15 | Keratosis/(1517)
16 | keratos#s.ti,ab. (1866)
17 | Sunburn/(880)
18 | Sunburn$.ti,ab. (839)
19 | Sunscreening Agents/(1645)
20 | sunscreen$.ti,ab. (1386)
21 | Sunlight/(3594)
22 | Ultraviolet Rays/(18712)
23 | sunlamp$.ti,ab. (67)
24 | tanning.ti,ab. (609)
25 | sunbed$.ti,ab. (97)
26 | photoprotection.ti,ab. (592)
27 | sun protecti$.ti,ab. (751)
28 | sun awareness.ti,ab. (25)
29 | sun safety.ti,ab. (57)
30 | sun exposure.ti,ab. (1438)
31 | or/1–30 (105418)
32 | Health Promotion/(21101)
33 | Health Education/(15625)
34 | Patient Education as Topic/(30487)
35 | Preventive Health Services/(3856)
36 | Consumer Health Information/(66)
37 | Counseling/(9180)
38 | Directive Counseling/(261)
39 | Behavior Therapy/(5865)
40 | Health Behavior/(13466)
41 | Physician's Role/(10481)
42 | Teaching Materials/(2315)
43 | Parents/ed [Education] (2509)
44 | counsel$.ti,ab. (24396)
45 | advice.ti,ab. (12052)
46 | advise.ti,ab. (2322)
47 | behavio$ intervention$.ti,ab. (2012)
48 | prevention intervention$.ti,ab. (1189)
49 | or/32–48 (129549)
50 | 31 and 49 (1282)
51 | limit 50 to (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial) (123)
52 | meta-analysis as topic/(6066)
53 | clinical trials as topic/or controlled clinical trials as topic/or randomized controlled trials as topic/(98957)
54 | (control$ adj3 trial$).ti,ab. (54622)
55 | random$.ti,ab. (269819)
56 | clinical trial$.ti,ab. (80740)
57 | or/52–56 (391015)
58 | 50 and 57 (193)
59 | 51 or 58 (224)
60 | limit 59 to english language (216)
61 | limit 60 to yr=“2001–2008” (146)
Protective Behaviors
Database: Ovid MEDLINE(R), Cochrane Central Controlled Trials Registry
Search Period: 1950 to December 2008
Search Strategy:
1 | sun exposure.ti,ab. (2123)
2 | sun exposed.ti,ab. (1203)
3 | Sunburn/(1851)
4 | sunburn$.ti,ab. (1457)
5 | sunbath$.ti,ab. (270)
6 | Sunlight/(8313)
7 | Ultraviolet Rays/(51710)
8 | Solar radiation.ti,ab. (1192)
9 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 (61284)
10 | Melanoma/(51583)
11 | melanoma$.ti,ab. (56926)
12 | skin neoplasms/(73435)
13 | skin cancer$.ti,ab. (8057)
14 | 10 or 11 or 12 or 13 (121192)
15 | 9 and 14 (6548)
16 | limit 15 to yr=“2001–2008” (2582)
17 | sun exposure.ti,ab. (2123)
18 | sun exposed.ti,ab. (1203)
19 | Sunburn/(1851)
20 | sunburn$.ti,ab. (1457)
21 | sunbath$.ti,ab. (270)
22 | Sunlight/(8313)
23 | Ultraviolet Rays/(51710)
24 | Solar radiation.ti,ab. (1192)
25 | 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (61284)
26 | Neoplasms, Basal Cell/(284)
27 | Carcinoma, Basal Cell/(11126)
28 | basal cell carcinoma.ti,ab. (5179)
29 | Neoplasms, Squamous Cell/(644)
30 | Carcinoma, Squamous Cell/(79676)
31 | squamous cell carcinoma.ti,ab. (33038)
32 | nonmelanom$.ti,ab. (1148)
33 | non melanom$.ti,ab. (901)
34 | 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 (96164)
35 | 25 and 34 (2035)
36 | limit 35 to yr=“1966–2008” (2021)
37 | Neoplasms, Basal Cell/(284)
38 | Carcinoma, Basal Cell/(11126)
39 | basal cell carcinoma.ti,ab. (5179)
40 | Neoplasms, Squamous Cell/(644)
41 | Carcinoma, Squamous Cell/(79676)
42 | squamous cell carcinoma.ti,ab. (33038)
43 | Melanoma/(51583)
44 | melanoma$.ti,ab. (56926)
45 | nonmelanom$.ti,ab. (1148)
46 | non melanom$.ti,ab. (901)
47 | Skin Neoplasms/(73435)
48 | skin cancer.ti,ab. (6709)
49 | 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 (199909)
50 | sunlamp$.ti,ab. (256)
51 | sunbed$.ti,ab. (155)
52 | tanning bed$.ti,ab. (63)
53 | tanning booth$.ti,ab. (17)
54 | tanning salon$.ti,ab. (57)
55 | tanning device$.ti,ab. (32)
56 | artificial light.ti,ab. (425)
57 | artificial UV.ti,ab. (104)
58 | indoor tanning.ti,ab. (67)
59 | 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 (1085)
60 | 49 and 59 (288)
61 | limit 60 to yr=“2005–2008” (64)
62 | Sunscreening Agents/(2763)
63 | sunscreen$.ti,ab. (2199)
64 | 62 or 63 (3384)
65 | Melanoma/(51583)
66 | melanoma$.ti,ab. (56926)
67 | skin neoplasms/(73435)
68 | skin cancer$.ti,ab. (8057)
69 | 65 or 66 or 67 or 68 (121192)
70 | 64 and 69 (1216)
71 | limit 70 to yr=“2002–2008” (499)
72 | Sunscreening Agents/(2763)
73 | sunscreen$.ti,ab. (2199)
74 | 72 or 73 (3384)
75 | Neoplasms, Basal Cell/(284)
76 | Carcinoma, Basal Cell/(11126)
77 | basal cell carcinoma.ti,ab. (5179)
78 | Neoplasms, Squamous Cell/(644)
79 | Carcinoma, Squamous Cell/(79676)
80 | squamous cell carcinoma.ti,ab. (33038)
81 | nonmelanom$.ti,ab. (1148)
82 | non melanom$.ti,ab. (901)
83 | 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 (96164)
84 | 75 and 83 (284)
85 | limit 84 to yr=“1966–2008” (282)
86 | 16 or 36 or 61 or 71 or 85 (4258)
87 | (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. (514646)
88 | Meta-Analysis as Topic/(8243)
89 | clinical trials as topic/or controlled clinical trials as topic/or randomized controlled trials as topic/(193771)
90 | (control$ adj3 trial$).ti,ab. (75931)
91 | random$.ti,ab. (408387)
92 | clinical trial$.ti,ab. (118671)
93 | observational.ti,ab. (29208)
94 | (cohort adj (study or studies)).ti,ab. (35294)
95 | cohort analys$.ti,ab. (1638)
96 | cohort studies/(84711)
97 | retrospective$.ti,ab. (206916)
98 | Retrospective Studies/(297957)
99 | longitudinal$.ti,ab. (86086)
100 | Longitudinal Studies/(51243)
101 | (follow up adj (study or studies)).ti,ab. (27678)
102 | Follow-Up Studies/(367133)
103 | prospective$.ti,ab. (259500)
104 | Prospective Studies/(243484)
105 | database$.ti,ab. (82828)
106 | nonrandomi$.ti,ab. (4953)
107 | population$.ti,ab. (640534)
108 | case control$.ti,ab. (42298)
109 | case-control studies/(97627)
110 | Cross-Sectional Studies/(88036)
111 | cross sectional.ti,ab. (77621)
112 | systematic$ review$.ti,ab. (14698)
113 | systematic$ overview$.ti,ab. (329)
114 | quantitative$ review$.ti,ab. (331)
115 | quantitative$ overview$.ti,ab. (61)
116 | (meta analy$ or metaanaly$).ti,ab. (21215)
117 | evidence based review$.ti,ab. (516)
118 | morbidity/or incidence/or prevalence/or mortality/or “cause of death”/or survival rate/(353096)
119 | (morbidity or incidence or prevalen$ or mortality or survival).ti,ab. (1122388)
120 | (epidemiology or etiology or genetics or mortality or statistics numerical data).fs. (4167223)
121 | (epidemiol$ or etiolog$ or aetiolog$).ti,ab. (322045)
122 | Risk Factors/(350233)
123 | risk factor$.ti,ab. (189335)
124 | Skin/re [Radiation Effects] (7487)
125 | associated.ti,ab. (1365964)
126 | association$.ti,ab. (442678)
127 | or/87–126 (6674934)
128 | 86 and 127 (3591)
129 | limit 128 to english language (3333)
130 | limit 129 to humans (2908)
131 | limit 129 to animals (736)
132 | 131 not 130 (409)
133 | 129 not 132 (2924)
134 | from 133 keep 1–500 (500)
Harms
Database: Ovid MEDLINE(R), Cochrane Central Controlled Trials Registry
Search Period: 1950 to December 2008
Search Strategy:
1 | Sunscreening Agents/(2766)
2 | sunscreen$.ti,ab. (2207)
3 | Protective Clothing/(3781)
4 | protective cloth$.ti,ab. (921)
5 | (((hat or hats) and (wear$ or wore or brim$)) or (use$ adj3 hat) or (use$ adj3 hats)).ti,ab. (306)
6 | TINOSORB FD.ti,ab. (1)
7 | TINOSORB FR.ti,ab. (0)
8 | ((UV absorb$ or photoprotect$ or UV protect$) and (laundry or detergent$)).ti,ab. (32)
9 | sun protect$.ti,ab. (1228)
10 | photoprotect$.ti,ab. (1347)
11 | ((seek$ or sun or sunscreen$) and shade).ti,ab. (305)
12 | ((avoid$ or minimiz$ or minimis$) and (sun exposure or midday sun)).ti,ab. (221)
13 | (avoid$ and (sunlamp$ or sunbed$ or tanning bed$ or tanning booth$ or tanning salon$ or tanning device$ or indoor tanning or artificial light or artificial UV)).ti,ab. (34)
14 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (9269)
15 | adverse effects.fs. (1016592)
16 | harm$.ti,ab. (48820)
17 | adverse$.ti,ab. (170899)
18 | (increas$ and ((time and sun) or sun exposure)).ti,ab. (1144)
19 | ((reduce$ or reduction) and physical activit$).ti,ab. (5670)
20 | sedentary behavio$.ti,ab. (414)
21 | depression/(49597)
22 | Depressive Disorder/(47333)
23 | mood disorders/(7539)
24 | mood.ti,ab. (27405)
25 | vitamin D deficiency/(4637)
26 | (vitamin D adj5 deficien$).ti,ab. (3478)
27 | 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 (1276195)
28 | 14 and 27 (3105)
29 | limit 28 to english language (2770)
30 | limit 29 to humans (2542)
31 | limit 29 to animals (326)
32 | 31 not 30 (139)
33 | 29 not 32 (2631)
34 | limit 33 to yr=“1966–2008” (2627)

Appendix A Table 2 Inclusion and Exclusion Criteria

Definitions of included diseases
[underlined: Include:] skin cancer including: cutaneous melanoma, squamous cell carcinoma of the skin, basal cell carcinoma of the skin
[underlined: Exclude:] acral lentiginous and subungual melanoma, mucosal melanoma, ocular melanoma, and pre-pubertal melanoma (“childhood melanoma”)
Settings
[underlined: Include:]
Key questions 1 to 3: studies performed in primary care (including pediatric, OB/GYN, internal medicine, family practice, military, adolescent, and school-based health clinics) or otherwise generalizable to primary care; studies conducted in English speaking countries, or those otherwise generalizable to the United States
Key questions 4 and 5: any setting
[underlined: Exclude:]
Key questions 1 to 3: settings not generalizable to primary care (e.g., inpatient hospital units, emergency departments, pharmacies, school-based programs, recreational settings, occupational settings, and other community-based settings); trials conducted in developing countries, as defined by the United Nations Human Development Index
Key questions 4 and 5: no a priori exclusion criteria
Populations
[underlined: Include:]
Key questions 1 to 3: populations generalizable to primary care, any age population without current or personal history of malignant or pre-malignant skin lesions; - infants/children and their parent(s) or care giver(s); - children/adolescents; - adults
Key questions 4 and 5: any population, as long as description of population host and environmental risk factors is provided
[underlined: Exclude:]
Key questions 1 to 3: persons with current or past history of malignant or pre-malignant skin lesions (e.g., Bowen’s disease, actinic keratoses, atypical/dysplasitic nevi); persons with syndromes at risk for skin cancer and who therefore have lowered immunity (inherited or acquired immunodeficiency) including: xeroderma pigmentosum, albinism, trauma or burn victims, basal cell nevus syndrome (Gorlin’s syndrome), exposure to arsenic, recessive dystrophic epidermolysis bullosa, psoralen or ultraviolet A treatment, familial atypical mole and melanoma syndrome, strong familial history of melanoma, or numerous melanocytic nevi (>100 nevi)
Key questions 4 and 5: persons with syndromes at risk for skin cancer (see above)
Interventions/Exposures
[underlined: Include:]
Key questions 1 to 3: primary care feasible or referable counseling interventions aimed at changing sun-protective behaviors (decreasing sun exposure, avoidance of sunlamps/tanning beds, or sunscreen use), based on any theoretical foundation (NOTE: primary care feasible or referable interventions that are part of a multicomponent intervention will be included but discussed separately); - Primary care feasible or conducted counseling interventions, either conducted in a primary care research setting or judged to be feasible in “usual” primary care; - Target: involve individual-level identification of being a patient or in need of intervention; - Delivery: usually involve primary care physicians, other physicians, nurses, nurse practitioners, physician assistants, or related clinical staff (e.g., health educators, other counselors); or the intervention is seen as connected to the health care system by the participant; - Format: to individuals or small groups (i.e., ≤15); does not primarily involve group-level interventions outside the primary care setting; generally does not involve more than eight group sessions and the intervention period is no longer than 12 months; - Location: anywhere, as long as linked to primary care; - Primary care referable such that intervention needs to be conducted as part of a health care setting, or is widely available in the community at a national level
Key questions 4 and 5: exposure due to sun, sunlamps/tanning beds, or sunscreen, with description of how exposure is measured
[underlined: Exclude:]
Key questions 1 to 3: noncounseling interventions; counseling interventions focused on secondary prevention (i.e., counseling for skin self-examinations); counseling interventions that are primarily community, nonreferral (e.g., occupational/worksite, recreational, or school-based); social marketing (e.g., media campaigns); policy (e.g., local or state public/health policy)
Key questions 4 and 5: no a priori exclusion criteria
Outcomes
[underlined: Include:]
Key questions 1 and 2: skin cancer incidence or associated morbidity/mortality, intermediate outcomes (sunburn, nevi, actinic keratosis) or behavioral outcomes at ≥3 months after counseling intervention (decreased sun exposure through avoidance of peak hours of sun exposure, wearing protective clothing, avoidance of sunlamps or tanning beds, and use of sunscreen)
Key question 4: skin cancer incidence or associated morbidity/mortality, intermediate outcomes (sunburn, nevi, actinic keratosis)
Key questions 3 and 5: any adverse effects (e.g., paradoxical increase in sun exposure, reduced physical activity, dysphoric mood, vitamin D deficiency, increased incidence of other types of cancer)
[underlined: Exclude:]
Key questions 1 and 2: any trial with >40 percent attrition or no behavioral outcome assessment beyond 3 months; attitude, knowledge, or ability changes
Key question 4: no a priori exclusion criteria
Key questions 3 and 5: opportunity cost of counseling
Study Design
[underlined: Include:]
Key questions 1 to 3: good-quality systematic reviews of trials and individual randomized or controlled clinical trials
Key questions 4 and 5: fair- to good-quality systematic reviews of observational studies, individual randomized or controlled clinical trials (only pertains to KQ4c), and individual observational (cohort, population-based case-control) studies not included in systematic reviews
[underlined: Exclude:] All poor-quality studies as dual reviewed and defined by USPSTF quality criteria
Key questions 1 to 3: any nonexperimental study design, modeling studies
Key questions 4 and 5: ecologic analyses, hospital-based case-control studies, cross-sectional studies, case-series, case reports

Appendix A Table 3 Quality Rating Criteria

Design | USPSTF Quality Rating Criteria137 | NICE Methodology Checklists138 | Newcastle-Ottawa Quality Assessment Scales139
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - Study addresses an appropriate and clearly focused question; - Description of the methodology used is included; - Literature search is sufficiently rigorous to identify all relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable | N/A
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate is reported; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - Sstudy addresses an appropriate and clearly focused question; - Cases and controls are taken from comparable populations; - Same exclusion criteria are used for both cases and controls; - Percentage of each group (cases and controls) that participated in the study is reported; - Comparison is made between participants and non- participants to establish similarities or differences; - Cases are clearly defined and differentiated from controls; - It is clearly established that controls are non-cases; - Measures have been taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid, and reliable way; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided | - Case definition is adequate; - Cases are representative; - Controls are from the same population as cases; - If cases are first occurrence of outcome, then controls have no history of this outcome; - Cases and controls are matched, and/or confounders are adjusted for in the analysis; - Same method of exposure ascertainment for cases and controls; - Acceptable ascertainment of exposure
Randomized controlled trials (RCTs) | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - Study addresses an appropriate and clearly focused question; - Assignment of subjects to treatment groups is randomized; - An adequate concealment method is used; - Subjects and investigators are kept blind about treatment allocation; - Treatment and control groups are similar at start of trial; - Only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid, and reliable way; - Percentage of individuals or clusters recruited into each treatment arm that dropped out before study completion is reported; - All subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - When the study is carried out at more than one site, results are comparable for all sites | N/A
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - Study addresses an appropriate and clearly focused question; - Groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - Study indicates how many of the people asked to take part did so, in each of the groups being studied; - Likelihood that some eligible subjects might have the outcome at time of enrollment is assessed and taken into account in the analysis; - Percentage of individuals or clusters recruited into each study arm that dropped out before study completion is reported; - Comparison is made between full participants and those lost to follow-up, by exposure status; - Outcomes are clearly defined; - Assessment of outcome is made blind to exposure status; - When blinding is not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - Measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided | - Exposed cohort is representative of exposed individuals in the community; - The non-exposed cohort is drawn from the same community as the exposed cohort; - Appropriate ascertainment of exposure; - Demonstration that the outcome of interest was not present at the start of the study; - Exposed and non-exposed cohorts are matched and/or confounders are adjusted for in the analysis; - Adequate assessment of outcomes; - Follow-up long enough for outcomes to occur; - Follow-up adequate to ensure that losses are not due to exposure or outcomes
Diagnostic accuracy studies | - Screening test relevant, available for primary care, and adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate results in a reasonable manner; - Spectrum of patients included in study; - Sample size reported; - Administration of reliable screening test | - Nature of the test being studied is clearly specified; - Test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - Test and gold standard are measured independently (blind) of each other; - Test and gold standard are applied as close together in time as possible; - Results are reported for all patients that entered the study; - A pre-diagnosis is made and reported | N/A

Hierarchy of research design

I Properly conducted randomized controlled trial
II-1 Well-designed controlled trial without randomization
II-2 Well-designed cohort or case-control analytic study
II-3 Multiple time series with or without the intervention; dramatic results from uncontrolled experiments
III Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees