# References

1 Hartmann EE, Dobson V, Hainline L, et al. Preschool vision screening: summary of a Task Force report. Pediatrics. 2000;106(5):1105-1116. [pmid: 11061783].
2 Webber AL, Wood JM, Gole GA, Brown B. Effect of amblyopia on self-esteem in children. Optom Vis Sci. 2008;85(11):1074-1081. [pmid: 18981922].
3 U.S. Preventive Services Task Force. Screening for visual impairment in children younger than age 5 years: recommendation statement. Ann Fam Med. 2004;2:263-266. [pmid: 15209205].
4 Doshi NR, Rodriguez ML. Amblyopia. Am Fam Physician. 2007;75(3):361-367. [pmid: 17304867].
5 Donahue SP, Arnold RW, Ruben JB. AAPOS Vision Screening Committee. Preschool vision screening: what should we be detecting and how should we report it? Uniform guidelines for reporting results of preschool vision screening studies. J AAPOS. 2003;7(5):314-316. [pmid: 14566312].
6 Ciner E, Schmidt P, Orel-Bixler D, et al. Vision screening of preschool children: evaluating the past, looking toward the future. Optom Vis Sci. 1998;75:571-584. [pmid: 9734801].
7 Webber A, Wood J. Amblyopia: prevalence, natural history, functional effects and treatment. Clin Exp Optom. 2005;88(6):365-375. [pmid: 16329744].
8 Multi-Ethnic Pediatric Eye Disease Study Group. Prevalence of amblyopia and strabismus in African American and Hispanic children ages 6 to 72 months: the Multi-Ethnic Pediatric Eye Disease Study. Ophthalmology. 2008;115:1229-1236. [pmid: 17953989].
9 Donahue SP, Baker JD, Scott WE, et al. Lions Clubs International Foundation Core Four Photoscreening: results from 17 programs and 400,000 preschool children. J AAPOS. 2006;10(1):44-48. [pmid: 16527679].
10 Barry JC, König HH. Non-cycloplegic screening for amblyopia via refractive findings with the Nikon Retinomax hand held autorefractor in 3 year old kindergarten children. Br J Ophthalmol. 2001;85(10):1179-1182. [pmid: 11567961].
11 Barry JC, König HH. Test characteristics of orthoptic screening examination in 3 year old kindergarten children. Br J Ophthalmol. 2003;87(7):909-916. [pmid: 12812897].
12 Newman DK, East MM. Preschool vision screening: negative predictive value for amblyopia. Br J Ophthalmol. 1999;83(6):676-679. [pmid: 10340974].
13 Friedman DS, Repka MX, Katz J, et al. Prevalence of decreased visual acuity among preschool-aged children in an American urban population. Ophthalmology. 2008;115:1786-1795. [pmid: 18538407].
14 Giordano L, Friedman DS, Repka MX, et al. Prevalence of refractive error among preschool children in an urban population: the Baltimore Pediatric Eye Disease Study. Ophthalmology. 2009;116(4):739-746. [pmid: 19243832].
15 Eye Diseases Prevalence Research Group. The prevalence of refractive errors among adults in the United States, Western Europe, and Australia. Arch Ophthalmol. 2004;122:495-505. [pmid: 15078666].
16 Simons K. Preschool vision screening: rationale, methodology and outcome. Surv Ophthalmol. 1996;41(1):3-30. [pmid: 8827927].
17 Rahi JS, Logan S, Timms C, Russell-Eggitt I, Taylor D. Risk, causes, and outcomes of visual impairment after loss of vision in the non-amblyopic eye: a population-based study. Lancet. 2002;360:597-602. [pmid: 12241931].
18 Rahi JS, Cumberland P, Peckham C. Does amblyopia affect educational, health and social outcomes? Findings from the 1958 British birth cohort. BMJ. 2006;332:820-825. [pmid: 16520328].
19 Paysse EA, Coats DK. Amblyopia. Nelson LB, Olitsky SE, editors. Harley’s Pediatric Ophthalmology. 5th ed. Philadelphia. Lippincott Williams & Wilkins. 2005:123-136.
20 Simons K, Preslan M. Natural history of amblyopia untreated owing to lack of compliance. Br J Ophthalmol. 1999;83(5):582-587. [pmid: 10216059].
21 Epelbaum M, Milleret C, Buisseret P, Dufier JL. The sensitive period for strabismic amblyopia in humans. Ophthalmology. 1993;100:323-327. [pmid: 8460000].
22 Flynn JT, Schiffman J, Feuer W, Corona A. The therapy of amblyopia: an analysis of the results of amblyopia therapy utilizing the pooled data of published studies. Trans Am Ophthalmol Soc. 1998;96:431-453. [pmid: 10360300].
23 Pediatric Eye Disease Investigator Group. Hertle RW, Scheiman MM, et al. Stability of visual acuity improvement following discontinuation of amblyopia treatment in children aged 7 to 12 years. Arch Ophthalmol. 2007;125(5):655-659. [pmid: 17502505].
24 Pediatric Eye Disease Investigator Group. Scheiman MM, Hertle RW, et al. Randomized trial of treatment of amblyopia in children aged 7 to 17 years. Arch Ophthalmol. 2005;123(4):437-447. [pmid: 15824215].
25 Schwartz SR, Blei F, Ceisler E, Steele M, Furlan L, Kodsi S. Risk factors for amblyopia in children with capillary hemangiomas of the eyelids and orbit. J AAPOS. 2006;10(3):262-268. [pmid: 16814181].
26 Williams C, Northstone K, Howard M, Harvey I, Harrad R, Sparrow J. Prevalence and risk factors for common vision problems in children: data from the ALSPAC study. Br J Ophthalmol. 2008;92(7):959-964. [pmid: 18480306].
27 Keech R, Kutschke P. Upper age limit for the development of amblyopia. J Pediatr Ophthalmol Strabismus. 1995;32:89-93. [pmid: 7629676].
28 Chen PL, Chen JT, Tai MC, Fu JJ, Chang CC, Lu DW. Anisometropic amblyopia treated with spectacle correction alone: possible factors predicting success and time to start patching. Am J Ophthalmol. 2007;143:54-60. [pmid: 17113556].
29 Cleary M. Efficacy of occlusion for strabismic amblyopia: can an optimal duration be identified?. Br J Ophthalmol. 2000;84(6):572-578. [pmid: 10837378].
30 Steele A, Bradfiled Y, Kushner BJ, France TD, Struck M, Gangnon R. Successful treatment of anisometropic amblyopie with spectacles alone. J AAPOS. 2006;10:37-43. [pmid: 16527678].
31 Stewart CE, Moseley MJ, Fielder AR, Stephens DA. Refractive adaptation in amblyopia: quantification of effect and implications for practice. Br J Ophthalmol. 2004;88:1552-1556. [pmid: 15548811].
32 Holladay JT. Visual acuity measurements. J Cataract Refract Surg. 2004;39:278-290.
33 American Academy of Pediatrics. Policy Statement: eye examination in infants, children, and young adults by pediatricians. Pediatrics. 2003;111(4):902-907. [pmid: 12671132].
34 American Academy of Pediatrics. Policy statement: use of photoscreening for children’s vision screening. Pediatrics. 2002;109(3):524-525. [pmid: 11875154].
35 Prevent Blindness America. Preschool Vision Screening for Health Care Professionals. Schaumburg, IL. Prevent Blindness America. 2005.
36 Kemper AR, Clark SJ. Preschool vision screening in pediatric practices. Clin Pediatr (Phila). 2006;45(3):263-266. [pmid: 16708140].
37 Morad Y, Werker E, Nemet P. Visual acuity tests using chart, line, and single optotype in healthy and amblyopic children. J AAPOS. 1999;3(2):94-97. [pmid: 10221802].
38 Donahue SP, Johnson TM, Leonard-Martin TC. Screening for amblyogenic factors using a volunteer lay network and the MTI photoscreener: initial results from 15,000 preschool children in a statewide effort. Ophthalmology. 2000;107(9):1637-1644. [pmid: 10964820].
39 American Academy of Family Physicians. Visual impairment, children. Recommendations for Clinical Preventive Services. Leawood, KS. American Academy of Family Physicians. 2004. Accessed at http://www.aafp.org/online/en/home/clinical/exam.html. 30 December 2010.
40 American Academy of Ophthalmology; American Association for Pediatric Ophthalmology and Strabismus. Policy statement: vision screening for infants and children. San Francisco. American Academy of Ophthalmology. 2007. Accessed at http://one.aao.org/CE/PracticeGuidelines/ClinicalStatements_Content.aspx?cid=0ad11e02-6a8b-437e-8d01-f45eb18bc0b6. 30 December 2010.
41 American Optometric Association. Optometric Clinical Practice Guideline: Pediatric Eye and Vision Examination. St. Louis, MO. American Optometric Association. 2002. Accessed at http://www.aoa.org/documents/CPG-2.pdf. 30 December 2010.
42 Feightner JW. Routine preschool screening for visual and hearing problems, Canadian Task Force on the Periodic Health Examination Canadian Guide to Clinical Preventive Health Care. Ottawa. Health Canada. 1994:298-304.
43 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
44 Leeflang MM, Deeks JJ, Gatsonis C, Bossuyt PM. Cochrane Diagnostic Test Accuracy Working Group. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149:889-897. [pmid: 19075208].
45 Begg CB, Greenes RA. Assessment of diagnostic tests when disease verification is subject to selection bias. Biometrics. 1983;39(1):207-215. [pmid: 6871349].
46 Deeks JJ, Altman DG. Diagnostic tests 4: likelihood ratios. BMJ. 2004;329:168-169. [pmid: 15258077].
47 Jaeschke R, Guyatt GH, Sackett DL. Evidence-Based Medicine Working Group. Users’ guides to the medical literature, III: how to use an article about a diagnostic test. B: what are the results and will they help me in caring for my patients?. JAMA. 1994;271:703-707. [pmid: 8309035].
48 Williams C, Harrad RA, Harvey I, Sparrow JM. ALSPAC Study Team. Screening for amblyopia in preschool children: results of a population-based, randomised controlled trial. Ophthalmic Epidemiol. 2001;8(5):279-295. [pmid: 11922382].
49 Williams C, Northstone K, Harrad RA, Sparrow JM, Harvey I. ALSPAC Study Team. Amblyopia treatment outcomes after screening before or at age 3 years: follow up from randomised trial. BMJ. 2002;324(7353):1549. [pmid: 12089090].
50 Williams C, Northstone K, Harrad RA, Sparrow JM, Harvey I. ALSPAC Study Team. Amblyopia treatment outcomes after preschool screening v. school entry screening: observational data from a prospective cohort study. Br J Ophthalmol. 2003;87(8):988-993. [pmid: 12881342].
51 Eibschitz-Tsimhoni M, Friedman T, Naor J, Eibschitz N, Friedman Z. Early screening for amblyogenic risk factors lowers the prevalence and severity of amblyopia. J AAPOS. 2000;4(4):194-199. [pmid: 10951293].
52 Feldman W, Sackett B, Milner R, Gilbert S. Effects of preschool screening for vision and hearing on prevalence of vision and hearing problems 6–12 months later. Lancet. 1980:1014-1016.
53 Kohler L, Stigmar G. Visual disorders in 7-year-old children with and without previous vision screening. Acta Paediatrica Scand. 1978;67:373-377.
54 Kirk VG, Clausen MM, Armitage MD, Arnold RW. Preverbal photoscreening for amblyogenic factors and outcomes in amblyopia treatment: early objective screening and visual acuities. Arch Ophthalmol. 2008;126(4):489-492. [pmid: 18413517].
55 Mulley L. The Airedale Vision Screening Program: a comparison of referral rates between two preschool age groups. Br Orthoptic J. 2000;57:39-41.
56 The Vision in Preschoolers Study Group V. Impact of confidence number on the screening accuracy of the retinomax autorefractor. Optom Vis Sci. 2007;84(3):181-188. [pmid: 17435531].
57 Arthur B, Riyaz R, Rodriguez S, Wong J. Field testing of the plusoptiX S04 photoscreener. J AAPOS. 2009;13:51-57. [pmid: 19121596].
58 Berry BE, Simons BD, Siatkowski RM, Schiffman JC, Flynn JT, Duthie MJ. Preschool vision screening using the MTI-Photoscreener. Pediatr Nurs. 2001;27(1):27-34. [pmid: 12025144].
59 Bertuzzi F, Orsoni JG, Porta MR, Paliaga GP, Miglior S. Sensitivity and specificity of a visual acuity screening protocol performed with the Lea Symbols 15-line folding distance chart in preschool children. Acta Ophthalmol Scand. 2006;84(6):807-811. [pmid: 17083543].
60 Chang CH, Tsai RK, Sheu MM. Screening amblyopia of preschool children with uncorrected vision and stereopsis tests in Eastern Taiwan. Eye. 2007;21(12):1482-1488. [pmid: 16946752].
61 Chui L, Fraser T, Hoar K, LaRoche GR. Negative predictive value of a vision screening program aimed at children aged 3 to 4 years old. J AAPOS. 2004;8(6):566-570. [pmid: 15616505].
62 Cogen M, Ottemiller D. Photorefractor for detection of treatable eye disorders in preverbal children. Ala Med. 1992;62:16-20. [pmid: 1442456].
63 Cooper CD, Gole GA, Hall JE, Colville DJ, Carden SM, Bowling FG. Evaluating photoscreeners, II: MTI and Fortune videorefractor. Aust N Z J Ophthalmol. 1999;27(6):387-398. [pmid: 10641896].
64 Dahlmann-Noor AH, Comyn O, Kostakis V, et al. Plusoptix vision screener: the accuracy and repeatability of refractive measurements using a new autorefractor. Br J Ophthalmol. 2009;93(3):346-349. [pmid: 19001013].
65 Dahlmann-Noor AH, Vrotsou K, Kostakis V, et al. Vision screening in children by Plusoptix vision screener compared with gold-standard orthoptic assessment. Br J Ophthalmol. 2009;93(3):342-345. [pmid: 19019940].
66 Ehrt O, Weber A, Boergen KP. Screening for refractive errors in preschool children with the vision screener. Strabismus. 2007;15(1):13-19. [pmid: 17523041].
67 Guo X, Jia X, Guo L, et al. Comparison of computer-photoscreening with non-cycloplegic retinoscopy for amblyopiogenic risk factors in children. Chin Med J. 2000;113(11):1007-1010. [pmid: 11776113].
68 Hope C, Maslin K. Random Dot Stereogram E in vision screening of children. Aust N Z J Ophthalmol. 1990;18:319-324. [pmid: 2261180].
69 Kemper AR, Keating LM, Jackson JL, Levin EM. Comparison of monocular autorefraction to comprehensive eye examinations in preschool-aged and younger children. Arch Pediatr Adolesc Med. 2005;159(5):435-439. [pmid: 15867116].
70 Kennedy RA, Sheps SB. A comparison of photoscreening techniques for amblyopic factors in children. Can J Ophthalmol. 1989;24(6):259-264. [pmid: 2692792].
71 Kennedy R, Sheps S, Bagaric D. Field trial of the Otago photoscreener. Can J Ophthalmol. 1995;30:193-197. [pmid: 7585311].
72 Kennedy R, Thomas D. Evaluation of the iScreen digital screening system for amblyogenic factors. Can J Ophthalmol. 2000;35:258-262. [pmid: 10959465].
73 Matta N, Singman L, Silbert DI. Performance of the Plusoptix vision screener for the detection of amblyopia risk factors in children. J AAPOS. 2008;12:490-492. [pmid: 18534881].
74 Miller JM, Harvey EM, Dobson V. Visual acuity screening versus noncycloplegic autorefraction screening for astigmatism in Native American preschool children. J AAPOS. 1999;3(3):160-165. [pmid: 10428590].
75 Miller JM, Dobson V, Harvey EM, Sherrill DL. Comparison of preschool vision screening methods in a population with a high prevalence of astigmatism. Invest Ophthalmol Vis Sci. 2001;42(5):917-924. [pmid: 11274067].
76 Molteno A, Hoare-Nairne J, Sanderson G, Peart D, Hodgkinson I. Reliability of the Otago photoscreener: a study of a thousand cases. Aust N Z J Ophthalmol. 1993;21(4):257-265. [pmid: 8148143].
77 Morgan KS, Johnson WD. Clinical evaluation of a commercial photorefractor. Arch Ophthalmol. 1987;105(11):1528-1531. [pmid: 3675285].
78 Ottar WL, Scott WE, Holgado S. Photoscreening for amblyogenic factors. J Pediatr Ophthalmol Strabismus. 1995;32:289-295. [pmid: 8531032].
79 Rogers DL, Neely DE, Chapman JB, et al. Comparison of the MTI photoscreener and the Welch-Allyn SureSight autorefractor in a tertiary care center. J AAPOS. 2008;12(1):77-82. [pmid: 18314072].
80 Shallo-Hoffmann J, Coulter R, Oliver P, Hardigan P, Blavo C. A study of pre-school vision screening tests’ testability, validity and duration: do group differences matter?. Strabismus. 2004;12(2):65-73. [pmid: 15672929].
81 Vision in Preschoolers Study Group. Preschool vision screening tests administered by nurse screeners compared with lay screeners in the Vision in Preschoolers study. Invest Ophthalmol Vis Sci. 2005;46(8):2639-2648. [pmid: 16043831].
82 Vision in Preschoolers Study Group. Comparison of preschool vision screening tests as administered by licensed eye care professionals in the Vision in Preschoolers study. Ophthalmology. 2004;111(4):637-650. [pmid: 15051194].
83 Tong PY, Bassin RE, Enke-Miyazaki E, et al. Screening for amblyopia in preverbal children with photoscreening photographs, II: sensitivity and specificity of the MTI photoscreener. Ophthalmology. 2000;107(9):1623-1629. [pmid: 10964818].
84 Weinand F, Graf M, Demming K. Sensitivity of the MTI photoscreener for amblyogenic factors in infancy and early childhood. Graefes Arch Clin Exp Ophthalmol. 1998;236:801-805. [pmid: 9825254].
85 Williams C, Lumb R, Harvey I, Sparrow JM. Screening for refractive errors with the Topcon PR2000 Pediatric Refractometer. Invest Ophthalmol Vis Sci. 2000;41(5):1031-1037. [pmid: 10752938].
86 Vision in Preschoolers Study Group. Sensitivity of screening tests for detecting Vision in Preschoolers-targeted vision disorders when specificity is 94%. Optom Vis Sci. 2005;82(5):432-438. [pmid: 15894920].
87 Donahue SP, Johnson TM, Ottar W, Scott WE. Sensitivity of photoscreening to detect high-magnitude amblyogenic factors. J AAPOS. 2002;6(2):86-91. [pmid: 11997804].
88 Freedman H. Vision screening. Ophthalmology. 2006;113(7):1248-1249. [pmid: 16815414].
89 Vision in Preschoolers Study Group. Does assessing eye alignment along with refractive error or visual acuity increase sensitivity for detection of strabismus in preschool vision screening?. Invest Ophthalmol Vis Sci. 2007;48(7):3115-3125. [pmid: 17591881].
90 Schmidt P, Maguire M, Kulp M, Dobson V, Quinn G. Vision in Preschoolers Study Group. Random Dot E stereotest: testability and reliability in 3- to 5-year-old children. J AAPOS. 2006;10(6):507-514. [pmid: 17189143].
91 Vision in Preschoolers Study Group. Preschool visual acuity screening with HOTV and Lea symbols: testability and between-test agreement. Optom Vis Sci. 2004;81(9):678-683. [pmid: 15365387].
92 Hered RW, Murphy S, Clancy M. Comparison of the HOTV and Lea Symbols charts for preschool vision screening. J Pediatr Ophthalmol Strabismus. 1997;34(1):24-28. [pmid: 9027676].
93 Kvarnstrom G, Jakobsson P. Is vision screening in 3-year-old children feasible? comparison between the Lea Symbol chart and the HVOT (LM) chart. Acta Ophthalmol Scand. 2005;83(1):76-80. [pmid: 15715562].
94 Salcido AA, Bradley J, Donahue SP. Predictive value of photoscreening and traditional screening of preschool children. J AAPOS. 2005;9(2):114-120. [pmid: 15838437].
95 Tarczy-Hornoch K, Lin J, Deneen J, et al. Steroeacuity testability in African-American and Hispanic pre-school children. Optom Vis Sci. 2008;85:158-163. [pmid: 18317330].
96 Becker R, Hubsch S, Graf MH, Kaufmann H. Examination of young children with Lea symbols. Br J Ophthalmol. 2002;86(5):513-516. [pmid: 11973243].
97 Williams C, Horwood J, Northstone K, et al. The timing of patching treatment and a child’s wellbeing. Br J Ophthalmol. 2006;90(6):670-671. [pmid: 16714262].
98 Donahue SP. How often are spectacles prescribed to “normal” preschool children?. J AAPOS. 2004;8(3):224-229. [pmid: 15226721].
99 Clarke MP, Wright CM, Hrisos S, Anderson JD, Henderson J, Richardson SR. Randomised controlled trial of treatment of unilateral visual impairment detected at preschool vision screening. BMJ. 2003;327(7426):1251. [pmid: 14644966].
100 Pediatric Eye Disease Investigator Group. A randomized trial to evaluate 2 hours of daily patching for strabismic and anisometropic amblyopia in children. Ophthalmology. 2006;113(6):904-912. [pmid: 16751033].
101 Awan M, Proudlock FA, Gottlob I. A randomized controlled trial of unilateral strabismic and mixed amblyopia using occlusion dose monitors to record compliance. Invest Ophthalmol Vis Sci. 2005;46(4):1435-1439. [pmid: 15790912].
102 Holmes JM, Kraker RT, Beck RW, et al. A randomized trial of patching regimens for treatment of moderate amblyopia in children. Arch Ophthalmol. 2003;121(5):603-611. [pmid: 12742836].
103 Stewart CE, Stephens DA, Fielder AR, Moseley MJ. ROTAS Cooperative. Objectively monitored patching regimens for treatment of amblyopia: randomised trial. BMJ. 2007;335(7622):707. [pmid: 17855283].
104 Repka MX, Cotter SA, Beck RW, et al. A randomized trial of atropine regimens for treatment of moderate amblyopia in children. Ophthalmology. 2004;111(11):2076-2085. [pmid: 15522375].
105 Pediatric Eye Disease Investigator Group. A randomized trial of atropine vs. patching for treatment of moderate amblyopia in children. Arch Ophthalmol. 2002;120(3):268-278. [pmid: 11879129].
106 Richardson SR, Wright CM, Hrisos S, Buck D, Clarke MP. Stereoacuity in unilateral visual impairment detected at preschool screening: outcomes from a randomized controlled trial. Invest Ophthalmol Vis Sci. 2005;46(1):150-154. [pmid: 15623768].
107 Pediatric Eye Disease Investigator Group. Treatment of anisometropic amblyopia in children with refractive correction. Ophthalmology. 2006;113(6):895-903. [pmid: 16751032].
108 Pediatric Eye Disease Investigator Group. Pharmacological plus optical penalization treatment for amblyopia. Arch Ophthalmol. 2009;127(1):22-30. [pmid: 19139333].
109 Repka MX, Wallace DK, Beck RW, et al. Two-year follow-up of a 6-month randomized trial of atropine vs. patching for treatment of moderate amblyopia in children. Arch Ophthalmol. 2005;123(2):149-157. [pmid: 15710809].
110 Pediatric Eye Disease Investigator Group. A randomized trial of atropine vs. patching for treatment of moderate amblyopia: follow-up at age 10 years. Arch Ophthalmol. 2008;126(8):1039-1044. [pmid: 18695096].
111 Pediatric Eye Disease Investigator Group. A comparison of atropine and patching treatments for moderate amblyopia by patient age, cause of amblyopia, depth of amblyopia, and other factors. Ophthalmology. 2003;110(8):1632-1637. [pmid: 12917184].
112 Hrisos S, Clarke MP, Wright CM. The emotional impact of amblyopia treatment in preschool children: randomized controlled trial. Ophthalmology. 2004;111(8):1550-1556. [pmid: 15288987].
113 Holmes JM, Beck RW, Kraker RT, et al. Impact of patching and atropine treatment on the child and family in the amblyopia treatment study. Arch Ophthalmol. 2003;121(11):1625-1632. [pmid: 14609923].
114 Cole SR, Beck RW, Moke PS, et al. The Amblyopia Treatment Index. J AAPOS. 2001;5(4):250-254. [pmid: 11507585].
115 Horwood J, Waylen A, Herrick D, Williams C. Common visual defects and peer victimization in children. Invest Ophthalmol Vis Sci. 2005;46:1177-1181. [pmid: 15790876].
116 Koklanis K, Abel LA, Aroni R. Psychosocial impact of amblyopia and its treatment: a multidisciplinary study. Clin Exp Ophthalmol. 2006;34(8):743-750.
117 Choong YF, Lukman H, Martin S, Laws DE. Childhood amblyopia treatment: psychosocial implications for patients and primary carers. Eye. 2004;18(4):369-375. [pmid: 15069432].
118 Chua BE, Johnson K, Martin F. A retrospective review of the associations between amblyopia type, patient age, treatment compliance and referral patterns. Clin Exp Ophthalmol. 2004;32(2):175-179.
119 Parkes LC. An investigation of the impact of occlusion therapy on children with amblyopia, its effect on their families and compliance with treatment. Br Orthoptic J. 2001;58:30-37.
120 Dixon-Woods M, Awan M, Gottlob I. Why is compliance with occlusion therapy for amblyopia so hard? a qualitative study. Arch Dis Child. 2006;91(6):491-494. [pmid: 16531452].
121 Searle A, Norman P, Harrad R, Vedhara K. Psychosocial and clinical determinants of compliance with occlusion therapy for amblyopic children. Eye. 2002;16(2):150-155. [pmid: 11988815].
122 Loudon SE, Fronius M, Looman CW, et al. Predictors and a remedy for noncompliance with amblyopia therapy in children measured with the occlusion dose monitor. Invest Ophthalmol Vis Sci. 2006;47(10):4393-4400. [pmid: 17003431].
123 Nelson H, Nygren P, Huffman L, et al. Screening for Visual Impairment in Children Younger Than Age 5 Years: Update of the Evidence From Randomized Controlled Trials, 1999–2003 for the U.S Preventive Services Task Force. Rockville, MD. Agency for Healthcare Research and Quality. 2004.
124 Shotton K, Elliott S. Interventions for strabismic amblyopia. Cochrane Database Syst Rev. 2008:CD006461.
125 Shotton K, Powell C, Voros G, Hatt SR. Interventions for unilateral refractive amblyopia. Cochrane Database Syst Rev. 2008:CD005137.
126 Pediatric Eye Disease Investigator Group. The course of moderate amblyopia treated with patching in children: experience of the amblyopia treatment study. Am J Ophthalmol. 2003;136:620-629. [pmid: 14516801].