# Discussion

## Summary of Review Findings

Results of this evidence synthesis, organized by KQ, are summarized in Table 15. Vision impairment and amblyopia or amblyogenic risk factors are relatively common in preschool-aged children ages 1 to 5 years. As in the previous USPSTF review,123 direct evidence on health outcomes of preschool vision screening remains limited. On the other hand, more evidence is now available on the accuracy and comparative accuracy of common vision screening tests in preschool-aged children, and more evidence is available to understand the effectiveness and comparative effectiveness of various treatment regimens for amblyopia and unilateral refractive error (with or without amblyopia).

Table 15 Summary of Evidence

Number of studies, quality score | Limitations | Consistency | Primary care applicability | Summary of findings
KQ 1. Is vision screening in children ages 1–5 years associated with improved health outcomes?
Screening vs. no screening: 4 cohort studies Intensive periodic vs. one-time screening: 1 RCT Fair to poor quality | No study evaluated school performance or other functional outcomes besides vision outcomes. 3 of the 4 cohort studies were retrospective and had important methodological shortcomings. The 1 prospective cohort study compared one-time screening to no screening. | Not applicable (not enough studies addressing the same question to judge consistency) | High | No randomized trial evaluated outcomes of preschool vision screening compared to no screening. One large, fair-quality randomized trial nested within a population-based cohort study found that intensive, periodic orthoptist screening from ages 8 to 37 months was associated with reduced likelihood of amblyopia at age 7.5 years compared to one-time orthoptist screening at age 37 months by about 1%, but the difference was only statistically significant for one of two definitions of amblyopia. A large prospective cohort study from this population found that one-time orthoptist screening at age 37 months was associated with no significant difference in risk for amblyopia at age 7.5 years compared to no screening, using any of three prestated definitions for amblyopia. Three retrospective cohort studies found that preschool screening was associated with improved school-age vision outcomes compared to no screening.
KQ 1a. Does effectiveness of vision screening in children ages 1–5 years vary in different age groups?
Earlier vs. later screening: 1 RCT, 1 cohort study Poor quality | In the RCT, it was not possible to determine whether differences in outcomes should be attributed to the earlier age at which screening was started or to the increased frequency of screening that also took place. In the retrospective cohort study, estimates were imprecise and based on a very small sample of children screened. | Not applicable | High | No randomized trial directly compared outcomes of preschool vision screening in different age groups. In one randomized trial, screening was initiated earlier in one group (age 8 months) compared to the control group (age 37 months), but the earlier group also received periodic screening. One poor-quality retrospective cohort study found no difference between screening at ages 2–4 years versus screening prior to 2 years in risk for at least mild vision impairment.
KQ 2. What is the accuracy and reliability of risk factor assessment for identifying children ages 1–5 years at increased risk for vision impairment?
No studies | No studies | Not applicable (no studies) | No studies | No study evaluated the accuracy or reliability of risk factor assessment in preschool vision screening, and no study evaluated outcomes of targeted versus universal preschool vision screening.
KQ 3. What is the accuracy of screening tests for vision impairment in children ages 1–5 years?
31 diagnostic accuracy studies Good quality | Estimates of the diagnostic accuracy of different types of screening tests as well as specific screening tests within the different categories varied substantially across studies, making it difficult to judge comparative diagnostic utility with certainty. | Some inconsistency in diagnostic accuracy estimates | Moderate (mostly specialty or enriched populations with high prevalence) | 31 studies evaluated the diagnostic accuracy of various preschool vision screening tests. Four studies evaluated visual acuity tests (LEA symbols and HOTV tests), three evaluated stereoacuity tests (Random dot E stereogram and Stereo Smile II), one evaluated the cover-uncover test, four evaluated some combination of clinical examination screening tests, 12 evaluated autorefractors, and 15 evaluated photoscreeners. Diagnostic accuracy estimates for all of these screening tests suggest utility for identification of children at higher risk for amblyogenic risk factors or specific visual conditions. Differences between studies in the populations evaluated, screening tests evaluated, screening thresholds applied, and target conditions sought make it difficult to reach strong conclusions about how they compare with one another. Studies that evaluated combinations of clinical tests (visual acuity, stereoacuity, and ocular alignment) generally showed superior likelihood ratios compared to studies of individual tests. In the largest study to directly compare the diagnostic accuracy of different individual screening tests (the Vision in Preschoolers [VIP] Study), differences in likelihood ratio estimates between the various tests evaluated were generally small, with overlapping confidence intervals.
KQ 3a. Does accuracy of screening tests for vision impairment in children ages 1–5 years vary in different age groups?
4 studies Fair quality | Limited numbers of studies with some inconsistency. | Some inconsistency | Moderate (mostly specialty or enriched populations with high prevalence) | Evidence on the comparative accuracy of preschool vision tests in different age groups among children ages 1 to 5 years is limited. Four studies found no clear differences in the diagnostic accuracy of various screening tests in preschool-aged children stratified according to age. Testability using common visual acuity tests, stereoacuity tests, photoscreening, and autorefractors generally exceeds 80% to 90% in children ages 3 years and older, with small increases in testability through age 5 years. Four studies found substantially lower testability with the Random dot E stereotest, Lea symbols visual acuity testing, and the SureSight autorefractor in preschool-aged children ages 1–3 years, compared to those ages 3–5 years. One large study of statewide screening with the MTI photoscreener found testability was 94% at age 1 year.
KQ 4. What are the harms of vision screening in children ages 1–5 years?
Psychosocial: 1 large cohort study False-positives: 7 studies Poor quality | Sparse evidence, except for positive predictive values. | Not applicable (not enough studies addressing the same question to judge consistency) | High | Evidence on harms of preschool vision screening is limited. Although preschool vision screening is associated with potential psychosocial harms related to treatment, one large cohort study found a 50% reduction in odds of being bullied at age 7.5 years among children offered screening compared to those who were not. In populations with a prevalence of visual conditions less than 10%, six of seven studies reported false-positive rates greater than 70%. One large study of a statewide preschool photoscreening program found that 20% of children with positive screens who did not meet criteria for amblyopia or amblyogenic risk factors (false-positives) were prescribed glasses. No study evaluated effects of unnecessary corrective lenses or treatment for amblyopia on long-term vision or functional outcomes.
KQ 5. What is the effectiveness of treatment for vision impairment in children ages 1–5 years?
Treatment vs. no treatment: 1 RCT Patching treatment vs. no treatment (>85% received eyeglasses): 2 RCTs Comparisons of treatment: 5 RCTs Fair quality | All trials evaluated older (ages ≥3 years) preschool-aged children. No trial evaluated effects of treatment compared to no treatment on school performance or other measures of function besides vision outcomes. | Consistent | High | In children with unilateral refractive error, one good-quality trial found that patching plus eyeglasses and eyeglasses alone were more effective than no treatment by an average of about 1 line on the Snellen eye chart after 1 year. Effects were larger (1 to 2 lines of visual acuity improvement) in the subgroup of children with worse baseline visual impairment. One fair- and one good-quality trial found that patching resulted in a statistically significant but small (<1 line on the Snellen eye chart) average improvement in visual acuity in children with amblyopia who were pretreated with eyeglasses if needed after 5 to 12 weeks of follow-up. Five fair- or good-quality trials found no differences in visual acuity improvement in the amblyopic eye between shorter and longer daily patching regimens (2 trials), different atropine regimens (2 trials), or between patching and atropine (1 trial). Three trials found no interaction between age and amblyopia treatment effects among preschoolers ages 3 to 7 years, and one trial found that delaying treatment for 1 year was associated with similar outcomes compared to immediate treatment in children ages 3 to 5 years. One trial found that younger preschoolers (age 3 years) required fewer hours per day of patching to experience optimal improvements in visual acuity compared to older preschool-aged children (ages 4–8 years).
KQ 6. What are the harms of treatment for children ages 1–5 years at increased risk for vision impairment or vision disorders?
Nonamblyopic eye visual acuity loss: 5 RCTs Fair quality Adverse psychosocial effects: 2 RCTs Poor quality | Sparse evidence on adverse psychosocial effects or effects of compliance on clinical outcomes. | Consistent | High | Although one short-term (5 weeks) trial found that patching versus no patching was not associated with an increased risk for visual acuity loss in the nonamblyopic eye, one trial found that patching was associated with an increased risk for ≥2 lines of visual acuity loss compared to atropine (9% vs. 1.4%; p<0.001) and one trial found that atropine plus a plano lens was associated with an increased risk for ≥1 line of visual acuity loss compared to atropine alone (17% vs. 4%; p=0.005). In both trials, visual acuity in the nonamblyopic eye subsequently returned to baseline in almost all children. Two other trials found no difference in risk for visual acuity loss in the nonamblyopic eye in direct comparisons of different patching or atropine regimens. Evidence on adverse psychosocial effects of amblyopia treatments is limited. One fair-quality follow-up study from a randomized trial found that children were more upset by patching plus eyeglasses compared to eyeglasses alone, and one good-quality trial found that patching was associated with worse emotional well-being compared to atropine.

Abbreviations: MTI=Medical Technologies, Inc.; RCT=randomized controlled study; vs=versus.

The only available randomized trial of preschool vision screening compared more intensive with less intensive screening, rather than screening versus no screening.49 Although it found that repeated preschool screening reduced the prevalence of subsequent (school-age) amblyopia by about 1 percent compared with one-time screening, the difference was only statistically significant for one of two definitions of amblyopia used in the trial. One fair-quality prospective cohort study found no significant difference between one-time screening at age 37 months compared with no screening in risk for amblyopia at age 7.5 years,50 but did find a 50 percent reduction in odds of being bullied,97 perhaps related to earlier completion of patching regimens. Retrospective cohort studies that found preschool vision screening to be more effective than no screening are of limited usefulness because of important methodological shortcomings.51–53

More evidence is now available on the accuracy of various preschool vision screening tests. There is good evidence that commonly used visual acuity tests, stereoacuity tests, cover-uncover tests, autorefractors, and photoscreeners are useful for screening, though differences among studies in the populations evaluated, screening tests evaluated, screening thresholds applied, and target conditions sought make it difficult to reach strong conclusions about how they compare with one another. In the largest study to directly compare many screening tests (the VIP study), differences in likelihood ratio estimates were generally too small to clearly distinguish superior from inferior tests.82 In addition to diagnostic accuracy, other factors that may affect the choice of screening tests include testability rates at the age being screened, convenience, costs, and how well different tests perform in combination.11, 61, 71, 80, 89 Studies11, 61, 71, 80 that evaluated combinations of clinical tests (visual acuity, stereoacuity, and ocular alignment) generally reported stronger likelihood ratios than studies that evaluated individual tests. Screening tests were generally associated with a high rate of false-positives in low-prevalence populations10–12, 60, 68, 80 which could result in unnecessary prescription of eyeglasses.98

There is good evidence that there are effective treatments for visual impairment in preschool-aged children. Although benefits of patching compared with no patching average 1 line or less of visual acuity, some trials pretreated all children with eyeglasses, and benefits appear larger (1 to 2 lines) in children with more severe baseline vision impairment.99–101 All of the trials enrolled children ages 3 years or older, so applicability to younger preschool-aged children is uncertain. Factors that may affect interpretation of the magnitude of treatment benefits are that the visual impairment associated with amblyopia can become irreversible, is not correctable with refraction, and potentially affects function over the lifespan of a child. Although patching and atropine appear to be similarly effective treatments for amblyopia,105 patching may be associated with more short-term (but usually reversible) visual acuity loss in the nonamblyopic eye compared with atropine,105 as well as more psychological distress,112 since it is a more visible treatment.

Evidence on when to initiate preschool screening remains limited. One randomized trial initiated screening at different ages, but effects of age could not be separated from effects of repeated versus one-time screening.49 Other studies indicate a lower rate of false-positive screening results in children screened at age 3.5 years compared with those screened at age 1.5 years,55 but there was no clear association between age at which treatment was started and effectiveness among preschool-aged children ages 3 years and older.99, 100, 102, 103, 109–111

Our conclusions regarding effectiveness of treatments for amblyopia are generally in accordance with Cochrane reviews on treatments for strabismic amblyopia124 and unilateral refractive amblyopia,125 even though the Cochrane reviews included studies of therapies not included in our review, as well as older (school-age) children and children with severe amblyopia, who are unlikely to be identified by screening alone.

## Limitations

Our evidence review has some potential limitations. First, we excluded nonEnglish-language studies, which could introduce language bias. However, we identified no relevant nonEnglish-language studies in our literature searches. Second, there were too few studies to assess for publication bias. Third, a number of studies evaluated diagnostic accuracy of screening tests or screening programs in community-based settings and eye specialty clinics, which could limit their applicability to primary care settings. Finally, we did not attempt to construct outcomes tables, because the best evidence on screening versus no screening (a large prospective cohort study from the ALSPAC investigators49) found no benefits.

## Emerging Issues

A number of trials by the PEDIG investigators on therapies for amblyopia, long-term follow-up of amblyopia treatments, and treatment of refractory amblyopia are currently under way or in the follow-up or analysis phase (for more information, go to http://pedig.jaeb.org/Studies.aspx).

## Future Research

We identified several important gaps in the evidence on preschool screening for impaired visual acuity. There are no randomized trials showing that preschool vision screening is effective for improving visual or other clinical outcomes compared with no screening, and the only prospective cohort study found no clear benefit from screening.50 Well-designed studies are needed to identify optimal methods for vision screening, to understand when to begin screening (e.g., before age 3 years or after age 3 years), to define appropriate screening intervals, and to develop effective strategies for linking preschool-aged children with vision impairment to appropriate care, while avoiding unnecessary use of eyeglasses and other treatments. More studies are also needed to understand optimal amblyopia treatment regimens and to identify optimal combinations of screening tests. At this time, most evidence suggests that less intensive interventions are as effective as more intensive interventions, but minimum effective treatments are not clearly established. Finally, almost all of the trials have focused on effects of preschool vision screening and treatment on visual acuity outcomes. Trials that also address function are needed to clarify how preschool vision screening may affect school performance and other aspects of child development.

## Conclusions

Direct evidence on effectiveness of preschool vision screening for improving visual acuity or other clinical outcomes remains very limited and does not adequately address the question of whether screening is more effective than no screening. However, good evidence on diagnostic accuracy and treatments suggest that preschool vision screening could lead to increased detection of visual impairment and greater improvement in visual outcomes than if children were never screened. Additional studies are needed to better understand effects of screening compared with no screening, to clarify the risk for potential unintended harms from screening (such as use of unnecessary treatments), and to define optimal time at which to initiate screening during the preschool years.