# Results

## Key Question 1 Is Vision Screening in Children Ages 1–5 Years Associated With Improved Health Outcomes?

### Summary

No randomized trial evaluated outcomes of preschool vision screening compared with no screening. One large, fair-quality randomized trial nested within a population-based cohort study found that intensive, periodic orthoptist screening from ages 8 to 37 months was associated with reduced likelihood of amblyopia at age 7.5 years compared with one-time orthoptist screening at age 37 months. Intensive orthoptist screening also reduced the likelihood of residual amblyopia among treated children for one of two predefined definitions for amblyopia. A large prospective cohort study from this population found that one-time orthoptist screening at age 37 months was associated with no significant difference in risk for amblyopia at age 7.5 years compared with no screening. Three retrospective cohort studies found that preschool screening was associated with improved school-age vision outcomes compared with no screening, but each had important methodological shortcomings. No study evaluated school performance or other functional outcomes.

### Evidence

We identified no randomized trials of vision screening compared with no screening in children ages 1–5 years. A fair-quality, nested randomized trial from the Avon Longitudinal Study of Parents and Children (ALSPAC) population-based cohort compared intensive orthoptist screening before age 3 years (at 8, 12, 18, 25, 31, and 37 months) versus one-time orthoptist screening at age 37 months in 3,490 children born in southwest England (Table 5, Appendixes B1 and B2).48, 49 The major methodological shortcoming of this trial was high loss to follow-up (nearly half of the children did not attend the final examination at age 7.5 years). Screening examinations by the orthoptist consisted of a clinical examination, age-specific visual acuity testing, and cover-uncover testing. All children were offered screening for reduced visual acuity by a school nurse at school entry (at ages 4–5 years). Children with positive screening findings were referred to the hospital eye service for further evaluation and treatment. Amblyopia was defined in two different ways (Table 5).

Table 5 Randomized Controlled Trials of Preschool Vision Screening

Study, year, study design | Number of treatment and control subjects | Subject age, sex, diagnosis | Country and setting | Screening intervention | Results | Quality score
Williams et al, 2002^49^ and 2003^50^ Randomized controlled trial | # approached and eligible: NR # enrolled: 3,490 (2,029 intensive screening, 1,490 one-time screening) # analyzed at 7.5 years: outcome 1,929 | Age: Initially tested at ages 8–37 months and followed to age 7.5 years Sex: 48% female (of those at final assessment) Diagnosis: Baseline amblyopia or amblyogenic risk factors NR | United Kingdom Hospital eye services clinic | Screening at 8, 12, 18, 25, 31, and 37 months Cover-uncover test; Cardiff cards at 8 and 12 months; Cardiff and Kays pictures test at 18, 25, and 31 months; Kays picture test and HOTV test at 37 months; noncycloplegic autorefraction (performed at all visits, but only used for referral at 37 months) Screening at 37 months Cover-uncover test; Kays picture test and HOTV test; noncycloplegic autorefraction | Screening at 8, 12, 18, 25, 31, and 37 months vs. screening at 37 months only Amblyopia A at 7.5 years: 1.4% (16/1088) vs. 2.7% (22/826); RR, 0.55 (95% CI, 0.29–1.04) Amblyopia B at 7.5 years: 0.6% (69/1088) vs. 1.8% (15/876); RR, 0.35 (95% CI, 0.15–0.86) Residual amblyopia A among children treated with occlusion: 25% (10/40) vs. 8% (3/40); OR, 1.56 (95% CI, 0.62–3.92) Residual amblyopia B among children treated with occlusion: OR, 4.11 (95% CI, 1.04–16.29) Mean visual acuity in worse eye after patching treatment (adjusted for confounding variables): 0.15 (95% CI, 0.083–0.22) vs. 0.26 (0.17–0.35); p<0.001 Amblyopia A: interocular difference in acuity ≥0.2 logMAR (2 lines on chart) Amblyopia B: interocular difference in acuity ≥0.3 log MAR | Fair

Abbreviations: NR=not reported; CI=confidence interval; LogMAR=logarithmic minimum angle of resolution; OR=odds ratio; RR=relative risk.

At age 7.5 years, prevalence of amblyopia was about 1 percent lower in the intensive screening group compared with the control group for both definitions of amblyopia, but the difference was statistically significant for only one definition (amblyopia A: 1.45 percent vs. 2.66 percent; relative risk [RR], 0.55 [95% CI, 0.29–1.04]; amblyopia B: 0.63 percent vs. 1.81 percent; RR, 0.35 [95% CI, 0.15–0.86]).49 Residual amblyopia despite patching treatment was more likely in the control group, but estimates were imprecise and only statistically significant for one of the two amblyopia definitions (amblyopia A: odds ratio [OR], 1.56 [95% CI, 0.62–3.92]; amblyopia B: OR, 4.11 [95% CI, 1.04–16.29]). Visual acuity at age 7.5 years in the (worse) amblyopic eye in patched children was better in the intensive screening group than in the one-time screening group, by an average of about 1 line on the Snellen eye chart (0.15 logMAR [95% CI, 0.08–0.22] vs. 0.26 logMAR [95% CI, 0.17–0.35]; p<0.001).

A large (n=6,081), fair-quality prospective cohort study from ALSPAC evaluated outcomes of orthoptist screening at age 3 years in one health district versus no preschool screening in two other health districts (Table 6, Appendix B1).50 Like the ALSPAC randomized trial, a large proportion of children in the cohort did not have examination results at age 7.5 years available, though the exact proportion was not reported. There was no difference in amblyopia at age 7.5 years between children who did or did not receive preschool vision screening based on any of three prestated definitions (Table 6) of amblyopia (amblyopia A: adjusted OR, 0.63 [95% CI, 0.32–1.23]; amblyopia B: adjusted OR, 0.72 [95% CI, 0.43–1.60]; amblyopia C: adjusted OR, 0.65 [95% CI, 0.38–1.10]). Trends toward better amblyopia outcomes in the screened group were even more attenuated when the analysis was based on whether children were offered screening or not, rather than on whether they received screening or not (about two third of the children invited to screening participated).

Table 6 Controlled Observational Studies of Preschool Vision Screening

Study, year, study design | Number of treatment and control subjects | Subject age, sex, diagnosis | Country and setting | Screening intervention | Results | Quality score
Eibschitz-Tsimhoni et al, 2000^51^ Retrospective cohort study | # approached and eligible: 988 in “screening city”; 782 in “nonscreening” city # enrolled: 1,590 (808 were screened at ages 1 to 2.5 years; 782 were not) Loss to follow-up: NR | Age: 8 years Sex: NR Diagnosis: 1% vs. 2.6% amblyopia | Israel Preschool screening | Ophthalmologic exam by orthoptist or ophthalmologist, including Hirschberg corneal reflex text, monocular fixation and following test, ductions and versions exam, cover-uncover test, alternative cover test, and retinoscopy without cycloplegia | Screening at 1 to 2.5 years vs. no screening at 1 to 2.5 years Amblyopia at 8 years: 1.0% (8/808) vs. 2.6% (20/782); RR, 0.39 (95% CI, 0.17–0.87) Amblyopia with visual acuity worse than 20/60 at 8 years: 0.1% (1/808) vs. 1.7% (13/782); RR, 0.07 (95% CI, 0.01–0.57) | Poor
Feldman et al, 1980^52^ Retrospective cohort study | # approached and eligible: NR # enrolled: 1,508 (745 were screened 6 to 12 months prior to school entry; 763 were not) Loss to follow-up: NR | Age: Mean, 6 years Sex: NR Diagnosis: 13% had at least mild (visual acuity of 20/40 or worse) best-corrected vision impairment | Canada Preschool and school screening | Illiterate E visual acuity test, administered by school nurse | Screening at 6 to 12 months prior to school entry vs. no screening prior to school entry Relative risk for at least mild vision impairment upon school entry: 10% (78/763) vs. 15% (112/745); RR, 0.68 (95% CI, 0.52–0.89) | Poor
Kohler et al, 1978^53^ Retrospective cohort study | # approached and eligible: NR # enrolled: 2,178 (619 were screened at age 4 years; 1,519 were not) Loss to follow-up: NR | Age: 7 years Sex: NR Diagnosis: 49% had vision disorders classified as requiring treatment, functional amblyopia, or strabismus | Sweden Preschool and school screening | Linear E-chart, administered by school nurse | Screening at 4 years vs. no screening at 4 years Relative risk for newly diagnosed vision disorder, amblyopia, or strabismus at 7 years: 5% (29/619) vs. 0.7% (11/1519); RR, 0.15 (95% CI, 0.08–0.31) | Poor
Williams et al, 2003^50^ Prospective cohort study | # approached and eligible: 8,042 (1,917 excluded due to inclusion in quasi-randomized trial; 44 excluded due to developmental delay or organic eye disease) # enrolled: 6,081 (1,516 were screened at age 37 months; 4,565 were not) Loss to follow-up: NR | Age: Cohort tested at 7.5 years; screening offered at 37 months Sex: 49% female Diagnosis: Baseline amblyopia or amblyogenic risk factors NR | United Kingdom Hospital eye services clinic | Kay's pictures or Sheridan Gardiner singles visual acuity test, cover-uncover test, and 20 diopter prism or stereopsis test (or both) | Screening at 37 months vs. no screening Amblyopia A at 7.5 years: 1.1% (11/1019) vs. 2.0% (100/5062); adjusted OR, 0.63 (95% CI, 0.32–1.23) Amblyopia B at 7.5 years: 0.7% (7/1019) vs. 1.3% (65/5062); adjusted OR, 0.72 (95% CI, 0.32–1.60) Amblyopia C at 7.5 years: 1.9% (19/1019) vs. 3.4% (171/5062); adjusted OR, 0.65 (95% CI, 0.38–1.10) Mean visual acuity in worse eye after patching treatment (adjusted for confounding variables): 0.14 (95% CI, 0.11–0.18) (n=25) vs. 0.22 (95% CI, 0.20–0.23) (n=166); p<0.0001 Amblyopia A: interocular difference in acuity ≥0.2 logMAR (2 lines on chart) Amblyopia B: visual acuity in amblyopic eye 0.3 logMAR or worse (6/12 or worse) Amblyopia C: visual acuity in amblyopic eye 0.18 logMAR or worse (6/9 or worse) | Fair

Abbreviations: NR=not reported; CI=confidence interval; LogMAR=logarithmic minimum angle of resolution; OR=odds ratio; RR=relative risk.

Three poor-quality retrospective cohort studies found that preschool vision screening was associated with lower likelihood of school-age vision impairment compared with no preschool vision screening (Table 6, Appendix B1).51–53 Compared with no screening, one study found that a complete ophthalmologic exam at ages 1 to 2.5 years was associated with lower risk for amblyopia after ages 5.5 to 7 years (amblyopia: RR, 0.39 [95% CI, 0.17–0.87]; amblyopia with visual acuity worse than 20/60: RR, 0.07 [95% CI, 0.01–0.57]).51 One study found that visual acuity testing by a school nurse 6 to 12 months prior to school entry was associated with lower risk for at least mild vision impairment upon school entry (RR, 0.68 [95% CI, 0.52–0.89]);52 and one study found that visual acuity testing by a school nurse at age 4 years was associated with lower risk for newly diagnosed vision disorder, amblyopia, or strabismus at age 7 years (RR, 0.15 [95% CI, 0.08–0.31]).53 Besides use of a retrospective design, major methodological shortcomings in these studies were failure to adjust for potential confounders and varying duration of follow-up within the same study. No study evaluated school performance or other functional outcomes.

## Key Question 1a Does Effectiveness of Vision Screening in Children Ages 1–5 Years Vary in Different Age Groups?

### Summary

No randomized trial compared outcomes of preschool vision screening in different age groups. In one randomized trial, screening was initiated earlier in one group (age 8 months) compared with the control group (age 37 months), but it is not possible to determine whether differences in outcomes should be attributed to the earlier age at which screening was started or to the increased frequency of screening that also took place. One poor-quality retrospective cohort study found no difference between screening at ages 2 to 4 years versus screening prior to age 2 years in risk for at least mild vision impairment, but estimates were imprecise and based on a very small sample of children screened. One retrospective cohort study found that the rate of false-positive screening examinations was about twice as high in children screened at age 1.5 years compared with those screened at age 3.5 years, but did not address other clinical outcomes.

### Evidence

No randomized trial directly evaluated effectiveness of screening at different age groups in preschool-aged children. The ALSPAC randomized trial initiated screening earlier (at age 8 months) in an intensive screening group compared with a one-time screening group (at age 37 months), but it is not possible to determine if differences in outcomes should be attributed to the age at which screening was started or the enhanced frequency of screening in the intensive screening group (Table 5, Appendixes B1 and B2).48, 49 One poor-quality retrospective cohort study of Alaskan children found no significant difference in risk for at least mild vision impairment (visual acuity worse than 20/40) between screening at ages 2 to 4 years and screening prior to age 2 years after 2 to 10 years of follow-up, but estimates were imprecise (RR, 3.10 [95% CI, 0.72–13]) (Table 7).54 In addition, this study only reported outcomes for 94 children from over a total of 10,000 screened by the age of 4 years, and did not adjust for potential confounders. One retrospective cohort study found that the rate of false-positives was about twice as high (25 percent vs. 13 percent) in children screened at age 1.5 years compared with those screened at age 3.5 years (screening included the cover-uncover test, a stereoacuity test, photorefraction, plus visual acuity testing in children age 3.5 years), but did not address other clinical outcomes.55

Table 7 Controlled Observational Studies of Vision Screening in Different Preschool Age Groups

Study, year, study design | Number of treatment and control subjects | Subject age, sex, diagnosis | Country and setting | Screening intervention | Results | Quality score
Kirk et al, 2008^54^ Retrospective cohort study | # approached and eligible: 10,620 screened # enrolled: 94 (58 screened between ages 2 and 4 years; 36 screened prior to age 2 years) Loss to follow-up: NR | Age: mean, 10.2 years Sex: NR Diagnosis: All referred for an abnormal screening examination | United States Preschool screening | Photoscreener, Inc. (previously MTI Photoscreener), administered by community lay screener | Screening between 2 and 4 years vs. screening prior to 2 years Relative risk for at least mild vision impairment (visual acuity 20/40 or worse) at follow-up: 17% (10/58) vs. 6% (2/36); RR, 3.10 (95% CI, 0.72–13.4) | Poor

Abbreviations: NR=not reported; CI=confidence interval; MTI=Medical Technologies, Inc.; RR=relative risk.

## Key Question 2 What is the Accuracy and Reliability of Risk Factor Assessment for Identifying Children Ages 1–5 Years at Increased Risk for Vision Impairment?

### Summary

No study evaluated the accuracy or reliability of using demographic or clinical features to identify children at higher risk for vision impairment prior to screening, and no study evaluated outcomes of targeted versus universal preschool vision screening.

### Evidence

Targeted screening of higher-risk children could be more efficient at identifying those with vision impairment compared with strategies that screen all children, but could also result in more missed diagnoses. No study evaluated the accuracy or reliability of using demographic or clinical features to identify patients at higher risk for vision impairment prior to screening, and no study evaluated yield or outcomes of targeted versus universal preschool vision screening.

## Key Question 3 What is the Accuracy of Screening Tests for Vision Impairment in Children Ages 1–5 Years?

### Summary

Thirty-one studies evaluated the diagnostic accuracy of various preschool vision screening tests. Four studies evaluated visual acuity tests (Lea symbols and HOTV tests), three evaluated stereoacuity tests (Random Dot E and Randot Stereo Smile II tests), one evaluated the cover-uncover test, four evaluated some combination of clinical examination screening tests, 12 evaluated autorefractors, and 15 evaluated photoscreeners. Diagnostic accuracy estimates for all of these screening tests suggest utility for identification of children at higher risk for amblyogenic risk factors or specific visual conditions, though no test was consistently associated with both high (>90 percent) sensitivity and specificity. In the largest study to directly compare the diagnostic accuracy of different individual screening tests, the Vision in Preschoolers (VIP) study, 56 differences in likelihood ratio estimates among the various tests were generally small, with overlapping confidence intervals. Studies that evaluated combinations of clinical tests (visual acuity, stereoacuity, and ocular alignment) generally reported stronger likelihood ratios than studies that evaluated individual tests.

### Evidence

We identified 31 studies on accuracy of various preschool vision screening tests compared with a reference standard10–12, 57–85 (Appendixes B3 and B4). Cycloplegic refraction was included in the reference standard examination in all but five studies.10–12, 66, 68 No study was rated good quality. All studies had at least one methodological shortcoming, though the degree to which studies met quality criteria was variable. Four studies were rated overall as poor quality due to one or more serious methodological shortcomings,12, 63, 66, 73 and the other 23 studies were rated as fair quality. The most frequent shortcomings were exclusion of or failure to include noncompliant children or those with uninterpretable screening tests (10 of 26 studies met this criterion), failure to describe random or consecutive enrollment of subjects (11 studies met this criterion), high or unclear rate of screening failures (12 studies met this criterion), and failure to enroll a representative spectrum of subjects (14 studies met this criterion).

Nineteen studies evaluated children recruited from pediatric ophthalmology clinics.58, 59, 62–64, 66–70, 72, 73, 76, 77, 79, 80, 83–85 In these studies, the median prevalence of amblyogenic risk factors was 48 percent (range, 6 to 81 percent),58, 59, 62, 66, 67, 69, 70, 72, 73, 76, 77, 79, 80, 84 and the prevalence of other target vision conditions (variously defined) ranged from 3 to 55 percent.64, 68, 83, 85 In eight studies of children recruited from primary care, community, or school settings, the median prevalence of amblyogenic risk factors was 12 percent (range, 2 to 20 percent) in five studies11, 57, 65, 71, 78 and the prevalence of amblyopia was 2 percent in three studies.10, 12, 60 Two studies evaluated Native American preschool-aged children enrolled in Head Start with a high prevalence of astigmatism and refractive error.74, 75 The large (n=2,588) VIP study preferentially enrolled children from Head Start with at least one of four target conditions (amblyopia, amblyogenic risk factors, reduced visual acuity, or strabismus) on a screening evaluation (prevalence of amblyopia: 3 percent; prevalence of any of the target conditions: 29 percent).82, 86

In addition to its large sample, the VIP study is uniquely informative because it directly compared the diagnostic accuracy of 10 different screening tests (noncycloplegic retinoscopy was also evaluated, but is not included in this review).82, 86 One issue in the methodological design of the VIP study is that abnormal screening results were not predefined for most screening tests. Rather, after data had been collected, sensitivities for different screening tests were calculated based on cutoffs necessary to achieve specificities of 0.90 or 0.94. An advantage of this approach is that it may facilitate comparisons of diagnostic accuracy across different screening tests since the specificities are roughly equal. A potential disadvantage is that screening cutoffs were determined on a post-hoc basis, which could overestimate accuracy. The main results of the VIP study may not be directly compared with the results of most other studies since it evaluated diagnostic accuracy for a broader range of target conditions, rather than just amblyopia and/or amblyogenic risk factors.

Visual acuity screening. Four fair-quality studies evaluated visual acuity testing with crowded Lea symbols in preschool-aged children (Table 8, Appendixes B3 and B4).59, 74, 75, 82 In the VIP study, an abnormal screening result on the Lea symbols test moderately increased the likelihood of detecting any of the four target visual conditions (PLR, 6.1 [95% CI, 4.8–7.6]), and a normal screening result weakly decreased the likelihood (NLR, 0.42 [95% CI, 0.38–0.50]) when screening thresholds were set to achieve specificities of 0.90.^82^ Results were similar when screening cutoffs were revised to achieve specificities of 0.94 (PLR, 8.2 [95% CI, 6.1–11]; NLR, 0.54 [95% CI, 0.49–0.60]).86 A smaller (n=149) study of children recruited from a pediatric ophthalmology clinic reported moderate to strong PLRs (5.7 [95% CI, 3.8–8.6] and 12 [95% CI, 5.8–24]) and NLRs (0.05 [95% CI, 0.01–0.36] and 0.23 [95% CI, 0.11–0.51]) for amblyogenic risk factors, depending on the cutoff used to define an abnormal screening result.59 Two other studies evaluated Native American children. One study found that abnormal Lea symbols screening results very weakly increased the likelihood of significant refractive error in preschoolers with astigmatism (PLR, 1.6 [95% CI, 1.4–1.9]),74 and another study found that abnormal Lea symbols screening results very weakly increased the likelihood of astigmatism (PLR, 1.9 [95% CI, 1.6–2.2]) in a population with high astigmatism prevalence (48 percent).75

Table 8 Diagnostic Accuracy of Visual Acuity Tests, Stereoacuity Tests, Strabismus Tests, and Combinations of Clinical Tests

Study, year | Screening test (reference standard) | Sensitivity (95% CI) | Specificity (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Quality score
Visual Acuity Tests
Bertuzzi et al, 2006^59^ | LEA symbols visual acuity test (comprehensive eye examination with cycloplegic refraction) | A. 0.96 (0.78–1.0); B. 0.78 (0.56–0.92) | A. 0.83 (0.75–0.90); B. 0.93 (0.87–0.97) | A. 5.7 (3.8–8.6); B. 12 (5.8–24) | A. 0.05 (0.01–0.36); B. 0.23 (0.11–0.51) | Fair
Miller et al, 1999^74^ | LEA symbols visual acuity test (cycloplegic refraction and retinoscopy) | 0.91 (0.82–0.96) | 0.44 (0.37–0.52) | 1.6 (1.4–1.9) | 0.21 (0.10–0.43) | Fair
Miller et al, 2001^75^ | LEA symbols visual acuity test (cycloplegic refraction) | 0.93 (0.87–0.97) | 0.51 (0.44–0.57) | 1.9 (1.6–2.2) | 0.14 (0.08–0.27) | Fair
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Crowded linear LEA symbols visual acuity test; A. 10/32 for age 3 years, 10/20 for ages 4 and 5 years; B. 10/32 for age 3 years, 10/25 for age 4 years, 10/20 for age 5 years^*^ (comprehensive eye examination with cycloplegic refraction) | Any condition; A. 0.61 (0.56–0.66); B. 0.49 (0.44–0.54); “Very important to detect and treat early” conditions; A. 0.77 (0.69–0.84); B. 0.65 (0.56–0.73) | Any condition; A. 0.90 (0.88–0.92); B. 0.94 (0.92–0.96) | Any condition; A. 6.1 (4.8–7.6); B. 8.2 (6.1–11) | Any condition; A. 0.43 (0.38–0.50); B. 0.54 (0.49–0.60) | Fair
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Crowded linear HOTV visual acuity test; A. 10/25 for ages 3 and 4 years, 10/20 for age 5 years; B. 10/32 for ages 3 and 4 years, 10/25 for age 5 years^*^ (comprehensive eye examination with cycloplegic refraction) | Any condition; A. 0.54 (0.49–0.59); B. 0.36 (0.31–0.41); “Very important to detect and treat early” conditions; A. 0.72 (0.64–0.79); B. 0.48 (0.40–0.57) | Any condition; A. 0.89 (0.87–0.91); B. 0.93 (0.91–0.95) | Any condition; A. 4.9 (3.9–6.1); B. 5.1 (3.8–6.8) | Any condition; A. 0.52 (0.46–0.58); B. 0.69 (0.63–0.74) | Fair
Chang et al, 2007^60^ | A1 Distance visual acuity worse than 0.5 at age 3 years, 0.6 at age 4 years, 0.7 at age 5 years, and 0.8 at age 6 years; A2 Distance visual acuity worse than 0.7 at age 3 years, 0.8 at age 4 years, 0.9 at age 5 years, and 1.0 at age 6 years; B Near visual acuity worse than 0.7 at age 3 years, 0.8 at age 4 years, 0.9 at age 5 years, and 1.0 at age 6 years (comprehensive eye examination with cycloplegic refraction) | A1 0.75^†^; A2 0.84^†^; B 0.49^†^ | A1 0.91^†^; A2 0.69^†^; B 0.92^†^ | A1 8.1^†^; A2 2.7^†^; B 6.4^†^ | A1 0.28^†^; A2 0.24^†^; B 0.55^†^ | Fair
Chang et al, 2007^60^ | NTU random dot stereogram (comprehensive eye examination with cycloplegic refraction) | 0.20^†^ | 0.98^†^ | 11.4^†^ | 0.81^†^ | Fair
Hope et al, 1990^68^ | Random dot E stereogram (comprehensive eye examination with cycloplegic refraction for abnormal random dot E stereogram, visual acuity test, or near cover test; otherwise visual acuity screening or near cover test) | 0.89 (0.52–1.0) | 0.76 (0.68–0.82) | 3.6 (2.5–5.2) | 0.15 (0.02–0.94) | Fair
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Random dot E stereoacuity test; A. Nonstereo card for age 3 years, stereo card at 50 cm for age 4 years, stereo card at 100 cm for age 5 years; B. Nonstereo card for ages 3 and 4 years, stereo card at 50 cm for age 5 years (comprehensive eye examination with cycloplegic refraction) | Any condition; A. 0.42 (0.37–0.47); B. 0.22 (0.18–0.27); “Very important to detect and treat early” conditions; A. 0.59 (0.50–0.67); B. 0.30 (0.22–0.38) | Any condition; A. 0.90 (0.88–0.92); B. 0.92 (0.90–0.94) | Any condition; A. 4.2 (3.3–5.3); B. 2.7 (2.0–3.7) | Any condition; A. 0.65 (0.59–0.71); B. 0.85 (0.80–0.90) | Fair
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Stereo smile II stereoacuity test; A. 240-arc sec card for ages 3 and 4 years, 120-arc sec card for age 5 years; B. 480-arc sec card for ages 3 and 4 years, 240-arc sec card for age 5 years^†^ (comprehensive eye examination with cycloplegic refraction) | Any condition; A. 0.44 (0.39–0.49); B. 0.33 (0.28–0.38); “Very important to detect and treat early” conditions; A. 0.72 (0.65–0.79); B. 0.57 (0.50–0.64) | Any condition; A. 0.91 (0.89–0.93); B. 0.94 (0.92–0.95) | Any condition; A. 4.9 (3.9–6.1); B. 5.5 (4.2–7.3) | Any condition; A. 0.62 (0.56–0.67); B. 0.71 (0.66–0.76) | Fair
Cover-Uncover Test
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Cover-uncover test (comprehensive eye examination with cycloplegic refraction) | Any condition 0.16 (0.12–0.20) “Very important to detect and treat early” conditions 0.24 (0.17–0.32) | Any condition 0.98 (0.97–0.99) | Any condition 7.9 (4.6–14) | Any condition 0.86 (0.82–0.90) | Fair
Combined Clinical Examination Screening Tests
Barry et al, 2003^11^ | Visual inspection, cover-uncover test, eye motility and head posture exam, LEA symbols visual acuity test (second orthoptic examination using more stringent criteria, followed by ophthalmological examination for abnormal, missing, or inconsistent results) | 0.91 (0.71–0.99) | 0.94 (0.92–0.95) | 15 (11–19) | 0.10 (0.03–0.36) | Fair
Chui et al, 2004^61^ | LEA symbols visual acuity test, Frisby stereoacuity test, and external visual inspection (comprehensive eye examination with cycloplegic refraction) | 0.67 (0.41–0.87) <41 months: 0.75 (0.43–0.94) ≥41 months: 0.50 (0.12–0.88) | 0.86 (0.79–0.92) <41 months: 0.90 (0.52–0.82) ≥41 months: 0.95 (0.88–0.99) | 4.8 (2.8–8.4) <41 months: 2.4 (1.4–4.1) ≥41 months: 10 (3.0–36) | 0.39 (0.20–0.75) <41 months: 0.37 (0.13–1.0) >41 months: 0.53 (0.24–1.2) | Fair
Kennedy et al, 1995^71^ | Snellen E or Stycar graded balls visual acuity test and Titmus stereotest (comprehensive eye examination without cycloplegic refraction) | 0.09 (0.04–0.20) ‡ | 1.0 (0.99–1.0) ‡ | 17 (5.5–54) ‡ | 0.91 (0.84–0.99)^‡^ | Fair
Newman et al, 1999^12^ | Sheridan-Gardiner visual acuity; cover-uncover test; ocular movements and convergence; prism test; TNO screening plate; Snellen visual acuity (comprehensive eye examination) | 1.0 (0.78–1.0) | 0.93 (0.91–0.95) | 14 (10–19) | 0.03 (0.002–0.51) | Poor
Shallo-Hoffmann et al, 2004^80^ | LEA symbol and HOTV charts and Random dot E stereoacuity test (comprehensive eye examination with cycloplegic refraction) | 0.73 (0.13–0.98) § | 0.94 (0.90–0.96) § | 12 (4.7–28) § | 0.28 (0.03–2.4)^§^ | Fair

* Determined by cutoff to achieve specificity of 0.95.

† Raw data not provided, unable to calculate confidence intervals.

‡ Adjusted for verification bias, based on a 20% sample of negative screens.

§ Adjusted for verification bias, based on a 25% sample of negative screens.

Abbreviations: CI=confidence interval; cm=centimeters.

Few studies directly compared the diagnostic accuracy of different tests of visual acuity. In the VIP study, HOTV and Lea symbols visual acuity testing were associated with similar accuracy (HOTV: PLR for any visual condition, 4.9 [95% CI, 3.9–6.1]; NLR, 0.52 [95% CI, 0.46–0.58]) (Table 8, Appendixes B3 and B4).86 A large (n=5,232), fair-quality Taiwanese study reported similar accuracy for distance and near visual acuity screening, but did not specify which visual acuity tests were evaluated (Table 8, Appendixes B3 and B4).60

Stereoacuity screening. In three fair-quality studies of the Random Dot E test, the median PLR was 4.2 (range, 3.6–11.4) and the median NLR was 0.65 (range, 0.15–0.81) (Table 8, Appendixes B3 and B4).60, 68, 82 Some of the variability among studies could be due to differences in the target conditions evaluated. The PLR was strongest (11.4) and the NLR weakest (0.81) in a large Chinese study that focused on identification of amblyopia. The other two studies focused on identification of a broader group of visual conditions, including amblyogenic risk factors and simple refractive error (PLR, 4.2 and 3.6; NLR, 0.65 and 0.15).68, 82

The VIP study was the only study to directly compare the accuracy of two different stereoacuity tests. It found similar results for the Random Dot E and Randot Stereo Smile II tests (PLR, 4.2 [95% CI, 3.3–5.3] and 4.9 [95% CI, 3.9–6.1], respectively; NLR, 0.65 [95% CI, 0.59–0.71] and 0.62 [95% CI, 0.56–0.67], respectively) when screening cutoffs were set to achieve specificities of 0.90.^82^ Results were slightly worse for the Random Dot E stereoacuity test when screening cutoffs were set to achieve specificities of 0.94 (PLR, 2.7 [95% CI, 2.0–3.7] and NLR, 0.85 [95% CI, 0.80–0.90]), but similar for the Randot Stereo Smile II test.86

Cover-uncover test. The VIP study found heterotropia on the cover-uncover test moderately useful for identifying children with any visual condition (PLR, 7.9 [95% CI, 4.6–14]), but a normal result had a likelihood ratio just slightly less than 1 (NLR, 0.86 [95% CI, 0.82–0.90]) (Table 8, Appendixes B3 and B4).82 No other study evaluated the diagnostic accuracy of the cover-uncover test.

Autorefractors. Twelve studies (11 fair-quality10, 57, 64, 65, 69, 73–75, 79, 82, 85 and one poor-quality66) evaluated autorefractors (Table 9, Appendixes B3 and B4). Four fair-quality studies evaluated the Retinomax autorefractor.10, 74, 75, 82 In two studies, the median PLR was 3.4 (range, 1.9–6.1) and the median NLR was 0.38 (range, 0.35–0.41).10, 82 This included the VIP study, with a PLR of 6.1 (95% CI, 5.2–7.0) and NLR of 0.41 (95% CI, 0.37–0.45) for identifying any of four target visual conditions, based on screening cutoffs set to achieve a specificity of 0.90.^82^ Results were similar when screening cutoffs were revised to achieve a specificity of 0.94 (PLR, 8.7 [95% CI, 7.2–10] and NLR, 0.51 [95% CI, 0.47–0.55]).86 A second, fair-quality study found that the Retinomax was associated with weak likelihood ratios (PLR, 1.9 [95% CI, 1.4–2.6] and NLR, 0.35 [95% CI, 0.10–1.2]), but the reference standard was suboptimal (did not necessarily include cycloplegic refraction) and differed according to the results of a repeat screening examination.10 Two fair-quality studies in Native American populations found moderate to strong PLRs and strong NLRs for identification of significant refractive error in preschoolers with astigmatism (PLR, 6.7 [95% CI, 4.5–9.8] and NLR, 0.11 [95% CI, 0.05–0.22])74 or for identification of astigmatism in a high-prevalence (48 percent) population (PLR, 18 [95% CI, 10–34] and NLR, 0.08 [95% CI, 0.04–0.13]).75

Table 9 Diagnostic Accuracy of Autorefractors

Study, year | Screening test (reference standard) | Sensitivity (95% CI) | Specificity (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Quality score
Retinomax Autorefractors
Barry et al, 2001^10^ | Retinomax autorefractor (Second orthoptic examination [LEA single symbol test, cover-uncover test, eye motility, and abnormal head posture] followed by ophthalmological examination for abnormal, missing, or inconsistent results) | 0.80 (0.44–0.98) | 0.58 (0.53–0.62) | 1.9 (1.4–2.6) | 0.35 (0.10–1.2) | Fair
Miller et al, 1999^74^ | Retinomax K-Plus autorefractor (Cycloplegic refraction and retinoscopy) | 0.91 (0.82–0.96) | 0.86 (0.80–0.91) | 6.7 (4.5–9.8) | 0.11 (0.05–0.22) | Fair
Miller et al, 2001^75^ | Retinomax K-Plus autorefractor (Cycloplegic refraction) | 0.93 (0.88–0.96) | 0.95 (0.91–0.98) | 18.0 (10.0–34.0) | 0.08 (0.04–0.13) | Fair
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Retinomax autorefractor (Comprehensive eye examination with cycloplegic refraction) | Any condition; A. 0.64 (0.60–0.67); B. 0.52 (0.48–0.56)^‡^; “Very important to detect and treat early” conditions; A. 0.87 (0.84–0.91); B. 0.81 (0.77–0.85)^‡^ | Any condition; A. 0.90 (0.88–0.91); B. 0.94 (0.93–0.95)^‡^ | Any condition; A. 6.1 (5.2–7.0); B. 8.7 (7.2–10)^‡^ | Any condition; A. 0.41 (0.37–0.45); B. 0.51 (0.47–0.55)^‡^ | Fair
SureSight Autorefractors
Kemper et al, 2005^69^ | SureSight autorefractor (Comprehensive eye examination with cycloplegic refraction) | Overall: 0.85 (0.69–0.95) Age <3 years (n=80): 0.80 (0.44–0.97) Age 3–5 years (n=90): 0.88 (0.68–0.97) | Overall: 0.52 (0.40–0.63) Age <3 years: 0.41 (0.24–0.61) Age 3–5 years: 0.58 (0.42–0.71) | Overall: 1.8^*^ Age <3 years: 1.4^*^ Age 3–5 years: 2.1^*^ | Overall: 0.29^*^ Age <3 years: 0.49^*^ Age 3–5 years: 0.21^*^ | Fair
Rogers et al, 2008^79^ | SureSight autorefractor Comprehensive eye examination with cycloplegic refraction | A. (manufacturer criteria): 0.97 (0.88–1.0); B. (VIP 90% specificity criteria): 0.79 (0.67–0.89); C. (VIP 94% specificity criteria): 0.67 (0.54–0.79); D. (Rowatt et al criteria): 0.62 (0.48–0.74) | A. 0.38 (0.24–0.54); B. 0.64 (0.48–0.78); C. 0.69 (0.53–0.82); D. 0.74 (0.58–0.86) | A. 1.6 (1.2–2.0); B. 2.2 (1.4–3.4); C. 2.2 (1.3–3.5); D. 2.4 (1.4–4.1) | A. 0.09 (0.02–0.37); B. 0.32 (0.18–0.56); C. 0.47 (0.31–0.72); D. 0.51 (0.35–0.75) | Fair
Vision in Preschoolers Study Group (Phase I), 2004^82^ | SureSight autorefractor (Comprehensive eye examination with cycloplegic refraction) | Any condition; A1 (manufacturer criteria): 0.85 (0.81–0.88); A2 (VIP criteria): 0.63 (0.59–0.65); B (VIP criteria): 0.51 (0.46–0.56)^‡^; “Very important to detect and treat early” conditions; A1 0.96 (0.93–0.99); A2 0.81 (0.75–0.87); B 0.75 (0.69–0.81)^‡^ | Any condition; A1 0.62 (0.59–0.65); A2 0.90 (0.88–0.92); B 0.94 (0.92–0.95)^‡^ | Any condition; A1 2.2 (2.0–2.4); A2 6.3 (5.2–7.7); B 8.6 (6.6–11)^‡^ | Any condition; A1 0.24 (0.19–0.30); A2 0.41 (0.36–0.47); B 0.52 (0.47–0.58)^‡^ | Fair
Plusoptix Autorefractors
Arthur et al, 2008^57^ | Plusoptix/Power Refractor autorefractor (Comprehensive eye examination with cycloplegic refraction) | 0.83 (0.67–0.93) | 0.95 (0.92–0.98) | 18 (10–33) | 0.17 (0.08–0.36) | Fair
Dahlmann-Noor et al, 2009a64 | Plusoptix/Power Refractor autorefractor (Comprehensive eye examination with cycloplegic refraction) | Myopia: 0.88 (0.30–1.0) Hyperopia: 0.20 (0.10–0.35) Astigmatism: 0.75 (0.36–0.96) Anisometropia: 0.50 (0.31–0.69) | Myopia: 0.96 (0.89–0.99) Hyperopia: 0.99 (0.92–1.0) Astigmatism: 0.93 (0.86–0.97) Anisometropia: 0.87 (0.77–0.93) | Myopia: 21 (7.8–55) Hyperopia: 26 (1.6–450) Astigmatism: 11 (4.7–24) Anisometropia: 3.7 (1.9–7.1) | Myopia: 0.13 (0.01–1.7) Hyperopia: 0.81 (0.70–0.94) Astigmatism: 0.27 (0.08–0.89) Anisometropia: 0.58 (0.40–0.84) | Fair
Dahlmann- Noor et al, 2009b65 | Plusoptix/Power Refractor autorefractor (Orthoptist screening with distance acuity testing, cover test, extraocular movements, prism test, and Lang stereotest; comprehensive eye examination with cycloplegic refraction for abnormal autorefractor or orthoptist screening results) | 0.45 (0.29–0.62) | 1.0 (0.98–1.0) | 230 (14–3680) | 0.56 (0.42–0.74) | Fair
Ehrt et al, 2007^66^ | Plusoptix/Power Refractor autorefractor (Comprehensive eye examination with cycloplegic refraction) | 0.71 (0.59–0.82) | 0.78 (0.68–0.86) | 3.2 (2.2–4.9) | 0.37 (0.25–0.54) | Poor
Matta et al, 2008^73^ | Plusoptix/Power Refractor autorefractor (Comprehensive eye examination with cycloplegic refraction) | A. (manufacturer criteria): 0.98 (0.85–1.0); B. (revised criteria): 0.98 (0.85–1.0) | A. 0.68 (0.51–0.81); B. 0.88 (0.74–0.96) | A. 3.0 (1.9–4.7); B. 8.4 (3.7–19) | A. 0.04 (0.01–0.26); B. 0.03 (0.00–0.20) | Fair
Other Autorefractors
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Power Refractor autorefractor (now called the Plusoptix) (Comprehensive eye examination with cycloplegic refraction) | Any condition; A. 0.54 (0.49–0.59); B. 0.36 (0.31–0.41)^‡^; “Very important to detect and treat early” conditions; A. 0.72 (0.65–0.79); B. 0.56 (0.48–0.63)^‡^ | Any condition; A. 0.90 (0.88–0.92); B. 0.94 (0.92–0.95)^‡^ | Any condition; A. 5.4 (4.4–6.6); B. 6.0 (4.6–7.9)^‡^ | Any condition; A. 0.51 (0.46–0.57); B. 0.68 (0.63–0.73)^‡^ | Fair
Williams et al, 2000^85^ | Topcon PR2000 autorefractor (Comprehensive eye examination with cycloplegic refraction) | Spherical error: 0.50 (0.33–0.67)^†^ Anisometropia: 0.74 (0.52–0.90)^†^ Astigmatism: 0.47 (0.28–0.66)^†^ | Spherical error: 0.95 (0.90–0.98)^†^ Anisometropia: 0.95 (0.91–0.98)^†^ Astigmatism: 0.96 (0.92–0.99)^†^ | Spherical error: 9.6 (4.5–20)^†^ Anisometropia: 15 (7.5–32)^†^ Astigmatism: 12 (5.2–30)^†^ | Spherical error: 0.53 (0.38–0.73)^†^ Anisometropia: 0.27 (0.14–0.55)^†^ Astigmatism: 0.55 (0.40–0.78)^†^ | Fair

* Unable to calculate confidence intervals, raw data not provided.

† Results based on cutoffs to obtain specificity of at least 95%.

‡ Results based on cutoffs to obtain specificity of 94%.

Abbreviations: CI=confidence interval

Three fair-quality studies found that abnormal results on the SureSight autorefractor, based on the manufacturer’s referral criteria, very weakly to weakly increased the likelihood of the target visual condition (median PLR, 2.2 [range, 1.6 to 2.2]), though normal results strongly to moderately decreased the likelihood (median NLR, 0.24 [range, 0.09 to 0.29]).69, 79, 82 In the VIP study, PLRs improved when definitions for a positive screening examination were modified to attain a specificity of 0.90 or 0.94 (6.3 [95% CI, 5.2–7.7]82 and 8.6 [95% CI, 6.6–11],86 respectively), with a relatively small decrease in NLRs (0.41 [95% CI, 0.36–0.47] and 0.52 [95% CI, 0.47–0.58], respectively). However, in another study, in lieu of manufacturer’s referral criteria, neither application of the VIP study’s 90 percent or 94 percent specificity referral criteria improved diagnostic accuracy (PLR, 2.2 [95% CI, 1.4–3.4] and NLR, 0.32 [95% CI, 0.18–0.56]; and PLR, 2.2 [95% CI, 1.3–3.5] and NLR, 0.47 [95% CI, 0.31–0.77], respectively).79

Six studies of the PlusOptix (previously the Power Refractor) autorefractor showed wide variability in diagnostic accuracy estimates.57, 64–66, 73, 82 One study66 was rated poor quality and the remainder were rated fair quality. In five studies that evaluated diagnostic accuracy for detection of amblyogenic risk factors (two studies65, 82 also included nonamblyogenic refractive error), the median PLR was 5.4 (range, 3.0–230) and the median NLR was 0.17 (range, 0.04–0.56).57, 65, 66, 73, 82 In the VIP study, similar results were obtained based on a screening cutoff to achieve a specificity of 0.90 (PLR, 5.4 [95% CI, 4.4–6.6] and NLR, 0.51 [95% CI, 0.46–0.57])82 and when screening cutoffs were modified to achieve a specificity of 0.94.^86^ Excluding the poor-quality study66 did not reduce variability in likelihood ratio estimates. One fair-quality study was an outlier, with a PLR of 230 (95% CI, 14 to 3,680).64 Specificity was 100 percent (252/252) in this study, but children with negative screening results did not undergo cycloplegic refraction unless they also failed an orthoptist examination (visual acuity, cover-uncover, extraocular movements, prism, and stereoacuity tests). One study reported an improved PLR (from 3.0 to 8.4) when the manufacturer’s referral criteria were modified to enhance specificity.73

The TopCon autorefractor was evaluated in one fair-quality study of children recruited from pediatric ophthalmology clinics.85 It found strong PLRs for impaired visual acuity, anisometropia, and astigmatism (range, 10.0 to 14.8) but weak NLRs (range, 0.28 to 0.55).

Only the VIP study directly compared the diagnostic accuracy of different autorefractors.82, 86 It found slightly stronger likelihood ratios for the Retinomax and SureSight autorefractors compared with the Power Refractor when the manufacturer’s referral criteria for the SureSight instrument were replaced with criteria to achieve a specificity of 0.90 or 0.94.

Photoscreeners. 15 studies (13 fair-quality58, 62, 67, 70–72, 75, 77–79, 81, 83, 84 and two poor-quality63, 76) evaluated the diagnostic accuracy of photoscreeners (Table 10, Appendixes B3 and B4). Eight studies evaluated the Medical Technologies, Inc. (MTI) photoscreener.58, 63, 75, 78, 79, 81, 83, 84 In seven studies, the median PLR was 6.2 (range, 2.4–8.7) and the median NLR was 0.26 (range, 0.06–0.67) for identification of amblyogenic risk factors.58, 63, 75, 78, 79, 81, 83, 84 Estimates from the VIP study fell within the observed range (PLR, 6.2 [95% CI, 2.7–8.1] and NLR, 0.67 [95% CI, 0.62–0.72]), even though the VIP study also evaluated nonamblyopic refractive error and primarily enrolled black (48 percent) or Hispanic (22 percent) children, in whom photoscreening images are typically more difficult to read because they have darker eyes.82, 88 Excluding the poor-quality study63 did not reduce the variability in likelihood ratios, nor did stratification of studies according to whether they evaluated pediatric ophthalmology populations or nonspecialty populations. There was also no clear correlation between prevalence of detected conditions and likelihood ratio estimates. One study of Native American children found that the MTI photoscreener was associated with a PLR of 2.3 (95% CI, 1.8–2.9) and a NLR of 0.48 (95% CI, 0.38–0.60) for identification of astigmatism (prevalence, 48 percent).75

Table 10 Diagnostic Accuracy of Photoscreeners

Study, year | Screening test (Reference standard) | Sensitivity (95% CI) | Specificity (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Quality score
MTI Photoscreener
Berry et al, 2001^58^ | MTI photoscreener (Comprehensive eye examination with cycloplegic refraction) | 0.83 (0.61–0.95) | 0.68 (0.48–0.84) | 2.6 (1.4–4.5) | 0.26 (0.10–0.65) | Fair
Cooper et al, 1999^63^ | MTI photoscreener (Comprehensive eye examination with cycloplegic refraction) | Reader 1: 0.56 (0.42–0.70) Reader 2: 0.68 (0.54–0.80) | Reader 1: 0.80 (0.65–0.90) Reader 2: 0.86 (0.70–0.95) | Reader 1: 2.8 (1.5–5.2) Reader 2: 4.9 (2.1–11) | Reader 1: 0.55 (0.39–0.77) Reader 2: 0.37 (0.25–0.56) | Poor
Miller et al, 2001^75^ | MTI photoscreener (Cycloplegic refraction) | 0.66 (0.59–0.73)^*^ | 0.71 (0.64–0.78)^*^ | 2.3 (1.8–2.9)^*^ | 0.48 (0.38–0.60)^*^ | Fair
Ottar et al, 1995^78^ and Donahue et al, 2002^87^ | MTI photoscreener (Comprehensive eye examination with cycloplegic refraction) | Any amblyogenic risk factor: 0.82 (0.76–0.87) Higher magnitude amblyogenic risk factor: 0.50 (0.39–0.61) | Any amblyogenic risk factor: 0.91 (0.88–0.93) Higher magnitude amblyogenic risk factor: 0.98 (0.97–0.99) | Any amblyogenic risk factor: 8.7 (6.9–11) Higher magnitude amblyogenic risk factor: 33 (18–58) | Any amblyogenic risk factor: 0.20 (0.15–0.27) Higher magnitude amblyogenic risk factor: 0.51 (0.41–0.63) | Fair
Rogers et al, 2008^79^ | MTI photoscreener (Comprehensive eye examination with cycloplegic refraction) | 0.95 (0.86–0.99) | 0.88 (0.74–0.96) | 8.0 (3.5–18) | 0.06 (0.02–0.18) | Fair
Tong et al, 2000^83^ | MTI Photoscreener (Comprehensive eye examination with cycloplegic refraction) | All photographs: 0.56 (0.50–0.62) Informative subset of 313 photographs: 0.65 (0.59–0.71) | All photographs: 0.91 (0.84–0.96) Informative subset of 313 photographs: 0.87 (0.76–0.94) | All photographs: 6.4 (3.4–12) Informative subset of 313 photographs: 4.9 (2.6–9.1) | All photographs: 0.48 (0.42–0.56) Informative subset of 313 photographs: 0.40 (0.33–0.47) | Fair
Vision in Preschoolers Study Group (Phase I), 2004^82^ | MTI photoscreener (Comprehensive eye examination with cycloplegic refraction) | Any condition: 0.37 (0.32–0.42) “Very important to detect and treat early” conditions: 0.55 (0.48–0.63) Amblyopia: 0.64 (0.54–0.74) Reduced visual acuity: 0.24 (0.16–0.31) Strabismus: 0.65 (0.53–0.76) Refractive error: 0.42 (0.37–0.48) | Any condition 0.94 (0.92–0.95) | Any condition 6.2 (4.7–8.1) | Any condition 0.67 (0.62–0.72) | Fair
Weinand et al, 1998^84^ | MTI photoscreener (Comprehensive eye examination with cycloplegic refraction) | Pediatrician interpreter: 0.94 (0.86–0.98) Orthoptist interpreter: 0.80 (0.69–0.88) Ophthalmologist 1 interpreter: 0.72 (0.61–0.82) Ophthalmologist 2 interpreter: 0.86 (0.76–0.92) | Pediatrician interpreter: 0.42 (0.20–0.66) Orthoptist interpreter: 0.74 (0.49–0.91) Ophthalmologist 1 interpreter: 0.74 (0.49–0.91) Ophthalmologist 2 interpreter: 0.58 (0.34–0.80) | Pediatrician interpreter: 1.6 (1.1–2.4) Orthoptist interpreter: 3.0 (1.4–6.5) Ophthalmologist 1 interpreter: 2.8 (1.3–5.9) Ophthalmologist 2 interpreter: 2.0 (1.2–3.5) | Pediatrician interpreter: 0.14 (0.05–0.39) Orthoptist interpreter: 0.28 (0.17–0.46) Ophthalmologist 1 interpreter: 0.38 (0.24–0.58) Ophthalmologist 2 interpreter: 0.25 (0.13–0.48) | Fair
iScreen Photoscreener
Kennedy et al, 2000^72^ | iScreen photoscreener (Comprehensive eye examination with cycloplegic refraction [in patients <age 4 years]) | 0.92 (0.88–0.95) | 0.89 (0.83–0.94) | 8.6 (5.4–14) | 0.09 (0.06–0.13) | Fair
Vision in Preschoolers Study Group (phase I), 2004^82^ | iScreen photoscreener (Comprehensive eye examination with cycloplegic refraction) | Any condition: 0.37 (0.32–0.42) “Very important to detect and treat early” conditions: 0.57 (0.50–0.64) Amblyopia: 0.63 (0.52–0.72) Reduced visual acuity: 0.27 (0.20–0.36) Strabismus: 0.50 (0.38–0.62) Refractive error: 0.43 (0.38–0.49) | Any condition 0.94 (0.92–0.95) | Any condition 6.2 (4.7–8.1) | Any condition 0.67 (0.62–0.72) | Fair
Otago-Type Photoscreener
Kennedy et al, 1989^70^ | Otago-type photoscreener; non- commercial (Comprehensive eye examination with cycloplegic refraction) | Any condition: 0.94 (0.87–0.98) Strabismus: 0.91 (0.81–1.01) Refractive error: 0.89 (0.74–1.03) Strabismus + refractive error: 0.98 (0.93–1.02) | Any condition 0.94 (0.89–0.98) | Any condition 16 (8.2–32) | Any condition 0.06 (0.03–0.14) | Fair
Kennedy et al, 1995^71^ | Otago-type photoscreener; non-commercial (Comprehensive eye examination without cycloplegic refraction) | 0.46 (0.22–0.72)^†^ | 1.0 (0.99–1.0)^†^ | 110 (38–310)^†^ | 0.54 (0.33–0.89)^†^ | Fair
Molteno et al, 1993^76^ | Otago-type photoscreener; non-commercial (History, inspection, cover test, examination of ocular media and fundoscopy through undilated pupils; cycloplegic refraction, dilated fundoscopy, and orthoptic examination with any abnormalities) | 0.89 (0.86–0.91) | 0.61 (0.55–0.66) | 2.3 (2.0–2.6) | 0.18 (0.14–0.22) | Poor
Visiscreen Photoscreener
Cogen et al, 1992^62^ | Visiscreen 100 photoscreener (Comprehensive eye examination with cycloplegic refraction “when possible”) | 0.85 (0.55–0.98) | 0.94 (0.87–0.98) | 14 (6.3–32) | 0.16 (0.05–0.59) | Fair
Morgan et al, 1987^77^ | Visiscreen 100 photoscreener (Comprehensive eye examination with cycloplegic refraction) | 0.91 (0.76–0.98) | 0.74 (0.52–0.90) | 3.5 (1.7–7.0) | 0.12 (0.04–0.36) | Fair
Other Photoscreeners
Cooper et al, 1999^63^ | Fortune Optical VRB-100 photoscreener (Comprehensive eye examination with cycloplegic refraction) | Reader 1: 0.60 (0.47–0.73) Reader 2: 0.69 (0.54–0.80) | Reader 1: 0.76 (0.60–0.87) Reader 2: 0.86 (0.72–0.95) | Reader 1: 2.5 (1.4–4.3) Reader 2: 4.9 (2.3–10) | Reader 1: 0.52 (0.37–0.75) Reader 2: 0.37 (0.24–0.55) | Poor
Guo et al, 2000^67^ | Computer-photorefractor (Comprehensive eye examination with cycloplegic refraction) | 0.95 (0.90–0.98) | 0.90 (0.84–0.95) | 9.6 (5.7–16) | 0.06 (0.03–0.11) | Fair
Kennedy et al, 1989^70^ | Off-axis-type photoscreener; non-commercial (Comprehensive eye examination with cycloplegic refraction) | Any condition: 0.85 (0.76–0.91) Strabismus: 0.73 (0.58–0.88) Refractive error: 0.89 (0.74–1.03) Strabismus + refractive error: 0.91 (0.82–0.99) | Any condition 0.87 (0.80–0.92) | Any condition 6.5 (4.2–10) | Any condition 0.18 (0.11–0.28) | Fair

* Calculations based on n=379, median sensitivity and specificity.

† Extrapolated from 20% sample of negative screens.

The VIP study and one other fair-quality study of the iScreen photoscreener reported moderate PLRs (6.2 [95% CI, 4.7–8.1]82 and 8.6 [95% CI, 5.4–14],72 respectively). The NLR was very weak in the VIP study (0.67 [95% CI, 0.62–0.7]; prevalence of any visual condition, 29 percent),82 but strong in the other study (0.09 [95% CI, 0.06–0.13]; prevalence of amblyogenic risk factors, 64 percent).72

Two fair-quality studies of the Visiscreen 100 photoscreener reported weak to strong PLRs (PLR, 14 [95% CI, 6.3–32]; prevalence of any visual condition, 12 percent;62 PLR, 3.5 [95% CI, 1.7–7.0]; prevalence of any visual condition, 60 percent),77 though NLRs were similar at 0.16 and 0.12. Three fair-quality studies found that noncommercial Otago-type photoscreeners (constructed by the study investigators) were associated with widely variable PLRs (median, 16 [range, 2.3 to 110]) and NLRs (median, 0.18 [range, 0.06 to 0.54]) for identification of amblyogenic risk factors.70, 71, 76 One Chinese study (prevalence of amblyogenic risk factors, 56 percent) found that a computer-photoscreener was associated with strong likelihood ratios (PLR, 9.5; NLR, 0.06 [95% CI not calculable]).67

Three studies directly compared the diagnostic accuracy of different photoscreeners.63, 70, 82 The VIP study reported identical diagnostic accuracy for the MTI and iScreen photoscreeners.82 One study found an Otago-type photoscreener to be more accurate than an off-axis-type photoscreener, but both were noncommercial photoscreeners constructed by the investigators.70 The third study found nearly identical diagnostic accuracy for the Fortune Optical VRB-100 and MTI photoscreeners, but was rated poor quality, in part because it used a case-control design.63

Combinations of screening tests. Four fair-quality studies11, 61, 71, 80 and one poor-quality study12 evaluated the diagnostic accuracy of screening visual acuity, stereoacuity, and ocular alignment in combination, though the specific tests evaluated in the studies varied (Table 8, Appendixes B3 and B4). The median PLR was 14 (range, 4.8–17) and the median NLR was 0.28 (range, 0.03–0.91). In four of the five studies, PLRs were strong (11 to 17), though NLRs varied substantially (range, 0.10 to 0.91).11, 12, 71, 80 In the fifth study, the PLR was weaker (4.8 [95% CI, 2.8–8.4]), with an NLR of 0.39 (95% CI, 0.20–0.75).61 Reasons for the lower PLR in this study are unclear, as all four studies evaluated similar clinical examination components (visual acuity testing, stereoacuity testing, and external visual inspection) in lower-prevalence populations.

None of the above studies compared different combinations of screening tests or multiple tests compared with single tests. The VIP study found that addition of a test of ocular misalignment (unilateral cover testing, Stereo Smile II test, or MTI photoscreener) to a test of visual acuity or refractive error (Retinomax or SureSight autorefractor and crowded Lea symbols or HOTV tests) increased sensitivity for detection of strabismus by 6 to 31 percent compared with using the test of visual acuity or refractive error alone at a specificity of 90 percent, with little effect on sensitivity for other target conditions.89 Results were most consistent for the cover-uncover test (15 to 25 percent increase in sensitivity). One other study found that addition of crowded Lea symbols visual acuity testing to the Retinomax autorefractor did not improve diagnostic accuracy for astigmatism in a high-prevalence Native American population, compared with the Retinomax alone.74

Direct comparisons of different types of screening tests. Few studies directly compared the accuracy of different types of preschool vision screening tests. The VIP study directly compared diagnostic accuracy of 10 preschool vision screening tests included in this review.82 With screening cutoffs set to achieve specificities of 0.90, it found that the Random Dot E stereoacuity test, Stereo Smile II test, iScreen photoscreener, and MTI photoscreener had lower sensitivity compared with the Lea symbols or HOTV visual acuity tests, Retinomax autorefractor, SureSight autorefractor, and Power Refractor for detecting any visual condition, but differences in likelihood ratio estimates were generally small (Table 11, Appendixes B3 and B4). For example, PLRs for the Random Dot E stereoacuity test and the MTI photoscreener were 4.2 (95% CI, 3.3–5.3) and 6.2 (95% CI, 4.7–8.1) with NLRs of 0.65 (95% CI, 0.59–0.71) and 0.67 (95% CI, 0.62–0.72), respectively, compared with PLRs of 6.1 (95% CI, 4.8–7.6) and 6.1 (95% CI, 5.2–7.0) with NLRs of 0.43 (95% CI, 0.38–0.50) and 0.41 (95% CI, 0.37–0.45) for the Lea symbols visual acuity test and the Retinomax autorefractor, respectively. The cover-uncover test was associated with markedly lower sensitivity but higher specificity than the other tests, resulting in a higher PLR (7.9 [95% CI, 4.6–14]) and a very weak NLR (0.86 [95% CI, 0.82–0.92]). In contrast to the VIP study, a small (n=100) fair-quality study of children recruited from a pediatric ophthalmology clinic (amblyopia prevalence, 58 percent) found that the MTI photoscreener (PLR, 8.0 [95% CI, 3.5–18]; NLR, 0.06 [95% CI, 0.02–018]; DOR, 140 [95% CI, 26–840]) performed better than the SureSight autorefractor (PLR range, 1.6 to 24; NLR range, 0.06 to 0.51; DOR range, 4.6 to 17), regardless of which referral criteria were used to define abnormal SureSight screening results, though estimates were relatively imprecise.79

Table 11 Diagnostic Accuracy of Preschool Vision Screening Tests

Test | Target condition | Sensitivity (95% CI) | Specificity (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI)
VISUAL ACUITY TESTS
Crowded Lea Symbols Visual Acuity Test (4 studies)
VIP, 2004^82^ | Amblyogenic risk factors or significant nonamblyogenic refractive error | 0.61 (0.56–0.66)^*^ | 0.90 (0.88–0.92)^*^ | 6.1 (4.8–7.6)^*^ | 0.43 (0.38–0.50)^*^
Bertuzzi et al, 2006^59^ | Amblyogenic risk factors | 0.96 (0.78–1.0)^†^ | 0.83 (0.75–0.90)^†^ | 5.7 (3.8–8.6)^†^ | 0.05 (0.01–0.36)^†^
| | | Median (range) | 5.9 (5.7–6.1) | 0.15 (0.05–0.43)
Miller et al, 1999^74^ | Significant refractive error | 0.91 (0.82–0.96)^‡^ | 0.44 (0.37–0.52)^‡^ | 1.6 (1.4–1.9)^‡^ | 0.21 (0.10–0.43)^‡^
Miller et al, 2001^75^ | Astigmatism | 0.93 (0.87–0.97)^‡^ | 0.51 (0.44–0.57)^‡^ | 1.9 (1.6–2.2)^‡^ | 0.14 (0.08–0.27)^‡^
Crowded HOTV Visual Acuity Test (1 study)
VIP, 2004^82^ | Amblyogenic risk factors or significant nonamblyogenic refractive error | 0.54 (0.49–0.59)^*^ | 0.89 (0.87–0.91)^*^ | 4.9 (3.9–6.1)^*^ | 0.52 (0.46–0.58)^*^
STEREOACUITY TESTS
Random Dot E Stereogram (3 studies)
Chang et al, 2007^60^ | Amblyopia | 0.20^§^ | 0.98^§^ | 11.4^§^ | 0.81^§^
VIP, 2004^82^ | Amblyogenic risk factors or significant nonamblyogenic refractive error | 0.42 (0.37–0.47)^*^ | 0.90 (0.88–0.92)^*^ | 4.2 (3.3–5.3)^*^ | 0.65 (0.59–0.71)^*^
Hope et al, 1990^68^ | Refractive error or strabismus | 0.89 (0.52–1.0) | 0.76 (0.68–0.82) | 3.6 (2.5–5.2) | 0.15 (0.02–0.94)
| | | Median (range) | 4.2 (3.6–11.4) | 0.65 (0.15–0.81)
Stereo Smile II Test (1 study)
VIP, 2004^82^ | Amblyogenic risk factors or significant nonamblyogenic refractive error | 0.44 (0.39–0.49)^*^ | 0.91 (0.89–0.93)^*^ | 4.9 (3.9–6.1)^*^ | 0.62 (0.56–0.67)^*^
OCULAR ALIGNMENT TESTS
Cover-Uncover Test (1 study)
VIP, 2004^82^ | Amblyogenic risk factors or significant nonamblyogenic refractive error | 0.16 (0.12–0.29) | 0.98 (0.97–0.99) | 7.9 (4.6–14.0) | 0.73 (0.15–0.85)
COMBINED CLINICAL TESTS (5 STUDIES)
Kennedy et al, 1995^71^ | Amblyogenic risk factors | 0.09 (0.04–0.20) | 1.0 (0.99–1.0) | 17 (5.5–54) | 0.91 (0.84–0.99)
Barry et al, 2003^11^ | Amblyopia or amblyogenic risk factors | 0.91 (0.71–0.99) | 0.94 (0.92–0.95) | 15 (11–19) | 0.10 (0.03–0.36)
Newman et al, 1999^12^ | Amblyopia | 1.0 (0.78–1.0) | 0.93 (0.91–0.95) | 14 (10–19) | 0.03 (0.002–0.51)
Shallo-Hoffman et al, 2004^80^ | Amblyogenic risk factors | 0.73 (0.13–0.98) | 0.94 (0.90–0.96) | 12 (4.7–28) | 0.28 (0.03–2.4)
Chui et al, 2004^61^ | Amblyogenic risk factors | 0.67 (0.41–0.87) | 0.86 (0.79–0.92) | 4.8 (2.8–8.4) | 0.39 (0.20–0.75)
| | | Median (range) | 14 (4.8–17) | 0.28 (0.03–0.91)
AUTOREFRACTORS
Retinomax (4 studies)
VIP, 2004^82^ | Amblyogenic risk factors or significant nonamblyogenic refractive error | 0.64 (0.60–0.67)^*^ | 0.90 (0.88–0.91)^*^ | 6.1 (5.2–7.0)^*^ | 0.41 (0.37–0.45)^*^
Barry et al, 2001^10^ | Amblyopia | | | 1.9 (1.4–2.6) | 0.35 (0.10–1.2)
| | | Median (range) | 3.4 (1.9–6.1) | 0.38 (0.35–0.41)
Miller et al, 1999^74^ | Significant refractive error | 0.91 (0.82–0.96)^‡^ | 0.86 (0.80–0.91)^‡^ | 6.7 (4.5–9.8)^‡^ | 0.11 (0.05–0.22)^‡^
Miller et al, 2001^75^ | Astigmatism | 0.93 (0.88–0.96)^‡^ | 0.95 (0.91–0.98)^‡^ | 18 (10–34)^‡^ | 0.08 (0.04–0.13)^‡^
Suresight (3 studies)
VIP, 2004^82^ | Amblyogenic risk factors or significant nonamblyogenic refractive error | 0.85 (0.81–0.88)\|\| 0.63 (0.59–0.65)^*,‡^ | 0.62 (0.59–0.65)\|\| 0.90 (0.88–0.92)^*,‡^ | 2.2 (2.0–2.4)\|\| 6.3 (5.2–7.4)^*,‡^ | 0.24 (0.19–0.30)\|\| 0.41 (0.36–0.47)^*,‡^
Kemper et al, 2005^69^ | Amblyogenic risk factors | 0.85 (0.69–0.95) | 0.52 (0.40–0.63) | 1.8^§^ | 0.29^§^
Rogers et al, 2008^79^ | Amblyogenic risk factors | 0.97 (0.88–1.0)\|\| 0.79 (0.67–0.89)^‡,¶^ | 0.38 (0.24–0.54)\|\| 0.64 (0.48–0.78)^‡,¶^ | 1.6 (1.2–2.0)\|\| 2.2 (1.4–3.4)^‡,¶^ | 0.09 (0.02–0.37)\|\| 0.32 (0.18–0.52)^‡,¶^
| | | Median (range) | 1.8 (1.6–2.2) \|\| | 0.24 (0.09–0.29) \|\|
Topcon PR 2000 (1 study)
Williams et al, 2000^85^ | Spherical error >3.75 D Anisometropia Astigmatism | 0.50 (0.33–0.67) 0.74 (0.52–0.90) 0.47 (0.28–0.66) | 0.95 (0.90–0.98) 0.95 (0.91–0.98) 0.96 (0.92–0.99) | 9.6 (4.5–20) 15 (7.5–32) 12 (5.2–30) | 0.53 (0.38–0.73) 0.27 (0.14–0.55) 0.55 (0.40–0.78)
Plusoptix/Power Refractor (6 studies)
Dahlmann-Noor et al, 2009b64 | Decreased visual acuity, strabismus, and ptosis | 0.45 (0.29–0.62) | 1.0 (0.98–1.0) | 230 (14–3680) | 0.56 (0.42–0.74)
Arthur et al, 2009^57^ | Amblyogenic risk factors | 0.83 (0.67–0.93) | 0.95 (0.92–0.98) | 18 (10–33) | 0.17 (0.08–0.36)
VIP, 2004^82^ | Amblyogenic risk factors or significant nonamblyogenic refractive error | 0.54 (0.49–0.59)^*^ | 0.90 (0.88–0.92)^*^ | 5.4 (4.4–6.6)^*^ | 0.51 (0.46–0.57)^*^
Ehrt et al, 2007^66^ | Amblyogenic risk factors | 0.71 (0.59–0.82) | 0.78 (0.68–0.86) | 3.2 (2.2–4.9) | 0.37 (0.25–0.54)
Matta et al, 2008^73^ | Amblyogenic risk factors | 0.98 (0.85–1.0) 0.98 (0.85–1.0) | 0.68 (0.51–0.81) 0.88 (0.74–0.96) | 3.0 (1.9–4.7)\|\| 8.4 (3.7–19)^*,‡^ | 0.04 (0.01–0.26)\|\| 0.03 (0.00–0.20)^*,‡^
| | | Median (range) | 5.4 (3.0–230) | 0.17 (0.04–0.56)
Dahlmann-Noor et al, 2009a64 | Myopia Hyperopia Astigmatism Anistometropia | 0.88 (0.30–1.0) 0.20 (0.10–0.35) 0.75 (0.36–0.96) 0.50 (0.31–0.69) | 0.96 (0.89–0.99) 0.99 (0.92–1.0) 0.93 (0.86–0.97) 0.87 (0.77–0.93) | 21 (7.8–55) 26 (1.6–450) 11 (4.7–24) 3.7 (1.9–7.1) | 0.13 (0.01–1.7) 0.81 (0.70–0.94) 0.27 (0.08–0.89) 0.58 (0.40–0.84)
PHOTOSCREENERS
MTI Photoscreener (8 studies)
Ottar et al, 1995^78^ and Donahue et al, 2002^87^ | Amblyogenic risk factors | 0.82 (0.76–0.87) | 0.91 (0.88–0.93) | 8.7 (6.9–11) | 0.20 (0.15–0.27)
Rogers et al, 2008^79^ | Amblyogenic risk factors | 0.95 (0.86–0.99) | 0.88 (0.74–0.96) | 8.0 (3.5–18) | 0.06 (0.02–0.18)
Tong et al, 2000^83^ | Amblyogenic risk factors | 0.56 (0.50–0.62) | 0.91 (0.84–0.96) | 6.4 (3.4–12) | 0.48 (0.42–0.56)
VIP, 2004^82^ | Amblyogenic risk factors or significant nonamblyogenic refractive error | 0.37 (0.32–0.42) | 0.94 (0.92–0.95) | 6.2 (4.7–8.1) | 0.67 (0.62–0.72)
Cooper et al, 1999^63^ | Amblyopia | 0.62 (range, 0.56–0.68)^#^ | 0.83 (range, 0.80–0.86)^#^ | 3.7 (range, 2.8–4.9)^#^ | 0.45 (range, 0.37–0.55)^#^
Berry et al, 2001^58^ | Amblyogenic risk factors | 0.83 (0.61–0.95) | 0.68 (0.48–0.84) | 2.6 (1.4–4.5) | 0.26 (0.10–0.65)
Weinand et al, 1998^84^ | Amblyogenic risk factors | 0.83 (range, 0.72–0.94)^#^ | 0.66 (range, 0.42–0.74)^#^ | 2.4 (range, 1.6–3.0)^#^ | 0.26 (range, 0.14–0.38)^#^
| | | Median (range) | 6.2 (2.4–8.7) | 0.26 (0.06–0.67)
Miller et al, 2001^75^ | Significant refractive error | 0.66 (0.59–0.73)^*^ | 0.71 (0.64–0.78)^*^ | 2.3 (1.8–2.9)^*^ | 0.48 (0.38–0.60)^*^
Ottar et al, 1995^78^ and Donahue et al, 2002^87^ | Higher magnitude amblyogenic risk factors | 0.50 (0.39–0.61) | 0.98 (0.97–0.99) | 33 (18–58) | 0.51 (0.41–0.63)
iScreen Photoscreener (2 studies)
Kennedy et al, 2000^72^ | Amblyogenic risk factors | 0.92 (0.88–0.95) | 0.89 (0.83–0.94) | 8.6 (5.4–14) | 0.09 (0.06–0.13)
VIP, 2004^82^ | Amblyogenic risk factors or significant nonamblyogenic refractive error | 0.37 (0.32–0.42) | 0.94 (0.92–0.95) | 6.2 (4.7–8.1) | 0.67 (0.62–0.72)
| | | Median (range) | 7.3 (6.2–8.6) | 0.25 (0.09–0.67)
Visiscreen 100 Photoscreener (2 studies)
Cogen et al, 1992^62^ | Amblyogenic risk factors | 0.85 (0.55–0.98) | 0.94 (0.87–0.98) | 14 (6.3–32) | 0.16 (0.05–0.59)
Morgan et al, 1987^77^ | Amblyogenic risk factors | 0.91 (0.76–0.98) | 0.74 (0.52–0.90) | 3.5 (1.7–7.0) | 0.12 (0.04–0.36)
| | | Median (range) | 7.0 (3.5–14) | 0.14 (0.12–0.16)
Fortune Optical VRB-100 Photoscreener (1 study)
Cooper et al, 1999^63^ | Amblyopia | 0.64 (range, 0.60–0.69)^#^ | 0.81 (range, 0.76–0.86)^#^ | 3.5 (range, 2.5–4.9)^#^ | 0.44 (range, 0.37–0.52)^#^
Computer Photoscreener (1 study)
Guo et al, 2000^67^ | Amblyogenic risk factors | 0.95 (0.90–0.98) | 0.90 (0.84–0.95) | 9.6 (5.7–16) | 0.06 (0.03–0.11)
Otago (Noncommercial) Photoscreener (3 studies)
Kennedy et al, 1995^71^ | Amblyogenic risk factors | 0.46 (0.22–0.72) | 1.0 (0.99–1.0) | 110 (38–310) | 0.54 (0.33–0.89)
Kennedy et al, 1989^70^ | Amblyogenic risk factors | 0.94 (0.87–0.98) | 0.94 (0.89–0.98) | 16 (8.2–32) | 0.06 (0.03–0.14)
Molteno et al, 1993^76^ | Amblyogenic risk factors | 0.89 (0.86–0.91) | 0.61 (0.55–0.66) | 2.3 (2.0–2.6) | 0.18 (0.14–0.22)
| | | Median (range) | 16 (2.3–110) | 0.18 (0.06–0.54)

* Based on 90% specificity.

† Based on 0.80 acuity score cutoff.

# Based on median results from multiple readers.

‡ Excluded from calculation of median.

§ Confidence intervals not calculable.

|| Based on manufacturer’s referral criteria.

¶ Based on VIP 90% specificity criteria.

Other evidence on comparative accuracy of different types of preschool vision screening is limited. One fair-quality study found that an Otago-type photoscreener was substantially more accurate than a combination of visual acuity and stereoacuity testing, but its applicability is limited because it evaluated a noncommercial device constructed by the study investigators.71 Two fair-quality studies compared preschool vision screening tests in Native American preschool-aged children.74, 75 One study found that the Retinomax autorefractor (PLR, 6.7 [95% CI, 4.5–9.8] and NLR, 0.11 [95% CI, 0.05–0.22]) was substantially more accurate than Lea symbols visual acuity testing (PLR, 1.6 [95% CI, 1.4–1.9] and NLR, 0.21 [95% CI, 0.10–0.43]) for identification of significant refractive error in children with astigmatism.74 The other study found that the Retinomax autorefractor (PLR, 18 [95% CI, 10–34] and NLR, 0.08 [95% CI, 0.04–13]) was substantially more accurate than the MTI photoscreener (PLR, 2.4; NLR, 0.5 [95% CI not calculable]) for identification of astigmatism in high-prevalence (48 percent) children.75

## Key Question 3a Does Accuracy of Screening Tests for Vision Impairment Vary in Different Age Groups in Children Ages 1–5 Years?

### Summary

Evidence on the comparative accuracy of preschool vision tests in different age groups among children ages 1 to 5 years is limited. Four studies found no clear differences in the diagnostic accuracy of various screening tests in preschool-aged children stratified according to age. Testability using common visual acuity tests, stereoacuity tests, photoscreening, and autorefractors generally exceeds 80 to 90 percent in children age 3 years, with small increases in testability rates through age 5 years. Four studies found substantially lower testability with the Random Dot E stereoacuity test, Lea symbols visual acuity test, and the SureSight autorefractor in children ages 1 to 3 years, compared with those ages 4 to 5 years. One large study of statewide screening with the MTI photoscreener by lay examiners found that testability was already 94 percent at age 1 year.

### Evidence

Evidence on the comparative accuracy of screening tests for vision impairment in different age groups among children ages 1 to 5 years is limited (Table 12, Appendixes B3 and B4).61, 69, 72, 83 Four studies found no clear differences in the diagnostic accuracy of various screening tests in preschool-aged children stratified according to age, though estimates were relatively imprecise. One study compared the accuracy of the SureSight autorefractor between children younger than 3 years and children ages 3 to 5 years;69 one compared the accuracy of the iScreen photoscreener between children ages 3 years or younger and children ages 4 to 6 years;72 and a third compared the accuracy of the MTI photoscreener in preschool-aged children stratified into age quartiles.83 A fourth study found no clear differences in the diagnostic accuracy of a battery of screening tests (Lea symbols test, Frisby stereoacuity test, and external visual inspection) between children younger than 41 months compared with those ages 41 months or older.61

Table 12 Diagnostic Accuracy of Screening Tests Stratified By Age

Study, year | Screening test | Sensitivity (95% CI) | Specificity (95% CI) | Positive likelihood ratio (95% CI)
Chui et al, 2004^61^ | LEA symbols visual acuity test, Frisby stereoacuity test, and external visual inspection | Overall: 0.67 (0.41–0.87) Age <41 months: 0.75 (0.43–0.94) Age ≥41 months: 0.50 (0.12–0.88) | Overall: 0.86 (0.79–0.92) Age <41 months: 0.90 (0.52–0.82) Age ≥41 months: 0.95 (0.88–0.99) | Overall: 4.8 (2.8–8.4) Age <41 months: 2.4 (1.4–4.1) Age ≥41 months: 10 (3.0–36)
Kemper et al, 2005^69^ | SureSight autorefractor | Overall: 0.85 (0.69–0.95) Age <3 years (n=80): 0.80 (0.44–0.97) Age 3–5 years (n=90): 0.88 (0.68–0.97) | Overall: 0.52 (0.40–0.63) Age <3 years: 0.41 (0.24–0.61) Age 3–5 years: 0.58 (0.42–0.71) | Overall: 1.8 Age <3 years: 1.4 Age 3–5 years: 2.1
Kennedy et al, 2000^72^ | iScreen photoscreener | Overall: 0.92 (0.88–0.95) Age ≤3 years: 1.0 Age 4–6 years: 0.92 | Overall: 0.89 (0.83–0.94) Age ≤3 years: 0.97 Age 4–6 years: 0.95 | Overall: 8.6 (5.4–14) Age ≤3 years: 33 Age 4–6 years: 18
Tong et al, 2000^83^ | MTI photoscreener | All photographs; informative subset of 313 photographs Any condition: 56% (159/284); 65% (159/245) Strabismus: 77% (131/170) Refractive error: 68% (123/181) | All photographs; informative subset of 313 photographs Any condition: 91% (94/103); 87% (59/68) | Informative subset of 313 photographs: 5.0
Chui et al, 2004^61^ | Overall: 0.39 (0.20–0.75) Age <41 months: 0.37 (0.13–1.0) Age >41 months: 0.53 (0.24–1.2) | Overall: 0.41 (0.24–0.61) Age <41 months: 0.41 (0.21–0.64) Age ≥41 months: 0.43 (0.10–0.82) | Overall: 0.95 (0.89–0.98) Age <41 months: 0.90 (0.74–0.98) Age ≥41 months: 0.96 (0.90–0.99) | Overall: 12 (3.6–45) Age <41 months: 6.5 (1.3–42) Age ≥41 months: 20 (1.8–180)
Kemper et al, 2005^69^ | Overall: 0.29 Age <3 years: 0.49 Age 3–5 years: 0.21 | Not calculable | Not calculable | Overall: 6.2 Age <3 years: 2.9 Age 3–5 years: 10
Kennedy et al, 2000^72^ | Overall: 0.09 (0.06–0.13) Age ≤3 years: not calculable Age 4–6 years: 0.08 | Overall: 0.94 (0.90–0.96) Age ≤3 years: 0.97 Age 4–6 years: 0.97 | Overall: 0.86 (0.80–0.91) | Overall: 100 (48–210) Age ≤3 years: not calculable Age 4–6 years: 220
Tong et al, 2000^83^ | Informative subset of 313 photographs: 0.40 | A. 0.95 (0.90–0.98); B. 0.95 (0.90–0.98) | A. 0.43 (0.36–0.50); B. 0.41 (0.33–0.49) | A. 13 (6.3–31); B. 12 (5.6–29)

Testability rates may provide additional information about the relative utility of screening tests in preschool-aged children at different ages. In general, testability was relatively high in children age 3 years, though small increases occurred through age 5 years in some studies for some screening tests. In the VIP study, Random Dot E testability was 86 percent in 3-year-olds and 93 percent in 5-year-olds,90 and HOTV and Lea symbols testability was over 95 percent at all ages between 3 and 5 years.91 Overall testability was nearly 100 percent for the Retinomax autorefractor, MTI photoscreener, Power Refractor II autorefractor, and the SureSight photoscreener.82 Most (93 percent) of the 3-year-olds in the VIP study were ages 42 to 47 months, so the applicability of these results to younger 3-year-olds is uncertain. Other smaller (n=777 and n=478) studies reported 85 to 92 percent testability for both HOTV and Lea symbols visual acuity testing in 3-year-olds compared with 97 to 100 percent in 4- or 5-year-olds.92, 93 In a study (n=1,052) that compared the MTI photoscreener with traditional screening (HOTV visual acuity testing, Random Dot E test, and cover-uncover test), testability rates for photoscreening were 77 percent in 3-year-olds and 87 percent in 4-year-olds compared with 85 percent and 94 percent, respectively, for traditional screening.94

Few large studies compared testability among children ages 1 to 3 years compared with those ages 3 to 5 years. In the available studies, testability of the most common vision screening tests was generally lower among younger preschool-aged children. One study (n=268) found that Random Dot E testability increased from 65 percent among 2-year-olds to 100 percent in 6-year-olds;80 another study (n=3,132) found that Random Dot E testability increased from 33 percent among children ages 30 to 36 months to 73 percent among children ages 37 to 48 months, and 96 percent among those ages 49 to 60 months.95 Another study (n=385) found that Lea symbols testability increased from 56 percent among children ages 31 to 36 months to 76 percent among children older than 36 months.96 Similarly, a fourth study (n=173) found that testability with the SureSight autorefractor increased from 49 percent among those younger than 3 years to 84 percent among those ages 3 years and older (p<0.001).69 On the other hand, a large (n=15,059) study of photoscreening in the state of Tennessee found that MTI photoscreener testability (administered by lay volunteers) was 94 percent among 1-year-olds, compared with 96 to 98 percent among those ages 2 to 5 years.38

## Key Question 4 What Are the Harms of Vision Screening in Children Ages 1–5 Years?

### Summary

Evidence on harms of preschool vision screening is limited. Although preschool vision screening is associated with potential psychosocial harms related to treatment, one large cohort study found a 50 percent reduction in odds of being bullied at age 7.5 years among children offered screening compared with those who were not offered screening. We identified no other studies on the psychosocial effects of screening.

In populations in which the prevalence of visual conditions is less than 10 percent, six of seven studies that performed the reference standard in all screened children (or a random subset) reported false-positive rates greater than 70 percent. One large study of a statewide preschool photoscreening program found that 20 percent of children with positive screening results who did not meet criteria for amblyopia (false-positives) were prescribed glasses. In about a quarter of cases, corrective lenses were prescribed even though the refractive error was clinically insignificant. No study evaluated the effects of unnecessary corrective lenses or treatment for amblyopia on long-term vision or functional outcomes.

### Evidence

Potential harms of preschool vision screening include psychosocial effects, such as labeling and anxiety, unnecessary referrals due to false-positive screening tests, or unnecessary use of corrective lenses or treatments to prevent amblyopia, with potential effects on long-term vision or function. Only one study evaluated potential psychosocial effects of screening. In the large ALSPAC population-based cohort, children offered screening at age 37 months reported a 50 percent decreased odds of being bullied at age 7.5 years, compared with those who were not offered screening.97 Benefits were observed among children who received patching treatment (adjusted OR, 0.39 [95% CI, 0.16 to 0.92]), but not among those treated with eyeglasses. We identified no other controlled studies on psychosocial effects of screening.

False-positive rates (1-positive predictive value) varied depending on the prevalence of the target condition in the population evaluated (Table 13). In populations with a prevalence of visual conditions less than 10 percent, six of seven studies that performed the reference standard in all children reported false-positive rates greater than 70 percent.10–12, 60, 68, 80 The screening tests evaluated included the Retinomax autorefractor,10 Random Dot E test,68 and various combinations of clinical screening tests.11, 12, 60, 80 The seventh study reported a false positive rate of 23 percent for a noncommercial Otago-type photoscreener and 46 percent for a combination of clinical screening tests.71 In studies with a prevalence of target visual conditions of at least 20 percent, false-positive rates ranged from 5 to 39 percent.58, 66, 67, 72, 77–79, 83, 84 In the VIP study (prevalence of any visual condition, 29 percent), false-positive rates ranged from 23 to 36 percent for 11 screening tests when screening cutoffs were set to achieve a specificity of 0.90.^82^

Table 13 Positive Predictive Values of Screening Tests

Study, year | Screening test | Age of enrollees | N | Proportion with condition | Positive predictive value (95% CI) | Negative predictive value (95% CI)
Barry et al, 2001^10^ | Retinomax autorefractor | 3 years | 404 | Amblyopia: 2.5% (10/404) | 0.05 (0.02–0.09) | 0.99 (0.97–1.0)
Barry et al, 2003^11^ | Visual inspection, cover-uncover test, eye motility and head posture exam, Lea symbols visual acuity test | 3 years | 1180 | Amblyopia or amblyogenic risk factors: 2.3% (26/1114) | 0.25 (0.16–0.36) | 1.0 (0.99–1.0)
Berry et al, 2001^58^ | MTI photoscreener | Preschool (subgroup) | 51 | Amblyogenic risk factors: 45% (23/51) | 0.68 (0.48–0.84) | 0.83 (0.61–0.95)
Bertuzzi et al, 2006^59^ | LEA symbols visual acuity test | 38 to 54 months | 149 | Amblyogenic risk factors: 16% (23/143) | A. 0.52 (0.36–0.68); B. 0.69 (0.48–0.86) | A. 0.99 (0.95–1.0); B. 0.96 (0.90–0.99)
Chang et al, 2007^60^ | A. Distance visual acuity; B. Near visual acuity; C. NTU random dot stereogram | Preschool | 5232 | Amblyopia: 2.20% (115/5232) | A1 0.12^*^; A2 0.04^*^; B 0.13^*^; C 0.17^*^ | A1 0.995^*^; A2 0.996^*^; B 0.988^*^; C 0.986^*^
Chui et al, 2004^61^ | LEA symbols visual acuity test, Frisby stereoacuity test, and external visual inspection | 35 to 58 months | 178 (141 completed evaluation) | Amblyogenic risk factors: 13% (18/141) | Overall: 0.41 (0.24–0.61) Age <41 months: 0.41 (0.21–0.64) Age ≥41 months: 0.43 (0.10–0.82) | Overall: 0.95 (0.89–0.98) Age <41 months: 0.90 (0.74–0.98) Age ≥41 months: 0.96 (0.90–0.99)
Cogen et al, 1992^62^ | Visiscreen 100 photoscreener | 6 months to 6 years | 127 | Any visual condition: 12% (13/113) Refractive error: 5% (6/113) Strabismus: 4% (5/113) Refractive error + strabismus: 1% (1/113) Media opacity: 1% (1/113) | 0.65 (0.38–0.86) | 0.98 (0.93–1.0)
Cooper et al, 1999^63^ | A. Fortune Optical VRB-100 photoscreener; B. MTI photoscreener | 12 to 44 months | 105 | 61 cases (amblyopia), 44 controls | A (reader 1): 0.76 (0.61–0.87); A (reader 2): 0.86 (0.72–0.95); B (reader 1): 0.78 (0.62–0.89); B (reader 2): 0.88 (0.74–0.96) | A (reader 1): 0.60 (0.46–0.72); A (reader 2): 0.69 (0.54–0.80); B (reader 1): 0.59 (0.46–0.72); B (reader 2): 0.65 (0.50–0.78)
Ehrt et al, 2007^66^ | Vision Screener video refractor | 0 to 7 years | 161 | Amblyogenic risk factors: 43% (70/161) | 0.71 (0.59–0.82) | 0.78 (0.68–0.86)
Guo et al, 2000^67^ | A. Computer-photorefractor; B. Noncycloplegic retinoscopy | 9 to 50 months | 300 | Amblyogenic risk factors: 56% (168/300) | A. 0.92 (0.87–0.96); B. 0.85 (0.79–0.90) | A. 0.93 (0.87–0.97); B. 0.82 (0.74–0.88)
Hope et al, 1990^68^ | Random dot E stereogram | 3 to 4 years | 176 | Refractive error or strabismus: 5% (9/168) Refractive error: 5% (9/168) Strabismus: 0.6% (1/168) | 0.17 (0.08–0.31) | 0.99 (0.96–1.0)
Kennedy et al, 1989^70^ | A. Otago-type photoscreener (noncommercial); B. Off-axis-type photoscreener (noncommercial) | 6 years or younger | 236 | Any amblyogenic risk factor: 42% (98/236) Strabismus only: 14% (33/236) Strabismus + refractive error or anisometropia: 18% (42/236) Refractive error or anisometropia: 8% (18/236) Anisocoria or lid tumor: 2% (5/236) | Any condition; A. 0.92 (0.85–0.96); B. 0.82 (0.73–0.89) | Any condition; A. 0.96 (0.91–0.98); B. 0.89 (0.82–0.94)
Kennedy et al, 1995^71^ | A. Otago-type photoscreener (noncommercial); B. Snellen E or Stycar graded balls visual acuity test and Titmus stereotest | Not reported | 264 | Any visual condition: 8% (21/264) Strabismus: 1.1% (3/264) Refractive error: 4.2% (11/264) Strabismus and refractive error: 0.8% (2/264) Structural: 0.4% (1/264) | A. 0.77 (0.60–0.95); B. 0.54 (0.28–0.81) | A. 0.98 (0.91–1.00); B. 0.94 (0.91–0.97)
Kennedy et al, 2000^72^ | iScreen photoscreener | 45% 6 years or younger | 449 | Amblyogenic risk factors: 64% (273/423) | Overall: 0.94 (0.90–0.96) Age ≤3 years: 0.97 Age 4–6 years: 0.97 | 0.86 (0.80–0.91)
Miller et al, 1999^74^ | A. LEA symbols visual acuity test; B. Retinomax K-Plus autorefractor | 3 to 5 years | 245 | Significant refractive error: 31% (76/245); all had astigmatism | A. 0.42 (0.35–0.50); B. 0.75 (0.65–0.83) | A. 0.92 (0.83–0.96); B. 0.95 (0.901–0.98)
Miller et al, 2001^75^ | A. LEA symbols visual acuity test; B. MTI photoscreener; C. Nidek KM-500 Keratometry screener; D. Retinomax K-Plus autorefractor | 3 to 5 years | 379 | Astigmatism ≥1.00 D: 48% (182/379) | A. 0.48 (0.41–0.54); B. 0.68 (0.60–0.75)^†^; C. 0.79 (0.73–0.84); D. 0.94 (0.90–0.97) | A. 0.93 (0.88–0.97); B. 0.70 (0.63–0.76)^†^; C. 0.94 (0.90–0.97); D. 0.94 (0.89–0.96)
Morgan et al, 1987^77^ | Visiscreen 100 photoscreener | 3 months to 8 years | 63 | Any visual condition: 60% (34/57) | 0.84 (0.68–0.94) | 0.85 (0.62–0.97)
Newman et al, 1999^12^ | Sheridan-Gardiner visual acuity; cover-uncover test; ocular movements and convergence; prism test; TNO screening plate; Snellen visual acuity | 3.5 years and at 5–6 years | Cohort of 936; data reported on 597 | Amblyopia: 2.5% (15/597) | 0.27 (0.16–0.41) | 1.0 (0.99–1.0)
Ottar et al, 1995^78^ and Donahue et al, 2002^87^ | MTI photoscreener | 6 to 59 months | 949 | Amblyogenic risk factors: 20% (192/949) | A. 0.69 (0.62–0.75); B. 0.77 (0.64–0.87)^‡^ | A. 0.95 (0.93–0.97); B. 0.95 (0.93–0.96)^‡^
Rogers et al, 2008^79^ | MTI photoscreener SureSight autorefractor | 1 to 6 years | 100 | Clinically significant amblyopia: 58% (58/100) | A. 0.68 (0.57–0.78); B. 0.75 (0.63–0.86); C. 0.75 (0.61–0.86); D. 0.77 (0.62–0.88); E. 0.92 (0.82–0.97) | A. 0.89 (0.65–0.99); B. 0.69 (0.52–0.83); C. 0.60 (0.45–0.74); D. 0.58 (0.44–0.72); E. 0.92 (0.80–0.98)
Shallo-Hoffmann et al, 2004^80^ | LEA symbol and HOTV charts, and random dot E stereoacuity test | 2 to 6 years | 269 | Any vision condition: 6% (5/81) | 0.24 (0.08–0.47) | 1.00 (0.94–1.0) (adjusted)
Tong et al, 2000^83^ | MTI photoscreener | <4 years | 387 | Strabismus: 49% (190/387) Refractive error: 55% (211/387) | All photographs; informative subset of 313 photographs Any condition: 0.95 (0.90–0.98); 0.95 (0.90–0.98) | All photographs; informative subset of 313 photographs Any condition: 0.43 (0.36–0.50); 0.41 (0.33–0.49)
Vision in Preschoolers Study Group (Phase I)82 | Crowded linear LEA symbols visual acuity test | 3, 4, or 5 years | 3121 | Any vision condition: 29% (755/2588) “Very important to detect and treat early” conditions: 5.4% (135/2588) Amblyopia: 2.9% (75/2588) Reduced visual acuity: 5.1% (132/2588) Strabismus: 1.9% (48/2588) Refractive error: 9.3% (240/2588) | Any condition; A. 0.73 (0.67–0.78); B. 0.78 (0.72–0.83) | Any condition; A. 0.84 (0.82–0.86); B. 0.81 (0.78–0.83)
Vision in Preschoolers Study Group (Phase I)82 | Crowded linear HOTV visual acuity test | 3, 4, or 5 years | 3121 | Any vision condition: 29% (755/2588) “Very important to detect and treat early” conditions: 5.4% (135/2588) Amblyopia: 2.9% (75/2588) Reduced visual acuity: 5.1% (132/2588) Strabismus: 1.9% (48/2588) Refractive error: 9.3% (240/2588) | Any condition; A. 0.68 (0.62–0.74); B. 0.69 (0.62–0.76) | Any condition; A. 0.82 (0.79–0.84); B. 0.77 (0.74–0.80)
Vision in Preschoolers Study Group (Phase I)82 | Random dot E stereoacuity test | | | | Any condition; A. 0.64 (0.58–0.71); B. 0.54 (0.46–0.63) | Any condition; A. 0.78 (0.75–0.81); B. 0.80 (0.78–0.83)
Vision in Preschoolers Study Group (Phase I)82 | Stereo smile II stereoacuity test | | | | Any condition; A. 0.66 (0.60–0.72); B. 0.68 (0.62–0.75) | Any condition; A. 0.73 (0.70–0.76); B. 0.78 (0.76–0.80)
Vision in Preschoolers Study Group (Phase I)82 | Retinomax autorefractor | | | | Any condition; A. 0.71 (0.68–0.75); B. 0.78 (0.74–0.82) | Any condition; A. 0.86 (0.84–0.87); B. 0.83 (0.81–0.84)
Vision in Preschoolers Study Group (Phase I)82 | SureSight autorefractor | | | | Any condition; A1 0.47 (0.43–0.51); A2 0.71 (0.66–0.76); B 0.77 (0.72–0.82) | Any condition; A1 0.91 (0.89–0.93); A2 0.86 (0.84–0.88); B 0.83 (0.81–0.85)
Vision in Preschoolers Study Group (Phase I)82 | iScreen photoscreener | | | | Any condition 0.71 (0.64–0.77) | Any condition 0.79 (0.77–0.81)
Vision in Preschoolers Study Group (Phase I)82 | MTI photoscreener | | | | Any condition 0.71 (0.64–0.77) | Any condition 0.79 (0.77–0.81)
Vision in Preschoolers Study Group (Phase I)82 | Power Refractor II | | | | Any condition; A. 0.68 (0.65–0.73); B. 0.70 (0.64–0.76) | Any condition; A. 0.83 (0.81–0.85); B. 0.79 (0.76–0.81)
Vision in Preschoolers Study Group (Phase I)82 | Cover-uncover test | | | | Any condition 0.78 (0.66–0.86) | Any condition 0.73 (0.70–0.76)
Weinand et al, 1998^84^ | MTI photoscreener | 6 to 48 months | 112 | Any abnormality: 81% (83/102) Refractive error: 41% (41/102) Strabismus w/out refractive error: 7% (7/102) Strabismus w/refractive error: 21% (21/102) Organic anomaly: 13% (13/102) | A. (Pediatrician interpreter): 0.88 (0.79–0.94); B. (Orthoptist interpreter): 0.93 (0.84–0.98); C. (Ophthalmologist 1 interpreter): 0.92 (0.83–0.98); D. (Ophthalmologist 2 interpreter): 0.90 (0.81–0.96) | A. (Pediatrician interpreter): 0.62 (0.32–0.86); B. (Orthoptist interpreter): 0.45 (0.27–0.64); C. (Ophthalmologist 1 interpreter): 0.38 (0.22–0.55); D. (Ophthalmologist 2 interpreter): 0.48 (0.27–0.69)
Williams et al, 2000^85^ | Topcon PR2000 autorefractor | 12.5 to 68.7 months | 222 | A. Spherical error >3.75 D: 19% (36/189); B. Anisometropia >1.25 D: 12% (23/189); C. Astigmatism >1.25 D: 16% (30/189) | A. 0.69 (0.48–0.86); B. 0.68 (0.46–0.85); C. 0.70 (0.46–0.88) | A. 0.89 (0.83–0.93); B. 0.96 (0.92–0.99); C. 0.91 (0.85–0.94)

* Raw data not provided; unable to calculate confidence intervals.

† Calculation based on n=379, median sensitivity and specificity.

‡ Based on reported sensitivity and specificity, does not match values reported in article.

One study from a statewide preschool photoscreening program in Tennessee (n=102,508) found that 20 percent (174/890) of children with false-positive screening results were prescribed glasses.98 About 25 percent of these children had clinically insignificant refractive error (as defined by anisometropia ≤0.75 D, hypermetropia ≤2.00 D, myopia ≤0.75 D, and astigmatism ≤0.75 D). The remainder had higher magnitude refractive error, though they did not meet standard criteria for amblyogenic risk factors and in many cases the clinical significance of the refractive error was unclear. No study evaluated effects of unnecessary corrective lenses on long-term vision or functional outcomes. We also identified no studies on rates of unnecessary treatment for amblyopia or amblyogenic risk factors following evaluation in a preschool vision screening program.

## Key Question 5 What is the Effectiveness of Treatment for Vision Impairment in Children Ages 1–5 Years?

### Summary

In children with unilateral refractive error, one good-quality trial found that patching plus eyeglasses and eyeglasses alone were more effective than no treatment by an average of about 1 line on the Snellen eye chart after 1 year. Effects were larger (1 to 2 lines of visual acuity improvement) in the subgroup of children with worse baseline visual impairment. One fair- and one good-quality trial found that patching resulted in a statistically significant but small (<1 line on the Snellen eye chart) average improvement in visual acuity in children with amblyopia after 5 to 12 weeks of follow-up who were pretreated with eyeglasses if needed for refractive error. Because all three trials evaluated older (ages 4 to 5 years) preschool-aged children, their applicability to younger children is uncertain. No trial evaluated effects of treatment compared with no treatment on school performance or other measures of function. Five fair- or good-quality trials found no differences in visual acuity improvement in the amblyopic eye between shorter and longer daily patching regimens (two trials), different atropine regimens (two trials), or between patching and atropine (one trial).

Evidence on whether age affects outcomes related to treatment is somewhat mixed. Two trials found no interaction between age and amblyopia treatment effects among preschoolers ages 3 to 7 years and one other trial found that delaying treatment for 1 year was associated with similar outcomes compared with immediate treatment in children ages 3 to 5 years. A trial of patching versus atropine found no interaction between age and visual acuity outcomes in preschoolers ages 3 to 7 years through 2 years of follow-up, but at age 10 years, age <5 years at study entry was associated with significantly increased likelihood of amblyopic eye visual acuity of 20/25 or better (57 vs. 38 percent; p=0.004). One other trial found that younger preschoolers (age 3 years) required fewer hours per day of patching to reach significant improvements in visual acuity compared with older preschool-aged children (ages 4 to 8 years).

### Evidence

Evidence from controlled trials. Two good-99, 100 and one fair-quality101 randomized trials compared effects on visual acuity of patching versus no patching in older (mean age range, 4 to 5 years) preschoolers (Table 14, Appendixes B5 and B6). Two of the trials enrolled children with amblyopia and pretreated those with refractive error using eyeglasses prior to allocation to patching or no patching.100, 101 The third trial compared patching plus eyeglasses or eyeglasses alone with no treatment in children with unilateral refractive error (with or without amblyopia).99 All trials found that patching was associated with greater improvements in visual acuity compared with no patching, though differences between treated and untreated children were small (less than or about 1 line of visual acuity), and visual acuity improved regardless of patching status. We did not pool results due to differences in baseline visual acuity in the amblyopic eye, inclusion criteria, use of pretreatment eyeglasses, and length of follow-up (range, 5 weeks to 1 year). No trial evaluated school performance or other functional outcomes.

Table 14 Randomized Controlled Trials of Amblyopia Treatments

Author, year | Population | Follow-up | Intervention: Mean change in visual acuity from baseline | Quality score
Patching + eyeglasses vs. eyeglasses alone vs. no treatment
Clarke et al, 2003^99^ | n=177 Mean age: 4.0 years Mean visual acuity in amblyopic eye: 0.36 logMAR (Snellen equivalent, 20/45) | 1 year | Patching (hrs/day not reported) + eyeglasses: 0.18 Mean difference vs. no treatment: 0.109 (95% CI, 0.005 to 0.17) Eyeglasses only: 0.13 Mean difference vs. no treatment: 0.085 (95% CI, 0.02 to 0.15) No treatment: 0.06; p=0.001 (ANOVA) [underlined: Results stratified according to baseline severity] Mild acuity loss at baseline Patching + eyeglasses: 0.23 Mean difference vs. no treatment: 0.04 (95% CI, −0.06 to 0.13) Eyeglasses only: 0.24 Mean difference vs. no treatment: 0.05 (95% CI, −0.03 to 0.13) No treatment: 0.19; p=0.38 (ANOVA) Moderate acuity loss at baseline Patching + eyeglasses: 0.52 Mean difference vs. no treatment: 0.27 (95% CI, 0.14 to 0.39) Eyeglasses only: 0.35; Mean difference vs. no treatment: 0.11 (95% CI, −0.03 to 0.24) No treatment: 0.25; p<0.001 (ANOVA) | Good
Patching vs. no patching, all children pretreated with eyeglasses if indicated
Awan et al, 2005^101^ | n=60 Mean age: 4.6 years Mean visual acuity in amblyopic eye: 0.64 logMAR (Snellen equivalent, 20/90) 55/60 (92%) received eyeglasses for correction of refractive error | 12 weeks | 3-hr patching: 0.29 (p=0.32 vs. no treatment) 6-hr patching: 0.34 (p=0.09 vs. no treatment) No treatment: 0.24 (p=0.11 vs. both treatments) | Fair
PEDIG, 2006^100^ | n=180 Mean age: 5.3 years Mean visual acuity in amblyopic eye: 0.55 logMAR (Snellen equivalent, 20/70) 155/180 (86%) received eyeglasses for correction of refractive error | 5 weeks | 2-hr patching: 0.12 No treatment: 0.04 Mean between-group difference: 0.07 (95% CI, 0.02 to 0.12); p=0.006 | Good
Occlusion regimens
PEDIG, 2003^102^ | n=189 Mean age: 5.2 years Mean visual acuity in amblyopic eye: 0.48 logMAR (Snellen equivalent, 20/63) | 4 months | 2-hr patching: 0.24 6-hr patching: 0.24 Mean between-group difference: 0.001 (95% CI, 0.040 to 0.042); p=0.9 | Good
Stewart et al, 2007^103^ | n=97 Mean age: 5.6 years Mean visual acuity in amblyopic eye: 0.44 logMAR (Snellen equivalent, 20/70) | mean 9 weeks (range, 5–26 weeks) | 6-hr patching: 0.26 12-hr patching: 0.24 Mean between-group difference: 0.02 (95% CI, 0.0 to 0.04); p=0.64 | Fair
Atropine regimens
PEDIG, 2004^104^ | n=168 Mean age: 5.3 years Mean visual acuity in amblyopic eye: 0.46 logMAR (Snellen equivalent, 20/60) | 4 months | Daily atropine: 0.23 Weekend atropine: 0.25 Mean between-group difference: 0.02 (95% CI, −0.21 to 0.09); p=0.52 | Good
Patching vs. atropine
PEDIG, 2002^105^ | n=419 Mean age: 5.3 years Mean visual acuity in amblyopic eye: 0.53 logMAR (Snellen equivalent, 20/65) | Initial trial: 6 months; voluntary follow-up through 10 years | 6-month results (mean age: 5.2 years) Patching: 0.25 Atropine: 0.21 Mean between-group difference: 0.04 (95% CI, 0.005 to 0.064) 2-year results (mean age: 7.2 years) Follow-up of patients in original study: 363/419 (86.6%) Patching: 0.16 Atropine: 0.17 Mean between-group difference: 0.01 (95% CI, −0.04 to 0.02); p=0.57 5-yr results (mean age: 10.3 years) Follow-up of patients in original study: 176/419 (42.0%) Patching 0.19 Atropine 0.16 Mean between-group difference: 0.03 (95% CI, −0.02 to 0.07); p=0.2 | Good

Abbreviations: ANOVA=analysis of variance between groups; CI=confidence interval; hr=hour; logMAR = logarithmic minimum angle of resolution; OR=odds ratio; PEDIG=Pediatric Eye Disease Investigator Group; RR=relative risk; vs.=versus.

Patching plus eyeglasses versus eyeglasses alone versus no treatment. One good-quality trial compared eyeglasses and patching, eyeglasses alone, and no treatment on visual acuity after 1 year in older (mean age, 4.3 to 5 years) preschool-aged children (n=177) with unilateral refractive error.99 All participants had unilateral refractive error based on two Snellen visual acuity tests (typically crowded, though uncrowded tests were used in some younger patients), but did not necessarily have amblyopia (the proportion with amblyopia was not reported). Seventy-two percent of participants had anisometropia. Mean logMAR visual acuity was about 0.36 (approximate Snellen equivalent, 20/45). The intensity of patching (hours per day) was not reported.

Both treatment groups experienced statistically significant but small improvements in best-corrected visual acuity after 1 year compared with no treatment (mean difference vs. no treatment, 0.11 logMAR [95% CI, 0.05–0.17] for eyeglasses plus patching; 0.08 logMAR [95% CI, 0.02–0.15] for eyeglasses alone). The average improvement from baseline in logMAR visual acuity was about 0.17 for eyeglasses plus patching, 0.13 for eyeglasses alone, and 0.06 for no treatment. There was no difference between groups in stereoacuity testing.106 The improvement in visual acuity varied in a preplanned subgroup analysis according to the severity of baseline visual impairment. In children with moderate (0.48 logMAR or worse) baseline refractive error, patching plus eyeglasses was associated with a larger difference compared with no treatment (0.27 logMAR [95% CI, 0.14 to 0.39]). The difference between eyeglasses alone and no treatment was also larger in this subgroup, but did not reach statistical significance (mean, 0.11 logMAR [95% CI, -0.03 to 0.24]). In children with mild (0.18 to 0.30 logMAR) baseline refractive error, average improvements were small in all three groups (mean, 0.19 to 0.24 logMAR), with trivial differences between the treatment and no treatment groups (mean, 0.04 to 0.05 logMAR).

Patching versus no patching in children pretreated with eyeglasses (if necessary). One good-quality trial by the Pediatric Eye Disease Investigator Group (PEDIG) compared eye patching of the nonamblyopic eye (n=87) with no treatment (n=93) in older preschoolers (mean age, 5.3 years) with amblyopia.100 Most children had no prior amblyopia treatment (89 percent) and most (86 percent) required refractive correction at baseline. Baseline visual impairment in the amblyopic eye was classified as moderate (20/40 to 20/100) in 78 percent of children and severe (20/125 to 20/400) in 17 percent. The study utilized a run-in phase, during which all enrollees wore updated eyeglass prescriptions, until visual acuity in the amblyopic eye stopped improving.107 Following this run-in period, children entered the treatment phase if they still had at least 2 lines of intraocular visual acuity difference between the amblyopic and nonamblyopic eyes. Children were randomly assigned to either 2 hours of continuous patching per day, including 1 hour of near activities, or no treatment. Both groups wore eyeglasses throughout the trial if required for refractive correction. Investigator-assessed adherence to treatment was good or excellent in 90 percent of patients.

Following 5 weeks of treatment, the mean logMAR visual acuity score in the amblyopic eye was 0.44 (standard deviation [SD], 0.22) in the patching group, compared with 0.51 (SD, 0.28) in the no-treatment group (adjusted mean difference, 0.07 [95% CI, 0.02 to 0.12]; p=0.006), or a difference of less than 1 line on a standard visual acuity chart (Snellen equivalent, 20/50 vs. 20/63). These results reflect a mean change from baseline of 0.12 logMAR in the amblyopic eye in the patching group, compared with a mean change from baseline of 0.04 logMAR in the no-treatment group. The proportion of patients who experienced an improvement of ≥2 lines of visual acuity was 45 percent in the patching group, compared with 23 percent in the no-treatment group (p=0.003). Results were similar in subgroups of children with moderate (visual acuity in amblyopic eye, 20/40 to 20/100) or severe (20/125 to 20/400) baseline amblyopia.

A smaller fair-quality trial (n=60) compared compliance rates between regimens of 3 and 6 hours per day of eye patching of the nonamblyopic eye in older (mean age, 4.6 years) preschoolers with amblyopia, but also included a no-treatment arm and evaluated visual acuity change as a secondary outcome.101 All children with refractive error (92 percent of enrollees) received 6 weeks of treatment with corrective lenses prior to allocation to patching or no patching. The mean refractive error in the amblyopic eye was 0.64 logMAR at baseline. Change in logMAR after 12 weeks of patching was 0.29, 0.34, and 0.24 in the 3-hour, 6-hour, and no-treatment group, respectively (p=0.11).

Comparisons of different treatment regimens. Two trials (n=189 and n=97) found similar effects when comparing less with more intense patching regimens in older (mean age, 5 years) preschool-aged children with amblyopia (mean visual acuity in amblyopic eye, 0.45 logMAR).102, 103 One good-quality PEDIG trial compared patching regimens of 2 versus 6 hours per day102 and one fair-quality trial compared patching regimens of 6 versus 12 hours per day.103 Mean logMAR changes in visual acuity from baseline were similar in all groups in both trials at around 0.25. The trial that randomly assigned children to 6 versus 12 hours per day of patching was limited in its ability to evaluate the effects of the intended regimens, as actual patch times averaged 4.2 hours per day (range, 3.7 to 4.7 hours) in the 6-hour/day group, compared with 6.2 hours per day (range, 5.1 to 7.3 hours) in the 12-hour/day group (p=0.06).103

Two good-quality PEDIG trials that enrolled similar patient populations (mean age, 5 years; mean visual acuity in amblyopic eye, 0.47 logMAR) found no clear differences in regimens involving atropine penalization of the nonamblyopic eye.104, 108 In these trials, atropine daily use, weekend use only, and weekend use only plus use of a plano lens in the nonamblyopic eye resulted in clinically significant increases in visual acuity in the amblyopic eye (mean improvement, 0.23 to 0.28 logMAR), with no significant differences in efficacy between compared regimens.

Another good-quality PEDIG trial found no difference between patching and atropine in children ages 3 to 7 years at study entry with moderate amblyopia (visual acuity, 20/40 to 20/100).105 It found similar improvements in visual acuity after 6 months of treatment (2.8 vs. 3.2 lines of mean visual acuity improvement; between group difference, 0.03 logMAR)105 as well as at 2 year follow-up (mean between group difference, 0.01 logMAR).109 Treatment after 6 months was at the discretion of the investigator. Mean visual acuity in the amblyopic eye on the Snellen chart was 20/32 in both groups compared with 20/63 at baseline. Follow-up at age 10 years in a subgroup of 45 percent (188/419) of the children originally enrolled in the trial also showed no difference between groups, with visual acuity improvement in the amblyopic eye largely maintained.110 At age 10 years, 46 percent of children had visual acuity of 20/25 or better in the amblyopic eye.

Effects of age on treatment outcomes. In children ages 3 years and older, most trials found no association between age at study entry and visual outcomes associated with treatments for amblyopia or unilateral refractive error. No treatment trial enrolled children younger than age 3 years. The PEDIG trial of patching versus no patching found no significant interaction between age at study entry (range, 3 to 7 years [40 percent <5 years]) and visual outcomes (p=0.14) in children with amblyopia after 5 weeks of treatment.100 A second trial found that delaying use of eyeglasses or patching for 1 year was not associated with worse visual outcomes after 6 additional months of follow-up compared with immediate treatment in children ages 3 to 5 years.99

Three trials that compared different treatment regimens also evaluated effects of age on visual outcomes.102, 103, 111 One trial found no interaction between age at study entry (range, 3 to 7 years [40 percent <5 years]) and visual outcomes associated with different patching durations after 4 months of treatment (p=0.76).102 The second trial found no interaction between age at study entry (range, 3 to 7 years [40 percent <5 years]) and visual outcomes associated with atropine or patching after 6 months of treatment (p=0.84)111 or at 2 year follow-up, with treatments after 6 months at the discretion of investigators (p=0.91).109 However, when a subgroup of 169 out of 419 children in this trial were evaluated at age 10 years, age <5 years at study entry was associated with slightly better visual acuity. Mean visual acuity in the amblyopic eye was 0.14 logMAR in patients younger than age 5 years at study entry, compared with 0.20 logMAR in patients older than age 5 years at study entry (p<0.001). A significantly higher proportion of patients younger than age 5 years at study entry also had amblyopic eye vision of at least 20/25 at age 10 years compared with patients enrolled at an older age (57 vs. 38 percent; RR, 1.2 [95% CI, 1.1 to 2.1]; p=0.01).110 The third trial (age range, 3 to 8 years) found that children younger than age 4 years experienced similar visual outcomes with <3 hours/day, 3 to 6 hours/day, and >6 hours/day of patching (p=0.54), but older preschoolers (older than age 4 years) experienced significantly greater improvement in visual acuity with 3 to 6 hours/day of patching compared with <3 hours/day (p=0.03).103

## Key Question 6 What Are the Harms of Treatment for Children Ages 1–5 Years at Increased Risk for Vision Impairment or Vision Disorders?

### Summary

Evidence from five good-quality trials suggests that some amblyopia treatments are associated with increased risk for short-term (reversible) visual acuity loss in the nonamblyopic eye. One trial found that patching was associated with increased risk for ≥2 lines of visual acuity loss compared with atropine (9 vs. 1.4 percent; p<0.001), and one trial found that atropine plus a plano lens was associated with increased risk for ≥1 line of visual acuity loss compared with atropine alone (17 vs. 4 percent; p=0.005). In both trials, visual acuity in the nonamblyopic eye subsequently returned to baseline in almost all children. Three other trials found no difference in risk for visual acuity loss in the nonamblyopic eye between patching versus no patching or in direct comparisons of different patching or atropine regimens.

Evidence on adverse psychosocial effects of amblyopia treatments is limited. One fair-quality follow-up study from a randomized trial found that children were more upset by patching plus eyeglasses compared with eyeglasses alone, and one good-quality trial found that patching was associated with worse emotional well-being compared with atropine.

No trial evaluated the effects of amblyopia treatment compliance on clinical outcomes. In trials that used dose occlusion monitors to measure compliance, the number of actual patching hours per day were about 50 percent of the hours prescribed. One trial found that an educational intervention increased compliance with the prescribed regimen.

### Evidence

Loss of visual acuity in the nonamblyopic eye. Five good-quality PEDIG trials evaluated loss of visual acuity in the nonamblyopic eye following amblyopia treatments (Appendix B5).100, 102, 104, 105, 108 One trial found no increased risk for ≥2 lines of visual acuity loss in the nonamblyopic with patching (2/85 [2.4 percent]) compared with no patching (6/88 [6.8 percent]; RR, 1.0 [95% CI, 0.98 to 1.1]; p=0.16) after 5 weeks of treatment.100 Two other trials found no difference in risk for ≥2 lines of visual acuity loss in the nonamblyopic eye after 4 months with 2-hour (7 percent) versus 6-hour (9 percent) patching regimens (p=0.59)102 or daily (3 percent) versus weekend (2 percent) atropine regimens (p=0.99).104

One trial found that patching was associated with higher risk for ≥2 lines visual acuity loss in the nonamblyopic eye at 6 month follow-up compared with atropine (17/194 [8.8 percent] vs. 3/208 [1.4 percent], respectively; RR, 0.93 [95% CI, 0.88 to 0.97]; p=0.001).105 Nineteen of the 20 children with visual acuity loss in the nonamblyopic eye recovered vision to 20/20 or at least equal to baseline at 2 years, with no between-group differences in mean visual acuity.109 One trial found that atropine plus a plano lens was associated with greater risk for ≥1 line of visual acuity loss in the nonamblyopic eye compared with atropine alone at 18 weeks (17 percent [15/88] vs. 4 percent [3/84], respectively; RR, 0.86 [95% CI, 0.78 to 0.95]; p=0.004).108 Nearly all (17/18) children with decreased visual acuity loss in the nonamblyopic eye at 18 weeks subsequently returned to baseline or better; the exception was one child with 20/25 visual acuity (20/20 at baseline).

Psychological effects. Evidence from randomized trials on the psychological effects of amblyopia treatment in preschool-aged children is limited to two studies.105, 112 One fair-quality study evaluated children and parents involved in a randomized trial99 through 2 years following study entry.112 An important limitation of this study is that follow-up (a questionnaire) was poor (78/177 [44 percent] of initially enrolled patients). Based on mean Rutter scores, there was no significant difference in emotional well-being among 4-year-olds who received glasses (n=46; mean score, 11.6 [SD, 5.3]) and/or patching (n=46; mean score, 11.0 [SD, 5.9]) versus the no-treatment group (n=51; mean score, 11.8 [SD, 5.5]; p=0.60).112 Based on the results of a questionnaire developed by the study’s authors, children randomly assigned to eyeglasses alone were less likely to be upset compared with those randomly assigned to patching plus eyeglasses (age 4 years: 29 vs. 85 percent; p=0.03; age 5 years: 26 vs. 62 percent; p=0.01). Parents of 4-year-olds were also significantly more upset by patching plus eyeglasses than eyeglasses alone (p=0.01), but parents of 5-year-olds showed no differences in feelings between the two regimens (p=0.80). The clinical significance of these results is difficult to interpret because the questionnaire has not been well validated.

One trial of atropine versus patching evaluated parent and child responses to treatment using the Amblyopia Treatment Index (ATI).113 The ATI is a validated, 18-item questionnaire (each question is scored from 1 to 5 points) that is divided into three subscales: adverse effects of treatment, lack of treatment compliance, and social stigma.114 Both patching (n=186) and atropine (n=178) were associated with ATI scores showing decreased emotional well-being (patching: 2.52 [SD, 0.63] vs. atropine: 2.02 [SD, 0.63]; p<0.001), as well as significantly higher (worse) mean scores relative to atropine on all three subscales (Appendix B5). Neither age (p=0.56) at treatment nor baseline severity of amblyopia (p=0.38) were significant predictors of ATI scores.113

Some observational studies have reported psychological distress and stigmatization associated with amblyopia treatment, particularly patching,115, 116 though others have found no such correlation.117

Compliance. Low levels of compliance with patching for amblyopia could limit effectiveness of treatments.118–121 However, no trial evaluated effects of compliance on effectiveness of treatment.

Three randomized trials used occlusion dose monitors to test levels of compliance with patching treatment.101, 103, 122 Two fair-quality trials of different patching regimens found that numbers of hours of patching per day were substantially lower than (by about half) prescribed numbers of hours per day, with greater compliance in those prescribed fewer hours of patching.101, 103 A third trial found that an educational intervention aimed to increase compliance in children was associated with better compliance (78 vs. 57 percent; RR, 1.4 [95% CI, 1.2 to 1.6]; p<0.0001).122

The good-quality PEDIG trial of 2 hours/day versus 6 hours/day of patching included investigator-assessed adherence to treatment as an outcome, based on daily calendar recordings by parents (rather than occlusion dose monitors).102 Adherence to treatment was judged to be poor in 3 percent of patients in the 2 hour/day group and 11 percent in the 6 hour/day group. However, it was not possible to accurately estimate actual number of hours per day of patching.