# Methods

Using the methods of the USPSTF that are fully detailed in Appendix A and with the input of members of the USPSTF, we developed an analytic framework and Key Questions (KQs) (Figure 1) to guide our literature search and review. The KQs for this update are:

KQ1 Is vision screening in children ages 1–5 years associated with improved health outcomes?
  1a Does effectiveness of vision screening in children ages 1–5 years vary in different age groups?
KQ2 What is the accuracy and reliability of risk factor assessment for identifying children ages 1–5 years at increased risk for vision impairment?
KQ3 What is the accuracy of screening tests for vision impairment in children ages 1–5 years?
  3a Does accuracy of screening tests for vision impairment vary in different age groups in children ages 1–5 years?
KQ4 What are the harms of vision screening in children ages 1–5 years?
KQ5 What is the effectiveness of treatment for vision impairment in children ages 1–5 years?
KQ6 What are the harms of treatment in children ages 1–5 years at increased risk for vision impairment or vision disorders?

Figure 1 Analytic Framework and Key Questions

Key Questions:

1. Is vision screening in children ages 1–5 years associated with improved health outcomes?
  1a Does effectiveness of vision screening in children ages 1–5 years vary in different age groups?
2. What is the accuracy and reliability of risk factor assessment for identifying children ages 1–5 years at increased risk for vision impairment?
3. What is the accuracy of screening tests for vision impairment in children ages 1–5 years?
  3a Does accuracy of screening tests for vision impairment in children ages 1–5 years vary in different age groups?
4. What are the harms of vision screening in children ages 1–5 years?
5. What is the effectiveness of treatment for vision impairment in children ages 1–5 years?
6. What are the harms of treatment for children ages 1–5 years at increased risk for vision impairment or vision disorders?

Figure 1 is an analytic framework that depicts the events that preschool-aged children experience while undergoing screening for vision impairment. The framework includes four headings: Risk Factor Assessment, Screening, Treatment, and Final Health and Functional Capacity Outcomes. The patient population undergoing risk factor assessment and screening is children ages 1 to 5 years. Treatment is one of the following risk reduction interventions: correcting refractive error, promoting use of the amblyopic eye, and correction of visual disturbances. The health outcomes include improved visual acuity, reduced incidence of long-term amblyopia, and better school performance. Potential harms of preschool vision screening include psychosocial effects, such as labeling and anxiety, unnecessary referrals due to false-positive screening results, and unnecessary use of corrective lenses or treatments to prevent amblyopia, with potential effects on long-term vision or function. Potential harms of amblyopia treatments include increased risk for short-term (reversible) visual acuity loss in the nonamblyopic eye and psychosocial distress and stigmatization.

## Search Strategies

We searched Ovid MEDLINE from 1950 to July 2009, the Cochrane Central Register of Controlled Trials, and the Cochrane Database of Systematic Reviews through the third quarter of 2009 (Appendix A1). We also reviewed reference lists of relevant articles and queried experts in the field for additional citations.

## Study Selection

We selected studies based on predefined inclusion and exclusion criteria developed for each KQ (Appendix A2). We defined the target population as children ages 1–5 years evaluated in primary care or community-based settings without known impaired visual acuity or obvious symptoms of impaired visual acuity. We also included studies of vision screening in eye specialty settings, but evaluated their applicability to primary care settings. Although the term “vision impairment” is broad, diseases covered in this review are amblyopia, amblyogenic risk factors (Table 1), strabismus, and simple refractive error. For screening tests, we included visual acuity tests, tests for ocular misalignment, stereoacuity tests, photoscreeners, and autorefractors.

We excluded visual acuity testing with cycloplegia and retinoscopy, as well as other tests not commonly used in primary care. For treatments, which are typically provided in eye specialty settings, we focused on risk reduction interventions, including correction of refractive error and penalization of the nonamblyopic eye (with patching or atropine). Outcomes of interest were visual acuity, risk for amblyopia, vision-related function, school performance, and adverse events related to screening or treatment (such as anxiety, labeling, or other psychosocial effects; false-positive rates; unnecessary treatments; and any negative effects on vision). We excluded children with severe congenital conditions or developmental delays, retinopathy of prematurity, glaucoma, congenital cataracts, and high myopia, as these were considered to be outside the scope of preschool vision screening in primary care. This review was limited to published studies available in the English language.

Two reviewers evaluated each study at the title/abstract and full-text article stages to determine eligibility for inclusion. The flow of studies from initial identification of titles and abstracts to final inclusion or exclusion is diagrammed in Appendix A3. Studies that were excluded after review of the full-text articles and reasons for exclusion are listed in Appendix A4.

## Data Abstraction and Quality Rating

We abstracted details about the study population, study design, data analysis, length of follow-up, results, and quality (Appendix B). We converted visual acuity measurements from Snellen to logMAR scales using published conversion charts.32 One author abstracted data and another author verified data abstraction for accuracy. Two authors independently rated the internal validity of each study as “good,” “fair,” or “poor” based on predefined criteria developed by the USPSTF (Appendix A5).43, 44 For diagnostic accuracy studies, we used the “diagti” procedure in Stata 10.0 (StataCorp, College Station, TX) to calculate sensitivities, specificities, and likelihood ratios. For studies where the reference standard was only performed in a random sample of negative screens, we corrected for verification bias when estimating sensitivity and specificity using the method of Begg and Greenes.45 In this review, the positive likelihood ratio (PLR) is the odds of a visual condition among subjects with the risk factor present compared with those without the risk factor.46 The negative likelihood ratio (NLR) is the odds of a visual condition among subjects without the risk factor compared with those with the risk factor present. We classified PLRs >10 and NLRs ≤0.1 as “large/strong,” PLRs >5 and ≤10 and NLRs >0.1 and ≤0.2 as “moderate,” PLRs >2 and ≤5 and NLRs >0.2 and ≤0.5 as “small/weak,” and PLRs >1 and ≤5 and NLRs >0.5 and ≤1 as “very small/very weak.”47

For all studies we evaluated applicability to populations likely to be encountered in primary care screening settings. Factors we considered when assessing applicability included whether children were recruited from primary care settings, the prevalence of visual conditions, and the severity of visual conditions. Discrepancies in quality ratings were resolved by discussion and consensus.

## Data Synthesis

We assessed the overall strength of the body of evidence for each KQ (“good,” “fair,” or “poor”) or part of a KQ using methods developed by the USPSTF, based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence.43 We did not attempt to quantitatively pool results of studies of diagnostic test accuracy due to marked differences among studies in populations, how screening cutoffs were defined, and target conditions, as well as substantial between-study heterogeneity in results. In addition, there were too few randomized trials of specific treatment comparisons to perform meta-analysis.

## External Review

We distributed a draft of the report for review by external experts not affiliated with the USPSTF (Appendix A6) and revised the report based on their comments.