# Introduction

## Scope and Purpose

In the United States, common visual problems in young children include refractive error, strabismus, and amblyopia.1 Vision impairment related to these conditions can reduce quality of life, function, and school performance.2 In addition, amblyopia and strabismus can affect normal visual development at a critical period of visual development, resulting in irreversible vision loss. Identification of vision problems prior to school entry could help identify children who might benefit from early interventions to correct or improve vision.

The U.S. Preventive Services Task Force (USPSTF) issued an updated recommendation on screening for visual impairment in preschool-aged children in 2004.^3^ Since 2004, additional evidence on screening programs and various screening modalities has become available. In 2009, the USPSTF commissioned a new evidence review in order to update its recommendation. The purpose of this report is to systematically evaluate the current evidence on screening for vision problems in preschool-aged children.

## Condition Definition

The most common causes of vision impairment in children are: 1) amblyopia and its associated (“amblyogenic”) risk factors, 2) strabismus not associated with amblyopia, and 3) refractive error not associated with amblyopia. Amblyopia is a disorder characterized by abnormal processing of visual images in the brain during a critical period of vision development, resulting in a functional reduction of visual acuity.4 It is associated with conditions that interfere with normal binocular vision, such as strabismus (ocular misalignment), anisometropia (a difference in refractive power between the two eyes), bilateral refractive error, and media opacity (such as cataracts) or other blockage of the visual pathway (such as ptosis or eyelid drooping). Vision impairment associated with amblyopia is not immediately correctable with use of refractive lenses. Standardized definitions for amblyogenic risk factors are available and have been widely adopted (Table 1).5 Strabismus is the most common risk factor for amblyopia, but can inhibit development of normal binocular vision even in the absence of amblyopia.6

Table 1 Amblyogenic Risk Factors

Amblyogenic risk factors
- Anisometropia (spherical or cylindrical) > 1.50; - Any manifest strabismus; - Hyperopia > 3.50 D in any meridian; - Any media opacity > 1 mm in size; - Astigmatism > 1.5 D at 90° or 180° in oblique axis (>10° eccentric to 90° or 180°); - Ptosis ≤ 1 mm margin reflex distance (the distance from the corneal light reflex to the upper lid margin; a standard objective measurement of ptosis); - Visual acuity per age-appropriate standards

Abbreviations: D=diopter; mm=millimeter.

Source: Donahue et al, 2003.^5^ Used with permission.

Refractive error is commonly due to myopia (nearsightedness), hyperopia (farsightedness), and astigmatism. Unlike vision impairment associated with amblyopia, simple refractive error is correctable with use of appropriate lenses, and is not thought to affect normal visual development. Mild hyperopia is normal in young children, who usually achieve normal (20/20) adult visual acuity between the ages of 3 to 7 years.

## Prevalence and Burden of Disease

1 to 5 percent of U.S. preschool-aged children have vision impairment.7 A population-based study of over 6,000 children in Los Angeles County found amblyopia present in 2.6 percent of Hispanic/Latino children and 1.5 percent of black children.8 Strabismus was present in about 2.5 percent of both ethnic groups. Among over 360,000 preschool-aged children who underwent photoscreening in 15 different programs in the United States, amblyogenic risk factors were identified in 2 percent.9 European studies of screening in community- and preschool-based settings also reported a prevalence of about 2 percent for amblyogenic risk factors.10–12 A population-based study of 1,504 white and black children ages 6 to 71 months in Baltimore, Maryland, found that 1.5 percent had decreased bilateral visual acuity and another 1.7 percent wore glasses at presentation.13 The prevalence of myopia ≥1.00 D was 0.7 percent in white children and 5.5 percent in black children, and the prevalence of hyperopia ≥3.00 D was 8.9 percent and 4.4 percent, respectively.14 The prevalence of myopia increases as children enter adolescence and can affect up to 25 percent of adults.15

In children, vision impairment can affect school performance and other functions, such as ability to safely participate in sports. Strabismus, the most common contributing factor to amblyopia, can also result in loss of stereopsis, leading to impaired depth perception, as well as teasing and other psychosocial consequences. Although amblyopia is often considered a disease of childhood, it is the most common cause of monocular visual loss in adults ages 20 to 70 years.16 One risk of amblyopia is that vision loss in the nonamblyopic eye can result in severe vision impairment or blindness. One study estimated at least a 1.2 percent lifetime risk for vision loss for an individual with amblyopia.17 Long-term functional effects of unilateral vision loss related to amblyopia are not well characterized. A study of a 1958 British birth cohort found no differences at ages 33 or 41 years in educational, health, or social outcomes among 8,432 adults with normal vision and 429 adults with amblyopia.18

## Etiology and Natural History

Amblyopia is usually unilateral, but bilateral amblyopia can also occur. In addition to decreased visual acuity, amblyopia affects other aspects of vision development, including fusion and stereopsis, which are necessary to form clear three-dimensional images. Amblyopia is associated with conditions that cause misuse or disuse of the eye (such as strabismus), asymmetric refractive error (anisometropia), and conditions associated with visual image deprivation (such as cataracts or ptosis). Although deprivation amblyopia is generally associated with the most severe vision loss, it is also the least common type.19 Regardless of the cause of amblyopia, the decreased visual acuity is not immediately reversible with simple refractive correction. Left untreated, amblyopia is unlikely to resolve spontaneously.7, 20 In one study of 18 children ages 4 to 6 years who were poorly adherent with amblyopia treatment, visual acuity improved in only one child after 1 year, stayed about the same in one half, and worsened in the other half.20 A traditional justification for preschool screening is that amblyopia becomes irreversible if not treated by the time the child reaches the ages of 6 to 10 years.21, 22 However, a recent trial found amblyopia treatments may be effective through ages 12 to 17 years, particularly in previously untreated children.23, 24

Unlike visual loss associated with amblyopia, simple refractive error is immediately correctable with eyeglasses. The three major types of refractive error are myopia (nearsightedness), hyperopia (farsightedness), and astigmatism (blurred vision at any distance because the radius of curvature of one meridian of the eye is different than that of the orthogonal meridian). These conditions are referred to as refractive error because light is not bent or “refracted” properly, resulting in images that are not accurately focused on the retina. Nearly 20 percent of children develop a refractive error that requires the use of eyeglasses before late adolescence. Some degree of hyperopia is normal in infants and young children and does not need to be treated unless it is severe or causing symptoms, since children have the ability to compensate for hyperopia through enhanced accommodation of the lens.

## Risk Factors

Risk factors for amblyopia include prematurity or low birth weight, deprivation of visual stimuli in early infancy up to age 6 years, familial history, and presence of strabismus or uncorrected refractive error (particularly severe asymmetric refractive error).4, 7, 25 A large (n=7,825) longitudinal study of British school-aged children found that maternal smoking during the first trimester of pregnancy and socioeconomic status were significantly associated with development of amblyopia.26 Standardized definitions for amblyogenic risk factors are shown in Table 1. Risk factors for simple refractive error include prematurity and family history.

## Rationale for Screening/Screening Strategies

Amblyopia occurs when amblyogenic risk factors are present or occur in early childhood.6 Normal vision cannot develop if the images seen by the two eyes are unequally clear, unclear in both eyes, or disparate due to misalignment. If amblyogenic risk factors develop after the ages of 6 to 8 years, amblyopia usually does not occur, as visual maturation has already occurred.27 Conversely, if amblyopia is treated too late, the visual pathways do not develop properly and visual loss may become permanent. Amblyopia is therefore considered to be a developmental disorder that is most effectively treated during an early, sensitive period. This understanding has been one of the key justifications for preschool vision screening. The other main justification for preschool vision screening is that it provides an opportunity to correct any vision problems before children enter school, potentially promoting school performance during an important period of social and functional development.

## Interventions/Treatments

Treatment for simple refractive error is correction with eyeglasses. When amblyopia or amblyogenic risk factors are present, treatment involves correction of the underlying amblyogenic risk factor if a structural abnormality (such as a cataract or ptosis) is present. When there is no clear structural abnormality, the standard approach in patients with some degree of reversible refractive error is to apply eyeglasses, which can improve or in some cases resolve amblyopia.28–31 If amblyogenic risk factors or amblyopia persists, the next step is to reduce or eliminate the visual suppressive effect of the nonamblyopic eye through patching (occlusion) or use of atropine drops (which causes visual blurring due to loss of accommodation). After cessation of amblyopia treatment, surgery may be performed for refractory strabismus. Recent randomized trials have investigated the comparative effectiveness of more intensive versus less intensive amblyopia treatments, as well as patching versus atropine. Areas of uncertainty include the optimal time at which to initiate therapy and the optimal duration of treatment. This review will focus on patching and atropine, by far the most common amblyopia treatments.

## Current Clinical Practice

Preschool vision screening is frequently offered in primary care and community-based settings. Measurement of visual acuity, commonly reported in Snellen or logarithmic minimum angle of resolutions (logMAR) scales (Table 2), along with assessments of strabismus and stereoacuity, are typical components of screening. Some areas of variability in screening practices include when to start screening, who performs screening, how often to screen, and which specific screening tests to use.32 Recommended visual acuity tests vary according to age (Table 3). In a national survey of U.S. pediatricians, only one third reported visual acuity screening in children age 3 years, compared with about 70 percent in children ages 4 or 5 years.36 Visual acuity testing with charts, such as HOTV or Lea symbols, and ocular alignment testing with the cover-uncover test are the most commonly used screening tests in primary care settings, though stereoacuity testing rates remain low. “Crowded” visual acuity tests (optotypes presented in a line or with crowding bars) are more sensitive for detecting amblyopia than “uncrowded” tests (single isolated optotypes) and are generally recommended in children able to cooperate with the test.37 Newer screening methods, including photoscreeners and autorefractors, have been proposed as potential replacements or supplements to traditional screening methods. Photoscreeners take optical images to evaluate ocular alignment and refractive error, based on the appearance of the fundus and corneal light reflexes. Autorefractors utilize automated optical methods to determine the refractive error of an eye. Potential advantages of photoscreeners and autorefractors are that they may reduce testing time, increase objectivity of screening, and enhance testability rates in younger children, who may be poorly cooperative with traditional tests. In a national survey, however, fewer than 10 percent of pediatricians reported using photoscreeners or autorefractors,36 though photoscreeners have been adopted in some mass community-based screening programs.38 Potential disadvantages of photoscreeners and autorefractors are the relatively high initial costs associated with the instruments, and the need with some photoscreeners for external interpretation of screening results. Children who fail a preschool vision screening test are typically referred for a full ophthalmological exam to confirm presence of vision problems, and further treatment once the visual acuity problem has been confirmed.

Table 2 Measurements of Visual Acuity

Snellen
Feet | Meters | Decimal | LogMAR
20/20 | 6/6 | 1.00 | 0.00
20/30 | 6/9 | 0.67 | −0.18
20/40 | 6/12 | 0.50 | −0.30
20/60 | 6/18 | 0.33 | −0.48
20/80 | 6/24 | 0.25 | −0.60
20/100 | 6/30 | 0.20 | −0.70
20/160 | 6/48 | 0.13 | −0.90
20/200 | 6/60 | 0.10 | −1.00

Note: Visual Impairment is 20/50 or worse; legal blindness is 20/200 or worse.

Abbreviation: LogMAR=logarithmic minimum angle of resolution.

Source: Holliday, 2004^32^

Table 3 Visual Acuity Tests

Test | Description | Applicable Ages
Allen Cards | Test involving 4 flash cards containing 7 schematic figures. The figures are identified from various distances. | 2 to 4 years
HOTV | Test involving identification of the letters “H,” “O,” “T,” and “V.” The letters decrease in size from the top to the bottom of the chart. | Older than 4 years
LEA Symbols | Test involving matching symbols on cards to symbols on the wall. The symbols decrease in size from the top to the bottom of the chart. | 2 to 4 years
Snellen Eye Chart | Test involving a chart with 11 lines of letters. The first line consists of one very large letter, and each row below has increasing numbers of letters that decrease in size. | Older than 4 years
Tumbling E | Test involving the letter “E” presented with the arms pointing in different directions. The letters decrease in size from the top to the bottom of the chart. | Older than 4 years

Source: American Academy of Pediatrics, 2003^33^; Prevent Blindness America, 2005^35^

## Recommendations of Other Groups

The American Academy of Family Practice, the American Academy of Pediatrics, the American Academy of Ophthalmology, and the American Association for Pediatric Ophthalmology and Strabismus recommend preschool vision screening. All recommend measurement of monocular distance visual acuity and testing for ocular misalignment, though the age at which to initiate screening and the specific tests recommended vary among groups (Table 4).

Table 4 Recommendations From Other Organizations

Organization | Year | Screening recommendations | Recommended screening age | Comments
American Academy of Family Physicians (AAFP)39 | Accessed Web site in 2009 | Recommends screening to detect amblyopia, strabismus, and defects in visual acuity in children younger than age 5 years. | Younger than 5 years
American Academy of Ophthalmology (AAO)40 | Revised and approved in 2007, original 1991 | Joint Policy Statement with AAPOS. Recommends timely screening for the early detection and treatment of eye and vision problems in children. This includes the institution of rigorous vision screening during the preschool years. Early detection of treatable eye disease in infancy and childhood can have far-reaching implications for vision and, in some cases, for general health. | Preschool-aged years
American Academy of Pediatrics (AAP)33, 34 | Reaffirmed in 2007, original 2003 | [underlined: Distance visual acuity] Tests: Snellen letters, Snellen numbers, Tumbling E, HOTV, Picture tests (e.g., Allen figures, LEA symbols) Referral criteria: Fewer than 4 of 6 correct on 20-ft line, with either eye tested at 10 ft monocularly (i.e., less than 10/20 or 20/40) OR 2-line difference between eyes, even within the passing range (i.e., 10/12.5 and 10/20 or 20/25 and 20/40) [underlined: Ocular alignment] Tests: Cross-cover test at 10 ft (3 m), Random Dot E test at 40 cm, simultaneous red reflex test (Bruckner test) Referral criteria: Any asymmetry of pupil color, size, or brightness [underlined: Ocular media clarity (e.g., cataracts, tumors)] Tests: Red reflex Referral criteria: White pupil, dark spots, absent reflex | 3–6+ years | 1. Tests are listed in decreasing order of cognitive difficulty; the highest test that the child is capable of performing should be used. In general, the tumbling E or the HOTV test should be used for children ages 3–5 years and Snellen letters or numbers for children ages 6 years and older.; 2. Testing distance of 10 ft is recommended for all visual acuity tests.; 3. A line of figures is preferred over single figures.; 4. The nontested eye should be covered by an occluder held by the examiner or by an adhesive occluder patch applied to eye; the examiner must ensure that it is not possible to peek with the nontested eye.; Direct ophthalmoscope used to view both red reflexes simultaneously in a darkened room from 2 to 3 feet away; detects asymmetric refractive error as well. Direct ophthalmoscope, darkened room. View eyes separately at 12 to 18 inches; white reflex indicates possible retinoblastoma.
American Academy of Pediatrics (AAP)33, 34 | Reaffirmed in 2008, original 2002 | [underlined: Photoscreening] All children should be screened for risk factors associated with amblyopia. Guidelines are suggested for the use of photoscreening to detect amblyopia and strabismus in children of various age groups. | Earliest possible age | AAP favors additional research on the efficacy and cost-effectiveness of photoscreening as a vision screening tool.
American Association for Pediatric Ophthalmology and Strabismus (AAPOS)40 | Revised and approved in 2007, original 1991 | Joint Policy Statement with AAO (same as above). | Preschool-aged years
American Optometric Association (AOA)41 | Reviewed in 2007, original 1994 | A comprehensive eye examination at age 3 years continues to be the most effective approach to prevention or early detection of eye and vision problems in the preschool-aged child. | 3 years
Canadian Task Force on Preventive Health Care (CTFPHC)42 | 1994 | There is fair evidence to recommend visual acuity testing, as systematic screening for visual deficits has been found to decrease prevalence later. | Preschool-aged years

## Previous USPSTF Recommendation

In 2004, the USPSTF recommended screening to detect amblyopia, strabismus, and defects in visual acuity in children younger than age 5 years (“B recommendation”).3 It found no direct evidence that screening leads to improved visual acuity compared with no screening, but found evidence that early detection and treatment of amblyopia and amblyogenic risk factors can improve visual acuity. The USPSTF found insufficient evidence to determine optimal screening tests, optimal screening frequency, or technical proficiency required of the screening clinician.