# Appendix B. Evidence Tables

Appendix B1 Screening Evidence Table

Study, year | Purpose of study | Study design | Inclusion criteria | Exclusion criteria | Number of subjects
Eibshitz-Timboni et al, 2000^51^ | Evaluate association between screening at ages 1 to 2.5 years and prevalence of amblyopia at age 8 years | Retrospective cohort | Children screened between ages 1 and 2.5 years in one Israeli city, compared to children not screened in another city | NR | # approached and eligible: 988 # enrolled: 1590 (808 had screening at ages 1 to 2.5 years; 782 did not)
Feldman et al, 1980^52^ | Evaluate association between screening 6 to 12 months prior to school entry and presence of visual impairment upon school entry | Retrospective cohort | Children screened before entry into kindergarten in one Ontario county compared to children screened at entry in another county; samples matched on SES status according to distribution in the counties | NR | # approached and eligible: NR # enrolled: 1508 (745 had screening 6 to 12 months prior to school entry; 763 did not)
Kirk et al, 2008^54^ | Evaluate association between screening prior to age 2 years and presence of visual impairment at least 2 years later | Retrospective cohort | Children screened prior to age 48 months with at least 2-year follow-up data | NR | # approached and eligible: 10620 screened # enrolled: 94 (58 screened prior to age 2 years; 36 not)
Kohler et al, 1978^53^ | Evaluate association between screening at age 4 years and risk for visual disorders at age 7 years | Retrospective cohort | Children born between 1963 and 1965 and screened at age 7 years | NR | # approached and eligible: NR # enrolled: 2178 (619 screened at age 4 years; 1519 not)

Study, year | Subject age, sex, diagnosis | Country and setting | Sponsor | Outcomes | Screening intervention
Eibshitz-Timboni et al, 2000^51^ | Age: 8 years Sex: NR Diagnosis: 1% vs. 2.6% amblyopia | Israel Preschool screening | Technion-Israel Institute of Technology | Presence of amblyopia at age 8 years | Ophthalmologic exam by an ophthalmologist or orthoptist, including Hirschberg corneal reflex text, monocular fixation and following test, ductions and versions examination, cover-uncover test, alternative cover test, and retinoscopy without cycloplegia
Feldman et al, 1980^52^ | Age: mean, 6 years Sex: NR Diagnosis: 13% had at least mild (visual acuity of 20/40 or worse) best-corrected vision impairment | Canada Preschool and school screening | Ontario Ministry of Health | Risk for vision impairment at school entry screening | Illiterate E visual acuity test, administered by school nurse
Kirk et al, 2008^54^ | Age: mean, 10.2 years Sex: NR Diagnosis: All referred for an abnormal screening examination | U.S. Preschool screening | Vision screening technology received from a number of vendors (no direct author payments) | Risk for vision impairment at follow-up of at least 2 years in children ages ≥6 years | The Photoscreener, Inc. (previously the MTI Photoscreener), administered by community lay screener
Kohler et al, 1978^53^ | Age: 7 years Sex: NR Diagnosis: 49% had vision disorders classified as requiring treatment, functional amblyopia, or strabismus | Sweden Preschool and school screening | H. Hierta’s and A. Pilt’s foundations | Risk for newly diagnosed vision disorder requiring treatment, amblyopia, or strabismus at age 7 years | Linear E-chart, administered by school nurse

Study, year | Results | Follow-up | Loss to follow-up | Compliance to treatment | Adverse events | Quality score
Eibshitz-Timboni et al, 2000^51^ | Screening at 1 to 2.5 years vs. no screening Amblyopia at age 8 years: 1.0% (8/808) vs. 2.6% (20/782); RR, 0.39 (95% CI, 0.17–0.87) Amblyopia with visual acuity worse than 20/60 at age 8 years: 0.1% (1/808) vs. 1.7% (13/782); RR, 0.07 (95% CI, 0.01–0.57) | 5.5–7 years | NR | 82% (180 out of 988) of children underwent screening at ages 1 to 2.5 years | NA | Poor
Feldman et al, 1980^52^ | Screening 6 to 12 months prior to school entry vs. no screening Relative risk for at least mild vision impairment upon school entry: 10% (78/763) vs. 15% (112/745); RR, 0.68 (95% CI, 0.52–0.89) | 6–12 months | NR | NA | NA | Poor
Kirk et al, 2008^54^ | Screening at 2 to 4 years vs. screening prior to 2 years Relative risk for at least mild vision impairment at age >6 years: 17% (10/58) vs. 6% (2/36); RR, 3.10 (95% CI, 0.72–13.4) | 2–10 years | NR | NA | NA | Poor
Kohler et al, 1978^53^ | Screening at 4 years vs. no screening Relative risk for newly diagnosed vision disorder, amblyopia, or strabismus at age 7 years: 5% (29/619) vs. 0.7% (11/1519); RR, 0.15 (95% CI, 0.08–0.31) | 3 years | NR | NA | NA | Poor

Study, year | Purpose of study | Study design | Inclusion criteria | Exclusion criteria | Number of subjects
Williams et al, 2002^49^ and Williams et al, 2003^50^ | Evaluate screening at ages 8, 12, 18, 25, 31, and 37 months vs. screening at age 37 months only on visual outcomes at age 7.5 years | Randomized trial | Children born in southwest England during the last six months of the ALSPAC study period | Children born in the first 15 months of the cohort or whose parents declined to continue with the study or had more than one participating child | # approached and eligible: NR # enrolled: 3490 (2029 had intensive screening; 1490 had one-time screening)

Study, year | Subject age, sex, diagnosis | Country and setting | Sponsor | Outcomes | Screening intervention
Williams et al, 2002^49^ and Williams et al, 2003^50^ | Age: 8 to 37 months (followed to 7.5 years) Sex: 48% female (of those who attended final assessment) Diagnosis: baseline amblyopia or amblyogenic risk factors NR | United Kingdom Hospital eye services clinic | Medical Research Council, R&D Directorate, National Health Service Executive South West, National Eye Research Centre | Prevalence of amblyopia at age 7.5 years; prevalence of residual amblyopia 7.5 years after patching treatment; visual acuity in worse eye after patching treatment Amblyopia A: interocular difference in acuity ≥0.2 logMAR (2 chart lines) Amblyopia B: interocular difference in acuity ≥0.3 logMAR | Screening at 8, 12, 18, 25, 31, and 37 months: cover testing; Cardiff cards at 8 and 12 months, Cardiff and Kays pictures test at 18, 25, and 31 months, Kays picture test and HOTV test at 37 months; noncycloplegic autorefraction (performed at all visits, but only used for referral at 37 months) Screening at 37 months: Cover testing, Kays picture test and HOTV test, noncycloplegic autorefraction

Study, year | Results | Follow-up | Loss to follow-up | Compliance to treatment | Adverse events | Quality score
Williams et al, 2002^49^ and Williams et al, 2003^50^ | Screening at 8, 12, 18, 25, 31, and 37 months vs. screening at 37 months only Amblyopia A at age 7.5 years: 1.4% (16/1088) vs. 2.7% (22/826); RR, 0.55 (95% CI, 0.29–1.04) Amblyopia B at age 7.5 years: 0.6% (69/1088) vs. 1.8% (15/876); RR, 0.35 (95% CI, 0.15–0.86) Residual amblyopia A at age 7.5 years among children treated with occlusion: 25% (10/40) vs. 8% (3/40); OR, 1.56 (95% CI, 0.62–3.92) Residual amblyopia B at age 7.5 years among children treated with occlusion: OR, 4.11 (95% CI, 1.04–16.29) Mean visual acuity in worse eye after patching treatment (adjusted for confounding variables): 0.15 (95% CI, 0.083–0.22) vs. 0.26 (95% CI, 0.17–0.35); p<0.001 | 4.5 years | 45% (1561 out of 3490) attended final exam | NA | NA | Fair

Study, year | Purpose of study | Study design | Inclusion criteria | Exclusion criteria | Number of subjects
Williams et al, 2003^50^ | Evaluate screening at age 37 months vs. screening at school entry (ages 4–5 years) on visual outcomes at age 7.5 years | Prospective cohort study | Children born in southwest England enrolled in the ALSPAC study who had a screening examination at age 7.5 years | Enrolled in a separately reported quasi-randomized trial (Williams et al, 2002^51^) | # approached and eligible: 8042 evaluated for inclusion # enrolled: 6081 (1516 were screened at 37 months; 4565 were not)

Study, year | Subject age, sex, diagnosis | Country and setting | Sponsor | Outcomes | Screening intervention
Williams et al, 2003^50^ | Age: 7.5 years (screening at 37 months) Sex: 49% female Diagnosis: Baseline amblyopia or amblyogenic risk factors NR | United Kingdom Hospital eye services clinic | Medical Research Council, the Wellcome Trust, UK Department of Health, Department of the Environment, DfEE, National Institutes of Health, “a variety of medical research charities and commercial companies,” R&D Directorate, NHS Executive South West | Prevalence of amblyopia at age 7.5 years; prevalence of residual amblyopia 7.5 years after patching treatment; visual acuity in worse eye after patching treatment Amblyopia A: interocular difference in acuity ≥0.2 logMAR (2 chart lines) Amblyopia B: visual acuity in amblyopic eye 0.3 logMAR or worse (6/12 or worse) Amblyopia C: visual acuity in amblyopic eye 0.18 logMAR or worse (6/9 or worse) | Screening at 37 months: Kay pictures or Sheridan Gardiner singles visual acuity test, cover test, and 20 diopter prism or test of stereopsis (or both) No screening at 37 months

Study, year | Results | Follow-up | Loss to follow-up | Compliance to treatment | Adverse events | Quality score
Williams et al, 2003^50^ | Received screening at 37 months vs. no screening Amblyopia A at 7.5 years: 1.1% (11/1019) vs. 2.0% (100/5062), adjusted OR, 0.63 (95% CI, 0.32–1.23) Amblyopia B at 7.5 years: 0.7% (7/1019) vs. 1.3% (65/5062), adjusted OR, 0.72 (95% CI, 0.32–1.60) Amblyopia C at 7.5 years: 1.9% (19/1019) vs. 3.4% (171/5062), adjusted OR, 0.65 (95% CI, 0.38–1.10) Mean visual acuity in worse eye after patching treatment: 0.14 (95% CI, 0.11–0.18) (n=25) vs. 0.22 (95% CI, 0.20–0.23) (n=166); p<0.0001 Offered screening at 37 months vs. not offered Amblyopia A at 7.5 years: 1.4% (21/1516) vs. 2.0% (100/5062); p=0.14 Amblyopia B at 7.5 years: 1.2% (18/1516) vs. 1.3% (65/5062); p=0.59 Amblyopia C at 7.5 years: 2.4% (36/1516) vs. 3.4% (171/5062); p=0.08 Mean visual acuity in worse eye after patching treatment: 0.18 (SD, 0.22) vs. 0.22 (SD, 0.23); p=0.22 | 4.5 years | NR | NA | NA | Fair

Abbreviations: NR=not reported; NA=not assessed; SES=socioeconomic status; #=number; CI=confidence interval; RR=relative risk; OR= odds ratio; SD=standard deviation.

Appendix B2 Screening Quality Ratings

Randomized Controlled Trial
Study, year | Random assignment | Allocation concealed | Groups similar at baseline | Eligibility criteria specified | Blinding of outcome assessors or data analysts | Intention- to-treat analysis | Reporting of attrition, contamination | Differential loss to follow-up or overall high loss to follow-up | Appropriate analysis, including cluster correlation | Funding source | External validity | Quality score
Williams et al, 2002^49^ and Williams et al, 2003^50^ | No | Yes | Yes | Yes | Can’t tell | No | No | Yes | Not applicable | Medical Research Council; R&D Directorate; National Health Service Executive South West; National Eye Research Centre | High | Fair

Appendix B3 Diagnostic Accuracy Evidence Table

Study, year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N
Arthur et al, 2009^57^ | Plusoptix autorefractor (previously called the Power Refractor) | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Kindergarten Canada | Dental assistant | 4–5 years | 307
Barry et al, 2001^10^ | Retinomax autorefractor | Second orthoptic exam (Lea single symbol test, cover/uncover test, eye motility, and abnormal head posture), followed by ophthalmological exam for abnormal, missing, or inconsistent results | Cross-sectional | Kindergarten Germany | Orthoptist | 3 years | 404
Barry et al, 2003^11^ | Visual inspection, cover-uncover test, eye motility and head posture exam, Lea single symbol visual acuity test | Second orthoptic exam (Lea single symbol test, cover/uncover test, eye motility, and abnormal head posture) using more stringent criteria, followed by ophthalmological exam for abnormal, missing, or inconsistent results | Cohort | Kindergarten Germany | Orthoptist | 3 years | 1180
Berry et al, 2001^58^ | MTI Photoscreener | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic; United States | Not described | Preschool (subgroup) | 51

Study, year | Proportion with condition | Definition of a positive screening exam | Definition of a case | Subjects
Arthur et al, 2009^57^ | Amblyogenic risk factors: 13% (36/275) | Anisometropia >1 D, astigmatism >1.25 D, myopia >3 D, hyperopia >3.5 D, anisocoria >1 mm, abnormal alignment | Anisometropia >1 D Astigmatism >1.25 D Myopia >3 D Hyperopia >3.5 D Anisocoria >1 mm Strabismus | Age: 4–5 years Female: Not reported
Barry et al, 2001^10^ | Amblyopia: 2.5% (10/404) | Acuity outside −1 D to +3 D, cylindric power >1.5 D, or anisometropia >1 D | Any newly administered patching therapy, or any newly administered patching therapy (visual acuity ≤0.4 (20/50) in either eye, or difference of visual acuity between eyes ≥2 log steps) | Age: 3 years Female: Not reported
Barry et al, 2003^11^ | Amblyopia or amblyogenic risk factors: 2.3% (26/1114) | Anatomic abnormality, manifest strabismus or unstable re-fusion upon uncovering, anomalies of eye motility and head posture, visual acuity worse than 10/25 or >1 line difference between eyes and visual acuity in worse eye 10/20 to 10/17 | Newly administered spectacle therapy if the corrected visual acuity ≤020/50 in either eye, or difference of visual acuity of >2 logarithmic lines (except for myopia); any newly administered patching therapy in presence of risk factors like monolateral strabismus or high refractive error (≥1.5 D, or astigmatism ≥3 D) | Age: 3 years Female: Not reported
Berry et al, 2001^58^ | Amblyogenic risk factors: 45% (23/51) | Presence of abnormal red reflex, asymmetric corneal light reflection, opacity, or crescent | Myopia ≥1.00 D, hyperopia ≥2.75 D, astigmatism >1.50 D, anisometropia >1.50 D, >1 mm difference in pupil size, any strabismus, any media opacity, any ptsosis, any fundus abnormality | Age: Not reported Female: Not reported

Study, year | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analyses | Sensitivity (95% CI) | Specificity (95% CI)
Arthur et al, 2009^57^ | 0.3% (1/307) | Excluded | 90% (275/306) | 0.83 (0.67–0.93) | 0.95 (0.92–0.98)
Barry et al, 2001^10^ | Not reported | Not described | 95% (404/427) | 0.80 (0.44–0.98) | 0.58 (0.53–0.62)
Barry et al, 2003^11^ | 11% (133/1180) | Excluded from analysis | 83% (975/1180) | 0.91 (0.71–0.99) | 0.94 (0.92–0.95)
Berry et al, 2001^58^ | Not reported | Not described | 100% (51/51) | 0.83 (0.61–0.95) | 0.68 (0.48–0.84)

Study, year | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality score
Arthur et al, 2009^57^ | 18 (10–33) | 0.17 (0.08–0.36) | 0.73 (0.57–0.85) | 0.97 (0.94–0.99) | Fair
Barry et al, 2001^10^ | 1.9 (1.4–2.6) | 0.35 (0.1–1.2) | 0.05 (0.02–0.09) | 0.99 (0.97–1.0) | Fair
Barry et al, 2003^11^ | 15 (11–19) | 0.10 (0.03–0.36) | 0.25 (0.16–0.36) | 1.0 (0.99–1.0) | Fair
Berry et al, 2001^58^ | 2.6 (1.4–4.5) | 0.26 (0.10–0.65) | 0.68 (0.48–0.84) | 0.83 (0.61–0.95) | Fair

Study, year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N
Bertuzzi et al, 2006^59^ | Crowded Lea Symbols visual acuity chart | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic Italy | Not described | 38 to 54 months | 149
Chang et al, 2007^60^ | A. Distance visual acuity (test not reported); B. Near visual acuity (test not reported); C. NTU random dot stereogram | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Public health service stations Taiwan | Nurse | Preschool | 5232
Chui et al, 2004^61^ | Crowded Lea Symbols visual acuity chart, Frisby stereoacuity test, and external visual inspection | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Not described Canada | Nurse | 35 to 58 months | 178 (141 completed gold standard evaluation)

Study, year | Proportion with condition | Definition of a positive screening exam | Definition of a case | Subjects
Bertuzzi et al, 2006^59^ | Amblyogenic risk factors: 16% (23/143) | Various cutoffs evaluated; results shown for:; A. Acuity (decimal score) 0.80; B. Acuity (decimal score) 0.63 | Bilateral myopia ≥3 D Unilateral myopia >1.5 D. Bilateral hyperopia ≥3 D Unilateral hyperopia ≥1 D Uni/bilateral astigmatism >1.5 D Lack of media transparency. Any retinal or optic nerve abnormality Strabismus | Age: 38 to 54 months Female: Not reported
Chang et al, 2007^60^ | Amblyopia: 2.20% (115/5232) | A1 Distance visual acuity worse than 0.5 at age 3 years, 0.6 at age 4 years, 0.7 at age 5 years, and 0.8 at age 6 years.; A2 Distance visual acuity worse than 0.7 at age 3 years, 0.8 at age 4 years, 0.9 at age 5 years, and 1.0 at age 6 years.; B Near visual acuity worse than 0.7 at age 3 years, 0.8 at age 4 years, 0.9 at age 5 years, and 1.0 at age 6 years.; C Stereoacuity worse than 300 sec-arc | Best corrected distance visual acuity worse than 1.0 | Age: 76% 3 to 5 years, 24% 6 years Female: 48%
Chui et al, 2004^61^ | Amblyogenic risk factors: 13% (18/141) | Visual acuity 6/12–2 or worse in one or both eyes, difference in visual acuity of two lines or more between eyes, stereoacuity worse than 600” on Frisby or worse than 400” on Titmus, presence of constant or intermittent tropia, monofixation syndrome, myopia >−0.75 D, hyperopia >+3.50 D, astigmatism ≥+1.50 D, anisometropia ≥1.00 D, any other anomaly or inability to complete gold standard exam | Lea Symbols visual acuity of 6/12–2 or worse in one or both eyes Difference in visual acuity of ≥2 lines between eyes Stereoacuity worse than 600” on Frisby or worse than 400” on Titmus Constant or intermittent tropia, monofixation syndrome Myopia ≥−0.75 D Hyperopia ≥3.50 D Astigmatism ≥1.50 D Anisometropia ≥1.00 D Any other abnormality warranting follow-up Unable to complete gold-standard exam | Age: 35 to 58 months Female: Not reported

Study, year | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analyses | Sensitivity (95% CI) | Specificity (95% CI)
Bertuzzi et al, 2006^59^ | 4% (6/149) (7% in those 38–42 months, 3% in those 43–48 months, and 0% in those 49–54 months) | Excluded from analysis | 96% (143/149) | A. 0.96 (0.78–1.0); B. 0.78 (0.56–0.92) | A. 0.83 (0.75–0.90); B. 0.93 (0.87–0.97)
Chang et al, 2007^60^ | A. 5% (239/5232); B. Not reported; C. 3% (174/5232) | Not described | Not described | A1 0.75^*^; A2 0.84^*^; B 0.49^*^; C 0.20^*^ | A1 0.91^*^; A2 0.69^*^; B 0.92^*^; C 0.98^*^
Chui et al, 2004^61^ | Not reported | Considered positive screens | 79% (141/179) | 0.67 (0.41–0.87) <41 months: 0.75 (0.43–0.94) ≥41 months: 0.50 (0.12–0.88) | 0.86 (0.79–0.92) <41 months: 0.90 (0.52–0.82) ≥41 months: 0.95 (0.88–0.99)

Study, year | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality score
Bertuzzi et al, 2006^59^ | A. 5.7 (3.8–8.6); B. 12 (5.8–24) | A. 0.05 (0.01–0.36); B. 0.23 (0.11–0.51) | A. 0.52 (0.36–0.68); B. 0.69 (0.48–0.86) | A. 0.99 (0.95–1.0); B. 0.96 (0.90–0.99) | Fair
Chang et al, 2007^60^ | A1 8.1^*^; A2 2.7^*^; B 6.4^*^; C 11.4^*^ | A1 0.28^*^; A2 0.24^*^; B 0.55^*^; C 0.81^*^ | A1 0.12^*^; A2 0.04^*^; B 0.13^*^; C 0.17^*^ | A1 1.0^*^; A2 1.0^*^; B 0.99^*^; C 0.99^*^ | Fair
Chui et al, 2004^61^ | 4.8 (2.8–8.4) <41 months: 2.4 (1.4–4.1) ≥41 months: 10 (3.0–36) | 0.39 (0.20–0.75) <41 months: 0.37 (0.13–1.0) >41 months: 0.53 (0.24–1.2) | 0.41 (0.24–0.61) <41 months: 0.41 (0.21–0.64) ≥41 months: 0.43 (0.10–0.82) | 0.95 (0.89–0.98) <41 months: 0.90 (0.74–0.98) ≥41 months: 0.96 (0.90–0.99) | Fair

Study, year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N
Cogen et al, 1992^62^ | Visiscreen 100 photoscreener | Comprehensive eye exam with cycloplegic refraction (“when possible”) | Cross-sectional | Pediatric ophthalmology clinic. United States | Technician | 6 months to 6 years | 127
Cooper et al, 1999^63^ | A. Fortune Optical VRB- 100 photoscreener; B. MTI photoscreener | Comprehensive eye exam with cycloplegic refraction | Case-control | Pediatric ophthalmology clinic Australia | Technician | 12 to 44 months | 105
Dahlmann-Noor et al, 2009a64 | Plusoptix autorefractor (previously called the Power Refractor) | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic United Kingdom | Ophthalmologist, orthoptist, or ophthalmic nurse | 4 to 7 years | 126
Dahlmann-Noor et al, 2009b65 | Plusoptix autorefractor (previously called the Power Refractor) | Orthoptist screening with distance acuity testing, cover test, extraocular movements, prism test, and Lang stereotest; comprehensive eye exam with cycloplegic refraction for abnormal autorefractor or orthoptist screening results | Cross-sectional | Preschool/kindergarten United Kingdom | Ophthalmologist or orthoptist | 4 to 7 years | 288
Ehrt et al, 2007^66^ | Power Refractor autorefractor (now called the Plusoptix) | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic Germany | Orthoptist or pediatric ophthalmologist | 0 to 7 years | 161
Guo et al, 2000^67^ | A. Computer- photorefractor; B. Non-cycloplegic retinoscopy | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic China | Not described | 9 to 50 months | 300

Study, year | Proportion with condition | Definition of a positive screening exam | Definition of a case | Subjects
Cogen et al, 1992^62^ | Any visual condition: 12% (13/113) Refractive error: 5% (6/113) Strabismus: 4% (5/113) Refractive error + strabismus: 1% (1/113) Media opacity: 1% (1/113) | Presence of abnormal red reflex, asymmetric corneal light reflection, opacity, or crescent | Hyperopia >4 D Myopia >5 D Astigmatism >2 D Anisometropia >1 D Strabismus Media opacity | Age: 6 months to 6 years Female: Not reported
Cooper et al, 1999^63^ | 61 cases (amblyopia), 44 controls | Presence of abnormal red reflex, asymmetric corneal light reflection, opacity, or crescent | Hyperopia >3.5 D Anisometropia >1 D Myopia >2 D Astigmatism >2 D Any media opacity or fundus abnormality affecting vision Manifest strabismus | Age: 12 to 44 months Female: Not reported
Dahlmann-Noor et al, 2009a64 | A. Myopia: 3% (3/108); B. Hypermetropia: 39% (42/108); C. Astigmatism: 12% (13/108); D. Anisometropia: 24% (28/117) | Not reported | Myopia >1 D Hyperopia >3 D Anisometropia >1 D Astigmatism >1.5 D | Age: Mean 5.5 years Female: 49%
Dahlmann-Noor et al, 2009b65 | Reduced vision in one or both eyes, manifest strabismus, or ptosis: 12% (36/288) | Spherical component <−1.0 D or >+3.0 D, cylinder power >1.5 D, anisometropia of spherical component or of cylinder power >1.0 D | Hyperopia >3.0 D Myopia >1.0 D Strabismus Ptosis | Age: 4 to 7 years (mean 5.6) Female: 52%
Ehrt et al, 2007^66^ | Amblyogenic risk factors: 43% (70/161) | Hyperopia ≥3.0 D, myopia ≤2.0 D, astigmatism ≥1.0 D, anisometropia ≥1 D | Hyperopia ≥3 D Myopia ≥2 D Astigmatism ≥1 D Anisometropia ≥1 D | Age: 0 to 7 years (89% 0 to 5 years, 35% 56/161 3 to 5 years)
Guo et al, 2000^67^ | Amblyogenic risk factors: 56% (168/300) | Presence of abnormal red reflex, asymmetric corneal light reflection, opacity, or crescent | Myopia ≥1.50 D Hyperopia ≥2.75 D Astigmatism ≥1.75 D Anisometropia v2.00 D Media opacity ≥1.5 mm Strabismus ≥5 ° | Age: 9 to 50 months, mean 28 months Female: 49%

Study, year | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analyses | Sensitivity (95% CI) | Specificity (95% CI)
Cogen et al, 1992^62^ | 11% (14/127) | Excluded from analysis | 89% (113/127) | 0.85 (0.55–0.98) | 0.94 (0.87–0.98)
Cooper et al, 1999^63^ | Reader 1: 3% (3/105) Reader 2: 8% (8/105) | Excluded from analysis | Unclear, results reported for 85% to 98% (89 to 103 of 105) patients | - A (reader 1): 0.60 (0.47–0.73); - A (reader 2): 0.69(0.54–0.80); - B (reader 1): 0.56 (0.42–0.70); - B (reader 2): 0.68 (0.54–0.80) | - A (reader 1): 0.76 (0.60–0.87); - A (reader 2): 0.86 (0.72–0.95); - B (reader 1): 0.80 (0.65–0.90); - B (reader 2): 0.86 (0.70–0.95)
Dahlmann-Noor et al, 2009a64 | 14% (18/126) | Excluded from analysis | 100% (108/108) | A. 0.88 (0.30–1.0); B. 0.20 (0.10–0.35); C. 0.75 (0.36–0.96); D. 0.50 (0.31–0.69) | A. 0.96 (0.89–0.99); B. 0.99 (0.92–1.0); C. 0.93 (0.86–0.97); D. 0.87 (0.77–0.93)
Dahlmann-Noor et al, 2009b65 | 100% (288/288) | Not applicable | 100% (288/288) | 0.45 (0.29–0.62) | 1.0 (0.98–1.0)
Ehrt et al, 2007^66^ | 43% (70/161) | Considered positive screens | 100% (161/161) | 0.71 (0.59–0.82) | 0.78 (0.68–0.86)
Guo et al, 2000^67^ | Not reported | Not described | 100% (300/300) | A. 0.95 (0.90–0.98); B. 0.86 (0.80–0.91) | A. 0.90 (0.84–0.95); B. 0.81 (0.73–0.87)

Study, year | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality score
Cogen et al, 1992^62^ | 14 (6.3–32) | 0.16 (0.05–0.59) | 0.65 (0.38–0.86) | 0.98 (0.93–1.0) | Fair
Cooper et al, 1999^63^ | - A (reader 1): 2.5 (1.4–4.3); - A (reader 2): 4.9 (2.3–10); - B (reader 1): 2.8 (1.5–5.2); - B (reader 2): 4.9 (2.1–11) | - A (reader 1): 0.52 (0.37–0.75); - A (reader 2): 0.37 (0.24–0.55); - B (reader 1): 0.55 (0.39–0.77); - B (reader 2): 0.37 (0.25–0.56) | - A (reader 1): 0.76 (0.61–0.87); - A (reader 2): 0.86 (0.72–0.95); - B (reader 1): 0.78 (0.62–0.89); - B (reader 2): 0.88 (0.74–0.96) | - A (reader 1): 0.60 (0.46–0.72); - A (reader 2): 0.69 (0.54–0.80); - B (reader 1): 0.59 (0.46–0.72); - B (reader 2): 0.65 (0.50–0.78) | Poor
Dahlmann-Noor et al, 2009a64 | A. 21 (7.8–55); B. 26 (1.6–450); C. 11 (4.7–24); D. 3.7 (1.9–7.1) | A. 0.13 (0.01–1.7); B. 0.81 (0.70–0.94); C. 0.27 (0.08–0.89); D. 0.58 (0.40–0.84) | A. 0.44 (0.14–0.78); B. 0.94 (0.57–1.0); C. 0.46 (0.20–0.74); D. 0.54 (0.34–0.73) | A. 1.0 (0.95–1.0); B. 0.66 (0.56–0.75); C. 0.98 (0.92–1.0); D. 0.85 (0.75–0.91) | Fair
Dahlmann-Noor et al, 2009b65 | 230 (14–3680) | 0.56 (0.42–0.74) | 0.97 (0.73–1.0) | 0.92 (0.89–0.95) | Fair
Ehrt et al, 2007^66^ | 3.2 (2.2–4.9) | 0.37 (0.25–0.54) | 0.71 (0.59–0.82) | 0.78 (0.68–0.86) | Poor
Guo et al, 2000^67^ | A. 9.6 (5.7–16); B. 4.5 (3.2–6.5) | A. 0.06 (0.03–0.11); B. 0.18 (0.12–0.26) | A. 0.92 (0.87–0.96); B. 0.85 (0.79–0.90) | A. 0.93 (0.87–0.97); B. 0.82 (0.74–0.88) | Fair

Study, year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N
Hope et al, 1990^68^ | Random dot E stereogram | Comprehensive eye exam with cycloplegic refraction for visual acuity worse than 4/4 with the LMT or worse than 6/6 for Kaye picture cards in children who failed random dot E stereogram, visual acuity screen, or near cover test; otherwise visual acuity screen or near cover test used as reference standard | Cross-sectional | Pediatric ophthalmology clinic New Zealand | Not described | 3 to 4 years | 176
Kemper et al, 2005^69^ | SureSight autorefractor | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic United States | Orthoptist or pediatric ophthalmologist | 0 to 5 years | 170
Kennedy et al, 1989^70^ | A. Otago-type photoscreener (non- commercial); B. Off-axis-type photoscreener (non- commercial) | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic Canada | Technician | 6 years or less | 236

Study, year | Proportion with condition | Definition of a positive screening exam | Definition of a case | Subjects
Hope et al, 1990^68^ | Refractive error or strabismus: 5% (9/168) Refractive error: 5% (9/168) Strabismus: 0.6% (1/168) | Unable to correctly identify the E at least four times in succession at 1 m | Visual acuity 6/12 or worse in either eye Manifest strabismus | Age: 3 to 4 years Female: Not reported
Kemper et al, 2005^69^ | Amblyopia: 17% (29/170) Refractive error: 26% (45/170) Strabismus: 18% (30/170) Any visual impairment: 36% (62/170) | SureSight manufacturer referral criteria (hyperopia >2.00 D, myopia >1.00 D, cylinder >1.00 D, or difference >1.00 D) | Anisometropia >1.5 D Hyperopia >3.50 D Myopia >3.00 D Media opacity >1 mm Astigmatism >1.5 D at 90° or 180° or >1.0 D in oblique axis Ptosis ≤1 mm margin reflex distance Visual acuity per age-appropriate standards Manifest strabismus | Age: 0 to 5 years (53% 3 to 5 years) Female: Not reported
Kennedy et al, 1989^70^ | Any amblyogenic risk factor: 42% (98/236) Strabismus only: 14% (33/236) Strabismus + refractive error or anisometropia: 18% (42/236) Refractive error or anisometropia: 8% (18/236) Anisocoria or lid tumor: 2% (5/236) | Presence of abnormal red reflex, asymmetric corneal light reflection, opacity, or crescent | Refractive error >3.00 D Astigmatism >2.00 D Corneal or lens opacity Fundus abnormality Strabismus | Age: 0 to 6 years (65% 2 to 6 years) Female: 48%

Study, year | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analyses | Sensitivity (95% CI) | Specificity (95% CI)
Hope et al, 1990^68^ | 5% (8/176) | Excluded from analysis | 95% (168/176) | 0.89 (0.52–1.0) | 0.76 (0.68–0.82)
Kemper et al, 2005^69^ | 32% (55/170) | Not described, appear to have been excluded | 100% (170/170) | Overall: 0.85 (0.69–0.95) <3 years old (n=80): 0.80 (0.44–0.97) 3–5 years old (n=90): 0.88 (0.68–0.97) | Overall: 0.52 (0.40–0.63) <3 years old: 0.41 (0.24–0.61) 3–5 years old: 0.58 (0.42–0.71)
Kennedy et al, 1989^70^ | Not reported | Not described | 100% (236/236) | Any condition; A. A: 0.94 (0.87–0.98); B. B: 0.85 (0.76–0.91); Strabismus; A. 0.91 (0.81–1.00); B. 0.73 (0.58–0.88); Refractive error; A. 0.89 (0.74–1.00); B. 0.89 (0.74–1.00); Strabismus + refractive error; A. 0.98 (0.93–1.00); B. 0.91 (0.82–0.99) | Any condition; A. 0.94 (0.89–0.98); B. 0.87 (0.80–0.92)

Study, year | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality score
Hope et al, 1990^68^ | 3.6 (2.5–5.2) | 0.15 (0.02–0.94) | 0.17 (0.08–0.31) | 0.99 (0.96–1.0) | Fair
Kemper et al, 2005^69^ | Overall: 1.8 <3 years old: 1.4 3–5 years old: 2.1 | Overall: 0.29 <3 years old: 0.49 3–5 years old: 0.21 | Not calculable | Not calculable | Fair
Kennedy et al, 1989^70^ | Any condition; A. 16 (8.2–32); B. 6.5 (4.2–10) | Any condition; A. 0.06 (0.03–0.14); B. 0.18 (0.11–0.28) | Any condition; A. 0.92 (0.85–0.96); B. 0.82 (0.73–0.89) | Any condition; A. 0.96 (0.91–0.98); B. 0.89 (0.82–0.94) | Fair

Study, year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N
Kennedy et al, 1995^71^ | A. Otago-type photoscreener (non-commercial); B. Snellen E or Stycar graded balls visual acuity test and Titmus stereotest | Comprehensive eye exam without cycloplegic refraction | Cross-sectional | Kindergarten Canada | Health care aide | Not reported | 264
Kennedy et al, 2000^72^ | iScreen photoscreener | Comprehensive eye exam with cycloplegic refraction (in patients younger than 4 years old) | Cross-sectional | Pediatric ophthalmology clinic Canada | Technician | 45% 6 years or younger | 449
Matta et al, 2008^73^ | Plusoptix autorefractor (previously called the Photo Refractor) | Comprehensive eye exam with cycloplegic refraction | Cross-sectional or retrospective | Pediatric ophthalmology clinic United States | Not stated | 1 to 5 years (data obtained for this subgroup) | 80
Miller et al, 1999^74^ | A. Crowded Lea Symbols visual acuity chart; B. Retinomax K-plus autorefractor | Cycloplegic refraction and retinoscopy | Cross-sectional | Head Start program United States (Native American population) | Head Start staff | 3 to 5 years | 245

Study, year | Proportion with condition | Definition of a positive screening exam | Definition of a case | Subjects
Kennedy et al, 1995^71^ | Any visual condition: 8% (21/264) Strabismus: 1.1% (3/264) Refractive error: 4.2% (11/264) Strabismus and refractive error: 0.8% (2/264) Structural: 0.4% (1/264) | A. Presence of abnormal red reflex, asymmetric corneal light reflection, opacity, or crescent; B. Vision less than 20/40 in either eye, or stereoacuity less than 80 seconds of arc | Visual acuity worse than 20/30 Constant tropia present Refractive error >± 3.00 D in either eye with ± 2 D astigmatism Corneal, lens or fundus abnormality | Age: Not reported Female: Not reported
Kennedy et al, 2000^72^ | Amblyogenic risk factors: 64% (273/423) | Presence of abnormal red reflex, asymmetric corneal light reflection, opacity, or crescent | Tropia, intermittent or otherwise Refractive error >3.50 D in both eyes Myopia >0.50 D Anisometropia >2.00 D Astigmatism >2.00 D Corneal or lens opacity Fundus abnormality | Age: Median 7 years Female: Not reported
Matta et al, 2008^73^ | Amblyogenic risk factors: 50% (40/80) | A. Manufacturer’s referral criteria: Anisometropia ≥1.0 D, astigmatism ≥0.75 D, myopia ≥2.0 D for 1–2 years and ≥1.0 D for 3–5 years, hyperopia ≥1.0 D, anisocoria ≥1 mm; B. Revised referral criteria: Anisometropia ≥1.25 D, astigmatism ≥1.0 D, myopia ≥2.0 D for 1–2 years and ≥1.0 D for 3–5 years, hyperopia ≥1.25 D, anisocoria ≥1 mm | Anisometropia >1.5 D Any manifest strabismus Hyperopia >3.50 D Myopia >3.00 D Media opacity >1 mm Astigmatism >1.5 D Ptosis <−1 mm margin reflex distance Visual acuity: per age-appropriate std | Age: Range 6 months to 192 months (72% 1–5 years)
Miller et al, 1999^74^ | Significant refractive error: 31% (76/245); all had astigmatism | Age 2–4: Myopia >2.50 D, hyperopia >4.00 D, astigmatism >2.00 D, anisometropia >1.50 D Age 4–7: Myopoia >1.50 D, hyperopia >4.00 D, astigmatism >1.50 D, anisometropia >1.50 D | For ages <2, 2–4, and 4–7 years, respectively. Myopia: >4.00 D, >2.50 D, or >1.50 D. Hyperopia: >5.00 D, >4.00 D, or >1.50 D. Astigmatism: >2.50 D, >2.00 D, or >1.50 D. Anisometropia: >1.50 D (all age groups) | Age: 36% 3 years old, 57% 4 years old, 7% 5 years old. Female: Not reported

Study, year | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analyses | Sensitivity (95% CI) | Specificity (95% CI)
Kennedy et al, 1995^71^ | Not reported | Not described | 100% (13/13 or 22/22) of positive screens, 20% random sample (241 or 242 of 1232 or 1223) of negative screens | A. 0.46 (0.22–0.72)^†^; B. 0.09 (0.04–0.20)^†^ | A. 1.0 (0.99–1.0)^†^; B. 1.0 (0.99–1.0)^†^
Kennedy et al, 2000^72^ | 6% (26/449) | Excluded from analysis | 94% (423/449) | 0.92 (0.88–0.95) ≤3 years 1.0 4–6 years 0.92 | 0.89 (0.83–0.94) ≤3 years 0.97 4–6 years 0.95
Matta et al, 2008^73^ | Not reported | Not described | 100% (109/109) | A. 0.98 (0.85–1.0); B. 0.98 (0.85–1.0) | A. 0.68 (0.51–0.81); B. 0.88 (0.74–0.96)
Miller et al, 1999^74^ | 4% (10/245) | Not described | 100% (245/245) | A. 0.91 (0.82–0.96); B. 0.91 (0.82–0.96) | A. 0.44 (0.37–0.52); B. 0.86 (0.80–0.91)

Study, year | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality score
Kennedy et al, 1995^71^ | A. 110 (38–310)^†^; B. 17 (5.5–54)^†^ | A. 0.54 (0.33–0.89)^†^; B. 0.91 (0.84–0.99)^†^ | A. 0.77 (0.60–0.95); B. 0.54 (0.28–0.81) | A. 0.98 (0.91–1.00); B. 0.94 (0.91–0.97) | Fair Age not reported.
Kennedy et al, 2000^72^ | 8.6 (5.4–14) ≤3 years 33 4–6 years 18 | 0.09 (0.06–0.13) ≤3 years not calculable 4–6 years 0.08 | 0.94 (0.90–0.96) ≤3 years 0.97 4–6 years 0.97 | 0.86 (0.80–0.91) | Fair Most patients ≥7 years; unable to calculate confidence intervals for ≤6 years, though point estimates provided.
Matta et al, 2008^73^ | A. 3.0 (1.9–4.7); B. 8.4 (3.7–19) | A. 0.04 (0.01–0.26); B. 0.03 (0.00–0.20) | A. 0.75 (0.61–0.86); B. 0.89 (0.75–0.96) | A. 0.96 (0.80–1.0); B. 0.97 (0.85–1.0) | Fair
Miller et al, 1999^74^ | A. 1.6 (1.4–1.9); B. 6.7 (4.5–9.8) | A. 0.21 (0.10–0.43); B. 0.11 (0.05–0.22) | A. 0.42 (0.35–0.50); B. 0.75 (0.65–0.83) | A. 0.92 (0.83–0.96); B. 0.95 (0.901–0.98) | Fair

Study, year | Screening test | Reference standard | Type of study | Setting | N
Miller et al, 2001^75^ | A. Crowded Lea Symbols visual acuity chart; B. MTI Photoscreener; C. Nidek KM-500 Keratometry Screener; D. Retinomax K-Plus Autorefractor | Cycloplegic refraction | Cross-sectional | Head Start program United States (Native American population) | 379
Molteno et al, 1993^76^ | Otago-type photoscreener | History, inspection, cover test, exam of ocular media and fundoscopy through undilated pupils; cycloplegic refraction, dilated fundoscopy, and orthoptic exam with any abnormalities | Cross-sectional | Pediatric ophthalmology clinic New Zealand | 1000
Morgan et al, 1987^77^ | Visiscreen 100 photoscreener | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic United States | 63

Study, year | Proportion with condition | Definition of a positive screening exam | Definition of a case | Subjects
Miller et al, 2001^75^ | Astigmatism ≥1.00 D: 48% (182/379) | A. Visual acuity worse than 20/40.; B. Presence of abnormal red reflex, asymmetric corneal light reflection, opacity, or crescent.; C. Astigmatism ≥2.25 D in either eye; D. Astigmatism ≥1.50 D in either eye | Astigmatism ≥2.00 D for children <48 months of age and ≥1.50 D for children ≥48 months of age | Age: 36–63 months Female: 53%
Molteno et al, 1993^76^ | Visual acuity worse than 20/20, heterophoria, or anisometropia ≥0.5 D sphere or >1.0 D cylinder: 34% (340/1000) | Yellow or white fundal reflex, deviation of papillary light reflex, inequality of pupil size, any other visible defect | Corrected visual acuity worse than 20/20 in the worse eye Heterophoria, either marked with good binocular vision or moderate with some defect of binocular vision and including intermittent squint with well developed binocular vision Anisometropia ≥0.5 D | Age: Not reported (“infants and children”) Female: Not reported
Morgan et al, 1987^77^ | Any visual condition: 60% (34/57) | Media opacity Crescent Asymmetric corneal reflex | Hyperopia ≥2.50 D Myopia ≥1 D Anisometropia >1 D Astigmatism >2 D | Age 3 months to 8 years (mean not reported) Female: Not reported

Study, year | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analyses | Sensitivity (95% CI) | Specificity (95% CI)
Miller et al, 2001^75^ | A. 8% (30/376); B. 6% (24/369)^‡^; C. 0.3% (1/379); D. 0.5% (2/379) | Unable to complete screening considered positive screen; uninterpretable photographs considered positive screen | 100% (379/379) | A. 0.93 (0.87–0.97); B. 0.66 (0.59–0.73)^§^; C. 0.95 (0.91–0.98); D. 0.93 (0.88–0.96) | A. 0.51 (0.44–0.57); B. 0.71 (0.64–0.78)^§^; C. 0.77 (0.71–0.83); D. 0.95 (0.91–0.98)
Molteno et al, 1993^76^ | Not reported | Not described | 100% (1000/1000) | 0.89 (0.86–0.91) | 0.61 (0.55–0.66)
Morgan et al, 1987^77^ | 10% (6/63) | Excluded from analysis | 90% (57/63) | 0.91 (0.76–0.98) | 0.74 (0.52–0.90)

Study, year | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality score
Miller et al, 2001^75^ | A. 1.9 (1.6–2.2); B. 2.3 (1.8–2.9)^§^; C. 4.1 (3.2–5.4); D. 18 (10–34) | A. 0.14 (0.08–0.27); B. 0.48 (0.38–0.60)^§^; C. 0.06 (0.03–0.12); D. 0.08 (0.04–0.13) | A. 0.48 (0.41–0.54); B. 0.68 (0.60–0.75)^§^; C. 0.79 (0.73–0.84); D. 0.94 (0.90–0.97) | A. 0.93 (0.88–0.97); B. 0.70 (0.63–0.76)^§^; C. 0.94 (0.90–0.97); D. 0.94 (0.89–0.96) | Fair
Molteno et al, 1993^76^ | 2.3 (2.0–2.6) | 0.18 (0.14–0.22) | 0.82 (0.78–0.84) | 0.74 (0.69–0.79) | Poor
Morgan et al, 1987^77^ | 3.5 (1.7–7.0) | 0.12 (0.04–0.36) | 0.84 (0.68–0.94) | 0.85 (0.62–0.97) | Fair

Study, year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N
Newman et al, 1999^12^ | Sheridan-Gardiner visual acuity; cover- uncover test; ocular movements and convergence; prism test; TNO screening plate; Snellen visual acuity | Comprehensive eye exam | Retrospective cohort | “Community setting” United Kingdom | Orthoptist | 3.5 years and at 5–6 years | Cohort of 936 children; data reported on 597
Ottar et al, 1995^78^ and Donahue et al, 2002^87^ | MTI photoscreener | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Public health and pediatric clinics United States | Orthoptist or pediatrician | 6 to 59 months | 949

Study, year | Proportion with condition | Definition of a positive screening exam | Definition of a case | Subjects
Newman et al, 1999^12^ | Amblyopia: 2.5% (15/597) | Visual acuity 6/6 or worse Manifest strabismus Decompensating heterophoria Abnormality of ocular movements Abnormal response to 20 base out prism test Negative response to TNO screening plate stereotest Any other ocular abnormality | Best corrected Snellen line acuity of 6/12 or worse in either eye and/or an interocular difference of two Snellen lines or more | Age: 3.5 years at initial screen, 5–6 years at re-screen Female: Not reported
Ottar et al, 1995^78^ and Donahue et al, 2002^87^ | Amblyogenic risk factors: 20% (192/949); higher-magnitude amblyogenic risk factors: 9% (88/939) | A. Media opacity; Strabismus; Myopic crescent ≥1 mm; Hyperopic crescent ≥2.5 mm; Astigmatism ≥2 mm; Difference between horizontal and vertical photographs of same eye; B. Media opacity >1 mm; Strabismus; Myopic crescent ≥2.5 mm (4 mm pupillary diameter), ≥4.5 mm (6 mm pupillary diameter), or ≥6.5 mm (8mm pupillary diameter); Hyperopic crescent ≥2.5 mm, ≥4.5 mm, or ≥6.5 mm; Astigmatism >1.5 mm, >2.0 mm, or >2.5 mm; Anisometropia (no crescent in fellow eye): Crescent ≥2.0 mm, ≥3.5 mm, or ≥4 mm; Anisometropia (crescent in fellow eye): Crescent ≥1 mm in fellow eye and 1 mm difference between eyes, ≤2.5 mm in fellow eye and 2 mm difference between eyes or ≥3 mm in fellow eye and 1 mm difference between eyes, or ≤3.5 mm in fellow eye and 2 mm difference between eyes or ≥4 mm crescent in fellow eye and 1 mm difference between eyes | A. Myopia >1.00 D; Hyperopia >2.75 D; Astigmatism >1.00 D; Anisometropia >1.50 D; Any media opacity; Any strabismus; Any abnormality of posterior pole; B. Myopia >3.00 D; Hyperopia >3.50 D; Astigmatism >1.50 D; Anisometropia >1.00 D | Age: Mean 29 months Female: Not reported

Study, year | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analyses | Sensitivity (95% CI) | Specificity (95% CI)
Newman et al, 1999^12^ | Not reported; screening results available for 82% (772/936) of children in cohort | Not described | 64% (597/936) | 1.0 (0.78–1.0) | 0.93 (0.91–0.95)
Ottar et al, 1995^78^ and Donahue et al, 2002^87^ | 2.5% (25/1004) small pupil diameter, poor mydriasis, or poor cooperation | Excluded from analysis | 98% (985/1004) | A. 0.82 (0.76–0.87); B. 0.50 (0.39–0.61) | A. 0.91 (0.88–0.93); B. 0.98 (0.97–0.99)

Study, year | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality score
Newman et al, 1999^12^ | 14 (10–19) | 0.03 (0.002–0.51) | 0.27 (0.16–0.41) | 1.0 (0.99–1.0) | Poor
Ottar et al, 1995^78^ and Donahue et al, 2002^87^ | A. 8.7 (6.9–11); B. 33 (18–58) | A. 0.20 (0.15–0.27); B. 0.51 (0.41–0.63) | A. 0.69 (0.62–0.75); B. 0.77 (0.64–0.87)\|\| | A. 0.95 (0.93–0.97); B. 0.95 (0.93–0.96)\|\| | Fair

Study, year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N
Rogers et al, 2008^79^ | MTI photoscreener SureSight autorefractor | Comprehensive eye exam with cycloplegic refraction | Randomized controlled trial | Pediatric ophthalmology clinic United States | Trained layperson | 1 to 6 years | 100
Shallo-Hoffmann et al, 2004^80^ | Crowded Lea Symbol and HOTV visual acuity charts, and Random Dot E stereoacuity test | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic United States (mostly attendees at Caribbean- American preschool and children of indigent Spanish- speaking farm workers) | Not described | 2 to 6 years | 269
Tong et al, 2000^83^ | MTI Photoscreener | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic | Not described | <4 years old | 387

Study, year | Proportion with condition | Definition of a positive screening exam | Definition of a case | Subjects
Rogers et al, 2008^79^ | Clinically significant amblyopia: 58% (58/100) | A. SureSight manufacturer referral criteria (hyperopia >2.00 D, myopia >1.00 D, cylinder >1.00 D, or difference >1.00 D); B. SureSight 90% VIP specificity referral criteria (≥4.00, ≥1.00, ≥1.50, or ≥3.00); C. SureSight 94% VIP specificity referral criteria (≥4.25, ≥1.00, ≥1.75, ≥3.50); D. SureSight Rowatt et al referral criteria (≥4.25, ≥1.00, ≥2.20, ≥3.00); E. MTI “gold standard” referral criteria (≥3.50, >3.00, >1.50, >1.00) | Anisometropia >1.5 D Hyperopia >3.50 D Myopia >3.00 D Media opacity >1 mm Astigmatism >1.5 D at 90 or 180° or >1.0 D in oblique axis Ptosis ≤1 mm margin reflex distance Visual acuity per age-appropriate standards Manifest strabismus | Age: 1 to 6 years (82≤5 years) Female: 55%
Shallo-Hoffmann et al, 2004^80^ | Any vision condition: 6% (5/81) | Required to pass threshold for one visual acuity test (Lea Symbol chart: correct identification of 4 of 5 symbols on the passing line for their age; HOTV chart: all or one less than all of the optotypes on the passing live for their age) and stereoacuity test (Random Dot E test: 4 out of 5 correct responses) | 2–3 years Isometropia: Myopia ≥3.00 D, hyperopia ≥4.50 D, hyperopia with esotropia >1.50 D, astigmatism >2.00 D Anisometropia: Myopia ≥2.00 D, hyperopia ≥1.50 D, astigmatism ≥2.00 D 3–5 years Isometropia: Myopia ≥3.00 D, hyperopia ≥3.50 D, hyperopia with esotropia >1.00 D, astigmatism >1.50 D Anisometropia: Myopia ≥2.00 D, hyperopia ≥1.00 D, astigmatism ≥1.50 D Any age Intermittent or constant strabismus Two-line difference in monocular visual acuities in association with monocular strabismus or amblyogenic refractive error Any pathology | Age: 2 to 5 years Female: Not reported
Tong et al, 2000^83^ | Strabismus: 49% (190/387) Refractive error: 55% (211/387) | Abnormal external exam, media opacity, strabismus, or refractive error (hyperopia ≥2.0 D, myopia ≥2.0 D, anisometropia ≥2.0 D, astigmatism ≥2.0 D) | Not described | Age: 1 to 47 months (44% 2 to 3 years)

Study, year | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analyses | Sensitivity (95% CI) | Specificity (95% CI)
Rogers et al, 2008^79^ | SureSight: 24% (24/100); 20% (9/45) among children 4 to 6 years old MTI: 4% (4/100); 0% (0/45) among children 4 to 6 years old | Considered positive screens | 100% (100/100) | A. 0.97 (0.88–1.0); B. 0.79 (0.67–0.89); C. 0.67 (0.54–0.79); D. 0.62 (0.48–0.74); E. 0.95 (0.86–0.99) | A. 0.38 (0.24–0.54); B. 0.64 (0.48–0.78); C. 0.69 (0.53–0.82); D. 0.74 (0.58–0.86); E. 0.88 (0.74–0.96)
Shallo-Hoffmann et al, 2004^80^ | HOTV: 19% (25/134) Lea: 5% (10/134) Random Dot E: 7% (20/268) | Considered positive screens | 100% (21/21) of positive screens, 24% (60/248) of negative screens | 0.73 (0.13–0.98)^¶^ | 0.94 (0.90–0.96)^¶^
Tong et al, 2000^83^ | 19% (74/387) | Classified as positive or negative screens, but unclear how this was done | 100% (387/387) | A. (all photographs):; 0.56 (0.50–0.62); B. (informative subset of 313 photographs):; 0.65 (0.59–0.71) | A. 0.91 (0.84–0.96); B. 0.87 (0.76–0.94)

Study, year | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality score
Rogers et al, 2008^79^ | A. 1.6 (1.2–2.0); B. 2.2 (1.4–3.4); C. 2.2 (1.3–3.5); D. 2.4 (1.4–4.1); E. 8.0 (3.5–18) | A. 0.09 (0.02–0.37); B. 0.32 (0.18–0.56); C. 0.47 (0.31–0.72); D. 0.51 (0.35–0.75); E. 0.06 (0.02–0.18) | A. 0.68 (0.57–0.78); B. 0.75 (0.63–0.86); C. 0.75 (0.61–0.86); D. 0.77 (0.62–0.88); E. 0.92 (0.82–0.97) | A. 0.89 (0.65–0.99); B. 0.69 (0.52–0.83); C. 0.60 (0.45–0.74); D. 0.58 (0.44–0.72); E. 0.92 (0.80–0.98) | Fair
Shallo-Hoffmann et al, 2004^80^ | 12 (4.7–28)^¶^ | 0.28 (0.03–2.4)^¶^ | 0.24 (0.08–0.47) | 1.00 (0.94–1.0) | Fair 25% sample (every 4th patient) of negative screens underwent reference standard
Tong et al, 2000^83^ | A. 6.4 (3.4–12); B. 4.9 (2.6–9.1) | A. 0.48 (0.42–0.56); B. 0.40 (0.33–0.47) | A. 0.95 (0.90–0.98); B. 0.95 (0.90–0.98) | A. 0.43 (0.36–0.50); B. 0.41 (0.33–0.49) | Fair

Study, year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Crowded Linear Lea Symbols visual acuity test | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Customized Head Start screening vans | Licensed eye professionals | 3, 4, or 5 years old | 3121

Study, year | Proportion with condition | Definition of a positive screening exam | Definition of a case | Subjects
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Any condition (amblyopia, reduced visual acuity, strabismus, or significant refractive error): 29% (755/2588) ”Very important to detect and treat early” conditions: 5.4% (135/2588) Amblyopia: 2.9% (75/2588) Reduced visual acuity: 5.1% (132/2588) Strabismus: 1.9% (48/2588) Significant refractive error: 9.3% (240/2588) | A. 10/32 for age 3 years, 10/20 for age 4 or 5 years; B. 10/32 for age 3 years, 10/25 for age 4 years, 10/20 for age 5 years^#^ | Amblyopia: ≥2 line interocular difference in visual acuity and unilateral amblyogenic factor; or visual acuity worse than 20/50 (3 years old) or 20/40 (4–5 years old) in one eye, worse than 20/40 (20/30) in contralateral eye, and bilateral amblyogenic factor Reduced visual acuity: Worse than 20/50 (20/40) in one eye, worse than 20/40 (20/30) in contralateral eye, and no bilateral amblyogenic factor; or worse than 20/50 (20/40) in one eye or ≥2-line difference between eyes (except 20/16 and 20/25), and no unilateral amblyogenic factor Strabismus Significant refractive error: Astigmatism >1.50 D, hyperopia >3.25 D, myopia >2.00 D, anisometropia (interocular difference >1.00 D for hyperopia, >3.00 for myopia, >1.50 D for astigmatism, anisometropia (defined) “Very important to detect and treat early” conditions: amblyopia presumed unilateral and worse eye visual acuity ≤20/64 or suspected bilateral; constant strabismus; anismetropia with interocular difference >2 D of hyperopia, >3 D of astigmatism, or >6 D of myopia; hyperopia ≥5.0 D; astigmatism ≥2.5 D; myopia ≥6.0 D | Age: 36 to 71 months (20% 3 years, 53% 4 years, 27% 5 years)

Study, year | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analyses | Sensitivity (95% CI) | Specificity (95% CI)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | 0.5% (6/1142) | Excluded from analysis | 83% (2588/3121) of enrolled patients | Any condition; A. 0.61 (0.56–0.66); B. 0.49 (0.44–0.54); “Very important to detect and treat early” conditions; A. 0.77 (0.70–0.84); B. 0.65 (0.57–0.73); Amblyopia; A. 0.76 (0.66–0.86); B. 0.65 (0.55–0.76); Reduced visual acuity; A. 0.58 (0.50–0.67); B. 0.48 (0.39–0.56); Strabismus; A. 0.56 (0.42–0.71); B. 0.48 (0.34–0.62); Refractive error; A. 0.70 (0.64–0.76); B. 0.40 (0.34–0.46) | Any condition; A. 0.90 (0.88–0.92); B. 0.94 (0.92–0.96)

Study, year | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality score
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Any condition; A. 6.1 (4.8–7.6); B. 8.2 (6.1–11) | Any condition; A. 0.43 (0.38–0.50); B. 0.54 (0.49–0.60) | Any condition; A. 0.73 (0.67–0.78); B. 0.78 (0.72–0.83) | Any condition; A. 0.84 (0.82–0.86); B. 0.81 (0.78–0.83) | Fair

Other screening tests from the Vision in Preschoolers Study Group82 are abstracted in the following abbreviated table
Study, year | Screening test | Definition of a positive screening exam | Proportion unexaminable by screening | Sensitivity (95% CI) | Specificity (95% CI) | Positive likelihood ratio (95% CI)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Crowded Linear HOTV visual acuity test | A. 10/25 for age 3 or 4, 10/20 for age 5 years; B. 10/32 for age 3 or 4, 10/25 for age 5 years^#^ | 0.6% (7/1141) | Any condition; A. 0.54 (0.49–0.59); B. 0.36 (0.31–0.41); “Very important to detect and treat early” conditions; A. 0.72 (0.64–0.79); B. 0.48 (0.40–0.57) | Any condition; A. 0.89 (0.87–0.91); B. 0.93 (0.91–0.95) | Any condition; A. 4.9 (3.9–6.1); B. 5.1 (3.8–6.8)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Random Dot E stereo-acuity test | A. Nonstereo card for age 3, stereo card at 50 cm for age 4, stereo card at 100 cm for age 5; B. Nonstereo card for age 3 or 4, stereo card at 50 cm for age 5 | 9.7% (111/1142) | Any condition; A. 0.42 (0.37–0.47); B. 0.22 (0.18–0.27); “Very important to detect and treat early” conditions; A. 0.59 (0.50–0.67); B. 0.30 (0.22–0.38) | Any condition; A. 0.90 (0.88–0.92); B. 0.92 (0.90–0.94) | Any condition; A. 4.2 (3.3–5.3); B. 2.7 (2.0–3.7)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Stereo Smile II stereo-acuity test | A. 240-arc sec card for age 3 or 4, 120-arc sec card for age 5; B. 480-arc sec card for age 3 or 4, 240-arc sec card for age 5 | 1.9% (27/1446) | Any condition; A. 0.44 (0.39–0.49); B. 0.33 (0.28–0.38); “Very important to detect and treat early” conditions; A. 0.72 (0.65–0.79); B. 0.57 (0.50–0.64) | Any condition; A. 0.91 (0.89–0.93); B. 0.94 (0.92–0.95) | Any condition; A. 4.9 (3.9–6.1); B. 5.5 (4.2–7.3)

Study, year | Screening test | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Crowded Linear HOTV visual acuity test | Any condition; A. 0.52 (0.46–0.58); B. 0.69 (0.63–0.74) | Any condition; A. 0.68 (0.62–0.74); B. 0.69 (0.62–0.76) | Any condition; A. 0.82 (0.79–0.84); B. 0.77 (0.74–0.80)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Random Dot E stereoacuity test | Any condition; A. 0.65 (0.59–0.71); B. 0.85 (0.80–0.90) | Any condition; A. 0.64 (0.58–0.71); B. 0.54 (0.46–0.63) | Any condition; A. 0.78 (0.75–0.81); B. 0.80 (0.78–0.83)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Stereo Smile II stereoacuity test | Any condition; A. 0.62 (0.56–0.67); B. 0.71 (0.66–0.76) | Any condition; A. 0.66 (0.60–0.72); B. 0.68 (0.62–0.75) | Any condition; A. 0.73 (0.70–0.76); B. 0.78 (0.76–0.80)

Study, year | Screening test | Definition of a positive screening exam | Proportion unexaminable by screening test | Sensitivity (95% CI) | Specificity (95% CI)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Retinomax autorefractor | A. Hyperopia ≥1.50 D, myopia ≥2.75 D, astigmatism ≥1.50 D, anisometropia ≥2.00 D (year 1) or ≥1.75 D (year 2); B. Hyperopia ≥1.75 D (year 1) or ≥2.50 (year 2), myopia ≥2.75 D, astigmatism ≥2.00 D (year 1) or ≥1.75 D (year 2), anisometropia ≥2.75 D (year 1) or ≥2.50 D (year 2)^#^ | 0.5% (6/1142) | Any condition; A. 0.64 (0.60–0.67); B. 0.52 (0.48–0.56); “Very important to detect and treat early” conditions; A. 0.87 (0.84–0.91; B. 0.81 (0.77–0.85) | Any condition; A. 0.90 (0.88–0.91); B. 0.94 (0.93–0.95)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | SureSight autorefractor | A1 Manufacturer criteria: Hyperopia ≥2.00 D, myopia >1.00 D, astigmatism >1.00 D, anisometropia >1.00 DSE; A2 VIP Study criteria: Hyperopia ≥4.00 D, myopia ≥1.00 D, astigmatism ≥1.50 D, anisometropia ≥3.00 D; B VIP Study criteria: Hyperopia ≥4.25 D, myopia ≥1.00 D, astigmatism ≥1.75 D, anisometropia ≥3.50 D^#^ | 0.3% (8/2577) | Any condition; A1 0.85 (0.81–0.88); A2 0.63 (0.59–0.65); B 0.51 (0.46–0.56); “Very important to detect and treat early” conditions; A1 0.96 (0.93–0.99); A2 0.81 (0.75–0.87); B 0.75 (0.69–0.81) | Any condition; A1 0.62 (0.59–0.65); A2 0.90 (0.88–0.92); B 0.94 (0.92–0.95)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | iScreen photoscreener | As specified by manufacturer or interpreter of iPower photoscreener | 0.1% (2/1439) | Any condition 0.37 (0.32–0.42) ”Very important to detect and treat early” conditions 0.57 (0.50–0.64) | Any condition 0.94 (0.92–0.95)

Study, year | Screening test | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Retinomax autorefractor | Any condition; A. 6.1 (5.2–7.0); B. 8.7 (7.2–10) | Any condition; A. 0.41 (0.37–0.45); B. 0.51 (0.47–0.55) | Any condition; A. 0.71 (0.68–0.75); B. 0.78 (0.74–0.82) | Any condition; A. 0.86 (0.84–0.87); B. 0.83 (0.81–0.84)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | SureSight | Any condition; A1 2.2 (2.0–2.4); A2 6.3 (5.2–7.7); B 8.6 (6.6–11) | Any condition; A. A1: 0.24 (0.19–0.30); B. A2: 0.41 (0.36–0.47); C. B: 0.52 (0.47–0.58) | Any condition; A. A1: 0.47 (0.43--0.51); B. A2: 0.71 (0.66–0.76); C. B: 0.77 (0.72–0.82) | Any condition; A. A1: 0.91 (0.89–0.93); B. A2: 0.86 (0.84–0.88); C. B: 0.83 (0.81–0.85)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | iScreen | Any condition 6.2 (4.7–8.1) | Any condition 0.67 (0.62–0.72) | Any condition 0.71 (0.64–0.77) | Any condition 0.79 (0.77–0.81)

Study, year | Screening test | Definition of a positive screening exam | Proportion unexaminable by screening test | Sensitivity (95% CI) | Specificity (95% CI)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | MTI photoscreener | As specified by manufacturer or interpreter of MTI photoscreener | 0% (0/1444) | Any condition 0.37 (0.32–0.42) ”Very important to detect and treat early” conditions 0.55 (0.48–0.63) | Any condition 0.94 (0.92–0.95)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Power Refractor II | A. Hyperopia ≥3.50 D, myopia ≥3.00 D, astigmatism ≥2.00 D, anisometropia ≥1.50 D; B. Hyperopia ≥5.00 D, myopia ≥3.75 D, astigmatism ≥2.25 D, anisometropia ≥2.75 D^#^ | 1.5% (22/1438) | Any condition; A. 0.54 (0.49–0.59); B. 0.36 (0.31–0.41); “Very important to detect and treat early” conditions; A. 0.72 (0.65–0.79); B. 0.56 (0.48–0.63) | Any condition; A. 0.90 (0.88–0.92); B. 0.94 (0.92–0.95)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Cover-uncover test | Heterotropia | 2.1% (24/1141) | Any condition: 0.16 (0.12–0.20) “Very important to detect and treat early” conditions: 0.24 (0.17–0.31) | Any condition 0.98 (0.97–0.99)

Study, year | Screening test | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive
Vision in Preschoolers Study Group (Phase I), 2004^82^ | MTI photoscreener | Any condition 6.2 (4.7–8.1) | Any condition 0.67 (0.62–0.72) | Any condition 0.71 (0.64–0.77) | Any condition 0.79 (0.77–0.81)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Power Refractor II | Any condition; A. 5.4 (4.4–6.6); B. 6.0 (4.6–7.9) | Any condition; A. 0.51 (0.46–0.57); B. 0.68 (0.63–0.73) | Any condition; A. 0.68 (0.65–0.73); B. 0.70 (0.64–0.76) | Any condition; A. 0.83 (0.81–0.85); B. 0.79 (0.76–0.81)
Vision in Preschoolers Study Group (Phase I), 2004^82^ | Cover-uncover test | Any condition 7.9 (4.6–14) | Any condition 0.86 (0.82–0.90) | Any condition 0.78 (0.66–0.86) | Any condition 0.73 (0.70–0.76)

Study, year | Screening test | Reference standard | Type of study | Setting | Screener | Age of enrollees | N
Weinand et al, 1998^84^ | MTI photoscreener | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic | Not described | 6 to 48 months | 112
Williams et al, 2000^85^ | Topcon PR2000 autorefractor | Comprehensive eye exam with cycloplegic refraction | Cross-sectional | Pediatric ophthalmology clinic United Kingdom | Orthoptist | 12.5 to 68.7 months | 222

Study, year | Proportion with condition | Definition of a positive screening exam | Definition of a case | Subjects
Weinand et al, 1998^84^ | Any abnormality: 81% (83/102) Refractive error: 41% (41/102) Strabismus without refractive error: 7% (7/102) Strabismus with refractive error: 21% (21/102) Organic anomaly: 13% (13/102) | Crescent at least half the pupil diameter, asymmetry of light reflexes, or organic abnormalities | Refractive error ≥2 D Manifest strabismus Any organic anomaly | Age: 6 to 48 months Female: Not reported
Williams et al, 2000^85^ | A. Spherical error; >3.75 D: 19% (36/189); B. Anisometropia; >1.25 D: 12% (23/189); C. Astigmatism; >1.25 D: 16% (30/189) | Various cutoffs evaluated, cutoffs not pre-defined | Spherical error >3.75 D Anisometropia >1.25 D Astigmatism >1.25 D | Age: Median 48 months Female: Not reported

Study, year | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analyses | Sensitivity (95% CI) | Specificity (95% CI)
Weinand et al, 1998^84^ | 9% (10/112) | Not described | 91% (102/112) | A. (Pediatrician interpreter): 0.94 (0.86–0.98); B. (Orthoptist interpreter): 0.80 (0.69–0.88); C. (Ophthalmologist 1 interpreter): 0.72 (0.61–0.82); D. (Ophthalmologist 2 interpreter): 0.86 (0.76–0.92) | A. (Pediatrician interpreter): 0.42 (0.20–0.66); B. (Orthoptist interpreter): 0.74 (0.49–0.91); C. (Ophthalmologist 1 interpreter): 0.74 (0.49–0.91); D. (Ophthalmologist 2 interpreter): 0.58 (0.34–0.80)
Williams et al, 2000^85^ | 15% (33/222) | Excluded from analysis | 85% (189/222) | A. 0.50 (0.33–0.67) **; B. 0.74 (0.52–0.90) **; C. 0.47 (0.28–0.66) ** | A. 0.95 (0.90–0.98) **; B. 0.95 (0.91–0.98) **; C. 0.96 (0.92–0.99) **

Study, year | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality score
Weinand et al, 1998^84^ | A. (Pediatrician interpreter):; 1.6 (1.1–2.4); B. (Orthoptist interpreter):; 3.0 (1.4–6.5); C. (Ophthalmologist 1 interpreter):; 2.8 (1.3–5.9); D. (Ophthalmologist 2 interpreter):; 2.0 (1.2–3.5) | A. (Pediatrician interpreter):; 0.14 (0.05–0.39); B. (Orthoptist interpreter):; 0.28 (0.17–0.46); C. (Ophthalmologist 1 interpreter):; 0.38 (0.24–0.58); D. (Ophthalmologist 2 interpreter):; 0.25 (0.13–0.48) | A. (Pediatrician interpreter):; 0.88 (0.79–0.94); B. (Orthoptist interpreter):; 0.93 (0.84–0.98); C. (Ophthalmologist 1 interpreter):; 0.92 (0.83–0.98); D. (Ophthalmologist 2 interpreter):; 0.90 (0.81–0.96) | A. (Pediatrician interpreter):; 0.62 (0.32–0.86); B. (Orthoptist interpreter):; 0.45 (0.27–0.64); C. (Ophthalmologist 1 interpreter):; 0.38 (0.22–0.55); D. (Ophthalmologist 2 interpreter):; 0.48 (0.27–0.69) | Fair
Williams et al, 2000^85^ | A. 9.6 (4.5–20); B. 15 (7.5–32); C. 12 (5.2–30) | A. 0.53 (0.38–0.73); B. 0.27 (0.14–0.55); C. 0.55 (0.40–0.78) | A. 0.69 (0.48–0.86); B. 0.68 (0.46–0.85); C. 0.70 (0.46–0.88) | A. 0.89 (0.83–0.93); B. 0.96 (0.92–0.99); C. 0.91 (0.85–0.94) | Fair

* Raw data not provided, unable to calculate confidence intervals.

† Corrected for verification bias based on a 20% sample of negative screens.

‡ Interpretable by at least 6 of 11 reviewers.

§ Calculation based on n=379, median sensitivity and specificity.

|| Based on reported sensitivity and specificity, does not match values reported in article.

¶ Corrected for verification bias based on a 25% sample of negative screens.

# Determined by cutoff to achieve specificity of 0.95.

** Results based on cutoffs to obtain specificity at least 95%.

Abbreviations: CI=confidence interval; RCT=randomized controlled trial.

Appendix B4 Diagnostic Accuracy Quality Ratings

Study, year | Representative spectrum | Random or consecutive sample | Screening test adequately described | Screening cutoffs predefined | Credible reference standard | Reference standard applied to all screened | Same reference standard applied to all | Reference standard and screening examination interpreted independently | High rate of uninterpretable results or non-compliance with screening test | Analysis includes patients with uninterpretable results or noncompliance | Quality Score
Arthur et al, 2009^57^ | Yes | Can’t tell | Yes | Yes | Yes | Yes | Yes | Yes | No | NA | Fair
Barry et al, 2001^10^ | Yes | Yes | Yes | Yes | Can’t tell | No | No | Can’t tell | Can’t tell | Can’t tell | Fair
Barry et al, 2003^11^ | Yes | Yes | Yes | Yes | Can’t tell | No | No | Yes | Yes | No | Fair
Berry et al, 2001^58^ | No | Can’t tell | Yes | Yes | Yes | Yes | Yes | Yes | Can’t tell | Can’t tell | Fair
Bertuzzi et al, 2006^59^ | Yes | Can’t tell | Yes | Yes | Yes | Yes | Yes | Can’t tell | No | No | Fair
Chang et al, 2007^60^ | Yes | Can’t tell | No | Yes | Yes | Yes | Yes | Can’t tell | No | Can’t tell | Fair
Chui et al, 2004^61^ | Yes | Can’t tell | Yes | Yes | Yes | No | Yes | Yes | Can’t tell | Yes | Fair
Cogen et al, 1992^62^ | Yes | Can’t tell | Yes | Yes | Yes | No | Yes | Yes | Yes | No | Fair
Cooper et al, 1999^63^ | No | Can’t tell | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Poor
Dahlmann-Noor et al, 2009a64 | No | Can’t tell | Yes | No | Yes | Yes | Yes | Yes | Yes | No | Fair
Dahlmann-Noor et al, 2009b65 | Yes | Can’t tell | Yes | Yes | Can’t tell | Yes | No | Can’t tell | No | NA | Fair
Ehrt et al, 2007^66^ | No | Can’t tell | Yes | Yes | Can’t tell | Can’t tell | No | Can’t tell | Yes | Yes | Poor
Guo et al, 2000^67^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Hope et al, 1990^68^ | Yes | Can’t tell | Yes | Yes | Yes | Yes | No | Can’t tell | No | No | Fair
Kemper et al, 2005^69^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Can’t tell | Can’t tell | Can’t tell | Fair
Kennedy et al, 1989^70^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | NA | Fair
Kennedy et al, 1995^71^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Can’t tell | No | NA | Fair
Kennedy et al, 2000^72^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Fair
Matta et al, 2008^73^ | No | Can’t tell | Yes | Yes | Yes | Yes | Yes | Can’t tell | Can’t tell | Can’t tell | Fair
Miller et al, 1999^74^ | No (High prevalence population) | Can’t tell | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Miller et al, 2001^75^ | No (High prevalence population) | Can’t tell | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Molteno et al, 1993^76^ | No | Can’t tell | Yes | Yes | No | Yes | No | Can’t tell | Can’t tell | Can’t tell | Poor
Morgan et al, 1987^77^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Fair
Newman et al, 1999^12^ | Yes | Yes | Yes | Yes | Can’t tell | No | Yes | Can’t tell | Can’t tell | Can’t tell | Poor
Ottar et al, 1995^78^ | Yes | Can’t tell | Yes | Yes | Yes | Yes | Yes | Can’t tell | No | Yes | Fair
Rogers et al, 2008^79^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Shallo-Hoffmann et al, 2004^80^ | Yes | Can’t tell | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Tong et al, 2000^83^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
VIP, 2004^82^ | No | Can’t tell | Yes | No | Yes | Yes | Yes | Yes | No | No | Fair
Weinand et al, 1998^84^ | No | Can’t tell | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Fair
Williams et al, 2000^85^ | Yes | Can’t tell | Yes | No | Yes | Yes | Yes | Yes | Yes | No | Fair

Appendix B5 Treatment Evidence Table

Author, year | Purpose of study | Study design | Inclusion criteria | Exclusion criteria | # screened/eligible/enrolled | Subject age, sex, diagnosis | Country & setting | Sponsor
Treatment vs. no treatment
Clarke et al, 2003^99^ | To test efficacy of treatment for unilateral visual loss detected by preschool vision screening and extent to which effectiveness varies with initial severity | RCT | Ages 3–5 years; presence of 6/6 (20/20) vision in one eye and 6/9 (20/30) to 6/36 (2/120) in the other following two screening tests | Ocular abnormalities other than amblyopia | 490/254/177 | Mean age: 4.0 years Proportion of patients with anisometropia: 127/177 (72%) Baseline visual acuity, amblyopic eye^*^: 58/177 (33%) 0.18; 52/177 (29%) 0.30; 42/177 (24%) 0.48; 12/177 (7%) 0.60; 13/177 (7%) 0.78; mean 0.36 | UK 8 clinical sites | National Health Service Research & Development
Patching treatment vs. no treatment ( >85% received eyeglasses)
Awan et al, 2005^101^ | To investigate compliance with patching therapy and dose-effect relationship in occlusion therapy for amblyopia | RCT | Ages ≤8 years; ability to perform a vision test with Glasgow acuity cards; 2 lines of difference in visual acuity on Snellen eye chart | Unable to reliably comply with visual acuity test; >2 lines interocular difference; previous occlusion; no strabismus | 77/70/60 | Mean age: 4.6 years Mean visual acuity, amblyopic eye: 0.64 Mean visual acuity, sound eye: 0.02 Strabismus: 27/60 (45%) Mixed amblyopia: 25/60 (42%) Proportion of patients requiring refractive correction at baseline: 55/60 (92%) | UK 1 clinical site | National Eye Research Centre; Ulverscroft Foundation

Author, year, title | Measures | Intervention Type | Results | Duration of follow-up | Loss to follow-up | Adverse events | Quality score
Treatment vs. no treatment
Clarke et al, 2003^99^ | BCVA in amblyopic eye after 1 year; follow-up at 1.5 years | Patching + eyeglasses (n=59) vs. eyeglasses only (n=59) vs. no treatment (n=59) for 52 weeks, after which the no-treatment group received eyeglass prescriptions | Mean BCVA Patching + eyeglasses: 0.193 (SD, 0.12) Eyeglasses only: 0.216 (SD, 0.17) No treatment: 0.301 (SD, 0.20); p=0.001 Mean BCVA according to baseline severity [underlined: Mild acuity loss at baseline] Patching + eyeglasses (n=33): 0.18 (SD, 0.11) Eyeglasses only (n=35): 0.16 (SD, 0.14) No treatment (n=33): 0.22 (SD, 0.17); p=0.11 [underlined: Moderate acuity loss at baseline] Patching + eyeglasses (n=21): 0.22 (SD, 0.13) Eyeglasses only (n=20): 0.31 (SD, 0.17) No treatment (n=22): 0.42 (SD, 0.19) Mean change in BCVA following 52 weeks of treatment, according to baseline severity [underlined: Mild acuity loss at baseline] Patching + eyeglasses (n=31): 0.23 (SD, 0.17) Eyeglasses only (n=31): 0.24 (SD, 0.14) No treatment (n=30): 0.19 (SD, 0.17) [underlined: Moderate acuity loss at baseline] Patching + eyeglasses (n=20): 0.52 (SD, 0.19) Eyeglasses only (n=18): 0.35 (SD, 0.20) No treatment (n=21): 0.25 (SD, 0.21) | 1.5 years (78 weeks) | At 54 weeks: 13/177 (7.3%) At 78 weeks: 23/177 (13.0%) | Proportion of patients w/loss of visual acuity in amblyopic eye, according to baseline severity [underlined: Mild acuity loss at baseline] Patching + eyeglasses: 3/31 (9.7%) Eyeglasses only: 2/31 (6.5%) No treatment: 4/30 (13.3%) [underlined: Moderate acuity loss at baseline] Patching + eyeglasses: 3/20 (15.0%) Eyeglasses only: 2/18 (11.1%) No treatment:5/21 (23.8%) | Good
Patching treatment vs. no treatment ( >85% received eyeglasses)
Awan et al, 2005^101^ | Primary outcome: mean compliance Other outcomes: improvement in visual acuity following 12 weeks of treatment | 3 hours patching/day (n=20) vs. 6 hours patching/day (n=20) vs. no treatment for 12 weeks | Mean change in visual acuity 3-hr patching: 0.29 (SD,0.14) 6-hr patching: 0.34 (SD, 0.19) No treatment: 0.24 (SD, 0.17) Snellen equivalent (lines of improvement) 3-hr patching: 1.9 (SD, 1.0) 6-hr patching: 2.3 (SD, 1.2) No treatment: 1.6 (SD, 0.12) | 12 weeks | 8/60 (13%) | Compliance 3-hr patching: 57.5% 6-hr patching: 41.2% Mean time patching 3-hr patching: 1 hour 43 minutes 6-hr patching: 2 hours 33 minutes | Fair

Author, year, title | Purpose of study | Study design | Inclusion criteria | Exclusion criteria
Pediatric Eye Disease Investigator Group, 2006^100^ | To compare 2 hrs of daily patching (combined with 1 hr of concurrent near visual activities) with a control group of eyeglass wear alone (if needed) for treatment of moderate to severe amblyopia in children ages 3 to 7 years | RCT | Age 3–7 years at enrollment; able to have visual acuity determined using the Amblyopia Treatment Study single-surround HOTV protocol; visual acuity in the amblyopic eye of 20/40 to 20/400; visual acuity in the sound eye of 20/40; interocular acuity difference ≥0.3 logMAR (3 lines); completed eyeglass phase or already in optimal correction at least 16 weeks or eyeglasses not needed; amblyopia associated with strabismus, anisometropia, or both meeting the following criteria:; - Strabismic amblyopia: amblyopia in the presence of a heterotropia at distance and/or near fixation, or a history of strabismus surgery (or botulinum), or a documented history of strabismus; - Anisometropic amblyopia: amblyopia in the presence of a 0.50-D difference between eyes in spherical equivalent and/or 1.50-D difference between eyes in astigmatism in any meridian; - Combined mechanism amblyopia: amblyopia in the presence of 1) a heterotropia at distance and/or near fixation, or a history of strabismus surgery (or botulinum), or a documented history of strabismus, and 2) a 1.00-D difference between eyes in spherical equivalent or 1.50-D difference between eyes in astigmatism in any meridian | Amblyopia treatment (other than eyeglasses) in the past month or 1 month of amblyopia treatment in the past 6 months; current vision therapy or orthoptics; ocular cause for reduced visual acuity; myopia more than a spherical equivalent of 6.00 D; prior intraocular or refractive surgery; known skin reactions to patch or bandage adhesives
Occlusion regimens
Pediatric Eye Disease Investigator Group, 2003^102^ | To compare 2 hrs vs. 6 hrs of daily patching as treatment for moderate amblyopia in children ages <7 years | RCT | Age <7 years; able to measure visual acuity using the Amblyopia Treatment Study visual acuity testing protocol with the Electronic Visual Acuity Tester 8; visual acuity in the amblyopic eye 20/40 and 20/80; visual acuity in the sound eye 20/40; intereye acuity difference ≥3 logMAR; if amblyopia was previously treated, no patching treatment within 6 months of enrollment and no other amblyopia treatment of any type (other than eyeglasses) within 1 month of enrollment (any treatment more than 6 month prior to enrollment was acceptable); refractive error corrected for at least 4 weeks; amblyopia associated with strabismus, refractive error/anisometropia, or both meeting the following criteria:; - Strabismic amblyopia: amblyopia 1) in the presence of either a heterotropia at distance and/or near fixation or a history of strabismus surgery (or botulinum), and 2) in the absence of refractive error meeting the criteria below for combined-mechanism amblyopia; - Refractive/anisometropic: amblyopia in the presence of anisometropia ≥0.5 D of spherical equivalent or ≥1.50 D difference in astigmatism in any meridian, with no measurable heterotropia at distance or near fixation, that persisted after at least 4 weeks of eyeglass correction; - Combined-mechanism (strabismic and anisometropic): amblyopia 1) in the presence of either a heterotropia at distance and/or near fixation or a history of strabismus surgery (or botulinum), and 2) anisometropia ≥1.00 D. spherical equivalent or ≥1.50 D difference in astigmatism in any meridian that persisted after at least 4 weeks of eyeglass correction. | Presence of an ocular cause for reduced visual acuity; myopia with a spherical equivalent of −6.00 D; prior intraocular surgery; known skin reaction to patch or bandage adhesive

Author, year, title | # screened/eligible/enrolled | Subject age, sex, diagnosis | Country & setting | Sponsor | Measures | Intervention Type
Pediatric Eye Disease Investigator Group, 2006^100^ | NR/NR/180 | Mean age: 5.3 years Sex: 49.4% female Ethnicity: 81% white; 6% black; 9% Hispanic/Latino; 1% Asian; 3% mixed race; <1% unknown History: 89% no prior amblyopia treatment; 8% prior patching; <1% prior atropine; 2% prior patching and atropine Diagnosis: 23% strabismus; 47% anisometropia; 30% strabismus and anisometropia Mean visual acuity, amblyopic eye: 0.55 (SD, 0.23); Snellen equivalent, 20/80 Mean visual acuity, sound eye: 0.03 (SD, 0.11); Snellen equivalent, 20/20 Mean refractive error, amblyopic eye: 4.92 (SD, 2.13) Mean refractive error, sound eye: 2.72 (SD, 1.93) Proportion of patients requiring refractive correction at baseline: 155/180 (86%) | U.S. 46 clinical sites | National Eye Institute | BCVA in amblyopic eye after 5 weeks of treatment | 16 week run-in for patients who required use of eyeglasses followed by randomization to patching (n=87) or control (n=93) groups for 5 weeks (with continued use of eyeglasses if needed, regardless of randomization group) Patching regimen: 2 continuous hrs per day, with at least 1 hr of near activities (requiring hand-eye coordination) during patching
Occlusion regimens
Pediatric Eye Disease Investigator Group, 2003^102^ | NR/NR/189 | Mean age: 5.2 years Sex: 44% female Ethnicity: 85% white; 4% African-American; 6% Hispanic; 1% Asian-American; 2% mixed race; 2% other Diagnosis: strabismus 40%; anisometropia 33%; strabismus and anisometropia 27% Mean visual acuity, amblyopic eye: 0.48 (SD, 0.10) Mean visual acuity, sound eye: 0.07 (SD, 0.10) Mean refractive error, amblyopic eye: 4.12 (SD, 3.00) Mean refractive error, sound eye: 3.07 (SD, 2.35) | U.S. 35 ophthalmology clinics | National Eye Institute | Visual acuity in amblyopic eye at 4 months | Sound eye occlusion, 2 hours/day (n=95) vs. 6 hours/day (n=94) for 4 months

Author, year, title | Results | Duration of follow-up | Loss to follow-up | Adverse events | Quality score
Pediatric Eye Disease Investigator Group, 2006^100^ | Mean change in visual acuity from baseline: patching 1.1 lines vs. control 0.5 lines (adjusted mean difference, 0.07 [95% CI, 0.02–0.12]; p=0.006) Proportion of patients with ≥2 lines of improvement in visual acuity: patching 38/85 (44.7%) vs. control 18/88 (20.5%) | 5 weeks | 7/180 (3.9%) | Withdrawals at 5 weeks: patching 2/87 (2.3%) vs. control 5/93 (5.4%) Withdrawals due to AEs not reported Proportion of patients with loss of ≥2 lines of visual acuity, amblyopic eye: patching 4/85 (4.7%) vs. control 8/88 (9.0%) Proportion of patients with loss of ≥2 lines of visual acuity, sound eye: patching 2/85 (2.4%) vs. control 6/88 (6.8%); p=0.28 | Good
Occlusion regimens
Pediatric Eye Disease Investigator Group, 2003^102^ | Mean improvement in visual acuity: 2.40 lines (SD, 1.34) 2- hr/day patching vs. 2.40 lines (SD, 1.63) 6-hr/day patching (mean between-group difference, 0.001 [95% CI, −0.040 to 0.042]) Physician-rated adherence, 2-hr/day patching vs. 6- hr/day patching: Excellent: 58% vs. 37% Fair:14% vs. 15% Poor: 3% vs. 11% | 4 months | 8/189 (4.2%) | Loss of ≥2 lines of visual acuity: 6/89 (7%) 2-hr/day patching vs. 8/92 (9%) 6-hr/day patching; p=0.59 Intermittent exotropia: 1/89 (1%) 2-hr/day patching vs. 1/92 (1%) 6-hr/day patching Small-angle strabismus: 2/89 (2%) 2-hr/day patching vs. 1/92 (1%) 6- hr/day patching | Good

Author, year, title | Purpose of study | Study design | Inclusion criteria | Exclusion criteria | # screened/eligible/enrolled
Stewart et al, 2007^103^ | To compare visual outcome in response to 2 prescribed rates of occlusion: 6 hrs/day vs. 12 hrs/day | RCT (not blinded) | Age 3–8 years with anisometropia and/or strabismus; a significant difference (at least 0.1 logMAR) in intraocular acuity; no occlusion therapy; no ocular pathology or learning difficulties | NR | NR/122/97 (refractive adaptation phase); 80 (occlusion phase)
Atropine regimens
Pediatric Eye Disease Investigator Group, 2004^104^ | To compare daily atropine as prescribed treatments for moderate amblyopia in children ages < 7 years | RCT | Age < 7 years; able to measure visual acuity using ATS visual acuity testing protocol on EVA Tester; visual acuity in amblyopic eye ≤20/40 and ≥20/80; visual acuity in sound eye ≥20/40; intereye acuity difference ≥3 logMAR lines; no amblyopia treatment (other than eyeglasses) in month before enrollment and no more than 1 month of amblyopia treatment in 6 months before enrollment (any treatment more than 6 months before enrollment acceptable); refractive error corrected for at least 4 wks; amblyopia associated with strabismus, refractive error/anisometropia, or both meeting the following criteria:; - Strabismic amblyopia: amblyopia 1) in the presence of either heterotropia at distance and/or near fixation or a history of strabismus surgery (or botulinum) and 2) in the absence of refractive error, meeting criteria below for combined mechanism amblyopia; - Refractive/anisometropic: amblyopia in the presence of anisometropia of ≥0.50 D of SE or ≥1.50-D difference in astigmatism in any meridian, with no measurable heterotropia at distance or near fixation, which persisted after at least 4 wks of eyeglass correction; - Combined mechanism: amblyopia 1) in the presence of either heterotropia at distance and/or near fixation or a history of strabismus surgery (or botulinum) and 2) anisometropia of ≥1.00-D SE or ≥1.50-D difference in astigmatism in any meridian, which persisted after at least 4 wks of eyeglass correction | Ocular cause for reduced visual acuity; myopia >SE − 6.00 D in amblyopic eye; myopia > SE − 0.50 D in sound eye; bifocal glasses; Down syndrome; prior intraocular surgery; known allergic reaction to atropine | NR/NR/168

Author, year, title | Subject age, sex, diagnosis | Country & setting | Sponsor | Measures | Intervention Type | Results
Stewart et al, 2007^103^ | Mean age: 5.6 years Sex: NR Anisometropia: 42/97 (43%) Strabismus: 21/97 (22%) Mixed anisometropia + strabismus: 34/97 (35%) Mean visual acuity, amblyopic eye: 0.55 logMAR (SD, 0.28) | UK; 2 ophthalmology clinics | Fight for Sight UK | Visual acuity following 18 wks of refractive adaptation followed by up to 26 wks of occlusion (mean duration of occlusion, 9 wks); objectively monitored rate of occlusion | 18 wks refractive adaptation w/eyeglasses, followed by occlusion 6 hrs/day (n=40) or 12 hrs/day (n=40) until visual acuity no longer improved (up to 26 wks; mean duration, 9 wks) | Mean change in visual acuity: 0.26 (95% CI, 0.21– 0.31) 6-hr/day vs. 0.24 (95% CI, 0.19– 0.29) 12-hr/day Mean daily occlusion: 4.2 hr/day (95% CI, 3.7–4.7) 6- hr/day group vs. 6.2 hr/day (95% CI, 5.1–7.3) 12-hr/day group; p=0.06
Atropine regimens
Pediatric Eye Disease Investigator Group, 2004^104^ | Mean age: 5.3 years; Sex: 39% female Ethnicity: 79% white; 4% black; 12% Hispanic; 2% Asian; 1% American Indian/Alaskan Native; 1% mixed race; 2% unknown/not reported Strabismus: 33%; Anisometropia: 41% Strabismus + anisometropia: 23% Mean distance visual acuity, amblyopic eye: 0.46 (SD, 0.10) Mean distance visual acuity, sound eye: 0.05 (SD, 0.10) Mean refractive error, amblyopic eye: 4.22 (SD, 2.37) Mean refractive error, sound eye: 3.03 (SD, 2.16) | US; 30 clinical sites | National Eye Institute | Visual acuity in amblyopic eye after 4 months of treatment | 1% atropine sulfate daily (n=83) vs. weekends only (n=85) for 4 months | Mean change in visual acuity at 4 months: daily group 2.3 lines vs. weekend group 2.3 lines (mean between-group difference, 0.00 [95% CI, −0.04 to 0.04]) Increase of ≥2 lines of visual acuity at 4 months (completers): daily use 56/77 (72.7%) vs. weekend use 60/83 (72.3%)

Author, year, title | Duration of follow-up | Loss to follow-up | Adverse events | Quality score
Stewart et al, 2007^103^ | Up to 26 weeks | 0/80 (occlusion group) | NR | Fair
Atropine regimens
Pediatric Eye Disease Investigator Group, 2004^104^ | 4 months; 26 daily and 32 weekend patients continued treatment beyond study endpoint (up to 26 weeks; mean 10 additional weeks) | 8/168 (4.8%) | Withdrawals due to AEs: 4/83 (4.8%) daily group vs. 0/84 (0%) weekend group Loss of ≥2 lines of visual acuity, sound eye: 2/77 (2.6%) daily use vs. 2/83 (2.4%) weekend use; p=0.99 | Good

Author, year, title | Purpose of study | Study design | Inclusion criteria | Exclusion criteria | # screened/eligible/enrolled | Subject age, sex, diagnosis
Patching versus atropine
Pediatric Eye Disease Investigator Group, 2002^105,†^ Additional publications: Pediatric Eye Disease Investigator Group, 2005^109^ 2008^110^ 2003^113^ 2003^126^ | To compare patching and atropine as treatments for moderate amblyopia in children age <7 years | RCT | Age <7 years; able to measure visual acuity using ATS visual acuity testing protocol; visual acuity in amblyopic eye 20/40 and 20/100; visual acuity in sound eye 20/40; intereye acuity difference 3 lines; no more than 2 months of amblyopia therapy in past 2 years (any treatment more than 2 years ago acceptable); refractive error corrected for at least 4 wks; amblyopia associated with strabismus, refractive error/anisometropia or both meeting the following criteria:; - Strabismic amblyopia: amblyopia 1) in presence of either heterotropia at distance and/or near fixation or history of strabismus surgery (or botulinum) and 2) in the absence of refractive error, meeting criteria below for combined-mechanism amblyopia.; - Refractive/anisometropic: amblyopia in presence of anisometropia 0.5-D spherical equivalent or 1.50-D difference in astigmatism in any meridian, with no measurable heterotropia at distance or near fixation, that persisted after at least 4 wks of eyeglass correction.; - Combined-mechanism: amblyopia in the presence of 1) either heterotropia at distance and/or near fixation or history of strabismus surgery (or botulinum), and 2) anisometropia 1.00-D spherical equivalent or 1.50-D difference in astigmatism in any meridian that persisted after at least 4 wks of eyeglass correction | Presence of ocular cause for reduced visual acuity; prior intraocular surgery; myopia (spherical equivalent of ≥ −0.50 D) in either eye; Down syndrome; known skin reaction to patch or bandage adhesive, or allergy to atropine or other cycloplegics | NR/NR/419 | Mean age: 5.3 years Sex: 47% female Ethnicity: 83% white; 5% black; 6% Hispanic; 2% Asian; 2% mixed; 2% other 74% no prior amblyopia treatment; 20% prior patching; 2% prior atropine use; 0.2% prior patching + atropine use; 5% other prior treatment (including eyeglass occluder and fogging) Cause of amblyopia: 38% strabismus; 37% amblyopia; 24% strabismus + anisometropia Mean visual acuity, amblyopic eye: 0.53 (SD, 0.13) Mean visual acuity, sound eye: 0.09 (SD, 0.11) Mean intereye acuity difference: 4.4 lines (SD, 1.3) Mean refractive error, amblyopic eye: 4.46 (SD, 2.13) Mean refractive error, sound eye: 2.82 (SD, 2.00)

Author, year, title | Country & setting | Sponsor | Measures | Intervention Type | Results
Patching vs. atropine
Pediatric Eye Disease Investigator Group, 2002^105,†^ Additional publications: Pediatric Eye Disease Investigator Group, 2005^109^ 2008^110^ 2003^113^ 2003^126^ | US; 47 clinical sites | National Eye Institute | Visual acuity after 6 months | Patching (n=215) vs. 1% atropine sulfate (n=204) 1 drop/day for 6 months Patching regimen: min 6 hr/day to max all waking hr/day; treatment maintained with minimal patching as long as reverse amblyopia did not develop; patching time could be reduced (but had to be at least 7 hrs/week) provided that visual acuity in amblyopic eye remained at least 1 or more lines of visual acuity worse than the sound eye; if visual acuity between two eyes became equal, patching was discontinued; if criteria for successful treatment not met by 16 wks, patching time increased to 12 (or more) hrs/day if not previously at that level Atropine regimen: Daily atropine use, with encouraged use of sunglasses and hats when in sunlight; if visual acuity in amblyopic eye met criteria for successful treatment, use of atropine could be reduced to 2x/wk; if visual acuity in both eyes became the same, atropine use could be discontinued; hyperopic patients (sound eye) had na eyeglass lens reduction if amblyopic eye visual acuity was not improved following 16 wks of treatment; if allergic to atropine, patients were switched to 5% topical homatropine | [underlined: 6-month results: mean age 5.2 years] Mean change in visual acuity from baseline, amblyopic eye: patching 3.16 lines (SD, 1.6) vs. atropine 2.84 lines (SD, 1.6) Patients with ≥3 lines of improvement from baseline: patching 146/208 (70.1%) vs. atropine 116/194 (59.8%) Patients with treatment success (visual acuity 20/30 or better or ≥3 lines of improvement from baseline): patching 164/208 (78.8%) vs. atropine 144/194 (74.2%) (95% CI, −4.0 to 13.0) [underlined: 2-year results: mean age 7.2 years] Follow-up of 363/419 (86.6%) enrolled patients; mean change in visual acuity from baseline, amblyopic eye: patching 3.7 lines (SD, 1.7) vs. atropine 3.6 lines (SD, 1.8) [underlined: 5-year results: mean age 10.3 years] 176/419 (42.0%) of patients in original study; mean visual acuity, amblyopic eye: patching 0.19 (SD, 0.14) vs. atropine 0.16 (SD, 0.16) Mean visual acuity, sound eye: −0.03 Mean visual acuity in amblyopic eye: patients <5 years at randomization 0.14 (20/25 or 2 lines; n=68/169) vs. patients >5 years at randomization 0.20 (20/32; n=101/169); p=<0.001 Visual acuity 20/25 or better at age 10 years: patients <5 years at randomization 57% vs. patients >5 years at randomization 38%; p=0.004 Proportion of patients with visual acuity 20/25 or better, amblyopic eye: patching 42% vs. atropine 49%; p=0.74

Author, year, title | Duration of follow-up | Loss to follow-up | Adverse events | Quality score | Comments
Patching vs. atropine
Pediatric Eye Disease Investigator Group, 2002^105,†^ Additional publications: Pediatric Eye Disease Investigator Group, 2005^109^ 2008^110^ 2003^113^ 2003^126^ | Initial trial: 6 months; voluntary follow-up to age 10 years | RCT: 17/419 (4.1%) | [underlined: 6-month results] Withdrawals: patching 7/215 (3.3%) vs. atropine 10/204 (4.9%); withdrawals due to AEs not reported Loss of 1 line of visual acuity, sound eye: patching 14/208 (6.7%) vs. atropine 30/194 (15.5%) Loss of ≥2 lines of visual acuity, sound eye: patching 3/208 (1.4%) vs. atropine 17/194 (8.8%); p<0.001 Loss of visual acuity requiring treatment: 0/208 (0%) patching vs. 1/194 (0.5%) atropine Skin irritation in patching group: 98/208 (47%) Any ocular AE in atropine group: 50/194 (26%) Amblyopia Treatment Index Score, mean overall score: patching 2.52 (SD, 0.63) vs. atropine 2.02 (SD, 0.63); p<0.001 Mean Adverse Effects subscale score: patching 2.35 (SD, 0.69) vs. atropine 2.11 (SD, 0.72); p=0.002 Mean Lack of Treatment Compliance subscale score: patching 2.46 (SD, 0.96) vs. atropine 1.99 (SD, 0.83); p<0.001 Mean Social Stigma subscale score: patching 3.09 (SD, 0.81) vs. 1.84 (SD, 0.74; p<0.001 [underlined: 2-year results] Mean visual acuity, sound eye: patching −0.02 (SD, 0.08) vs. atropine −0.01 (0.10); p=0.27 Recovery of loss of visual acuity in patients with previous loss of ≥2 lines of visual acuity (to 20/20 or equal): patching 3/3 (100%) vs. atropine 16/17 (94.1%) | Good | At 10 yrs follow-up, patients <5 yrs at randomization had significantly better amblyopic eye visual acuity than patients >5 yrs at randomization regardless of initial cause of amblyopia. Mean visual acuity at 10-yr follow-up: age <5 yrs 0.14 logMAR (68/154) vs. age >5 yrs 0.20 logMAR (101/265); p<0.001

* Converted from Snellen metric measures.

† Included in previous version of report; results of long-term follow-up subsequently published in 2005 and 2008.

Abbreviations: AE=adverse effects; BCVA=best corrected visual acuity; CI=confidence interval, D=diopter; NR=not reported, RCT=randomized controlled study, SD=standard deviation; SE= spherical equivalent.

Appendix B6 Treatment Quality Ratings

Study, year | Random assignment | Allocation concealed | Groups similar at baseline | Eligibility criteria specified | Blinding | Blinding outcome assessors or data analysts | Intention-to-treat analysis | Reporting of attrition, contamination | Differential loss to follow-up, overall high loss to follow- up, or incomplete follow-up | Funding source | External validity | Quality score
Awan et al, 2005^101^ | Can't tell | Yes | Yes | Yes | Patients: No Providers: No | No | Yes | Yes | No | National Eye Research Center; Ulverscroft Foundation | Mean age: 4.6 years Mean visual acuity amblyopiceye: 0.64; mean visual acuity sound eye: 0.02 Strabismus: 27/60 (45%) Mixed amblyopia: 25/60 (42%) | Fair
Clarke et al, 2003^99^ | Yes | Yes | Yes | Yes | Patients: No Providers: No | Yes | Yes | Yes | No | National Health Service Research and Development | Mean age: 4.0 years Proportion w/anisometropia: 127/177 (72%) Baseline visual acuity amblyopic eye^*^: 58/177 (33%) 0.18; 52/177 (29%) 0.30; 42/177 (24%) 0.48; 12/177 (7%) 0.60; 13/177 (7%) 0.78 | Good
Pediatric Eye Disease Investigator Group, 2006^100^ | Yes | Can't tell | Yes | Yes | Patients: No Providers: No | Yes | Yes | Yes | No | National Eye Institute | Mean age 5.3 years 49.4% female; 81% white; 6% black; 9% Hispanic/Latino; 1% Asian; 3% mixed race; <1% other 89% no prior amblyopia treatment; 8% prior patching; <1% prior atropine; 2% prior patching + atropine 23% strabismus; 47% anisometropia; 30% strabismus + anisometropia Mean visual acuity amblyopic eye: 0.55 (SD 0.23); Snellen equivalent 20/80; mean visual acuity sound eye: 0.03 (SD 0.11); Snellen equivalent 20/20; mean refractive error amblyopic eye: 4.92 (SD 2.13); mean refractive error sound eye: 2.72 (SD 1.93) | Good
Pediatric Eye Disease Investigator Group, 2003^102^ | Yes | Can't tell | Yes | Yes | Patients: No Providers: No | Yes | Yes | Yes | No | National Eye Institute | Mean age: 5.2 years 44% female; 85% white; 4% black; 6% Hispanic; 1% Asian; 2% mixed race; 2% other Strabismus 40%; anisometropia 33%; Strabismus + anisometropia 27% Mean visual acuity sound eye: 0.07 (SD 0.10); mean visual acuity amblyopic eye: 0.48 (SD 0.10); mean refractive error sound eye: 3.07 (SD 2.35); mean refractive error amblyopic eye: 4.12 (SD 3.00) | Good
Stewart et al, 2007^103^ | Yes | Can't tell | Yes | Yes | Patients: No Providers: No | Can't tell | Yes | Yes | No | Fight for Sight UK | Mean age: 5.6 years Sex: NR Anisometropia 42/97 (43%); strabismus 21/97 (22%); mixed anisometropia + strabismus 34/97 (35%) | Fair
Pediatric Eye Disease Investigator Group, 2004^104^ | Yes | Can't tell | Yes | Yes | Patients: No Providers: No | Yes | Yes | Yes | No | National Eye Institute | Mean age: 5.3 years 39% female; 79% white; 4% black; 12% Hispanic; 2% Asian; 1% American Indian/Alaskan Native; 1% mixed race; 2% unknown Strabismus 33%; anisometropia 41%; strabismus + anisometropia 23% Mean distance visual acuity amblyopic eye 0.46 (SD 0.10); mean distance visual acuity sound eye 0.05 (SD 0.10); mean refractive error amblyopic eye 4.22 (SD 2.37); mean refractive error sound eye 3.03 (SD 2.16) | Good
Pediatric Eye Disease Investigator Group, 2002^105^ | Yes | Can't tell | Yes | Yes | Patients: No Providers: No | Yes | Yes | Yes | No | National Eye Institute | Mean age: 5.3 years 47% female; 83% white; 5% black; 6% Hispanic; 2% Asian; 2% mixed; 2% other 74% no prior amblyopia treatment; 20% prior patching; 2% prior atropine; 0.2% prior patching + atropine; 5% other prior treatment (eyeglass occluder and fogging) Cause of amblyopia: 38% strabismus; 37% amblyopia; 24% strabismus + anisometropia Mean visual acuity amblyopic eye: 0.53 (SD 0.13); mean visual acuity sound eye: 0.09 (SD 0.11); mean intereye acuity difference (lines): 4.4 (SD 1.3); mean refractive error amblyopic eye: 4.46 (SD 2.13); mean refractive error sound eye: 2.82 (SD 2.00) | Good

* Converted from Snellen metric measures.