# Appendix A. Detailed Methods

Appendix A1 Literature Search Strategies

Appendix A2 Inclusion and Exclusion Criteria for Key Questions

Appendix A3 Literature Flow Diagram

Appendix A4 Excluded Studies

Appendix A5 U.S. Preventive Services Task Force Quality Rating Criteria for Randomized Controlled Trials and Observational Studies

Appendix A6 Expert Reviewers of the Draft Report