# Expert Reviewers of the Draft Report

Michael P. Clarke, MB, FRCOphth

Pediatric Ophthalmologist/Reader in Ophthalmology, Newcastle University, United Kingdom

Mary Frances Cotch, PhD

Chief of Epidemiology, Division of Epidemiology and Clinical Applications, National Eye Institute, National Institutes of Health

Sean P. Donahue, MD, PhD

Associate Professor, Vanderbilt Eye Institute, Vanderbilt University Medical Center

Lynne Haverkos, MD, MPH

Director, Pediatric Behavior and Health Promotion Program, National Institute of Child Health and Human Development, National Institutes of Health

Mark B. Horton, OD, MD

Chief, Eye and Ear, Nose, and Throat Department, Phoenix Indian Medical Center; Director, Indian Health Service/Joslin Vision Network Teleophthalmology Program

Kurt Simons, PhD

Director, Pediatric Vision Laboratory, Krieger Children’s Eye Center, Wilmer Eye Institute, Johns Hopkins School of Medicine