# Excluded Studies

## Contextual Only

Atkinson J, Braddick O, Bobier B, et al. Two infant vision screening programmes: prediction and prevention of strabismus and amblyopia from photo and videorefractive screening. Eye. 1996;10:189-198. [pmid: 8776448].
Becker R, Hubsch S, Graf MH, Kaufmann H. Examination of young children with Lea symbols. Br J Ophthalmol. 2002;86(5):513-516. [pmid: 11973243].
Begg C. Biases in the assessment of diagnostic tests. Stat Med. 1987;6(4):411-423. [pmid: 3114858].
Bland JM, Altman DG. Statistical methods for assessing agreement between two methods of cllinical assessment. Lancet. 1986;1:307-310. [pmid: 2868172].
Carlton J, Karnon J, Czoski-Murray C, Smith KJ, Marr J. The clinical effectiveness and cost-effectiveness of screening programmes for amblyopia and strabismus in children up to the age of 4–5 years: a systematic review and economic evaluation. Health Technol Assess. xi. 2008;12(25):iii-194. [pmid: 18513466].
Cordonnier M, De Maertelaer V. Comparison between two hand-held autorefractors: the Sure-Sight and the Retinomax. Strabismus. 2004;12(4):261-274. [pmid: 15545144].
Donahue S. The relationship between anisometropia, patient age, and the development of amblyopia. Trans Am Ophthalmol Soc. 2005;103:313-336. [pmid: 17057809].
Donahue SP. How often are spectacles prescribed to “normal” preschool children?. J AAPOS. 2004;8(3):224-229. [pmid: 15226721].
Donahue SP. Relationship between anisometropia, patient age, and the development of amblyopia. Am J Ophthalmol. 2006;142(1):132-140. [pmid: 16815261].
Donahue SP, Johnson TM, Leonard-Martin TC. Screening for amblyogenic factors using a volunteer lay network and the MTI photoscreener: initial results from 15,000 preschool children in a statewide effort. Ophthalmology. 2000;107(9):1637-1644. [pmid: 10964820].
Easterbrook P, Berlin J, Gopalan R, Matthews D. Publication bias in clinical research. Lancet. 1991;337(8746):867-872. [pmid: 1672966].
Freedman HL, Preston KL. Polaroid photoscreening for amblyogenic factors: an improved methodology. Ophthalmology. 1992;99:1785-1795. [pmid: 1480393].
Gray R, Begg C, Greenes R. Construction of receiver operating characteristic curves when disease verification is subject to selection bias. Med Decis Making. 1984;4(2):151-164. [pmid: 6472063].
Hartmann EE, Dobson V, Hainline L, et al. Preschool vision screening: summary of a Task Force report. On behalf of the Maternal and Child Health Bureau and National Eye Institute Task Force on Vision Screening in the Preschool Child. Pediatrics. 2000;106(5):1105-1116. [pmid: 11061783].
Hartmann EE, Dobson V, Hainline L, et al. Preschool vision screening: summary of a Task Force report. Ophthalmology. 2001;108(3):479-486. [pmid: 11237901].
Hatch S, Tibbles CD, Mestito IR, Read R, Traveis L, Richman J. Validity and reliability of the MTI photoscreener. Optom Vis Sci. 1997;74(10):859-864. [pmid: 9383800].
Hered RW, Murphy S, Clancy M. Comparison of the HOTV and Lea Symbols charts for preschool vision screening. J Pediatr Ophthalmol Strabismus. 1997;34(1):24-28. [pmid: 9027676].
Holladay JT. Visual acuity measurements. J Cataract Refract Surg. 2004;39:278-290.
Horwood J, Waylen A, Herrick D, Williams C. Common visual defects and peer victimization in children. Invest Ophthalmol Vis Sci. 2005;46:1177-1181. [pmid: 15790876].
Howard C, Firth AY. Is the Cardiff acuity test effective in detecting refractive errors in children?. Optom Vis Sci. 2006;83(8):E577-E582.
Jensen H, Goldschmidt E. Visual acuity in Danish school children. Acta Ophthalmologica. 1986;64:187-191. [pmid: 3727959].
Jones D, Westall C, Averbeck K, Abdolell M. Visual acuity assessment: a comparison of two tests for measuring children’s vision. Ophthalmic Physiol Opt. 2003;23(6):541-546. [pmid: 14622358].
Keech R, Kutschke P. Upper age limit for the development of amblyopia. J Pediatr Ophthalmol Strabismus. 1995;32:89-93. [pmid: 7629676].
Kvarnstrom G, Jakobsson P. Is vision screening in 3-year-old children feasible? Comparison between the Lea Symbol chart and the HVOT (LM) chart. Acta Ophthalmol Scand. 2005;83(1):76-80. [pmid: 15715562].
L’Abbe KA, Detsky AS, O’Rourke K. Meta-analysis in clinical research. Ann Intern Med. 1987;107:224-233. [pmid: 3300460].
Lang D, Leman R, Arnold AW, Arnold RW. Validated portable pediatric vision screening in the Alaska Bush: a VIPS-like study in the Koyukon. Alaska Med. 2007;49(1):2-15. [pmid: 17479731].
Manny RE, Hussein M, Gwiazda J, Marsh-Tootle W. COMET Study Group. Repeatability of ETDRS visual acuity in children. Invest Ophthalmol Vis Sci. 2003;44(8):3294-3300. [pmid: 12882773].
Mant D, Fowler G. Mass screening: theory and ethics. BMJ. 1990;300:916-918. [pmid: 2110841].
Morgan KS, Kennemer JC. Off-axis photorefractive eye screening in children. J Refract Surg. 1997;23:423-428.
Mulley L. The Airedale Vision Screening Program: a comparison of referral rates between two preschool age groups. Br Orthoptic J. 2000;57:39-41.
Mulrow CD, Linn WD, Gaul MK, Pugh JA. Assessing quality of a diagnostic test evaluation. J Gen Intern Med. 1989;4:288-295. [pmid: 2760697].
Multi-Ethnic Pediatric Eye Disease Study Group. Varma R, Deneen J, et al. The Multi-Ethnic Pediatric Eye Disease Study: design and methods. Ophthalmic Epidemiol. 2006;13(4):253-262. [pmid: 16877284].
Mulvihill A, MacCann A, Flitcroft I, O’Keefe M. Outcome in refractive accommodative esotropia. Br J Ophthalmol. 2000;84(7):746-749. [pmid: 10873987].
Newsham D. Parental non-concordance with occlusion therapy. Br J Ophthalmol. 2000;84(9):957-962. [pmid: 10966944].
Packwood E, Cruz OA, Rychwalski P, Keech R. The psychosocial effects of amblyopia study. J AAPOS. 1999;3:15-17. [pmid: 10071896].
Pediatric Eye Disease Investigator Group. The clinical profile of moderate amblyopia in children younger than 7 years. Arch Ophthalmol. 2002;120(3):281-287. [pmid: 11879130].
Pediatric Eye Disease Investigator Group. The amblyopia treatment study visual acuity testing protocol. Arch Ophthalmol. 2001;119(9):1345-1353. [pmid: 11545641].
Pediatric Eye Disease Investigator Group. A comparison of atropine and patching treatments for moderate amblyopia by patient age, cause of amblyopia, depth of amblyopia, and other factors. Ophthalmology. 2003;110(8):1632-1637. [pmid: 12917184].
Pediatric Eye Disease Investigator Group. A randomized trial of atropine vs patching for treatment of moderate amblyopia: follow-up at age 10 years. Arch Ophthalmol. 2008;126(8):1039-1044. [pmid: 18695096].
Pediatric Eye Disease Investigator Group. Two-year follow-up of a 6-month randomized trial of atropine vs patching for treatment of moderate amblyopia in children. Arch Ophthalmol. 2005;123(2):149-157. [pmid: 15710809].
Powell C, Porooshani H, Bohorquez MC, Richardson S. Screening for amblyopia in childhood. Cochrane Database Syst Rev. 2005:CD005020.
Preslan M, Novak A. Baltimore vision screening project. Ophthalmology. 1996;103:105-109. [pmid: 8628540].
Preslan M, Novak A. Baltimore vision screening project: phase 2. Ophthalmology. 1998;105:150-153. [pmid: 9442791].
Rahi JS, Cumberland P, Peckham C. Does amblyopia affect educational, health and social outcomes? Findings from the 1958 British birth cohort. BMJ. 2006;332:820-825. [pmid: 16520328].
Ransohoff D, Feinstein A. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. 1978;299(17):926-930. [pmid: 692598].
Robaei D, Rose KA, Kifley A, Cosstick M, Ip JM, Mitchell P. Factors associated with childhood strabismus: findings from a population-based study. Ophthalmology. 2006;113(7):1146-1153. [pmid: 16675019].
Salcido AA, Bradley J, Donahue SP. Predictive value of photoscreening and traditional screening of preschool children. J AAPOS. 2005;9(2):114-120. [pmid: 15838437].
Schmidt P, Maguire M, Dobson V, et al. Comparison of preschool vision screening tests as administered by licensed eye care professionals in the Vision in Preschoolers Study. Ophthalmology. 2004;111(4):637-650. [pmid: 15051194].
Shotton K, Elliott S. Interventions for strabismic amblyopia. Cochrane Database Syst Rev. 2008:CD006461.
Snowdon S, Stewart-Brown SL. Preschool vision screening. Health Technol Assess. 1997;1(8):1-83.
Tarczy-Hornoch K, Lin J, Deneen J, et al. Steroeacuity testability in African-American and Hispanic pre-school children. Optom Vis Sci. 2008;85:158-163. [pmid: 18317330].
The Vision in Preschoolers Study Group. Sensitivity of screening tests for detecting vision in preschoolers-targeted vision disorders when specificity is 94%. Optom Vis Sci. 2005;82(5):432-438. [pmid: 15894920].
The Vision in Preschoolers Study Group. Does assessing eye alignment along with refractive error or visual acuity increase sensitivity for detection of strabismus in preschool vision screening?. Invest Ophthalmol Vis Sci. 2007;48(7):3115-3125. [pmid: 17591881].
The Vision in Preschoolers Study Group. Preschool visual acuity screening with HOTV and Lea symbols: testability and between-test agreement. Optom Vis Sci. 2004;81(9):678-683. [pmid: 15365387].
The Vision in Preschoolers Study Group. Random Dot E stereotest: testability and reliability in 3- to 5-year-old children. J AAPOS. 2006;10(6):507-514. [pmid: 17189143].
Tong PY, Macke JP, Bassin RE, et al. Screening for amblyopia in preverbal children with photoscreening photographs, III: improved grading criteria for hyperopia. Ophthalmology. 2000;107(9):1630-1636. [pmid: 10964819].
Virgili G, Angi M, Heede S, Rodriguez D, Bottega E, Molinari A. PowerRefractor versus Canon R-50 Autorefraction to assess refractive error in children: a community-based study in Ecuador. Optom Vis Sci. 2007;84(2):144-148. [pmid: 17299345].
Virgili G, Angi M, Molinari A, Casotto V. Cox regression was used to compare the measurement error of two tests vs. a gold standard. J Clin Epidemiol. 2007;60(4):345-349. [pmid: 17346607].
Webber A, Wood J. Amblyopia: prevalence, natural history, functional effects and treatment. Clin Exp Ophthalmol. 2005;88(6):365-375.
Williams C, Harrad RA, Harvey I, Frankel S, Golding J. Methodology for a randomised controlled trial of preschool vision screening: a new approach with the ALSPAC project. Ophthalmic Epidemiol. 1996;3(2):63-76. [pmid: 8841058].
Williams C, Northstone K, Howard M, Harvey I, Harrad R, Sparrow J. Prevalence and risk factors for common vision problems in children: data from the ALSPAC study. Br J Ophthalmol. 2008;92(7):959-964. [pmid: 18480306].
Yang YF, Cole MD. Visual acuity testing in schools: what needs to be done. BMJ. 1996;313:1053. [pmid: 8898598].

## Wrong Population

Adams RJ, Courage ML. Can the visual acuity of infants be predicted from a measurement of contrast sensitivity?. J Pediatr Ophthalmol Strabismus. 2003;40(1):35-38. [pmid: 12580270].
Adams RJ, Dalton SM, Murphy AM, Hall HL, Courage ML. Testing young infants with the Welch Allyn SureSight non-cycloplegic autorefractor. Ophthalmic Physiol Opt. 2002;22(6):546-551. [pmid: 12477019].
Al-Mahdi HS, Bener A. Outcome of occlusion treatment for strabismic amblyopia in children below 12 years old. Saudi Med J. 2006;27(10):1611-1612. [pmid: 17013499].
Anker S, Atkinson J, Braddick O, et al. Identification of infants with significant refractive error and strabismus in a population screening program using noncycloplegic videorefraction and orthoptic examination. Invest Ophthalmol Vis Sci. 2003;44(2):497-504. [pmid: 12556374].
Antonio-Santos A, Hatt S, Powell C, Vedula SS. Interventions for stimulus deprivation amblyopia. Cochrane Database Syst Rev. 2006:CD005136.
Arikan G, Yaman A, Berk AT. Efficacy of occlusion treatment in amblyopia and clinical risk factors affecting the results of treatment. Strabismus. 2005;13(2):63-69. [pmid: 16020359].
Arnold RW, Arnold AW, Stark L, Arnold KK, Leman R, Armitage MD. Amblyopia detection by camera: gateway to portable, inexpensive vision screening (calibration and validation of inexpensive, pocket-sized photoscreeners). Alaska Med. 2004;46(3):63-72. [pmid: 15839597].
Arnold RW, Stark L, Leman R, Arnold KK, Armitage MD. Tent photoscreening and patched HOTV visual acuity by school nurses: validation of the ASD-ABCD protocol. Binocul Vis Strabismus Q. 2008;23(2):83-94. [pmid: 18702611].
Atilla H, Oral D, Coskun S, Erkam N. Poor correlation between “fix-follow-maintain” monocular/binocular fixation pattern evaluation and presence of functional amblyopia. Binocul Vis Strabismus Q. 2001;16(2):85-90. [pmid: 11388880].
Atkinson J, Anker S, Bobier W, et al. Normal emmetropization in infants with spectacle correction for hyperopia. Invest Ophthalmol Vis Sci. 2000;41(12):3726-3731. [pmid: 11053269].
Atkinson J, Braddick O, Nardini M, Anker S. Infant hyperopia: detection, distribution, changes and correlates-outcomes from the Cambridge infant screening programs. Optom Vis Sci. 2007;84(2):84-96. [pmid: 17299337].
Atkinson J, Braddick OJ, Durden K, Watson PG, Atkinson S. Screening for refractive errors in 6- to 9-month-old infants by photorefraction. Br J Ophthalmol. 1984;68(2):105-112. [pmid: 6691952].
Autrata R, Rehurek J. Laser-assisted subepithelial keratectomy and photorefractive keratectomy versus conventional treatment of myopic anisometropic amblyopia in children. J Cataract Refract Surg. 2004;30(1):74-84. [pmid: 14967271].
Autrata R, Rehurek J, Vodickova K. Visual results after primary intraocular lens implantation or contact lens correction for aphakia in the first year of age. Ophthalmologica. 2005;219(2):72-79. [pmid: 15802930].
Birch E, Fawcett S, Stager D. Why does early surgical alignment improve stereoacuity outcomes in infantile esotropia?. J AAPOS. 2000;4:10-14. [pmid: 10675865].
Birch EE, Morale SE, Jeffrey BG, O’Connor AR, Fawcett SL. Measurement of stereoacuity outcomes at ages 1 to 24 months: Randot stereocards. J AAPOS. 2005;9(1):31-36. [pmid: 15729278].
Blade PJ, Candy TR. Validation of the PowerRefractor for measuring human infant refraction. Optom Vis Sci. 2006;83(6):346-353. [pmid: 16772892].
Buchner TF, Schnorbus U, Grenzebach UH, Busse H. Examination of preschool children for ametropia: first experiences using a new hand-held autorefractor. Strabismus. 2004;12(2):111-117. [pmid: 15672934].
Calloway SL, Lloyd IC, Henson DB. A clinical evaluation of Random Dot stereoacuity cards in infants. Eye. 2001;15(Pt 5):629-634. [pmid: 11702975].
Cheng K, Hiles D, Biglan A, Pettapiece M. Visual results after early surgical treatment of unilateral congenital cataracts. Ophthalmology. 1991;98:903-910. [pmid: 1866144].
Choi M, Weiss S, Schaeffel F, et al. Laboratory, clinical, and kindergarten test of a new eccentric infrared photorefractor (PowerRefractor). Optom Vis Sci. 2000;77(10):537-548. [pmid: 11100892].
Chua WH, Balakrishnan V, Chan YH, et al. Atropine for the treatment of childhood myopia. Ophthalmology. 2006;113(12):2285-2291. [pmid: 16996612].
Congdon NG, Ruiz S, Suzuki M, Herrera V. Determinants of pediatric cataract program outcomes and follow-up in a large series in Mexico. J Cataract Refract Surg. 2007;33(10):1775-1780. [pmid: 17889776].
Cosgrave E, Scott C, Goble R. Ocular findings in low birthweight and premature babies in the first year: do we need to screen?. Eur J Ophthalmol. 2008;18(1):104-111. [pmid: 18203094].
Dadeya S, Kamlesh MS. Is it mandatory to treat amblyopia prior to surgery in esotropia?. Acta Ophthalmol Scand. 2001;79(1):28-30. [pmid: 11167282].
Dias L, Hyman L, Manny RE, Fern K. COMET Study Group. Evaluating the self-esteem of myopic children over a three-year period: the COMET experience. Optom Vis Sci. 2005;82(4):338-347. [pmid: 15829861].
Dobson V, Quinn GE, Siatkowski RM, et al. Agreement between grating acuity at age 1 year and Snellen acuity at age 5.5 years in the preterm child. Invest Ophthalmol Vis Sci. 1999;40(2):496-503. [pmid: 9950610].
Donahue SP, Johnson TM. Age-based refinement of referral criteria for photoscreening. Ophthalmology. 2001;108(12):2309-2314. [pmid: 11733276].
Drover JR, Courage ML, Dalton SM, Adams RJ. Accuracy of the contrast sensitivity card test for infants: retest variability and prediction of spatial resolution. Optom Vis Sci. 2006;83(4):228-232. [pmid: 16614578].
Drover JR, Earle AE, Courage ML, Adams RJ. Improving the effectiveness of the infant contrast sensitivity card procedure. Optom Vis Sci. 2002;79(1):52-59. [pmid: 11828899].
Edwards MH, Shing FC. Is refraction in early infancy a predictor of myopia at the age of 7 to 8 years? The relationship between cycloplegic refraction at 11 weeks and the manifest refraction at age 7 to 8 years in Chinese children. Optom Vis Sci. 1999;76(5):272-274. [pmid: 10375240].
Elliott S, Shafiq A. Interventions for infantile esotropia. Cochrane Database Syst Rev. 2005:CD004917.
Fawcett SL, Birch EE. Validity of the Titmus and Randot circles tasks in children with known binocular vision disorders. J AAPOS. 2003;7(5):333-338. [pmid: 14566315].
Fu VL, Birch EE, Holmes JM. Assessment of a new distance Randot stereoacuity test. J AAPOS. 2006;10(5):419-423. [pmid: 17070476].
Gadaginamath S, Menon V, Sharma S, Saxena R, Kedar S. Clinical trial of occlusion vs. atropine penalization for the treatment of amblyopia. Paper presented at: 109th Annual Meeting of the American Academy of Ophthalmology. October 15–18, 2005. Chicago, IL.
Gole GA, Schluter PJ, Hall J, Colville D. Comparison of the Retinomax autorefractor with hand-held retinoscopy in 1-year-old infants. Clin Exp Ophthalmol. 2003;31(4):341-347.
Granet DB, Hoover A, Smith AR, Brown SI, Bartsch DU, Brody B. A new objective digital computerized vision screening system. J Pediatr Ophthalmol Strabismus. 1999;36(5):251-256. [pmid: 10505829].
Grant S, Melmoth DR, Morgan MJ, Finlay AL. Prehension deficits in amblyopia. Invest Ophthalmol Vis Sci. 2007;48(3):1139-1148. [pmid: 17325157].
Guyatt G, Tugwell P, Feeny DH, Haynes RB, Drummond M. Sensitivity of the MTI photoscreener for amblyogenic factors in infancy and early childhood. Can Med Assoc J. 1986;134:587-594. [pmid: 3512062].
Gwiazda J, Hyman L, Hussein M, et al. A randomized clinical trial of progressive addition lenses versus single vision lenses on the progression of myopia in children. Invest Ophthalmol Vis Sci. 2003;44(4):1492-1500. [pmid: 12657584].
Hajnal BL, Ferriero DM, Partridge JC, Dempsey DA, Good WV. Is exposure to cocaine or cigarette smoke during pregnancy associated with infant visual abnormalities?. Dev Med Child Neurol. 2004;46(8):520-525. [pmid: 15287242].
Hall HL, Courage ML, Adams RJ. The predictive utility of the Teller acuity cards for assessing visual outcome in children with preterm birth and associated perinatal risks. Vision Res. 2000;40(15):2067-2076. [pmid: 10828473].
Harvey EM, Dobson V, Clifford-Donaldson CE, Miller JM. Optical treatment of amblyopia in astigmatic children: the sensitive period for successful treatment. Ophthalmology. 2007;114(12):2293-2301. [pmid: 18054643].
Harvey EM, Dobson V, Miller JM, Sherrill DL. Treatment of astigmatism-related amblyopia in 3- to 5-year-old children. Vision Res. 2004;44(14):1623-1634. [pmid: 15135999].
Hatt S, Gnanaraj L. Interventions for intermittent exotropia. Cochrane Database Syst Rev. 2006:CD003737.
Hertle R, Scheiman M, Beck R, et al. Stability of visual acuity improvement following discontinuation of amblyopia treatment in children aged 7 to 12 years. Arch Ophthalmol. 2007;125(5):655-659. [pmid: 17502505].
Hickson AM, Schmidt PP. Maximizing refractive error detection in preschool vision screening. Invest Ophthalmol Vis Sci. 2004;4317.
Holmstrom G, Larsson E. Long-term follow-up of visual functions in prematurely born children—a prospective population-based study up to 10 years of age. J AAPOS. 2008;12(2):157-162. [pmid: 18083590].
Horwood A, Williams B. Does neonatal ocular misalignment predict later abnormality?. Eye. 2001;15(Pt 4):485-491. [pmid: 11767024].
Huffman SJ, Schimmoeller KL, Schmidt P, Mitchell G. Repeatability and accuracy of autorefractor measurements in young children. Invest Ophthalmol Vis Sci. 2004;45:E-Abstract 2736.
Ingram RM, Gill LE, Lambert TW. Effect of spectacles on changes of spherical hypermetropia in infants who did, and did not, have strabismus. Br J Ophthalmol. 2000;84(3):324-326. [pmid: 10684846].
Ingram RM, Walker C, Wilson JM, Arnold PE, Dally S. Prediction of amblyopia and squint by means of refraction at age 1 year. Br J Ophthalmol. 1986;70:12-15. [pmid: 3947594].
Ip JM, Robaei D, Kifley A, Wang JJ, Rose KA, Mitchell P. Prevalence of hyperopia and associations with eye findings in 6- and 12-year-olds. Ophthalmology. 2008;115(4):678-685. [pmid: 17664011].
Isenberg SJ, Del Signore M, Madani-Becker G. Use of the HARK autorefractor in children. Am J Ophthalmol. 2001;131(4):438-441. [pmid: 11292405].
Iuorno JD, Grant WD, Noel LP. Clinical comparison of the Welch Allyn SureSight handheld autorefractor versus cycloplegic autorefraction and retinoscopic refraction. J AAPOS. 2004;8(2):123-127. [pmid: 15088044].
Javitt JC, Brenner MH, Curbow B, Legro MW, Street DA. Outcomes of cataract surgery: improvement in visual acuity and subjective visual function after surgery in the first, second, and both eyes. Arch Ophthalmol. 1993;111(5):686-691. [pmid: 8489454].
Kothari MT. Can the Bruckner test be used as a rapid screening test to detect significant refractive errors in children?. Indian J Ophthalmol. 2007;55(3):213-215. [pmid: 17456940].
Kowalski PM, Wang Y, Owens RE, Bolden J, Smith JB, Hyman L. Adaptability of myopic children to progressive addition lenses with a modified fitting protocol in the Correction of Myopia Evaluation Trial (COMET). Optom Vis Sci. 2005;82(4):328-337. [pmid: 15829860].
Larsson EK, Rydberg AC, Holmstrom GE. A population-based study of the refractive outcome in 10-year-old preterm and full-term children. Arch Ophthalmol. 2003;121(10):1430-1436. [pmid: 14557179].
Lengyel D, Gottlob I. Comparison between grating acuity measured by visual tracking and preferential looking in infants. Strabismus. 2003;11(2):85-93. [pmid: 12854016].
Lim HC, Quah BL, Balakrishnan V, Tay V, Emmanuel SC. Vision screening of 4-year-old children in Singapore. Singapore Med J. 2000;41(6):271-278. [pmid: 11109343].
Matsuo T, Matsuo C, Matsuoka H, Kio K. Detection of strabismus and amblyopia in 1.5- and 3-year-old children by a preschool vision-screening program in Japan. Acta Med Okayama. 2007;61(1):9-16. [pmid: 17332837].
Mocan MC, Najera-Covarrubias M, Wright KW. Comparison of visual acuity levels in pediatric patients with amblyopia using Wright figures, Allen optotypes, and Snellen letters. J AAPOS. 2005;9(1):48-52. [pmid: 15729280].
Morad Y, Werker E, Nemet P. Visual acuity tests using chart, line, and single optotype in healthy and amblyopic children. J AAPOS. 1999;3(2):94-97. [pmid: 10221802].
Moutakis K, Stigmar G, Hall-Lindberg J. Using the KM visual acuity chart for more reliable evaluation of amblyopia compared to the HVOT method. Acta Ophthalmol Scand. 2004;82(5):547-551. [pmid: 15453851].
Nassif DS, Piskun NV, Hunter DG. The Pediatric Vision Screener III: detection of strabismus in children. Arch Ophthalmol. 2006;124(4):509-513. [pmid: 16606876].
O’Connor AR, Stephenson T, Johnson A, et al. Long-term ophthalmic outcome of low birth weight children with and without retinopathy of prematurity. Pediatrics. 2002;109(1):12-18. [pmid: 11773536].
Pediatric Eye Disease Investigator Group. A randomized trial of prescribed patching regimens for treatment of severe amblyopia in children. Ophthalmology. 2003;110(11):2075-2087. [pmid: 14597512].
Pott JW, Kingma C, Verhoeff K, Grootendorst RJ, de Faber JT. The Polaroid suppression test in a pediatric population with ophthalmologic disorders. J AAPOS. 2003;7(2):137-141. [pmid: 12736628].
Prager TC, Zou YL, Jensen CL, Fraley JK, Anderson RE, Heird WC. Evaluation of methods for assessing visual function of infants. J AAPOS. 1999;3(5):275-282. [pmid: 10532572].
Robaei D, Kifley A, Gole GA, Mitchell P. The impact of modest prematurity on visual function at age 6 years: findings from a population-based study. Arch Ophthalmol. 2006;124(6):871-877. [pmid: 16769841].
Satterfield D, Keltner JL, Morrison TL. Psychosocial aspects of strabismus study. Arch Ophthalmol. 1993;111(8):1100-1105. [pmid: 8166786].
Saunders KJ, McCulloch DL, Shepherd AJ, Wilkinson AG. Emmetropisation following preterm birth. Br J Ophthalmol. 2002;86(9):1035-1040. [pmid: 12185134].
Schalij-Delfos NE, de Graaf ME, Treffers WF, Engel J, Cats BP. Long term follow up of premature infants: detection of strabismus, amblyopia, and refractive errors. Br J Ophthalmol. 2000;84(9):963-967. [pmid: 10966945].
Schimitzek T, Lagreze WA. Accuracy of a new photo-refractometer in young and adult patients. Graefes Arch Clin Exp Ophthalmol. 2005;243(7):637-645. [pmid: 15650858].
Schimitzek T, Wesemann W. Clinical evaluation of refraction using a handheld wavefront autorefractor in young and adult patients. J Cataract Refract Surg. 2002;28(9):1655-1666. [pmid: 12231328].
Sharma P, Bairagi D, Sachdeva MM, Kaur K, Khokhar S, Saxena R. Comparative evaluation of Teller and Cardiff acuity tests in normals and unilateral amblyopes in under-two-year-olds. Indian J Ophthalmol. 2003;51(4):341-345. [pmid: 14750623].
Shortt AJ, Lanigan B, O’Keefe M. Pars plana lensectomy for the management of ectopia lentis in children. J Pediatr Ophthalmol Strabismus. 2004;41(5):289-294. [pmid: 15478741].
Simons BD, Siatkowski RM, Schiffman JC, Berry BE, Flynn JT. Pediatric photoscreening for strabismus and refractive errors in a high-risk population. Ophthalmology. 1999;106(6):1073-1080. [pmid: 10366073].
Somer D, Budak K, Demirci S, Duman S. Against-the-rule (ATR) astigmatism as a predicting factor for the outcome of amblyopia treatment. Am J Ophthalmol. 2002;133(6):741-745. [pmid: 12036662].
Stankovic B, Milenkovic S. Continuous full-time occlusion of the sound eye vs full-time occlusion of the sound eye periodically alternating with occlusion of the amblyopic eye in treatment of amblyopia: a prospective randomized study. Eur J Ophthalmol. 2007;17(1):11-19. [pmid: 17294378].
Stifter E, Burggasser G, Hirmann E, Thaler A, Radner W. Monocular and binocular reading performance in children with microstrabismic amblyopia. Br J Ophthalmol. 2005;89:1324-1329. [pmid: 16170125].
Sundaram V, Haridas A. Adjustable versus non-adjustable sutures for strabismus. Cochrane Database Syst Rev. 2005:CD004240.
Syniuta L, Isenberg SJ. Atropine and bifocal can slow the progression of myopia in children. Binocul Vis Strabismus Q. 2001;16(3):203-208. [pmid: 11511287].
Travi GM, Schnall BM, Lehman SS, et al. Visual outcome and success of amblyopia treatment in unilateral small posterior lens opacities and lenticonus initially treated nonsurgically. J AAPOS. 2005;9(5):449-454. [pmid: 16213394].
Tuppurainen K, Herrgard E, Martikainen A, Mantyjarvi M. Ocular findings in prematurely born children at 5 years of age. Graefes Arch Clin Exp Ophthalmol. 1993;231:261-266. [pmid: 8319915].
Uretmen O, Civan BB, Kose S, Yuce B, Egrilmez S. Accommodative esotropia following surgical treatment of infantile esotropia: frequency and risk factors. Acta Ophthalmol. 2008;86(3):279-283. [pmid: 18039348].
Vedantham V, Ratnagiri PK. The Sweep-VEP: a faster estimation of visual acuity in preverbal children. Indian J Ophthalmol. 2004;52(2):175. [pmid: 15283233].
Walline JJ, Jones LA, Mutti DO, Zadnik K. A randomized trial of the effects of rigid contact lenses on myopia progression. Arch Ophthalmol. 2004;122(12):1760-1766. [pmid: 15596577].
Weakley DR Jr. The association between nonstrabismic anisometropia, amblyopia, and subnormal binocularity. Ophthalmology. 2001;108(1):163-171. [pmid: 11150283].
Weakley DR Jr, Birch E, Kip K. The role of anisometropia in the development of accommodative esotropia. J AAPOS. 2001;5(3):153-157. [pmid: 11404741].
Weissberg E, Boisvert N, Bourdeau H, Moore BD, Thorn F. Comparison of two hand held autorefractors to retinoscopy under screening conditions [abstract]. Optom Vis Science. 2001;78(Suppl 12):250.
Ziylan S, Yabas O, Zorlutuna N, Serin D. Isoametropic amblyopia in highly hyperopic children. Acta Ophthalmol Scand. 2007;85(1):111-113. [pmid: 17244222].

## Wrong Screening Test

Brown S, Story I. A new approach to visual acuity screening for pre-school children. Ophthalmic Epidemiol. 1998;5(1):21-27. [pmid: 9575535].
Cooper CD, Bowling FG, Hall JE, et al. Evaluation of photoscreener instruments in a childhood population, 1: Otago photoscreener and Dortmans videophotorefractor. Aust N Z J Ophthalmol. 1996;24(4):347-355. [pmid: 8985547].
Paysse EA, Camejo L, Hussein MA, Coats DK. Parent-administered visual acuity testing: is it reliable and can it improve office efficiency?. J AAPOS. 2004;8(4):332-337. [pmid: 15314593].
Schimitzek T, Schworm HD. Wave-front analysis as screening technique for amblyogenic ametropia with and without cycloplegia. Strabismus. 2003;11(3):133-143. [pmid: 14710471].
Simon JW, Siegfried JB, Mills MD, Calhoun JH, Gurland JE. A new visual evoked potential system for vision screening in infants and young children. J AAPOS. 2004;8(6):549-554. [pmid: 15616502].

## Wrong Intervention

Ahmadieh H, Javadi MA, Ahmady M, et al. Primary capsulectomy, anterior vitrectomy, lensectomy, and posterior chamber lens implantation in children: limbal versus pars plana. J Cataract Refract Surg. 1999;25(6):768-775. [pmid: 10374155].
Fielder AR. Electronic monitoring of treatment compliance in patching for amblyopia. Surv Ophthalmol. 2000;44(6):539-540. [pmid: 10914521].
Loudon SE, Polling JR, Simonsz HJ. Electronically measured compliance with occlusion therapy for amblyopia is related to visual acuity increase. Graefes Arch Clin Exp Ophthalmol. 2003;241(3):176-180. [pmid: 12644939].
Mohan K, Dhankar V, Sharma A. Visual acuities after levodopa administration in amblyopia. J Pediatr Ophthalmol Strabismus. 2001;38(2):62-67. [pmid: 11310708].
Moke PS, Turpin AH, Beck RW, et al. Computerized method of visual acuity testing: adaptation of the amblyopia treatment study visual acuity testing protocol. Am J Ophthalmol. 2001;132(6):903-909. [pmid: 11730656].
Newsham D. A randomised controlled trial of written information: the effect on parental non-concordance with occlusion therapy. Br J Ophthalmol. 2002;86(7):787-791. [pmid: 12084751].
Paysse EA. Photorefractive keratectomy for anisometropic amblyopia in children. Trans Am Ophthalmol Soc. 2004;102:341-371. [pmid: 15747767].
Pediatric Eye Disease Investigator Group. A randomized trial of near versus distance activities while patching for amblyopia in children aged 3 to less than 7 years. Ophthalmology. 2008;115(11):2071-2078. [pmid: 18789533].
Schimitzek T, Haase W. Efficiency of a video-autorefractometer used as a screening device for amblyogenic factors. Graefes Arch Clin Exp Ophthalmol. 2002;240(9):710-716. [pmid: 12271366].
Simonsz HJ, Kolling GH, Unnebrink K. Final report of the Early vs. Late Infantile Strabismus Surgery Study (ELISSS), a controlled, prospective, multicenter study. Strabismus. 2005;13:169-199. [pmid: 16361188].
Steele G, Ireland D, Block S. Cycloplegic autorefraction results in pre-school children using the Nikon Retinomax Plus and the Welch Allyn SureSight. Optom Vis Sci. 2003;80(8):573-577. [pmid: 12917576].

## Wrong Outcome

Arnold RW, Clausen M, Ryan H, Leman RE, Armitage D. Predictive value of inexpensive digital eye and vision photoscreening: “PPV of ABCD.”. Binocul Vis Strabismus Q. 2007;22(3):148-152. [pmid: 17983349].
Bagheri A, Givrad S, Yazdani S, Reza Mohebbi M. Optimal dosage of cyclopentolate 1% for complete cycloplegia: a randomized clinical trial. Eur J Ophthalmol. 2007;17(3):294-300. [pmid: 17534806].
Barry JC, Reher C, Konig HH. Factors influencing the detection of visual developmental deficits in 3-year-old kindergarten children. Strabismus. 2004;12(4):211-219. [pmid: 15545139].
Becker RH, Hubsch SH, Graf MH, Kaufmann H. Preliminary report: examination of young children with Lea symbols. Strabismus. 2000;8(3):209-213. [pmid: 11035563].
Bobier W, Shankar S, Evans MA. Vision screening and the effects of vision problems on the emergent literacy skills of young children. Paper presented at: 82nd Annual Meeting of the American Academy of Optometry. December 9–12, 2004. Tampa, FL.
Bolger PG, Stewart-Brown SL, Newcombe E, Starbuck A. Vision screening in preschool children: comparison of orthoptists and clinical medical officers as primary screeners. BMJ. 1991;303(6813):1291-1294. [pmid: 1747671].
Borchert M, Wang Y, Tarczy-Hornoch K, et al. Testability of the Retinomax autorefractor and IOLMaster in preschool children: the Multi-Ethnic Pediatric Eye Disease Study. Ophthalmology. 2008;115(8):1422-1425. [pmid: 18164067].
Breyer A, Jiang X, Rutsche A, Mojon DS. A new 3D monitor-based random-dot stereotest for children. Invest Ophthalmol Vis Sci. 2006;47(11):4842-4846. [pmid: 17065496].
Brown MM, Brown GC, Sharma S, Busbee B, Brown H. Quality of life associated with unilateral and bilateral good vision. Ophthalmology. 2001;108:643-648. [pmid: 11297474].
Choong YF, Lukman H, Martin S, Laws DE. Childhood amblyopia treatment: psychosocial implications for patients and primary carers. Eye. 2004;18(4):369-375. [pmid: 15069432].
Chua BE, Johnson K, Martin F. A retrospective review of the associations between amblyopia type, patient age, treatment compliance and referral patterns. Clin Exp Ophthalmol. 2004;32(2):175-179.
Cyert L, Schmidt P, Maguire M, et al. Threshold visual acuity testing of preschool children using the crowded HOTV and Lea Symbols acuity tests. J AAPOS. 2003;7(6):396-399. [pmid: 14730291].
Dixon-Woods M, Awan M, Gottlob I. Why is compliance with occlusion therapy for amblyopia so hard? A qualitative study. Arch Dis Child. 2006;91(6):491-494. [pmid: 16531452].
Dobson V, Miller JM, Harvey EM, Mohan KM. Amblyopia in astigmatic preschool children. Vision Res. 2003;43(9):1081-1090. [pmid: 12676249].
Donaldson LA, Karas MP, Charles AE, Adams GG. Paediatric community vision screening with combined optometric and orthoptic care: a 64-month review. Ophthalmic Physiol Opt. 2002;22(1):26-31. [pmid: 11829007].
Drover JR, Felius J, Cheng CS, Morale SE, Wyatt L, Birch EE. Normative pediatric visual acuity using single surrounded HOTV optotypes on the Electronic Visual Acuity Tester following the Amblyopia Treatment Study protocol. J AAPOS. 2008;12(2):145-149. [pmid: 18155943].
FitzGerald DE, Krumholtz I. Maintenance of improvement gains in refractive amblyopia: a comparison of treatment modalities. Optometry. 2002;73(3):153-159. [pmid: 12365698].
Havertape SA, Whitfill CR, Cruz OA. Early-onset accommodative esotropia. J Pediatr Ophthalmol Strabismus. 1999;36(2):69-73. [pmid: 10204132].
Holmes JM, Fawcett SL. Testing distance stereoacuity with the Frisby-Davis 2 (FD2) test. Am J Ophthalmol. 2005;139(1):193-195. [pmid: 15652852].
Hulstein AM, Reuter K, Schmidt P. Maximizing the performance of autorefractors as vision screening tools in young children. Paper presented at: 80th Annual Meeting of the American Academy of Optometry. December 12–15, 2002. San Diego, CA.
Ingram RM, Arnold PE, Dally S, Lucas J. Results of a randomised trial of treating abnormal hypermetropia from the age of 6 months. Br J Ophthalmol. 1990;74(3):158-159. [pmid: 2182103].
Ingram RM, Arnold PE, Dally S, Lucas J. Emmetropisation, squint, and reduced visual acuity after treatment. Br J Ophthalmol. 1991;75(7):414-416. [pmid: 1854694].
Kupl MT, Dobson V, Peskin E, Quinn G, Schmidt P. Vision in Preschoolers Study Group. The electronic visual acuity tester: testability in preschool children. Optom Vis Sci. 2004;81(4):238-244. [pmid: 15097765].
Laidlaw DA, Tailor V, Shah N, Atamian S, Harcourt C. Validation of a computerised logMAR visual acuity measurement system (COMPlog): comparison with ETDRS and the electronic ETDRS testing algorithm in adults and amblyopic children. Br J Ophthalmol. 2008;92(2):241-244. [pmid: 17993577].
Laws D, Noonan CP, Ward A, Chandna A. Binocular fixation pattern and visual acuity in children with strabismic amblyopia. J Pediatr Ophthalmol Strabismus. 2000;37(1):24-28. [pmid: 10714692].
Maguire MG. Vision in Preschoolers Study Group. Children unable to perform screening tests in vision in preschoolers study: proportion with ocular conditions and impact on measures of test accuracy. Invest Ophthalmol Vis Sci. 2007;48(1):83-87. [pmid: 17197520].
Mazow ML, Chuang A, Vital MC, Prager T. 1999 Costenbader Lecture: outcome study in amblyopia: treatment and practice pattern variations. J AAPOS. 2000;4(1):1-9. [pmid: 10675864].
Miller JM, Dobson V, Harvey EM, Sherrill DL. Cost-efficient vision screening for astigmatism in Native American preschool children. Invest Ophthalmol Vis Sci. 2003;44(9):3756-3763. [pmid: 12939288].
Morale SE, Jeffrey BG, Fawcett SL, et al. Preschool Worth 4-Shape test: testability, reliability, and validity. J AAPOS. 2002;6(4):247-251. [pmid: 12185352].
Multi-Ethnic Pediatric Eye Disease Study Group. Cotter S, Tarczy-Hornoch K, et al. Visual acuity testability in African-American and Hispanic children: the Multi-Ethnic Pediatric Eye Disease Study. Am J Ophthalmol. 2007;144(5):663-667. [pmid: 17868633].
Pediatric Eye Disease Investigator Group. Risk of amblyopia recurrence after cessation of treatment. J AAPOS. 2004;8(5):420-428. [pmid: 15492733].
Pediatric Eye Disease Investigator Group. A randomized pilot study of near activities versus non-near activities during patching therapy for amblyopia. J AAPOS. 2005;9(2):129-136. [pmid: 15838439].
Pediatric Eye Disease Investigator Group. The effect of amblyopia therapy on ocular alignment. J AAPOS. 2005;9(6):542-545. [pmid: 16414520].
Richard F, De Guise D, Gresset J. Comparison of four pediatric stereotests in children aged two to five years old. Optom Vis Sci. 2003;4(2):200342.
Richardson SR, Wright CM, Hrisos S, Buck D, Clarke MP. Stereoacuity in unilateral visual impairment detected at preschool screening: outcomes from a randomized controlled trial. Invest Ophthalmol Vis Sci. 2005;46(1):150-154. [pmid: 15623768].
Rydberg A, Ericson B, Lennerstrand G, Jacobson L, Lindstedt E. Assessment of visual acuity in children aged 1 1/2–6 years, with normal and subnormal vision. Strabismus. 1999;7(1):1-24. [pmid: 10401500].
Rydberg A, Han Y. Assessment of contrast sensitivity in children aged 3 years 9 months–6 years with normal vision, visual impairment due to ocular disease and strabismic amblyopia. Strabismus. 1999;7(2):79-95. [pmid: 10420213].
Schmidt PP, Dobson V. Vision in Preschoolers Study Group. Vision in Preschoolers (VIP) Study: results of phase II. Invest Ophthalmol Vis Sci. 2005;2354.
Schmidt PP, Maguire MG, Moore B, Cyert L. Vision in Preschoolers Study Group. Testability of preschoolers on stereotests used to screen vision disorders. Optom Vis Sci. 2003;80(11):753-757. [pmid: 14627942].
Searle A, Vedhara K, Norman P, Frost A, Harrad R. Compliance with eye patching in children and its psychosocial effects: a qualitative application of protection motivation theory. Psychol Health Med. 2000;5(1):43-54.
Shih YF, Ho TC, Hsiao CK, Lin LL. Long-term visual prognosis of infantile-onset high myopia. Eye. 2006;20(8):888-892. [pmid: 16096663].
Simmers AJ, Gray LS, McGraw PV, Winn B. Functional visual loss in amblyopia and the effect of occlusion therapy. Invest Ophthalmol Vis Sci. 1999;40(12):2859-2871. [pmid: 10549646].
Simonsz HJ, Polling JR, Voorn R, et al. Electronic monitoring of treatment compliance in patching for amblyopia. Strabismus. 1999;7(2):113-123. [pmid: 10420216].
Stewart CE, Moseley MJ, Stephens DA, Fielder AR. Modeling of treatment dose-response in amblyopia. Invest Ophthalmol Vis Sci. 2005;3595.
Tejedor J, Rodriguez JM. Management of nonresolving consecutive exotropia following botulinum toxin treatment of childhood esotropia. Arch Ophthalmol. 2007;125(9):1210-1213. [pmid: 17846360].
The Vision in Preschoolers Study Group. Threshold visual acuity testing of preschool children using the crowded HOTV and Lea symbols acuity tests. J Pediatr Ophthalmol Strabismus. 2003;7(6):396-399.
The Vision in Preschoolers Study Group. Schmidt P, Maguire M, Moore B, Cyert L. Testability of preschoolers on stereotests used to screen vision disorders. Optom Vis Sci. 2003;80(11):753-757. [pmid: 14627942].
The Vision in Preschoolers Study Group. Impact of confidence number on the screening accuracy of the retinomax autorefractor. Optom Vis Sci. 2007;84(3):181-188. [pmid: 17435531].
Thompson AM, Nawrot M. Abnormal depth perception from motion parallax in amblyopic observers. Vision Res. 1999;39(7):1407-1413. [pmid: 10343851].
Tomac S. Binocularity in refractive accommodative esotropia. J Pediatr Ophthalmol Strabismus. 2002;39(4):226-230. [pmid: 12148556].
Wasserman RC, Croft CA, Brotherton SE. Preschool vision screening in pediatric practice: a study from the Pediatric Research in Office Settings (PROS) network. Pediatrics. 1992;89(5):834-838. [pmid: 1579390].
Webber AL, Wood JM, Gole GA, Brown B. The effect of amblyopia on fine motor skills in children. Invest Ophthalmol Vis Sci. 2008;49(2):594-603. [pmid: 18235004].
Westall CA, Ainsworth JR, Buncic JR. Which ocular and neurologic conditions cause disparate results in visual acuity scores recorded with visually evoked potential and teller acuity cards?. J AAPOS. 2000;4(5):295-301. [pmid: 11040480].

## Retrospective or Uncontrolled Study (for Key Question 4)

Archer SM, Musch DC, Wren PA, Guire KE. Social and emotional impact of strabismus surgery on quality of life in children. J AAPOS. 2005;9:148-151. [pmid: 15838442].
Beardsell R, Clarke S, Hill M. Outcome of occlusion treatment for amblyopia. J Pediatr Ophthalmol Strabismus. 1999;36(1):19-24. [pmid: 9972510].
Bhola R, Keech RV, Kutschke P, Pfeifer W, Scott WE. Recurrence of amblyopia after occlusion therapy. Ophthalmology. 2006;113(11):2097-2100. [pmid: 17074568].
Bowman RJC, Williamson TH, Andrews RGL, Aitchison TC, Dutton GN. An inner city preschool visual screening programme: long term visual results. Br J Ophthalmol. 1998;82(5):543-548. [pmid: 9713063].
Bradford G, Kutschke P, Scott W. Results of amblyopia therapy in eyes with unilateral structural abnormalities. Ophthalmology. 1992;99:1616-1621. [pmid: 1454331].
Bray LC, Clarke MP, Jarvis SN, Francis PM, Colver A. Preschool vision screening: a prospective comparative evaluation. Eye. 1996;10(Pt 6):714-718. [pmid: 9091368].
Cleary M. Efficacy of occlusion for strabismic amblyopia: can an optimal duration be identified?. Br J Ophthalmol. 2000;84(6):572-578. [pmid: 10837378].
Cobb CJ, Russell K, Cox A, MacEwen CJ. Factors influencing visual outcome in anisometropic amblyopes. Br J Ophthalmol. 2002;86:1278-1281. [pmid: 12386089].
Dorey SE, Adams GG, Lee JP, Sloper JJ. Intensive occlusion therapy for amblyopia. Br J Ophthalmol. 2001;85(3):310-313. [pmid: 11222336].
Hussein MA, Coats DK, Muthialu A, Cohen E, Paysse EA. Risk factors for treatment failure of anisometropic amblyopia. J AAPOS. 2004;8(5):429-434. [pmid: 15492734].
Ingram RM, Gill LE, Lambert TW. Emmetropisation in normal and strabismic children and the associated changes of anisometropia. Strabismus. 2003;11(2):71-84. [pmid: 12854015].
Krumholtz I, FitzGerald D. Efficacy of treatment modalities in refractive amblyopia. J Am Optom Assoc. 1999;70(6):399-404. [pmid: 10437342].
Loudon SE, Fronius M, Looman CW, et al. Predictors and a remedy for noncompliance with amblyopia therapy in children measured with the occlusion dose monitor. Invest Ophthalmol Vis Sci. 2006;47(10):4393-4400. [pmid: 17003431].
Loudon SE, Polling JR, Simonsz HJ. A preliminary report about the relation between visual acuity increase and compliance in patching therapy for amblyopia. Strabismus. 2002;10(2):79-82. [pmid: 12221485].
Newman DK, East MM. Prevalence of amblyopia among defaulters of preschool vision screening. Ophthalmic Epidemiol. 2000;7(1):67-71. [pmid: 10652173].
Pediatric Eye Disease Investigator Group. Treatment of strabismic amblyopia with refractive correction. Am J Ophthalmol. 2007;143(6):1060-1063. [pmid: 17524783].
Pediatric Eye Disease Investigator Group. Treatment of anisometropic amblyopia in children with refractive correction. Ophthalmology. 2006;113(6):895-903. [pmid: 16751032].
Pediatric Eye Disease Investigator Group. Factors associated with recurrence of amblyopia on cessation of patching. Ophthalmology. 2007;114(8):1427-1432. [pmid: 17363058].
Pediatric Eye Disease Investigator Group. Treatment of bilateral refractive amblyopia in children three to less than 10 years of age. Am J Ophthalmol. 2007;144(4):487-496. [pmid: 17707330].
Scott WE, Kutschke PJ, Keech RV, Pfeifer WL, Nichols B, Zhang L. Amblyopia treatment outcomes. J AAPOS. 2005;9(2):107-111. [pmid: 15838435].
Searle A, Norman P, Harrad R, Vedhara K. Psychosocial and clinical determinants of compliance with occlusion therapy for amblyopic children. Eye. 2002;16(2):150-155. [pmid: 11988815].
Simons K, Stein L, Cumhur Sener E, Vitale S, Guyton DL. Full-time atropine, intermittent atropine, and optical penalization and binocular outcome in treatment of strabismic amblyopia. Ophtalmology. 1997;104:2143-2155.
Steele A, Bradfiled Y, Kushner BJ, France TD, Struck M, Gangnon R. Successful treatment of anisometropic amblyopie with spectacles alone. J AAPOS. 2006;10:37-43. [pmid: 16527678].
Stewart CE, Fielder AR, Stephens DA, Moseley MJ. Design of the Monitored Occlusion Treatment of Amblyopia Study (MOTAS). Br J Ophthalmol. 2002;86(8):915-919. [pmid: 12140215].
Stewart CE, Fielder AR, Stephens DA, Moseley MJ. Treatment of unilateral amblyopia: factors influencing visual outcome. Invest Ophthalmol Vis Sci. 2005;46(9):3152-3160. [pmid: 16123414].
Stewart CE, Moseley MJ, Fielder AR, et al. Optimization of the dose-response of occlusion therapy for amblyopia: the ROTAS study. Invest Ophthalmol Vis Sci. 2004;2579.
Stewart CE, Moseley MJ, Fielder AR, Stephens DA. Refractive adaptation in amblyopia: quantification of effect and implications for practice. Br J Ophthalmol. 2004;88:1552-1556. [pmid: 15548811].
Stewart CE, Moseley MJ, Stephens DA, Fielder AR. Treatment dose-response in amblyopia therapy: the Monitored Occlusion Treatment of Amblyopia Study (MOTAS). Invest Ophthalmol Vis Sci. 2004;45(9):3048-3054. [pmid: 15326120].
Stewart-Brown S, Haslum M, Butler N. Educational attainment of 10-year-old children with treated and untreated visual defects. Dev Med Child Neurol. 1985;27(4):504-513. [pmid: 4029521].
Subharngkasen I. Successful amblyopia therapy by using synoptophore. J Med Assoc Thai. 2003;86(Suppl 3):S556-S562. [pmid: 14700148].
Tacagni DJ, Stewart CE, Moseley MJ, Fielder AR. Factors affecting the stability of visual function following cessation of occlusion therapy for amblyopia. Graefes Arch Clin Exp Ophthalmol. 2007;245(6):811-816. [pmid: 17047980].
Tejedor J, Ogallar C. Comparative efficacy of penalization methods in moderate to mild amblyopia. Am J Ophthalmol. 2008;145(3):562-569. [pmid: 18207121].
Waddingham PE, Butler TK, Cobb SV, et al. Preliminary results from the use of the novel Interactive Binocular Treatment (I-BiT) system, in the treatment of strabismic and anisometropic amblyopia. Eye. 2006;20(3):375-378. [pmid: 15832181].

## Wrong Publication Type

Ahmed R, Dua HS. Modified Sheridan-Gardiner vision test with a semitransparent card. Br J Ophthalmol. 1999;83(12):1407. [pmid: 10660317].
Altemeier WA 3rd. Preschool vision screening: the importance of the two-line difference. Pediatr Ann. 2000;29(5):264. [pmid: 10826320].
Black BC. The influence of refractive error management on the natural history and treatment outcome of accommodative esotropia (an American Ophthalmological Society thesis). Trans Am Ophthalmol Soc. 2006;104:303-321. [pmid: 17471349].
Cackett P, Weir C, Houston CA. Transient monocular diplopia resulting from the treatment of amblyopia. J Pediatr Ophthalmol Strabismus. 2003;40(4):245-246. [pmid: 12908542].
Chua B, Mitchell P. Consequences of amblyopia on education, occupation, and long term vision loss. Br J Ophthalmol. 2004;88:1119-1121. [pmid: 15317699].
Cotter SA. Pediatric Eye Disease Investigator Group. A randomized trial of atropine versus patching for treatment of moderate amblyopia in children. Optometry. 2002;73(351).
Day S, Norcia A. Photographic detection of amblyogenic factors. Ophthalmology. 1986;93:25-28. [pmid: 3951813].
Dutton G, Cleary M. Should we be screening for and treating amblyopia?. BMJ. 2003;327:1242-1243. [pmid: 14644938].
Eustis H, Chamberlain D. Treatment for amblyopia: results using occlusive contact lens. J Pediatr Ophthalmol. 1996;33:319-322.
Fawcett SL, Birch EE. Interobserver test-retest reliability of the Randot preschool stereoacuity test. J AAPOS. 2000;4(6):354-358. [pmid: 11124670].
Fern KD. A comparison of vision screening techniques in preschool children. Invest Ophthalmol Vis Sci. 1991;32(Suppl 4):962.
Flynn JT, Woodruff G, Thompson JR, et al. The therapy of amblyopia: an analysis comparing the results of amblyopia therapy utilizing two pooled data sets. Trans Am Ophthalmol Soc. 1999;97:373-390. [pmid: 10703134].
Friedmann L, Biedner B, David R, Sachs U. Screening for refractive errors, strabismus and other ocular anomalies from ages 6 months to 3 years. J Pediatr Ophthalmol Strabismus. 1980;17(5):315-317. [pmid: 7441442].
Gnanaraj L, Richardson SR. Interventions for intermittent distance exotropia: review. Eye. 2005;19(6):617-621. [pmid: 15359253].
Harrad RA, McKee SP. Preschool vision screening: results of a systematic review. Surv Ophthalmol. 1999;43(4):374-376. [pmid: 10025522].
Hartmann EE, Bradford GE, Chaplin PK, et al. Project universal preschool vision screening: a demonstration project. Pediatrics. 2006;117(2):e226-237. [pmid: 16452332].
Hiscox F, Strong N, Thompson JR, Minshull C, Woodruff G. Occlusion for amblyopia: a comprehensive survey of outcome. Eye. 1992;6:300-304. [pmid: 1446765].
Huffman SJ, Schimmoeller KL, Schmidt P, Mitchell G. Repeatability and accuracy of autorefractor measurements in young children. Invest Ophthalmol Vis Sci. 2004;45:2736.
Hulstein AM, Reuter KS, Schmidt PP. Performance of autorefractors as screening tools in young children. Invest Ophthalmol Vis Sci. 2002;43:2671.
Kemper AR, Uren RL, Clark SJ. Barriers to follow-up eye care after preschool vision screening in the primary care setting: findings from a pilot study. J AAPOS. 2006;10(5):476-478. [pmid: 17070487].
Kushner BJ. Atropine vs patching for treatment of amblyopia in children. JAMA. 2002;287(16):2145-2146.
Mazyn L, Lenoir M, Montagne G, Delaey C, Savelsbergh G. Stereo vision enhances the learning of a catching skill. Exp Brain Res. 2007;179(4):723-726. [pmid: 17487478].
McGraw PV, Winn B, Gray LS, Elliott DB. Improving the reliability of visual acuity measures in young children. Ophthalmic Physiol Opt. 2000;20(3):173-184. [pmid: 10897339].
Miller J, Schwiegerling J, Leising-Hall H, Surachatkumtonekul T. Detection of improper fixation in MTI photoscreening images. J AAPOS. 2001;5(1):35-43. [pmid: 11182671].
Miller JM, Dobson VM, Harvey EM, Sherrill DL. Astigmatism and Amblyopia among Native American Children (AANAC): design and methods. Ophthalmic Epidemiol. 2000;7(3):187-207. [pmid: 11035554].
Mohan KM, Miller JM, Dobson V, Harvey EM, Sherrill DL. Inter-rater and intra-rater reliability in the interpretation of MTI photoscreener photographs of Native American preschool children. Optom Vis Sci. 2000;77(9):473-482. [pmid: 11014674].
Molteno AC, Sanderson GF, Hoare-Nairne J. Clinical experience with the Otago photoscreener. Aust N Z J Ophthalmol. 1985;13(1):49-58. [pmid: 4015879].
Moore B. The Massachusetts preschool vision screening program. Optometry. 2006;77(8):371-377. [pmid: 16877202].
Multi-Ethnic Pediatric Eye Disease Study Group. Tarczy-Hornoch K, Lin JP, et al. Stereoacuity testability in African-American and Hispanic pre-school children. Optom Vis Sci. 2008;85(3):158-163. [pmid: 18317330].
Nawratzki I, Oliver M, Newmann E. Screening for amblyopia in children under three years of age in Israel. Isr J Med Sci. 1972;8(8):1469-1472. [pmid: 4647807].
Parkes LC. An investigation of the impact of occlusion therapy on children with amblyopia, its effect on their families and compliance with treatment. Br Orthoptic J. 2001;58:30-37.
Pediatric Eye Disease Investigator Group. The course of moderate amblyopia treated with patching in children: experience of the amblyopia treatment study. Am J Ophthalmol. 2003;136:620-629. [pmid: 14516801].
Pediatric Eye Disease Investigator Group. A randomized trial of atropine regimens for treatment of moderate amblyopia in children. Ophthalmology. 2004;111(11):2076-2085. [pmid: 15522375].
Pediatric Eye Disease Investigator Group. The effect on refractive error of unilateral atropine as compared with patching for the treatment of amblyopia. J AAPOS. 2007;11(3):300-302. [pmid: 17572346].
Repka MX, Ray JM. The efficacy of optical and pharmacological penalization. Ophthalmology. 1993;100(5):769-774. [pmid: 8493022].
Romano PE. Strabismus surgery dosage and timing; outcomes: minitropias and microtropias; stereotests for screening. Binocul Vis Strabismus Q. 2000;15(3):207-211. [pmid: 10960223].
Rutstein RP, Corliss DA. The clinical course of intermittent exotropia. Optom Vis Sci. 2003;80(9):644-649. [pmid: 14502045].
Sandfeld Nielsen L, Skov L, Jensen H. Vision screening in children with developmental delay can be improved: analysis of a screening programme outside the ophthalmic clinic. Dev Med Child Neurol. 2007;49(7):508-512. [pmid: 17593122].
Saw SM, Shih-Yen EC, Koh A, Tan D. Interventions to retard myopia progression in children: an evidence-based update. Ophthalmology. 2002;109(3):415-421. [pmid: 11874738].
Shotton K, Powell C, Voros G, Hatt SR. Interventions for unilateral refractive amblyopia. Cochrane Database Syst Rev. 2008:CD005137.
Simon JW, Kaw P. Vision screening performed by the pediatrician. Pediatr Ann. 2001;30(8):446-452. [pmid: 11510342].
Simons K. Preschool vision screening: rationale, methodology and outcome. Surv Ophthalmol. 1996;41(1):3-30. [pmid: 8827927].
Simons K. Amblyopia characterization, treatment, and prophylaxis. Surv Ophthalmol. 2005;50(2):123-166. [pmid: 15749306].
U.S. Public Health Service. Vision screening in children. Am Fam Physician. 1994;50(3):587-590. [pmid: 8067325].
von Noorden GK, Campos EC. Patching regimens. Ophthalmology. 2004;111(5):1063. [pmid: 15121389].
Weakley DR Jr, Birch E. The role of anisometropia in the development of accommodative esotropia. Trans Am Ophthalmol Soc. 2000;98:71-76. [pmid: 11190042].
Webber A. Amblyopia treatment: an evidence-based approach to maximising treatment outcome. Clin Exp Optom. 2007;90(4):250-257. [pmid: 17535363].
Williams C, Harvey I, Frankel S, Golding J, Harrad R. A randomised controlled trial of preschool vision screening. Invest Ophthalmol Vis Sci. 1994;35:1648.
Woodruff G, Hiscox F, Thompson JR, Smith LK. Factors affecting the outcome of children treated for amblyopia. Eye. 1994;8:627-631. [pmid: 7867817].

## Not English Language

Zeng SM, Yan YM, Chen Q, Li M, Lai YZ. [Binocular vision rebuilding in patients with intermittent exotropia operation followed fusion function training]. Int J Ophthalmol. 2005;5(5):958-960.

## Specific Risk Factor Paper Only

Anker S, Atkinson J, Braddick O, Nardini M, Ehrlich D. Non-cycloplegic refractive screening can identify infants whose visual outcome at 4 years is improved by spectacle correction. Strabismus. 2004;12(4):227-245. [pmid: 15545141].
Birch EE, Fawcett SL, Morale SE, Weakley DR Jr, Wheaton DH. Risk factors for accommodative esotropia among hypermetropic children. Invest Ophthalmol Vis Sci. 2005;46(2):526-529. [pmid: 15671278].
Ponsonby AL, Brown SA, Kearns LS, et al. The association between maternal smoking in pregnancy, other early life characteristics and childhood vision: the Twins Eye Study in Tasmania. Ophthalmic Epidemiol. 2007;14(6):351-359. [pmid: 18161608].
Rudanko SL, Fellman V, Laatikainen L. Visual impairment in children born prematurely from 1972 through 1989. Ophthalmology. 2003;110(8):1639-1645. [pmid: 12917186].
Rudanko SL, Laatikainen L. Visual impairment in children born at full term from 1972 through 1989 in Finland. Ophthalmology. 2004;111(12):2307-2312. [pmid: 15582091].

## Reference Standard Not Performed in All Children (Or a Random Subset)

Arnold RW. Highly specific photoscreening at the Alaska state fair. Alaska Med. 2003;45:34-40. [pmid: 12971063].
Arnold RW, Gionet EG, Jastrzebski AI, et al. The Alaska Blind Child Discovery project: rationale, methods and results of 4000 screenings. Alaska Med. 2000;42(3):58-72. [pmid: 11042938].
Clausen MM, Arnold RW. Pediatric eye/vision screening: referral criteria for the PediaVision PlusOptix S04 photoscreener compared to visual acuity and digital photoscreening. Binocul Vis Strabismus Q. 2007;22(2):83-89. [pmid: 17688416].
Cordonnier M, Dramaix M. Screening for abnormal levels of hyperopia in children: a non-cycloplegic method with a hand held refractor. Br J Ophthalmol. 1998;82:1260-1264. [pmid: 9924329].
Cordonnier M, Dramaix M. Screening for refractive errors in children: accuracy of the hand held refractor Retinomax to screen for astigmatism. Br J Ophthalmol. 1999;83(2):157-161. [pmid: 10396190].
Cordonnier M, Kallay O. Non-cycloplegic screening for refractive errors in children with the hand-held autorefractor Retinomax: final results and comparison with non-cycloplegic photoscreening. Strabismus. 2001;9(2):59-70. [pmid: 11458294].
De Becker I, MacPherson HJ, LaRoche GR, et al. Negative predictive value of a population-based preschool vision screening program. Ophthalmology. 1992;99(6):998-1003. [pmid: 1630790].
Leman R, Clausen MM, Bates J, Stark L, Arnold KK, Arnold RW. A comparison of patched HOTV visual acuity and photoscreening. J Sch Nurs. 2006;22(4):237-243. [pmid: 16856779].
Lim HT, Yu YS, Park SH, et al. The Seoul Metropolitan Preschool Vision Screening Programme: results from South Korea. Br J Ophthalmol. 2004;88(7):929-933. [pmid: 15205240].
Robinson B, Bobier WR, Martin E, Bryant L. Measurement of the validity of a preschool vision screening program. Am J Public Health. 1999;89(2):193-198. [pmid: 9949748].
Rowatt AJ, Donahue SP, Crosby C, Hudson AC, Simon S, Emmons K. Field evaluation of the Welch Allyn SureSight vision screener: incorporating the vision in preschoolers study recommendations. J AAPOS. 2007;11(3):243-248. [pmid: 17140828].
Silverstein E, Lorenz S, Emmons K, Donahue SP. Limits on improving the positive predictive value of the Welch Allyn SureSight for preschool vision screening. J AAPOS. 2009;13(1):45-50. [pmid: 18976944].
Spierer A, Royzman Z, Chetrit A, Novikov I, Barkay A. Vision screening of preverbal children with Teller acuity cards. Ophthalmology. 1999;106(4):849-854. [pmid: 10201612].
Tong PY, Enke-Miyazaki E, Bassin RE, et al. Screening for amblyopia in preverbal children with photoscreening photographs. Ophthalmology. 1998;105(5):856-863. [pmid: 9593387].

## Systematic Review

Kemper A, Margolis P, Downs S, Bordley WC. A systematic review of vision screening tests for the detection of amblyopia. Pediatrics. 1999;104(5):1220-1222. [pmid: 10545578].

## Uncontrolled Study of Screening

Abrahamsson M, Magnusson G, Sjostrand J. Inheritance of strabismus and the gain of using heredity to determine populations at risk of developing strabismus. Acta Ophthalmol Scand. 1999;77(6):653-657. [pmid: 10634557].
Arnold RW, Donahue SP. The yield and challenges of charitable state-wide photoscreening. Binocul Vis Strabismus Q. 2006;21(2):93-100. [pmid: 16792524].
Bowman RJ, Williamson TH, Andrews RG, Aitchison TC, Dutton GN. An inner city preschool visual screening programme: long-term visual results. Br J Ophthalmol. 1998;82(5):543-548. [pmid: 9713063].
Cameron J, Cameron M. Visual screening of pre-school children. BMJ. 1978;2:1693-1694. [pmid: 737442].
Clarke N, Shacks J, Kerr AR, Bottrell CL, Poulsen MK, Yin L. Use of a noncycloplegic autorefractor to perform vision screening in preschools. J Sch Nurs. 2008;24(3):158-163. [pmid: 18557675].
Cordonnier M, de Maertelaer V. Screening for amblyogenic factors in preschool children with the retinomax hand-held refractor: do positive children have amblyopia and is treatment efficacious?. Strabismus. 2005;13(1):27-32. [pmid: 15824014].
Donahue SP, Baker JD, Scott WE, et al. Lions Clubs International Foundation Core Four Photoscreening: results from 17 programs and 400,000 preschool children. J AAPOS. 2006;10(1):44-48. [pmid: 16527679].
Donahue SP, Johnson TM, Ottar W, Scott WE. Sensitivity of photoscreening to detect high-magnitude amblyogenic factors. J AAPOS. 2002;6(2):86-91. [pmid: 11997804].
Edwards R, Whitelaw A, Abbott A. Orthoptists as pre-school screeners: a 2-year study. Br J Ophthalmol. 1989;46:14-19.
Hug T. Full-time occlusion compared to part-time occlusion for the treatment of amblyopia. Optometry. 2004;75(4):241-244. [pmid: 15117057].
Ingram RM. Review of children referred from the school vision screening programme in Kettering during 1976–8. BMJ. 1989;298:935-936. [pmid: 2497866].
Jarvis SN, Tamhne RC, Thompson L, Francis PM, Anderson J, Colver AF. Preschool vision screening. Arch Dis Child. 1991;66(3):288-294. [pmid: 2025002].
Juttmann R. Rotterdam Amblyopia Screening Effectiveness Study (RAMSES): compliance and predictive value in the first 2 years. Br J Ophthalmol. 2001;85:1332-1335. [pmid: 11673301].
Kohler L, Stigmar G. Vision screening of four-year-old children. Acta Paediatr Scand. 1973;62(1):17-27. [pmid: 4691252].
Kvarnstrom G, Jakobsson P, Lennerstrand G. Screening for visual and ocular disorders in children, evaluation of the system in Sweden. Acta Paediatr. 1998;87(11):1173-1179. [pmid: 9846920].
Kvarnstrom G, Jakobsson P, Lennerstrand G. Visual screening of Swedish children: an ophthalmological evaluation. Acta Ophthalmol Scand. 2001;79(3):240-244. [pmid: 11401631].
Latvala M, Paloheimo M, Karma A. Screening of amblyopic children and long-term follow-up. Acta Ophthalmol Scand. 1996;74:488-492. [pmid: 8950400].
Newman DK, Hitchcock A, McCarthy H, Keast-Butler J, Moore AT. Preschool vision screening: outcome of children referred to the hospital eye service. Br J Ophthalmol. 1996;80(12):1077-1082. [pmid: 9059274].
Williamson T, Andrews R, Dutton G, Murray G, Graham N. Assessment of an inner city visual screening programme for preschool children. Br J Ophthalmol. 1995;79(12):1068-1073. [pmid: 8562537].
Wormald RP. Preschool vision screening in Cornwall: performance indicators of community orthoptists. Arch Dis Child. 1991;66(8):917-920. [pmid: 1929487].
Yawn B, Lydick E, Epstein R, Jacobsen S. Is school vision screening effective?. J Sch Health. 1996;66:171-175. [pmid: 8735581].
Zaba JN, Reynolds W, Mozlin R, Costich J, Slavova S, Steele GT. Comparing the effectiveness of vision screenings as part of the school entrance physical examination to comprehensive vision examinations in children ages 3 to 6: an exploratory study. Optometry. 2007;78(10):514-522. [pmid: 17904492].

## Unable to Calculate Diagnostic Accuracy

Abrahamsson M, Ohlsson J, Bjorndahl M, Abrahamsson H. Clinical evaluation of an eccentric infrared photorefractor: the PowerRefractor. Acta Ophthalmol Scand. 2003;81(6):605-610. [pmid: 14641262].
Birch E, Williams C, Drover J, et al. Randot Preschool Stereoacuity Test: normative data and validity. J AAPOS. 2008;12(1):23-26. [pmid: 17720573].
Chat SW, Edwards MH. Clinical evaluation of the Shin-Nippon SRW-5000 autorefractor in children. Ophthalmic Physiol Opt. 2001;21(2):87-100. [pmid: 11261351].
Clifford CE, Haynes BM, Dobson V. Are norms based on the original Teller Acuity Cards appropriate for use with the new Teller Acuity Cards II?. J AAPOS. 2005;9(5):475-479. [pmid: 16213399].
Cordonnier M, Dramaix M, Kallay O, de Bideran M. How accurate is the hand-held refractor Retinomax in measuring cycloplegic refraction: a further evaluation. Strabismus. 1998;6(3):133-142. [pmid: 10623951].
el-Defrawy S, Clarke WN, Belec F, Pham B. Evaluation of a hand-held autorefractor in children younger than 6. J Pediatr Ophthalmol Strabismus. 1998;35:107-109. [pmid: 9559510].
Felius J, Wang YZ, Birch EE. The accuracy of the amblyopia treatment study visual acuity testing protocol. J AAPOS. 2003;7(6):406-412. [pmid: 14730293].
Harvey E, Miller J, Wagner L, Dobson V. Reproducibility and accuracy of measurements with a hand held autorefractor in children. Br J Ophthalmol. 1997;81:941-948. [pmid: 9505815].
Harvey EM, Miller JM, Dobson V, Tyszko R, Davis AL. Measurement of refractive error in Native American preschoolers: validity and reproducibility of autorefraction. Optom Vis Sci. 2000;77(3):140-149. [pmid: 10772231].
Hunt O, Wolffsohn J, Gilmartin B. Evaluation of the measurement of refractive error by the PowerRefractor: a remote, continuous and binocular measurement system of oculomotor function. Br J Ophthalmol. 2003;87:1504-1508. [pmid: 14660462].
Kallay O, Cordonnier M, Dramaix M. Cycloplegic refractive errors in children: comparison of a standard and a hand-held refractor. Strabismus. 1998;6(1):3-7. [pmid: 10623942].
Letourneau J, Giroux R. Reliability and validity of the dot visual acuity test. Am J Optom Assoc. 1988;59(2):131-134.
Lewis RC, Marsh-Tootle WL. The reliability of interpretation of photoscreening results with the MTI PS-100 in Headstart school children. J Am Optom Assoc. 1995;66:429-434. [pmid: 7560731].
Liang CL, Hung KS, Park N, Chan P, Juo SH. Comparison of measurements of refractive errors between the hand-held Retinomax and on-table autorefractors in cyclopleged and noncyclopleged children. Am J Ophthalmol. 2003;136(6):1120-1128. [pmid: 14644224].
Liang CL, Hung KS, Park N, Chan P, Juo SH. Comparison of the handheld Retinomax K-Plus2 and on-table autokeratometers in children with and without cycloplegia. J Cataract Refract Surg. 2004;30(3):669-674. [pmid: 15050266].
McBrien N, Millodot M. Clinical evaluation of the Canon Autoref R-1. Am J Optom Physiol Opt. 1985;62:786-792. [pmid: 4073216].
McDonald M, Chaudry N. Comparison of four methods of assessing visual acuity in young children. Optom Vis Sci. 1989;66:363-369. [pmid: 2771321].
Salt AT, Wade AM, Proffitt R, Heavens S, Sonksen PM. The Sonksen logMAR test of visual acuity, I: testability and reliability. J AAPOS. 2007;11(6):589-596. [pmid: 17681815].
Savage HI, Lee HH, Zaetta D, et al. Pediatric Amblyopia Risk Investigation Study (PARIS). Am J Ophthalmol. 2005;140(6):1007-1013. [pmid: 16376643].
Schaeffel F, Mathis U, Bruggemann G. Noncycloplegic photorefractive screening in pre-school children with the “PowerRefractor” in a pediatric practice. Optom Vis Sci. 2007;84(7):630-639. [pmid: 17632312].
Sener EC, Mocan MC, Gedik S, Ergin A, Sanac AS. The reliability of grading the fixation preference test for the assessment of interocular visual acuity differences in patients with strabismus. J AAPOS. 2002;6(3):191-194. [pmid: 12075297].
Tomac S, Altay Y. Near stereoacuity: development in preschool children; normative values and screening for binocular vision abnormalities; a study of 115 children. Binocul Vis Strabismus Q. 2000;15(3):221-228. [pmid: 10960225].
Wood IC, Papas E, Burghardt D, Hardwick G. A clinical evaluation of the Nidek autorefractor. Opththal Physiol Opt. 1984;4(2):169-178.
Yildirim C, Altinsoy HI. Distance alternate-letter suppression test for objective assessment of sensorial status in intermittent exotropia. Eur J Ophthalmol. 2000;10(1):4-10. [pmid: 10744198].

## Inadequate or Unclear Reference Standard

Yang JW, Son MH, Yun IH. A study on the clinical usefulness of digitalized random-dot stereoacuity test. Korean J Ophthalmol. 2004;18(2):154-160. [pmid: 15635829].