# Inclusion and Exclusion Criteria for Key Questions

## OVERALL

### Ages

Include: Children ages 1–5 years

Exclude: Newborns and children younger than age 1 year, children ages 6 years or older

### Diseases

Include: Amblyopia, amblyogenic risk factors, refractive error

Exclude: Children with severe congenital conditions or developmental delay, retinopathy of prematurity, glaucoma, congenital cataract, pathologic myopia

### Language/publication status

Include: Full-text (i.e., not available only as a conference abstract) journal article published in English

### Settings

Include: Studies performed in primary care, community-based, and school settings

Exclude: Countries with populations not similar to the United States

### Study designs

Exclude: Systematic reviews

## KEY QUESTIONS 1 (Screening and Outcomes) and 1a (Variation in Age Groups)

### Interventions/diagnostic tests

Include: Studies of screening tests used or available in primary care settings (e.g., visual acuity tests, tests of stereopsis, tests for strabismus, photoscreeners, autorefractors)

Exclude: Studies of screening tests not used or available in primary care settings (e.g., contrast sensitivity testing, fundoscopic examination, visual acuity testing with cyclopegia) or not intended to detect amblyopia, amblyogenic risk factors, or refractive error (e.g., white reflex screening)

### Outcomes

Include: Improved visual acuity, reduced long-term amblyopia, school performance, function, quality of life

### Study designs

Include: Randomized controlled trials and controlled observational studies

## KEY QUESTION 2 (Accuracy/Reliability of Risk Factor Assessment)

### Outcomes

Include: Studies on accuracy or yield of risk factor assessment for targeted screening, or clinical outcomes associated with use of targeted versus universal screening

### Study designs

Include: Randomized controlled trials and controlled observational studies

## KEY QUESTIONS 3 (Accuracy of Screening Tests) and 3a (Variation in Age Groups)

### Diagnostic tests

Include: Studies of screening tests used or available in primary care settings (e.g., visual acuity tests, tests of stereopsis, tests for strabismus, photoscreeners, autorefractors)

Exclude: Studies of screening tests not used or available in primary care settings (e.g., contrast sensitivity testing, fundoscopic examination, visual acuity testing with cyclopegia) or not intended to detect amblyopia, amblyogenic risk factors, or refractive error (e.g., white reflex screening)

### Outcomes

Include: Sensitivity, specificity, positive and negative predictive values, likelihood ratios, diagnostic odds ratios (or able to calculate such outcomes from data provided)

### Study designs

Include: Studies on diagnostic accuracy of a screening question or diagnostic test compared to a credible reference standard (i.e., cycloplegic refraction)

Exclude: Studies that do not attempt to perform the reference standard in all patients or a random sample

## KEY QUESTION 4 (Harms of Screening)

### Interventions/diagnostic tests

Include: Studies of screening tests used or available in primary care settings (e.g., visual acuity tests, tests of stereopsis, tests for strabismus, photoscreeners, autorefractors)

Exclude: Studies of screening tests not used or available in primary care settings (e.g., contrast sensitivity testing, fundoscopic examination, visual acuity testing with cyclopegia) or not intended to detect amblyopia, amblyogenic risk factors, or refractive error (e.g., white reflex screening)

### Outcomes

Include: Harms, including psychological distress, labeling, anxiety, other psychological effects, false-positives, adverse effects on vision in nonimpaired eye

### Study designs

Include: Randomized controlled trials and controlled observational studies

## KEY QUESTION 5 (Effectiveness of Treatment)

### Interventions/treatments

Include: Correction of refractive error (eyeglasses), patching, and atropine

### Outcomes

Include: Improved visual acuity, reduced long-term amblyopia, school performance, function, quality of life

### Study designs

Include: Randomized controlled trials

## KEY QUESTION 6 (Harms of Treatment)

### Interventions/treatments

Include: Correction of refractive error and penalization of the nonamblyogenic eye (patching, atropine)

### Outcomes

Include: Harms, including psychological distress, labeling, anxiety, other psychological effects, false-positives, adverse effects on vision in nonimpaired eye

### Study designs

Include: Randomized controlled trials and controlled observational studies