# Literature Search Strategies

## Overall Searches

### Database: EBM Reviews – Cochrane Central Register of Controlled Trials

1. amblyopia.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. strabismus.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. refractive error.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. 1 or 2 or 3
5. 4 and (child$ or pediatri$ or preschool).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6. limit 5 to yr=“2003 – 2008”

### Database: EBM Reviews – Cochrane Database of Systematic Reviews

1. amblyopia.mp. [mp=title, short title, abstract, full text, keywords, caption text]
2. strabismus.mp. [mp=title, short title, abstract, full text, keywords, caption text]
3. refractive error.mp. [mp=title, short title, abstract, full text, keywords, caption text]
4. 1 or 2 or 3
5. 4 and (child$ or pediatri$ or preschool).mp. [mp=title, short title, abstract, full text, keywords, caption text]

## Risk Search

### Database: Ovid MEDLINE

1. exp Amblyopia/
2. exp Refractive Errors/
3. exp Vision Disorders/
4. or/1–3
5. limit 4 to (“newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)”)
6. exp Risk/ or exp Risk Factors/
7. 5 and 6
8. limit 7 to yr=“1999 – 2008”
9. Case Reports/
10. 8 not 9

## Screening Search

### Database: Ovid MEDLINE

1. vision tests/ or refraction, ocular/ or vision screening/
2. limit 1 to (“newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)”)
3. limit 2 to yr=“1999 – 2008”
4. limit 3 to humans
5. limit 4 to English language
6. limit 4 to abstracts
7. 5 or 6
8. Case Reports/
9. 7 not 8
10. English abstract.mp.
11. 9 not 10

## Treatment Search

### Database: Ovid MEDLINE

1. exp Amblyopia/dt, pc, th [Drug Therapy, Prevention & Control, Therapy]
2. exp Refractive Errors/dt, th, pc [Drug Therapy, Therapy, Prevention & Control]
3. 1 or 2
4. limit 3 to (“newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)”)
5. limit 4 to English language
6. limit 4 to abstracts
7. 5 or 6
8. limit 7 to yr=“1999 – 2008”